# The Effectiveness of Decision Aids

This chapter focuses on those studies that evaluated the effectiveness of a DA in a clinical rather than a research situation. As discussed in Chapter 2, we defined a DA as "an intervention designed primarily to help patients or patients and clinicians together, with making cancer-related health care decisions, when options are available for prevention, screening and treatment. At a minimum, it should target some component of decisionmaking (e.g., information exchange, involvement in the decision process)." In this chapter, we address all but one of the questions posed by our partners at NCI. These questions are listed below. Following each question, we indicate the relevant sections of text and tables where information can be found. In Chapters 6 and 7, we return to the questions.

The chapter is organized into sections. After listing the questions, we describe the characteristics of the studies, including the types of design, interventions, outcomes, and comparisons. We then report the methodological quality of each study. The results are presented according to the type of intervention and outcome.

## Types of Decision Aids

- What models of decisionmaking (e.g., informed, shared) underpin decision aids that have been used? (Model of decisionmaking; Table 29)
- What clinical contexts (e.g., prevention, screening, and treatment) have been investigated? (Type of decision aid interventions by type of decision; Tables 20 to 22)
- What has been the clinical focus of the decision aids (e.g., type of cancer and extent of disease)? (Type of decision and type of cancer; Tables 20 to 22)
- What has been the mode of delivery (e.g., print, interactive video)? (Type of decision aid interventions; Tables 20 to 22)

Table 20. Type of DA intervention by type of decision: RCT studies

Type of Decision | Author (Year) | Type of Cancer | Components of DA Intervention and Comparison Groups | Type of Comparison
Genetic Testing | Lerman (1997) | Breast | Wait list control group vs. DA educational session + DA brochure vs. DA educational session + DA brochure + Standard genetic counseling | Wait list control group vs. DA only vs. Standard genetic counseling + DA
Genetic Testing | Inglehart (1998) | Breast and Ovarian | DA brochure + Standard genetic counseling vs. Individualized DA brochure + Standard genetic counseling | Standard genetic counseling + DA vs. Standard genetic counseling + DA
Genetic Testing/ Prevention | Watson (1998) | Breast | Genetic Counseling + Physical Examination + Summary Letter vs. Genetic Counseling + Physical Examination + Summary Letter + Audiotape of Consultation | Usual Care vs. Usual Care + DA
Screening | Davison (1999) | Prostate | Usual Care + Unrelated Discussion vs. Usual Care + Counseling + DA brochure | Usual Care vs. Usual Care + DA
Screening | Pignone (2000) | Colorectal | Usual Care + unrelated videotape and brochure about car safety vs. Usual Care + DA videotape + targeted DA brochure + chart marker | Usual Care vs. Usual Care + DA
Screening | Schapira (2000) | Prostate | Information pamphlet + research assistant (RA) available to answer questions + followup visit vs. DA brochure + RA available to answer questions + followup visit | Usual Care vs. DA
Screening | Volk ^a^ (1999) | Prostate | Usual Care vs. Usual Care + DA videotape + DA brochure vs. Usual Care + DA videotape + DA brochure + Utility assessment | Usual Care vs. Usual Care + DA vs. Usual Care + DA
Screening | Wolf (1996) | Prostate | Brief information statement vs. Educational DA script read by a research assistant | Usual Care vs. DA
Screening | Wolf (2000) | Colorectal | Listening to a brief statement vs. Listening to an educational relative risk reduction DA script vs. Listening to an educational absolute risk reduction DA script | Usual Care vs. DA1 vs. DA2
Treatment | Davison (1997) | Prostate | Usual Care + Information pamphlet vs. Usual Care + Information pamphlet + Counseling + Audiotape of consultation + Question List | Usual Care vs. Usual Care + DA
Treatment | Goel (2001) | Breast | Usual Care + DA brochure vs. Usual Care + Audiotape workbook with values clarification exercise | Usual Care + DA vs. Usual Care + DA
Treatment | Hack ^b^ (1999) | Breast and Prostate | Usual Care vs. Usual Care + Audiotape of consultation vs. Usual Care + Option to have audiotape of consultation | Usual Care vs. Usual Care + DA vs. Usual Care + DA
Treatment | Irwin (1999) | Breast | Decision Board with treatment presentation AC ^c^ - CMF ^d^ vs. Decision Board with treatment presentation CMF** - AC* | DA vs. DA
Treatment | Maslin (1998) | Breast | Usual Care vs. Usual Care + Interactive Computer Program | Usual Care vs. Usual Care + DA
Treatment | North (1992) | Not Specified | Usual Care + Physician Checklist vs. Usual Care + Physician Checklist + Audiotape of Consultation | Usual Care vs. Usual Care + DA
Treatment | Street (1995) | Breast | Usual Care + DA brochure vs. Usual Care + Interactive Computer Program | Usual Care + DA vs. Usual Care + DA

a The authors reported no significant difference between the two intervention groups and presented results as pooled intervention group data. Note: In Chapter 5 summary table, only the pooled data are discussed.

b The authors reported much of the result data pooled for the two intervention groups. Note: In Chapter 5 summary table, only the pooled data are discussed.

c Adriamycin + Cyclophosphamide

d Cyclophosphamide + Methotrexate + 5-Fluorouracil

Table 21. Type of DA intervention by type of decision: Controlled trials and nonconcurrent cohort studies

Type of Decision | Author (Year) | Type of Cancer | Components of DA Interventionand Comparison Groups | Type of Comparison
Screening | Flood (1996) | Prostate | Usual Care vs. Usual Care + Pamphlet (no description) + DA videotape | Usual Care vs. Usual Care + DA
Screening | Flood (1996) | Prostate | Information videotape (advocates PSA test) vs. DA videotape + Pamphlet (no description) | Usual Care vs. DA
Treatment | Molenaar (2001) | Breast | Usual Care + Information Pamphlet vs. Usual Care + Interactive computer program | Usual Care vs. Usual Care + DA
Treatment | Sepucha (2000) | Breast | Usual care + Preconsultation Planning + Consultation Observation vs. Usual care + Preconsultation Planning + Consultation Recording | Usual Care + DA vs. Usual Care + DA
Treatment | Whelan (1995) | Breast | Usual Care vs. Usual Care + Physician Checklist vs. Usual Care + DB + Take-home version of DB | Usual Care vs. Usual Care vs. Usual Care + DA
Treatment | Whelan (1999) | Breast | Usual Care vs. Usual Care + DB + Take-home version of DB | Usual Care vs. Usual Care + DA

Table 22. Type of DA intervention by type of decision: Case series

Type of Decision | Author (Year) | Type of Cancer | Components of Decision Aid Intervention
Genetic Testing | Stalmeier (1999) | Breast | Individual counseling + Utility assessment + Information videotape and pamphlet
Treatment | Adler (1999) | Breast | Usual Care + Pamphlet (no description provided)
Treatment | Ashcroft (1985) | Breast | Usual Care + Informal Decision Analysis
Treatment | Brundage (2000) | Lung | Usual Care + Counseling + Decision Board + Treatment Tradeoff Exercises + DA brochure
Treatment | Cassileth (1989) | Prostate | Usual Care + DA brochure
Treatment | Cotton (1991) | Breast | Usual Care + Individual Counseling with visual aids + Information pamphlet
Treatment | Cotton (1995) | Breast | Usual Care + Individual Counseling + Information pamphlet
Treatment | Fiset (2000) | Lung | Usual Care + Audiotape booklet with worksheet
Treatment | Gramlich (1998) | Breast | Usual Care + Interactive Video Disc Program
Treatment | Klass (1992) | Prostate | Usual Care + DA brochure
Treatment | Levine (1992) | Breast | Usual Care + Decision Board + Take-home version of Decision Board
Treatment | Okamato (1999) | Hypopharyngeal | Usual Care + Individual counseling with visual aids + Additional counseling sessions as needed
Treatment | Onel (1998) | Prostate | Usual Care + DA videotape
Treatment | Protiere (2000) | Breast | Usual Care (consultation based on pamphlet) + DA brochure
Treatment | Sandison (1996) | Breast | Usual Care + Individual Counseling + DA brochure
Treatment | Wilson (1988) | Breast | Usual Care + Individual Counseling + Tape/slide Presentation
Treatment | Wolberg (1987) | Breast | Usual Care + Individual Counseling + Slide/tape Presentation + DA brochure

Table 29. Model of decisionmaking used

Type of Intervention | Study Design | Author (year) | Decisionmaking Model Stated by Authors | Decisionmaking Model Determined by Reviewers
Information Pamphlet or DA brochure | RCT | Schapira (2000) | Informed | Informed
Information Pamphlet or DA brochure | RCT | Street (1995) | NR | Informed
Information Pamphlet or DA brochure | RCT | Iglehart (1998) | NR | Informed
Information Pamphlet or DA brochure | RCT | Goel (2001) | Shared | Not clear
Information Pamphlet or DA brochure | Case series | Cassileth (1989) | NR | Informed
Information Pamphlet or DA brochure | Case series | Adler (1999) | NR | Informed
Information Pamphlet or DA brochure | Case series | Protiere (2000) | Shared | Informed
Information Pamphlet or DA brochure | Case Series | Klass (1992) | NR | Informed
Educational Script | RCT | Wolf (1996) | NR | Informed
Educational Script | RCT | Wolf (2000) | NR | Informed
Audiotape | RCT | Watson (1998) | NR | Informed
Audiotape | RCT | Hack (1999) | NR | Informed
Audiotape | RCT | North (1992) | NR | Informed
Audiotape | RCT | Goel (2001) | See pamphlet section | See pamphlet section
Audiotape | Case Series | Fiset (2000) | NR | Informed
Videotape | RCT | Volk (1999) | Shared | Informed
Videotape | RCT | Pignone (2000) | NR | Informed
Videotape | CT | Flood (1996) | Shared | Informed
Videotape | CT | Flood (1996) | Shared | Informed
Videotape | Case series | Onel (1998) | Shared | Informed
Videotape | Case series | Wilson (1988) | NR | Informed
Interactive Computer Program | RCT | Maslin (1998) | Shared | Informed
Interactive Computer Program | RCT | Street (1995) | See pamphlet section | See pamphlet section
Interactive Computer Program | CT | Molenaar (2001) | Shared | Informed
Interactive Computer Program | Case series | Gramlich (1998) | Shared | Not Clear
Counselling | RCT | Davison (1999) | NR | Informed
Counselling | Case series | Cotton (1995) | NR | Informed
Counselling | Case series | Cotton (1991) | NR | Informed
Counselling | Case series | Sandison (1996) | NR | Informed
Counselling | Case series | Okamato (1999) | NR | Informed
Informal Decision Analysis | Case series | Ashcroft (1985) | NR | Shared
Decision Board | RCT | Irwin (1999) | Shared | Informed
Decision Board | Nonconcurrent cohort studies | Whelan (1995) | Shared | Informed
Decision Board | Nonconcurrent cohort studies | Whelan (1999) | Shared | Not Clear
Decision Board | Case series | Levine (1992) | Shared | Informed
Complex Decision Aids | RCT | Lerman (1997) | Informed | Informed
Complex Decision Aids | RCT | Davison (1997) | Other: empowerment | Informed
Complex Decision Aids | CT | Sepucha (2000) | Shared | Shared
Complex Decision Aids | Case series | Stalmeier (1999) | Shared | Informed
Complex Decision Aids | Case series | Wolberg (1987) | NR | Informed
Complex Decision Aids | Case series | Brundage (2000) | NR | Informed

a The following definitions were used to categorize the model of decisionmaking :Paternalistic model: Explicitly assumes a passive role for the patient in the decisionmaking process. The clinician is seen as dominating the encounter. This model leaves the patient outside the decisionmaking process.Informed model: Incorporates the idea of information sharing (primarily from clinician to patient), but the information sharing does not necessarily lead to a sharing of the decisionmaking process. This model leaves the clinician out of the decisionmaking process.Shared model: Involves at least two participants in the decision: the clinician and the patient. Both parties take steps to participate in the process of treatment decisionmaking. Information sharing is a prerequisite to this model: both patient and clinician bring information and values to the process and they come together to make the decision.

a Definitions are from Charles et al. (1999): Decision-making in the physician-patient encounter: revisiting the shared treatment decision-making model.

## Populations Using Decision Aids

On what populations has the research been conducted? (Tables 23 to 25) Have decision aids been used by members of special populations (e.g., the elderly, minorities, persons with less than a high school education)? (See DAs for Special Populations, page 71.)

Table 23. Study demographics: RCT studies

Author (Year) | Type of Cancer | Gender (# of subjects) | | Age | Annual Family Income (# of subjects) | Education (# of subjects) | | Ethnicity (# of subjects)
Author (Year) | Type of Cancer | Male | Female | Age | Annual Family Income (# of subjects) | < High school | > High school | Caucasian | African-American | Other
Davison (1997) | Prostate | IG: 30 CG: 30 | N/A | IG: mean 66.0, SD 8.3 range: NR CG: mean 69.8, SD 5.0 range: NR | NR | IG: 15 CG: 20 | IG: 15 CG: 10 | NR | NR | NR
Davison (1999) | Prostate | IG: 50 CG: 50 | N/A | Men 50 to 79 years: IG: mean 63.8 years, SD 8.0 CG: mean 60.7 years, SD 8.6 | NR | IG: 23 CG: 21 | IG: 27 CG: 29 | NR | NR | NR
Goel (2001) | Breast | NA | IG1:50 IG2: 86 | IG1: mean 57.4 years, SD 12.8, range: NR IG2: mean 57.6 years, SD 12.0, range: NR | NR | IG1: 27 IG2: 46 | IG1: 23 IG2: 40 | NR | NR | NR
Hack (1999) | Breast & Prostate | 18 | 18 | Female: mean 52 years, SD NR range: 34 to 77 years Male: mean 67 years, SD NR range: 51 to 79 years | NR | Total: 8 | Total: 28 | NR | NR | NR
Iglehart (1998) | Breast & Ovarian | NA | 213 ^a^ | Total: mean 49 years, SD NR, range: 28 to 88 years | NR | 0 | 213 | 202 | 8 | 3
Irwin (1999) | Breast | N/A | Total: 46 | Total: mean 45.5 years, SD NR range: 34 to 53 years | < $30,000 (Cdn): 29 | Total: 7 | Total: 39 | NR | NR | NR
Lerman (1997) | Breast | N/A | IG1: 114 IG2: 122 CG: 164 | Age > 50 years: IG1: mean 34 years, SD, range: NR IG2: mean 30 years SD, range: NR CG: mean 50 years SD, range: NR | < $35,000 (US): IG1: 22; IG2: 27 CG: 107 | IG1: 7 IG2: 14 CG: 20 | IG1: 107 IG2: 108 CG: 144 | IG1: 84 IG2: 92 CG: 107 | IG1: 29 IG2: 28 CG: 49 | IG1: 1 IG2: 2 CG: 7
Maslin (1998) | Breast | N/A | IG: 51 CG: 49 | Total: mean 52.1 years, SD NR range: 28 to 73 years | NR | NR | NR | NR | NR | NR
North (1992) | Not Specified | IG: 9 CG: 7 | IG: 9 CG: 9 | IG: mean 54.1 years, SD, range NR CG: mean 56.4 years, SD, range NR | NR | NR | NR | NR | NR | NR
Pignone (2000) | Colorectal | IG: 51 CG: 48 | IG: 74 CG: 76 | IG: mean: 63.1 years, SD NR CG: mean: 62.7 years, | NR | IG: 34 CG: 20 | IG: 91 CG: 104 | IG: 105 CG: 112 | NR | NR
Schapira (2000) | Prostate | IG: 122 CG: 135 | N/A | Men 50 to 80 years: IG: mean 69.4 years, SD 7.3 CG: mean 70.4 years, SD 6.4 | NR | NR | NR | IG: 116 CG: 122 | IG: 1 CG: 6 | IG: 5 CG: 6
Street (1995) | Breast | N/A | IG: 30 CG: 30 | IG: mean 57.4, SD NR range: 35 to 76 years CG: mean 60.8, SD NR range: 35 to 82 years | NR | IG: 1 CG: 0 | IG: 29 CG: 30 | IG: 28 CG: 27 | NR | IG: 2 CG: 3
Volk (1999) | Prostate | IG: 80 CG: 80 | N/A | Men 45 to 70 years: IG: mean 58.5, SD NR CG: mean 59.5, SD NR | < $9,999 (US): IG: 14 CG: 17 | IG: 14 CG: 21 | IG: 64 CG: 59 | IG: 48 CG: 49 | IG: 18 CG: 12 | IG: 14 CG: 19
Watson (1998) | Breast | N/A | IG: 55 CG: 56 | NR | NR | NR | NR | NR | NR | NR
Wolf (2000) | Colorectal | IG1: 48 IG2: 48 CG: 51 | IG1: 82 IG2: 88 CG: 82 | IG1: mean 74 years, SD 6 IG2: mean 74 years, SD 6 CG: mean 75 years, SD 6 | < $15,000 (US) IG1: 79 IG2: 77 CG: 82 | IG1: 58 IG2: 61 CG: 70 | IG1: 72 IG2: 75 CG: 63 | IG1: 98 IG2: 98 CG: 102 | NR | IG1: 32 IG2: 38 CG: 31
Wolf (1996) | Prostate | IG: 103 CG: 102 | N/A | Men > 50 years of age: IG: mean 64.5, SD 9.8 CG: mean 65.0, SD 8.4 | < $15,000 (US): IG: 69 CG: 64 | IG: 72 CG: 69 | IG: 31 CG: 33 | IG: 64 CG: 65 | NR | IG: 39 CG: 37

a Demographic data are on the 213 subjects who completed genetic testing.

Table 24. Study demographics: Controlled trials and nonconcurrent cohort studies

Author (Year) | Type of Cancer | Gender (# of subjects) | | Age | Annual Family Income (# of subjects) | Education (# of subjects) | | Ethnicity (# of subjects)
Author (Year) | Type of Cancer | Male | Female | Age | Annual Family Income (# of subjects) | < High school | > High school | Caucasian | African-American | Other
Flood (1996) | Prostate | 409 | NA | IG: mean 64.3 years, SD NR CG: mean 63.6 years, SD NR | NR | NR | IG: 99 CG: 107 | NR | NR | NR
Flood (1996) | Prostate | 222 | NA | Men > 50 years of age: IG: mean 66.5 years, SD NR CG: mean 64.4 years, SD NR | NR | NR | IG: 81 CG: 60 | NR | NR | NR
Molenaar (2001) | Breast | NA | IG: 92 CG: 88 | IG: mean 55.4 years, SD 10.8 CG: mean 54.6 years, SD 10.6 | NR | IG: 9 CG: 9 | IG: 83 CG: 79 | NR | NR | NR
Sepucha (2000) | Breast | NA | IG: 12 CG: 12 | IG: mean 47 years, SD 6.9 CG: mean 48 years, SD 6.7 | NR | NR | IG: 11 CG: 12 | IG: 10 CG: 11 | NR | IG: 2 CG: 1
Whelan (1995) | Breast | NA | IG: 30 CG1: 23 CG2: 29 | # women > 50 years: IG: 23 CG1: 19; CG2: 21 | NR | IG: 5 CG1: 0 CG2: 6 | IG: 25 CG1: 23 CG2: 23 | NR | NR | NR
Whelan (1999) | Breast | NA | IG: 175 CG: 194 | IG: mean 56.2 years, SD NR Number > 60 years: 66 CG1: mean, SD NR; Number > 60 years: 90 | NR | IG: 52 CG: NR | IG: 123 CG: NR | NR | NR | NR

Table 25. Study demographics: Case series

Author (Year) | Type of Cancer | Gender (# of subjects) | | Age | Annual Family Income (# of subjects) | Education (# of subjects) | | Ethnicity (# of subjects)
Author (Year) | Type of Cancer | Male | Female | Age | Annual Family Income (# of subjects) | < High school | > High school | Caucasian | African-American | Other
Adler (1999) | Breast | NA | 41 | mean, SD NR; range: 21 to 60 years | NR | NR | NR | NR | NR | NR
Ashcroft (1985) | Breast | NA | 18 | mean, SD NR; range: 20 to 70 years | NR | NR | NR | NR | NR | NR
Brundage (2000) | Lung | 10 | 8 | mean 68.2 years, SD 8.0 | NR | 11 | 7 | NR | NR | NR
Cassileth (1989) | Prostate | 147 | NA | mean, SD NR; range: 48 to 96 years | NR | 59 | 88 | 99 | NR | NR
Cotton (1995) | Breast | NA | 20 | mean, SD NR; range: 51 to 67 years | NR | NR | NR | NR | NR | NR
Cotton (1991) | Breast | NA | 91 | Not clear | NR | NR | NR | NR | NR | NR
Fiset (2000) | Lung | 12 | 8 | mean 63 years, SD 11, range: 38 to 83 years | NR | 5 | 15 | NR | NR | NR
Gramlich (1998) | Breast | NA | Not clear (103?) | NR | NR | NR | NR | 46% (n=47?) | NR | NR
Klass (1992) | Prostate | 101 | NA | mean 73 years, SD NR | NR | NR | NR | NR | NR | NR
Levine(1992) | Breast | NA | 37 | mean 43.6 years, SD NR | NR | NR | NR | NR | NR | NR
Okamato (1999) | Hypopharyngeal | NR | NR | mean, SD, range: NR | NR | NR | NR | NR | NR | NR
Onel (1998) | Prostate | 111 | NA | mean 67 years, SD NR | NR | 0 | 111 | NR | NR | NR
Protiere (2000) | Breast | NA | 71 | Not clear | NR | 27 | 44 | NR | NR | NR
Sandison (1996) | Breast | NA | 50 | Women age >70 years: mean, SD NR, range 70 to 94 years | NR | NR | NR | NR | NR | NR
Stalmeier (1999) | Breast | NA | 54 | mean 38 years, SD 11 | NR | 7 | 47 | NR | NR | NR
Wilson (1988) | Breast | NA | 153 | mean, SD NR; range 27 to 65 years | NR | NR | NR | NR | NR | NR
Wolberg (1987) | Breast | NA | 250 | NR | NR | NR | NR | NR | NR | NR

## Decision Aids and Outcomes

- What outcomes have been evaluated (e.g., increase in knowledge, satisfaction, and behaviors)? (See Type of Outcome Measures, page 72, and Tables 26 to 28.)
- Are there any key outcomes that are associated with specific characteristics of decision aids? (Chapter)

Table 26. Outcomes measured by type of cancer: RCT Studies

Author (year) | Type of Decision | | | | | Outcomes Measured
| Genetic Testing | Screening | Prevention | Treatment | | Decision | Acceptability of DA | Anxiety | Decisional conflict | Decisional regret | Depression | Determinants of choice | Knowledge | Limitation of The test | Optimism | Quality of life | Risk perception | Satisfaction | Other
Prostate Cancer
Davison (1997) | | | | X | | X | X | X | | | X
Davison (1999) | | X | | | | X | | X | X | | | X
Schapira (2000) | | X | | | | X | | | | | | | X
Volk (1999) | | X | | | | X | X | | | | | | X
Wolf (1996) | | X | | | | X | | | | | | | X
Breast Cancer
Goel (2001) | | | | X | | X | | X | X | X | | | X | | | | | | X
Irwin (1999) | | | | X | | X | X | | | | | X | X
Lerman (1997) | X | | | | | X | | | | | | | X | X | | | X
Maslin (1998) | | | | X | | X | X | X | | | X | | | | | X | | X
Street (1995) | | | | X | | X | | | | | | | X | | X
Iglehart (1998) | X | | | | | X | | | | | | | X | | | | X | | X
Watson (1998) | X | X | X | | | X | X | X | | | | | X
Breast and Prostate cancer
Hack (1999) | | | | X | | | | X | | | | | X | | | | | X
Colorectal cancer
Wolf (2000) | | X | | | | X | | | | | | | X | | | | | | X
Pignone (2000) | | X | | | | X | | | | | | | | | | | | | X
Not specified
North (1992) | | | | X | | | X | X | | | | | X

Table 27. Outcomes measured by type of cancer: nonrandomized controlled trials and nonconcurrent cohort studies

Author (Year) | Design | Type of Decision | | | | Outcomes Measured
| | Genetic testing | Screening | Treatment | | Decision | Acceptability of DA | Decisional conflict | Determinants of choice | Knowledge | Quality of life | Satisfaction | Would recommend DA to others
Prostate Cancer
Flood (1996) | Controlled Trial | | X | | | X | | | | X
Flood (1996) | Controlled Trial | | X | | | X | | | | X
Breast Cancer
Molenaar (2001) | Controlled Trial | | | X | | X | | X | | | X | X
Sepucha (2000) | Controlled Trial | | | X | | X | | | | | | X
Whelan (1995) | Nonconcurrent cohorts | | | X | | X | | | X | X
Whelan (1999) | Nonconcurrent cohorts | | | X | | X | X | | | X | | X | X

Table 28. Outcomes measured by type of cancer: Case series

Author (Year) | Type of Decision | | | | | Outcomes Measured
| Genetic Testing | Screening | Prevention | Treatment | | Decision | Anxiety | DA acceptability | DA helps patient decide | Decision burden | Decisional conflict | Decision uncertainty | Depression | Determinants of choice | Knowledge | Quality of life | Satisfaction | Would choose again | Would recommend DA | Other
Breast
Adler (1999) | | | | X | | X | | | | | | | | | | | X | X | | X
Ashcroft (1985) | | | | X | | X | X | | | | | | X
Cotton (1995) | | | | X | | X | | | X | | | | | X | | | X | X
Cotton (1991) | | | | X | | X
Gramlich (1998) | | | | X | | X | | X | | | | | | | | | X | | X
Levine (1992) | | | | X | | X | | X | X | | | | | | | | | | X | X
Protiere (2000) | | | | X | | X | | | | | | | | X | | X | X | | X | X
Sandison (1996) | | | | X | | X | | | | | | | | | | | X
Stalmeier (1999) | | X | X | | | X | | | | X | | X | | | X | | | | | X
Wilson (1988) | | | | X | | X | | | | | | | | X | | | X | X
Wolberg (1987) | | | | X | | X | X | | | | | | X | X | | | X | | | X
Lung
Brundage (2000) | | | | X | | X | | | X | | | X | | | X | | | | X | X
Fiset (2000) | | | | X | | X | | X | | | X | | | | X
Prostate
Cassileth (1999) | | | | X | | X | | | | | | | | X | | | X | X
Klass (1992) | | | | X | | X | | | | | | | | | | | X
Onel (1998) | | | | X | | X | | | | | | | | X | X | | X | X | | X
Hypopharyngeal
Okamato (1999) | | | | X | | X | | | | | | | | | | | | | | X

## Effectiveness of Decision Aids

- What is the effectiveness of decision aids? (See Chapters 6 and 7.)
- What is the effectiveness of decision aids in different clinical contexts? (See Type of DA Interventions and Type of Decisions, below, and Tables 20 to 22.)
- What is the effectiveness of different modes of delivery? (See Type of DA Interventions, below, and Tables 20 to 22.)

What is the effectiveness of decision aids on special populations? (See DAs for Special Populations, page 71, and Chapters 6 and 7.)

## General Characteristics of Included Studies

Thirty-nine studies evaluated a DA intervention with patients who were offered an actual choice or who expressed a preference in a clinical rather than a hypothetical situation.

### Type of Study Designs

Of the 39 studies, 16 were RCTs,^50-65^ four were nonrandomized controlled trials,^66-69^ two were nonconcurrent cohort studies,^70,71^ six were pre/post designs,^72-77^ and the remaining 11 were case series.^78-88^ For the remainder of the chapter, the pre/post studies will be reported with the case series studies.

### Type of DA Interventions

The DAs evaluated in these studies range from simple take-home pamphlets to complex interventions consisting of multiple components (Tables 20 to 22). In eight studies, written materials or DA brochures were used.^55,59,62,65,84-87^ Three studies gave patients an audiotape of their consultation.^51,57,60^ Two studies evaluated the use of audiotape workbooks.^65,77^ Six studies investigated videotape (or slide/tape interventions).^52,63,66,67,74,81^ Four studies evaluated interactive computer programs.^56,59,69,75^ In seven studies, the DAs were primarily counseling or educational sessions.^53,54,64,79,80,83,88^ One study used informal decision analysis to assist patients in making a decision.^76^ There were four studies that assessed the use of DBs.^61,70,71,78^ The remaining six studies involved complex DA interventions with a number of the above components.^50,58,68,72,73,82^ (Refer to Tables 20 to 22.)

### Type of Decisions

We used a continuum of cancer care to order the types of decisions (preventive care, screening, diagnosis, and treatment). There were two studies that used DAs to support women at high risk for developing breast cancer in deciding between taking preventive measures or opting for breast cancer surveillance.^51,72^ One study evaluated a DA to assist women in deciding whether to provide a blood sample for future genetic testing.^50^ One study explored the use of a DA to help women with breast or ovarian cancer who had a high probability of carrying a breast cancer gene mutation in deciding whether to undergo genetic testing.^62^ In eight studies, DAs were used to assist patients in deciding whether to have a screening test.^52-55,63,64,66,67^ The majority of DA interventions (27 of 39 studies) were used to facilitate a choice between different treatment options.^56-61,65,68-71,73-88^

### Type of Cancer

Twenty-two studies evaluated DAs related to the prevention or treatment of breast cancer.^50,51,56,59,61,62,65,68-72,75,76,78-85^ In 10 studies, the interventions were related to prostate cancer.^52-55,58,66,67,74,86,87^ One study assessed a DA in both breast and prostate cancer patients.^57^ Two studies evaluated DAs to assist patients with advanced non-small-cell lung cancer make a treatment decision.^73,77^ Two studies assessed interventions related to colorectal screening.^63,64^ One study involved the use of a DA intervention for patients with hypopharyngeal cancer.^88^ One study evaluated an audiotape DA in a diverse group of cancer patients.^60^

### Type of Populations

The sample characteristics of the 39 studies are summarized in Tables 23 to 25. In eight studies, the eligibility criteria limited the sample to a certain age range.^52-55,63,64,67,83^ Five of these studies involved prostate cancer screening.^52-55,67^ All of these studies restricted their samples to middle or older age men (lower age limit varied from 45 to 50 years; upper limit from 70 years to no limit). Similarly, the two studies investigating colorectal screening restricted their samples to older individuals (lower age limit varied from 50 to 65 years; upper limit from 75 years to no limit).^63,64^ The study by Sandison, et al.^83^ investigated breast cancer treatment decisionmaking in women age 70 years or older (refer to DAs for special populations section below for more detail). Only five studies reported information regarding income level.^50,52,54,61,64^ None of the studies targeted a particular SES class. However, in the prostate cancer screening study by Wolf and colleagues,^54^ more than 50 percent of the participants had annual incomes below $15,000. Of the 39 studies, 25 provided information about participants' level of education.^50,52-54,57-59,61-75,77,84,86^ The majority of participants in each of these 19 studies had at least a high school education, except for three studies.^54,58,73^ No study targeted a DA intervention for a specific education level. Ethnicity of participants was reported in 11 studies.^50,52,54,55,59,62-64,68,75,86^ In all of these studies, the majority of participants were Caucasian, except for the study by Gramlich, et al.^75^ This study was conducted in Hawaii, and approximately 50 percent of the participants were from an Asian ethnic group (Japanese, Chinese, Filipino, or Korean). In no study was the DA intervention designed to target a particular ethnic group.

### DAs for Special Populations

Only one study assessed a DA in a special population. In this case series, Sandison, et al.^83^ explored whether women aged 70 and over with breast cancer would elect to choose their own treatment from four options or ask their surgeon to decide. In addition to the normal consultation, the DA consisted of individual counseling with a nurse and take-home information. Of the 50 women studied, 38 decided to choose their own treatment. The majority of these women (n=34) opted for breast conservation (plus radiation therapy and tamoxifen or tamoxifen only). The authors reported that at 1-year followup only two patients who chose their own treatment were unhappy with their decision. Lerman, et al.^50^ conducted a study that compared two DA interventions designed to help women at low to moderate risk for breast cancer decide whether to undergo BRCA1 gene testing. The authors reported results from a post hoc analysis that assessed ethnic differences in motivation for BRCA1 genetic testing in Lerman et al.^89^ The authors concluded that, in low to moderate risk African-American women, the DA intervention consisting of education plus counseling may increase BRCA1 testing.

### Type of Outcome Measures

A variety of outcomes were investigated in the 39 effectiveness studies identified. All but two studies assessed patient decisions (either actual choice or stated preference).^57,60^ "Knowledge" (including the measurement of knowledge, understanding, or recall) was the second most frequently measured outcome. Knowledge was assessed in 12 of the 16 RCTs,^50-52,54,55,57,59-62,64,65^ in four out of six controlled trials and nonconcurrent cohort studies^66,67,70,71^ and in 4 of the 17 case series.^72-74,77^ Overall, anxiety and/or depression were measured in nine studies: seven RCTs^51,53,56-58,60,65^ and two case series.^76,82^ Patients' decision burden, decision uncertainty, or decisional conflict were measured in two RCTs^53,65^ and three case series.^72,73,77^ Acceptability of the decision aid intervention was assessed in six RCTs,^51,52,56,58,60,61^ one nonconcurrent cohort study,^71^ and four case series.^75,77-79^ Patient satisfaction with the decision aid, the decisionmaking process, or the actual decision was assessed in two RCTs,^56,57^ two controlled trials,^68,69^ one nonconcurrent cohort study,^71^ and 10 case series.^74,75,79,81-87^ Refer to Tables 26, 27, and 28 for further information on outcomes measured.

### Type of Comparisons

Of the 16 RCTs, 8 compared one DA intervention to another DA intervention.^50,54,55,59,61,62,64,65^ Of these eight studies, four had a third comparison group.^50,52,57,64^ The study by Lerman, et al.^50^ also compared the two DA interventions to a wait list control group, while the three other studies compared the two DA interventions to the medical care that patients would typically receive (usual care).^52,57,64^ There were eight RCT studies that compared a DA intervention to usual care.^51,53-56,58,60,63^ Of the four nonrandomized controlled trials, one compared a DA intervention to another DA,^68^ and three compared a DA intervention to usual care.^66,67,69^ Both of the nonconcurrent cohort studies compared a DA intervention to usual care.^70,71^ Refer to Tables 20 and 21 for further details of the types of comparisons made.

### Type of Decisionmaking Models or Frameworks

In 18 of the 39 studies, the type of decisionmaking model was reported. The majority of these studies (15 of 18) stated that a "shared" model of decisionmaking was used.^52,56,61,65-72,74,75,78,84^ Two studies identified use of an "informed" model,^50,55^ and one stated use of an "empowerment" model.^58^ In the remaining 21 studies, the type of decisionmaking model was not identified.^51,53,54,57,59,60,73,76,79-83,85,86^ We attempted to classify the model of decisionmaking as "shared," "informed," or "paternalistic" by using the descriptions in each study (refer to Table 29). We classified only three studies as having used a "shared" model.^58,68,76^ Thirty-three studies were classified as having used an "informed" model.^50-57,59-64,66,67,69,70,72-74,77-88^ In three studies, the model of decisionmaking could not be determined because certain details of the intervention were not described.^65,71,75^

## Quality Assessment

Each of the 39 studies was assessed independently by two reviewers using the Downs and Black scale^22^ (Tables 30 to 32). The Downs and Black scale consists of four subscales: reporting, internal validity (bias), internal validity (confounding), and external validity. The quality of the 16 RCTs was also measured with the Guyatt et al.^23^ and Jadad et al.^21^ scales. Refer to Appendix F for detailed results of the quality assessment using these scales.

Table 30. Quality assessment of RCT studies using the Downs & Black Checklist

Author (year) | Reporting (Maximum score: 9) | External Validity (Maximum score: 3) | Internal Validity: Bias (Maximum score: 6) | Internal Validity: Confounding (Maximum score: 6) | FINAL SCORE (Maximum score: 24)
Maslin, 1998 | 3 | 1 | 1 | 3 | 8
North, 1992 | 5 | 0 | 1 | 3 | 8
Inglehart, 1998 | 4 | 2 | 1 | 3 | 10
Watson, 1998 | 4 | 1 | 2 | 3 | 10
Hack, 1999 | 3 | 2 | 3 | 3 | 11
Shapira, 2000 | 5 | 2 | 2 | 3 | 12
Irwin, 1999 | 6 | 2 | 2 | 3 | 13
Davison, 1999 | 6 | 2 | 3 | 3 | 14
Street, 1995 | 7 | 1 | 3 | 3 | 14
Wolf, 2000 | 7 | 2 | 2 | 3 | 14
Davison, 1997 | 6 | 2 | 4 | 3 | 15
Lerman, 1997 | 8 | 2 | 2 | 3 | 15
Wolf, 1996 | 7 | 2 | 2 | 4 | 15
Volk, 1999 | 7 | 2 | 3 | 4 | 16
Pignione, 2000 | 9 | 2 | 3 | 4 | 18
Goel, 2001 | 9 | 3 | 3 | 5 | 20
Davison, 1997 | 6 | 2 | 4 | 3 | 15
Davison, 1999 | 6 | 2 | 3 | 3 | 14
Goel, 2001 | 9 | 3 | 3 | 5 | 20
Hack, 1999 | 3 | 2 | 3 | 3 | 11
Inglehart, 1998 | 4 | 2 | 1 | 3 | 10
Irwin, 1999 | 6 | 2 | 2 | 3 | 13
Lerman, 1997 | 8 | 2 | 2 | 3 | 15
Maslin, 1998 | 3 | 1 | 1 | 3 | 8
North, 1992 | 5 | 0 | 1 | 3 | 8
Pignione, 2000 | 9 | 2 | 3 | 4 | 18
Shapira, 2000 | 5 | 2 | 2 | 3 | 12
Street, 1995 | 7 | 1 | 3 | 3 | 14
Volk, 1999 | 7 | 2 | 3 | 4 | 16
Watson, 1998 | 4 | 1 | 2 | 3 | 10
Wolf, 2000 | 7 | 2 | 2 | 3 | 14
Wolf, 1996 | 7 | 2 | 2 | 4 | 15

### Randomized Controlled Trials

All three of the quality scales used to assess the RCTs yielded similar findings. Overall, 13 of these studies were rated as low methodological quality across all three scales. Only three studies^52,63,65^ were found to be of high quality. The results of the quality assessment highlighted several common areas of weakness among the RCTs. Most of the studies had satisfactory scores on the reporting subscale; however, many of the RCTs did not fully describe the DA intervention, nor did many of the studies report the number of patients lost to followup. On the internal validity (bias) subscale, all of the studies with the exception of the study by Davison^58^ had low scores. Only one study used a blinded assessment of the outcome measures,^63^ but there was no blinding among the included subjects or in statistical analyses in any of the RCTs. Only four studies^54,61^ reported reliability and/or validity of the intervention (DA). The outcome measures used were valid and reliable in 8 of the 16 studies.^52,53,53,56,56,57,57,58,58,59,59,60,60,65^ Compliance with the intervention was described in only two studies.^51,51,58^ On the internal validity (confounding) subscale, only five studies^52,53,53,58,58,65,90^ gave a complete description of the method used for random assignment; furthermore, none of the studies discussed whether there was randomization concealment.

### Nonrandomized Controlled Trials, Nonconcurrent Cohort Studies, and Case Series

The Downs and Black scale^22^ was used to evaluate all of these studies. The maximum possible score for each subscale was modified according to the study design. The number of items assessed was less than for the RCT studies. Scores for nonrandomized controlled trials and non-concurrent cohort studies were 12,^66,68,70,68,70^ 13,^67,71^ and 17^69^ of the 22 achievable points. The highest scores were seen on the reporting subscale and the lowest on the external validity sub-scale (Table 31). Across all of the studies, the comparison groups had similar baseline characteristics. In only one study was there an intention to "blind" the intervention,^68^ but outcome measurement was not blinded in any of the studies.

Table 31. Quality assessment of nonrandomized controlled trials and nonconcurrent cohort studies using the Downs & Black Checklist

Author (year) | Reporting (Maximum score: 9) | External Validity (Maximum score: 3) | Internal Validity: Bias (Maximum score: 6) | Internal Validity: Confounding (Maximum score: 4) | FINAL SCORE (Maximum score: 22)
Flood, 1996 ^a^ Study 1 | 8 | 0 | 2 | 2 | 12
Sepucha, 2000 ^b^ | 5 | 2 | 3 | 2 | 12
Whelan, 1995 ^b^ | 7 | 2 | 2 | 1 | 12
Flood, 1996 ^a^ Study 2 | 7 | 2 | 2 | 2 | 13
Whelan, 1999 ^b^ | 7 | 2 | 3 | 1 | 13
Molenaar, 2001 ^a^ | 9 | 2 | 3 | 3 | 17

a Controlled trial

b Nonconcurrent cohort

Similar results were found for the case series studies. Overall, total scores ranged from 6 to 14. The four highest scoring case series^73,77,80,84,84^ received 14 of 22 possible points. As seen in the other non-RCT studies, the reporting subscale had the highest scores and the validity sub-scales the lowest scores. Not surprisingly, the internal validity scores for the case series were lower than for the other study designs (Table 32).

Table 32. Quality assessment of case series studies using the Downs & Black Checklist

Author (Year) | Reporting (Maximum score: 8) | External Validity (Maximum score: 3) | Internal Validity: Bias (Maximum score: 6) | Internal Validity: Confounding (Maximum score: 2) | FINAL SCORE (Maximum score: 19)
Adler (1999) | 4 | 2 | 2 | 1 | 9
Ashcroft (1985) | 5 | 2 | 3 | 0 | 10
Brundage (2000) | 8 | 1 | 3 | 2 | 14
Cassileth (1989) | 5 | 3 | 2 | 1 | 11
Cotton (1991) | 7 | 3 | 2 | 2 | 14
Cotton (1995) | 3 | 1 | 2 | 2 | 8
Fiset (2000) | 8 | 1 | 3 | 2 | 14
Gramlich (1998) | 2 | 1 | 2 | 1 | 6
Klass (1992) | 6 | 0 | 2 | 1 | 9
Levine (1992) | 5 | 1 | 2 | 2 | 10
Okamoto (1999) | 4 | 0 | 2 | 1 | 7
Onel (1998) | 5 | 0 | 2 | 2 | 9
Protiere (2000) | 7 | 3 | 2 | 2 | 14
Sandison (1996) | 6 | 2 | 2 | 2 | 12
Stalmeier (1999) | 8 | 1 | 2 | 2 | 13
Wilson (1988) | 5 | 3 | 2 | 1 | 11
Wolberg (1987) | 5 | 2 | 3 | 0 | 10

## Outcomes by Type of DA Intervention

The studies in this section are organized by the mode of delivery and degree of interaction of the DA intervention. In most studies, the DA intervention was supplemented by some form of usual care. In some studies, it was difficult to disentangle distinct components of the DA intervention, and we recognize that our categorization of the type of intervention may be arbitrary. We made a careful distinction between general information pamphlets and DA brochures. In DA brochures, screening or treatment options were clearly identified, along with associated risks and benefits, and the objective was to support decisionmaking. In this section, we discuss DA interventions in the following order: DA brochure, educational script, audiotape, videotape, interactive computer program, counseling, DB, and complex interventions (more than one component). Within each category, RCT studies are reported first, followed by nonrandomized controlled trials and then case series. For each study, we report the type and stage of cancer, the type of decision and options, the DA intervention, and primary outcome data. Details of each study are reported in their respective evidence tables.

### DA Brochure (Evidence Tables 5.1 to 5.6, 5.12, and 5.21)

Eight studies assessed the use of DA brochures (four RCTs and four case series).

#### Randomized Controlled Trials

Schapira and colleagues^55^ compared the use of a DA brochure to an information pamphlet. They tested the effect of an illustrated 8-page DA brochure on screening decisions (prostate specific antigen test [PSA] or digital rectal examination [DRE]) of men aged 50 to 80 who had attended an outpatient visit at a Department of Veterans Affairs Hospital. Men in the intervention group (n=122) received an 8-page illustrated pamphlet containing basic prostate cancer information and balanced descriptions of the quantitative and qualitative outcomes regarding risks and benefits of screening with DRE and PSA test. A research assistant was present to answer questions and a followup visit was scheduled. Menin the control group(n = 135)received a 5-page pamphlet containing basic prostate cancer information (i.e., epidemiology, symptoms of prostate cancer) as well as the other components (i.e., research assistant and followup visit).

Iglehart and colleagues^62^ published preliminary results of an RCT that compared two DA brochures designed to assist women at high risk of carrying a breast/ovarian cancer mutation in deciding whether to undergo genetic testing. One group of participants received a DA brochure that was individually tailored to each participant's education level, carrier probability, and preference for quantitative or qualitative risk estimates. The other group received a DA brochure containing generic information on genetic testing and breast and ovarian genetics. After receiving the DA brochures, all participants had the option of attending free genetic counseling and testing. The purpose of the study was to determine the effect of the individualized DA brochure compared to the generic DA brochure on participants' decisions, attitudes, and knowledge. To date, three interim papers have been published: the first two report baseline data^62,91^ and the third details the mutations identified and provides some preliminary results.^92^ In all three studies, the only data presented has been combined for two intervention groups. The authors report that the trial is now closed and participants are in the process of finishing genetic counseling, making genetic testing decisions, and entering the followup phase. Refer to Evidence Tables 5.2a and b for details of the outcomes measured.

Two RCTs compared DA brochures to another type of DA intervention. Goel and colleagues^65^ compared a DA brochure to an audiotape workbook. Refer to the Audiotape section for a discussion of this study. Street and colleagues^59^ compared a DA brochure to an interactive computer program. Refer to the Interactive Computer section for further details.

#### RCT Outcomes

##### Decision

Schapira and colleagues^55^ found that the DA did not influence decisions regarding screening uptake (p=0.60).

##### Knowledge/Beliefs

They also assessed knowledge between the groups. They used an 18-item closed-ended questionnaire that was developed and pretested before its application. There were no baseline differences in the scores between the groups. After the intervention, both groups increased their scores, but those in the DA brochure group were statistically higher than those in the informational pamphlet group (p < 0.01).

They also assessed men's beliefs using a prostate cancer belief-assessment survey consisting of 10 closed-ended items that was previously pilot-tested. Domains in the belief assessment included natural history, intentions to use screening, intentions to follow physician advice, perceptions of test characteristics, and how well informed participants felt. Postintervention beliefs were compared between groups; men in the intervention group provided more accurate responses in 2 of the 10 items (p < 0.01, and p < 0.05, respectively).

#### Case Series

Four case series evaluated written information provided to patients as DA interventions.^84-87^ In three studies a DA brochure was used, and in one study no detail about the material was provided.

Two of the studies dealt with adjuvant breast cancer treatment options.^84,85^ In Adler,^85^ the intervention consisted of education by a team (oncologist and oncology nurses) about the differences between two chemotherapy regimens including side effects, duration, administration, and number of needles. In addition, women were given take-home information (details not specified). Forty-one women with early stage breast cancer were given a choice between two types of adjuvant chemotherapy: doxorubicin/cyclophosphamide (AC) and cyclosphosphamide/methotrexate/fluorouracil (CMF). Protière and colleagues^84^ offered 64 breast cancer patients with nonmetastatic disease a choice of receiving their adjuvant chemotherapy and radiation therapy either sequentially or concomitantly. The intervention consisted of a consultation based upon a DA brochure. Patients were given the DA brochure to take home.

The two other case series evaluated DA brochures for advanced prostate cancer treatment options. Cassileth and colleagues^86^ gave men (n=159) the choice between surgical and hormonal castration. After discussing treatment choices with their physicians, patients took home a 2-page DA brochure. Klass and colleagues^87^ also gave men (n=101) the choice between surgical and hormonal castration. Following the oncology consultation, participants were provided with a DA brochure that they could takehome to review.

#### Case Series Outcomes

##### Decision

In the study by Adler,^85^ 41 women were given the choice between two types of chemotherapy and 36 women answered a questionnaire after completing their selected treatment. Two women stated they did not remember being given a choice, 22 chose AC, and 12 opted for CMF chemotherapy. In Protière and colleagues,^84^ 41 breast cancer patients elected to have the shorter concomitant treatment, while 23 patients decided to have their adjuvant treatment sequentially. In the Cassileth and colleagues^86^ study with advanced prostate cancer patients, surgical castration was chosen by 32 patients, while the majority of patients (115/147) chose hormonal castration. In the other prostate cancer study, Klass and colleagues^87^ reported that an equal number of patients chose surgical castration (n=46) and hormonal castration (n=46). Five patients in this study could not decide between the two options.

##### Satisfaction with decisionmaking

In Adler's study^85^ investigating choice between two types of adjuvant chemotherapy, 27 women felt that being given the chance to decide their treatment was beneficial, while 7 reported being unsure whether choosing their treatment was beneficial. Protière and colleagues^84^ reported that 51 of 57 patients were "fully satisfied" with participating in the selection of their adjuvant treatment schedule.

##### Satisfaction with choice

In Klass and colleagues,^87^ all 46 patients who selected surgical castration reported being at least reasonably satisfied with their choice. Of the 46 patients who opted for hormonal castration, only 1 patient responded that he was not at all satisfied with his choice.

##### Acceptability of the DA

In Alder's study,^85^ 5 of the 34 women studied felt that "they were not given enough information to make an informed choice."

#### Other Outcomes

##### Patient would make same decision again

In Adler's study,^85^ women were asked whether "in hindsight they wish they had chosen the alternate treatment." One hundred percent of the AC group said no, compared with 33 percent of the CMF patients having stated they wished they had chosen AC. Three months after choosing either surgical or hormonal castration, men were asked if they would make the same treatment decision again. Of the patients available for followup, all 22 who had surgical castration said they would choose surgery again.^86^ Similarly, 88 of 89 men who chose hormonal treatment would again choose the same option.

##### Quality of life

In Protière and colleagues,^84^ quality of life was measured both pre- and postadjuvant treatment for breast cancer. Global quality of life at the end of treatment was significantly better among patients who decided to have treatment sequentially compared to patients who chose concomitant treatment (p<0.05).

### Educational Script (Evidence Tables 5.7 to 5.8)

#### Randomized Controlled Trials

Two RCTs were conducted using educational script DA interventions, both of which were conducted by Wolf.^54,64^ In the first study, Wolf and colleagues^54^ determined the impact of a scripted educational intervention on patients' interest in undergoing PSA screening. Men older than 50 years visiting their primary care physicians were included in the study and randomly assigned to one of two groups. In the intervention group (n = 103), the research assistant (RA) read aloud the script that contained information related to known risk factors for developing prostate cancer, the ability of the PSA test to detect early symptomatic cancer, the uncertain outcome of early intervention, and a brief description of treatment options for early prostate cancer and their complications. In the control group (n = 102), the RA read aloud a brief statement that a blood test known as the PSA is available that can sometimes detect early prostate cancer before it is otherwise apparent.

In the second study, Wolf and colleagues^64^ compared the impact of two scripted educational interventions on patients' interest in undergoing colorectal screening. Patients 65 years or older attending a routine visit with their primary care physician were included in the study. Participants were randomly assigned to one of three groups. In the first intervention group (n = 130), an RA read aloud a relative risk reduction script that contained information describing two colorectal screening tests; the evidence regarding mortality reduction was presented as a relative risk reduction. In the second intervention group (n = 136), the RA read aloud an absolute risk reduction script that contained the same information describing two colorectal screening tests; however, the evidence regarding mortality reduction was presented as an absolute risk reduction. In the control group (n = 133), an RA read aloud a brief description of the two colorectal screening tests.

#### RCT Outcomes

##### Decision

In the first study, Wolf and colleagues^54^ measured the interest in PSA screening on a 5-point Likert scale. The results showed that men in the experimental group were less interested in PSA testing (p < 0.001). In a subsequent analysis,^93^ the authors evaluated the intervention in a subsample (control group, n = 48; intervention group, n = 56) of men > 65 years old. Again, participants in the intervention group were significantly less interested in screening (p = 0.006).

In the second study, Wolf and colleagues^64^ used a 5-point Likert scale to measure interest in colorectal screening. No statistically significant difference in colorectal screening interest was found between the three groups. Participants were also asked about their intent to have colorectal screening. Again, no statistically significant difference was observed between the three groups.

##### Knowledge

In the colorectal screening study, participants were asked about the positive predictive value of the fecal occult blood test. No significant difference was found between the two intervention groups. However, significantly more intervention group subjects (combined data) answered the question correctly compared to the control group subjects (p=0.0007).

##### Other outcomes

In the prostate cancer study, participants were queried regarding potential predictors of interest derived from the Health Belief Model. The authors reported that there was no significant difference between groups in perceived susceptibility to prostate cancer and in the perceived seriousness of an abnormal PSA test. They also reported that the intervention group considered the PSA test to be less efficacious, and the control group was more willing to accept prostate cancer treatment risks. No raw data were provided, however. Among participants > 65 years, authors reported that men in the intervention group considered PSA screening to be significantly less efficacious than did the control group (p = 0.004). Again, no raw data were reported.

The authors assessed factors associated with the interest in PSA screening using an ordinal logistic regression model. The informational script (p < 0.001) and advancing age (p = 0.04) were associated with decreased interest in PSA testing. On the other hand, family history of prostate cancer was associated with increased interest in screening (p = 0.005).

Wolf and colleagues^64^ also assessed the perceived efficacy of screening in the colorectal cancer study. Participants were asked whether screening reduced the risk of dying from cancer "a great deal," "somewhat," or "very little." The perceived efficacy was highest in the control group, followed by the relative risk reduction script group, and lowest in the absolute risk reduction script group (p=0.0002).

### Audiotapes (Evidence Tables 5.9 to 5.13)

Five studies assessed the use of audiotape interventions (four RCTs and one case series).

#### Randomized Controlled Trials

Four RCTs evaluated the use of audiotapes as DA interventions, three assessed the use of audiotapes of consultations,^51,57,60^ and one investigated the effect of an audiotape workbook.^65^ Watson et al.^51^ studied the effectiveness of a DA in women who had a family history of breast cancer. The intervention group (n = 60) received the standard consultation (which included genetic counseling, physical examination, and a summary letter of the consultation) plus an audiotape of the consultation. The control group (n = 55) received only the standard consultation. The outcome measures were women's recall of risk information, cancer-related worry, and uptake of risk management methods postintervention (i.e., mammography, breast self examination [BSE], tamoxifen, prophylactic mastectomy).

Hack and colleagues^57^ examined the efficacy of offering patients with an initial diagnosis of breast cancer (n = 18) or prostate cancer (n = 18) an audiotape of their primary oncology consultation. The options available to the patients were not reported. Of those with breast cancer, most had early disease, and the stage of prostate cancer was not specified. Cancer patients were randomly assigned to one of three groups: one group did not receive the audiotape, patients in the second group received the audiotape, and participants in the third group were given the choice of receiving or not receiving an audiotape. The authors did not report the number of patients included in each group. Most of the outcomes were reported by type of cancer (prostate or breast), rather than by intervention group, so it was not possible to describe the effectiveness of the DA. Only one outcome (knowledge) was reported by group, and these results are described in the outcome section below.

In North and colleagues,^60^ authors randomly tape-recorded the initial oncologist consultation in 34 consecutive new skin, gastric, lung, ovary, and pancreatic cancer patients with advanced disease in a medical oncology outpatient clinic. The treatment options were not reported. The consultant oncologist used a checklist to ensure that both groups received the same topics and facts during the consultation. All patients in the intervention group (n = 18) took home the tape recording, while those in the control group (n = 16) received nothing in addition to the consultation.

Goel and colleagues^65^ studied 136 women with early breast cancer making decisions about mastectomy or lumpectomy plus radiation therapy. They compared the use of an audiotape workbook (n=86) to a DA brochure (n=50). The audiotape workbook intervention consisted of an audiotape that reviewed the advantages and disadvantages of each treatment option plus an accompanying workbook containing color photographs and graphics. The intervention incorporated a 3-step values clarification exercise in which, after reviewing the pros and cons of each option, a patient assigned a value to each advantage or disadvantage, then examined the values assigned to determine which option was favored. The DA brochure contained identical information as the audiotape workbook, with the exception that it did not contain numbers, photographs, graphics, or a values clarification exercise.

#### RCT Outcomes

##### Decision/Uptake

Watson and colleagues^51^ reported that there were no differences in the uptake of prevention/screening options between the groups; however, no raw data for each group were provided. The various options included mammograms, breast examination (self or clinical), cervical smears and other screening, prophylactic surgery, and taking tamoxifen. North and colleagues^60^ reported that the audiotape aided decisionmaking regarding treatment in 11 of 18 (61 percent) patients. No control group data were reported. Goel and colleagues^65^ only reported the initial treatment preference measured at the baseline survey pre-intervention.

##### Knowledge

One month after the intervention, Watson and colleagues^51^ asked women to recall risk information provided by the clinical geneticist during the consultation. Accuracy of recalling their risk of developing cancer was not statistically significant between the intervention and control groups (p = 0.15). More women in the intervention group (64 percent vs. 42 percent) were able to remember correctly whether they had been given information on risk before age 50; this finding was statistically significant (p < 0.05). There were no differences between groups in the other five items assessed. Hack and colleagues^57^ reported that patients with prostate cancer who received the audiotape by choice (Group 3 -- all patients chose to receive the tape) recalled a more thorough consultation than did patients who were given the audiotape (Group 2) and those patients who were not given the audiotape (Group 1) (p < .05). No data were reported for those with breast cancer. North and colleagues^60^ asked patients to recall information discussed during the consultation, such as treatment options and prognosis. After the consultation, both groups recalled about the same amount the information. One week after the consultation, patients in the intervention group were able to recall significantly more information than were those in the control group (p < 0.0001).

Goel and colleagues^65^ measured knowledge approximately 3 days postintervention using the Breast Cancer Information Test -- Revised (BCIT -- R). This test consists of 18 true/false questions. No significant difference in breast cancer knowledge was observed between the audiotape workbook intervention group and the DA brochure group.

##### Anxiety

Watson and colleagues^51^ also assessed concerns about developing cancer and the impact of cancer worry on daily functioning, using the Cancer Worry Scale (Lerman et al., 1991).^94^ The authors reported that the intervention group scores significantly decreased from baseline at 1 and 6 months postconsultation; however, postintervention control group scores were not provided. Using the Hospital Anxiety and Depression scale, North and colleagues^60^ evaluated anxiety scores before and after the intervention. Baseline scores were similar in both groups. After the intervention, scores in both groups decreased, but the reduction was statistically significant in the intervention grouponly (p < 0.001).

Goel and colleagues^65^ measured anxiety at three points (pre-intervention, postintervention, and at 6-month followup) using the State component of the State-Trait Anxiety Inventory. Pre-intervention, there was no statistically significant difference between the audiotape workbook intervention group and the DA brochure group. The mean anxiety in both groups was high (greater than 50 points). Two to 3 days postintervention (pre-operatively), the mean anxiety score in both groups continued to be high, with no significant difference between the groups. At 6-month followup, the mean anxiety score in both groups decreased to approximately 35 points, which was within the normal range. Again, no significant difference was observed between intervention groups.

##### Acceptability of DA

Watson and colleagues^51^ rated the usefulness of the information on a visual analogue scale (VAS), from 1 = not useful to 10 = very useful. The authors reported that there were no statistically significant differences between the groups; however, no raw data were provided. The audiotape was rated on a VAS (1 = not very helpful, 10 = extremely helpful); and the median score was 8.3 (range 0.2-10). Of 60 women, 8 expressed satisfaction with having the audiotape at home, 5 found it useful for clarifying what the doctor had said, and 4 found it reassuring. Three other women said that the audiotape reinforced their memory of the visit and the information given. Other women said that it helped them to explain information to relatives. North and colleagues^60^ asked patients to express their opinion about using the tape. Seventeen of 18 expressed "very positive feelings." Only one patient reported being "mildly upset" by the audiotape. They also reported that 5 of the 18 patients with the audiotape said it enabled other family members to listen to the interview. The authors also reported that "...several used the tape to explain to their family and at least three patients played the tapes to, and discussed them with, their general practitioners."

##### Decision conflict

Goel and colleagues^65^ measured decision conflict using the O'Connor Decisional Conflict Scale^48^ 2 to 3 days postintervention. There was no significant difference in decision conflict between the audiotape workbook group and the DA brochure group. In a posthoc subgroup analysis, the audiotape workbook reduced decision conflict in women whose initial treatment preference (pre-intervention) was either uncertain or favoring mastectomy (statistical analysis was not reported).

##### Decisional regret

Goel and colleagues^65^ measured decisional regret at 6-month followup. Participants were asked whether they regretted their treatment choice and whether the decision did them a lot of harm. There was no significant difference in decisional regret between the audiotape workbook group and the DA brochure group.

##### Patient would make the same decision again

Goel and colleagues^65^ asked participants at 6-month followup whether they would choose the same treatment again, whether it was the right decision, and whether the decision was a wise one. There was no significant difference in responses between the audiotape workbook group and the DA brochure group.

##### Use of the audiotape

Hack and colleagues^57^ reported that more patients who chose to receive the tape (Group 3) listened to a portion of the tape than those who were given the tape (Group 2) (83 percent vs. 55 percent, p= NS).

#### Case Series

Fiset and colleagues^77^ evaluated an audiotape workbook intervention for patients (n=20) with stage IV lung cancer making the decision whether to have chemotherapy in addition to supportive care and radiation therapy.

#### Case Series Outcomes

##### Decision

Participants were asked about their chemotherapy preference pre- and post-intervention. Pre-intervention, 13 patients preferred chemotherapy, 1 patient preferred supportive care, and 6 patients were unsure. Postintervention, 14 patients preferred chemotherapy, 4 preferred supportive care, and 2 patients remained uncertain.

##### Knowledge

Knowledge was assessed both pre- and postintervention using 16 true/false/unsure items based on information contained in the audiotape workbook intervention. There was a significant improvement in knowledge postintervention (p<0.001).

##### Decision conflict

Decision conflict was measured both pre- and postintervention using two of the subscales from the O'Connor Decision Conflict Scale.^48^ A significant decrease in decision conflict was observed postintervention (p<0.001).

##### Acceptability of DA

All 20 participants found the audiotape workbook intervention helpful and would recommend it to others. Sixteen of the participants reported being satisfied with the amount and clarity of information presented. Fifteen participants thought the information was balanced. Four participants reported that they found the survival information upsetting.

### Videotapes (Evidence Tables 5.14 to 5.19)

There were six studies that examined the effectiveness of a videotape as a DA. There were two RCTs, two nonrandomized controlled trials, and two case series.

#### Randomized Controlled Trials

One RCT^52^ addressed the effectiveness of videotapes in the prostate cancer screening decisionmaking context. Volk and colleagues^52^ included asymptomatic primary care patients who were assigned to one of three groups. One of the intervention groups (n = 40) viewed the videotape, "The PSA Decision: What YOU Should Know," developed by The Foundation for Informed Medical Decision Making, Inc., prior to their office visit. Participants in the other intervention group, after viewing the same videotape, had a utility assessment and then the office visit (n = 40). Patients in the control group only attended their office visit (n = 80). The authors reported that both intervention groups did not differ significantly on any of the sociodemographic indicators, previous PSA testing, or any outcome measure, so the two intervention groups were collapsed into one for further analysis.

Pignone and colleagues^63^ evaluated the impact of a DA videotape plus accompanying DA brochure on colorectal screening decisions of patients 50 to 75 years of age who were attending a visit with their primary care physician. Participants in the intervention group (n=125) viewed a DA videotape that provided information regarding susceptibility to colon cancer and the availability of effective screening tests. After watching the DA videotape, participants were asked to select the color-coded brochure that best reflected their interest in colorectal screening. Each type of DA brochure reinforced the information contained in the DA videotape. Participants in the control group (n=124) viewed an videotape about car safety and then received a car safety information pamphlet.

#### RCT Outcomes

##### Decision

Volk and colleagues^52^ assessed participants' preferences for PSA testing. After the intervention, men who received the DA were less likely to want PSA testing in comparison with men who did not receive the videotape (62 percent vs. 80 percent, p = 0.009). Among intervention group participants, there was a statistically significant decrease from baseline in the percentage (79 percent vs. 62 percent, p = 0.01 of participants wanting PSA testing);no significant change was observed in the control group (78 percent vs. 80 percent).

Pignone and colleagues^63^ assessed participants' decisions to have colorectal screening in two ways. First, they asked participants whether a screening test had been ordered during the visit with their primary care physician immediately following the intervention. Second, they conducted a followup chart review at 6 months postintervention. Significantly more participants in the intervention group reported ordering colorectal screening tests compared to the control group (no p value provided). The results of the chart review were: (1) significantly more colorectal screening tests had been ordered for the intervention group participants compared to the control group (no p value provided), and (2) significantly more colorectal screening tests had been completed for participants in the intervention group compared to the control group (no p value provided).

##### Knowledge

Volk and colleagues^52^ developed a 10-item instrument that included domains related to the videotape content (i.e., prostate cancer epidemiology, screening accuracy, treatment effectiveness) to evaluate prostate cancer knowledge. Two weeks after the intervention, more participants in the intervention group answered at least 5 out of 10 questions correctly compared to control participants (62 percent vs. 31 percent, p=0.001). The intervention groups' score compared to baseline was also significantly improved (p = 0.001).

##### Acceptability of DA

In the study by Volk and colleagues,^52^ the intervention group was asked to rate the videotape. Ninety-two percent reported that they would recommend its use to other patients, 79 percent considered the information was about right, and 86 percent felt that the videotape length was about right. Eighty-six percent rated the issues as clearly presented, and 79 percent rated the presentation as completely balanced. The perceived influence of the DA on their decisions was expressed as "a great deal" by 35 percent, "quite a bit" by 28 percent, "a moderate amount" by 20 percent, "not much" by 11 percent; and "not at all" by 7 percent of the subjects in the intervention groups.

##### Nonrandomized controlled trials

Flood and colleagues performed two studies^66,67^ to evaluate educational videotapes designed to inform men about the uncertainty surrounding PSA screening. Both studies were reported in the same article. In the first study,^66^ the authors included men attending a clinic that was offering free prostate screening examinations and evaluated two different videotapes. The control group (n = 203), enrolled on day 1, viewed a videotape that advocated the utilization of PSA testing ("Shering Video"), while men in the intervention group (n = 206), enrolled on day 2, viewed the "Prostate-PORT Video" that was specifically developed for the study. This videotape was designed to encourage patients to participate in the decision to screen for prostate cancer, presenting not only the pros and cons of the screening, but also the uncertainty surrounding the effectiveness of treatment and the complications that may occur. After the intervention, men were invited to receive a DRE and a PSA test. The authors also asked about treatment preferences for prostate cancer: radical prostatectomy, radiation therapy, or watchful waiting.

In the second study,^67^ Flood and colleagues included men older than 50 years who were scheduled for a routine physical examination (RPE) or nonurgent followup at a general internal medicine clinic. The trial consisted of viewing the "Prostate-PORT Video," its associated brochure, and the RPE (experimental group, n = 120); or only receiving the RPE (control group, n = 102). After the physicians were informed of the study, the authors began to enroll the participants. The control group was completed first, and afterwards the authors began the intervention group recruitment. The physicians were not told the dates of recruitment initiation, when the intervention started, or the ending of the study. The options in the second study were the same as in the first.

#### Controlled Trial Outcomes

##### Decision

In the first study, there was no statistically significant difference between the intervention and control groups in the proportion of men who actually had a PSA test (98.4 vs. 100 percent, p = 0.07), although the only three patients that refused the test were from the intervention group. When men indicated their likelihood of having another PSA test within the next 2 years, there was a significant difference between the groups. After viewing the video, more control group men rated the chances of having the test within the next 2 years as "high" (89.7 vs. 73.9 percent, p = 0.002).

When asked about preferences for prostate cancer treatment (radical prostatectomy, radiation therapy, or watchful waiting), there were statistically significant differences between the groups. Sixty-three percent of the intervention group preferred watchful waiting, and 51.2 percent of the control group preferred radical prostatectomy (p = 0.0000).

In the second study, the proportion of men in the intervention group who actually had a PSA test was significantly lower than the proportion of men in the control group (11.7 percent vs. 22.6 percent, p = 0.041). Also, more men in the intervention group estimated the chances of having a PSA within the next 2 years as "low" (30.4 percent vs. 67.0 percent, p = 0.0000). After the intervention, most intervention group men preferred watchful waiting (85.9 percent), whereas most men in the control group preferred either radical prostatectomy (40.7 percent) or watchful waiting (39.5 percent). This difference was statistically significant (p = 0.0000).

##### Knowledge

In both studies, the authors compared correct responses to three questions: one was about the PSA test predictive value and the natural history of prostate cancer, the second corresponded to prostate cancer treatment efficacy, and the third was related to the prostate cancer treatment efficacy. In the first study, a significantly higher proportion of men in the intervention group answered all three questions accurately (50.3 vs. 71.7 percent, p = 0.0002; 61.0 vs. 11.4 percent, p = 0.0000; and 64.2 vs. 30.5 percent, p = 0.0000, respectively). Similar results were found in the second study: the proportion of more accurate responses for each question was higher in the intervention group (92.9, 69.9, and 71.8 percent) than in the control group (40.9, 23.7, and 14.5 percent). For all the questions, the differences were statistically significant (p value = 0.000 for the three proportions).

#### Case Series

Men with localized prostate cancer viewed a DA videotape (one of six versions, each identical except for variations in risk factors that were adjusted according to patient age and Gleason score) prior to an oncology consultation in which they decided among four treatment options (radical surgery, radiation therapy, watchful waiting, hormonal treatment).^74^ In another case series, women less than 65 years of age with early stage breast cancer viewed tape-slide presentations (one for mastectomy and one for lumpectomy plus radiation therapy) to assist them in deciding between the two treatment options.^81^ The women in this study also received counseling from the oncology staff.

#### Case Series Outcomes

##### Decision

In the Onel and colleagues study,^74^ of the 95 men included, 32 chose radical surgery, 33 selected radiation therapy, 22 opted for watchful waiting, and 8 decided to have hormonal treatment. In Wilson and colleagues,^81^ of 153 women, 99 chose mastectomy and 54 opted for lumpectomy plus radiation.

##### Knowledge

Onel and colleagues^74^ asked men with prostate cancer to rate their knowledge of the disease at three points: pre-DA, post-DA and post-DA+consultation. According to the authors, their data suggest that the DA (videotape) greatly increased patients' knowledge of prostate cancer (no statistical analysis reported).

#### Other Outcomes

##### Patient would make same decision again

Wilson and colleagues^81^ reported they were aware of only 1 woman out of 153 who regretted her decision. This patient had chosen mastectomy instead of lumpectomy plus radiation therapy. In the study by Onel and colleagues,^74^ men with prostate cancer were asked if they would choose the same treatment again: 55 percent of men who chose radiation therapy, 66 percent of radical prostatectomy patients, 68 percent of watchful waiting patients, and 71 percent of men on hormonal treatment said "yes."

##### Satisfaction with decisionmaking

In the study by Wilson and colleagues,^81^ 28 of the 153 women offered a choice between mastectomy and lumpectomy were interviewed 2 years post-surgery. Two of the 28 women reported that, in retrospect, they were unhappy with having had to choose their treatment. Two prostate cancer patients in the Onel study^74^ reported they would have preferred the doctor to make the treatment decision; the remaining 95 patients said they were pleased to have participated in the decisionmaking. It is surprising, given the relatively low number of participants who would choose the same treatment again in Onel and colleagues,^74^ that 93 percent of the men reported being either "delighted," "pleased," or "mostly satisfied" with their decision.

### Interactive Computer Programs (Evidence Tables 5.20 to 5.23)

Four studies evaluated the use of interactive computer program interventions (two RCTs, one nonrandomized controlled trial, and one case series).

#### Randomized Controlled Trials

Two RCT studies^56,59^ about interactive computer programs were reviewed. Maslin and colleagues^56^ evaluated the usefulness of an interactive video disk system (IVDS) in women with early breast cancer considering surgical and adjuvant treatment options. One hundred patients were randomized to receive either standard care based on information they were given from a multidisciplinary team (n = 49) or to receive the IVDS in addition to the standard care (n = 51). The IVDS consisted of two parts. Initially, the patient's own details such as age and tumor size were entered. In the second section, the patient could choose to go forward or backward within the IVDS to review pertinent information at their discretion. The system offered information based on a current overview of RCTs as well as on current areas of debate and a rationale for treatment options. The system recognized that patients have values and preferences that may influence their choice of local or systemic treatment. For this study, raw data pertaining to choices were reported as bar graphs, making it difficult to extract the results of the study.

Street and colleagues^59^ studied 60 women with early breast cancer who were making decisions about mastectomy or lumpectomy and radiation therapy. They compared an interactive multimedia program (IMP) (n = 30) to an eight-page DA brochure that described treatment options (n = 30). The IMP was called "Options for Treating Breast Cancer" and was operated on an Apple computer with a touch screen monitor. The program consisted of text, graphic display, audio narration, and audiovisual clips divided into four sections: Introduction, Understanding the Problem, Treatment Options, and Experiences of Other Women.

#### RCT Outcomes

##### Decision

For the Maslin study,^56^ we could not extract the results of the treatment that women chose (surgery, chemotherapy and/or radiation therapy) from each group, although the authors reported: "The women's treatment option choice showed no statistically significant difference, p = 0.8...." Street and colleagues^59^ compared the proportion of women selecting breast conservation and breast removal in both experimental conditions; 76 percent of the IMP group and 58 percent of the DA brochure group chose breast conservation. The authors did not find any significant differences between the groups.

##### Knowledge

Street and colleagues^59^ assessed knowledge about breast cancer treatment with an 11-item questionnaire. This outcome was measured before and after the intervention and after the consultations with physicians. Scores in both groups showed a statistically significant increase from baseline after receiving the intervention (p < 0.001). No difference was detected between the groups (p = 0.07).

##### Acceptability of DA

Maslin and colleagues^56^ asked women in the intervention group to give their opinion about the IVDS. Fifty-four percent stated that the IVDS had not influenced their ultimate decision, and 30 percent felt it had influenced their treatment decision. Ninety-six percent found the IVDS interesting, 92 percent easy or very easy to understand, and 82 percent just about the right length; 72 percent felt they had gained a much clearer idea about breast cancer; and 92 percent would recommend the IVDS to someone else with the disease.

#### Other Outcomes

Maslin and colleagues^56^ assessed anxiety, depression, and satisfaction with decision, reporting the results by group. Street and colleagues^59^ expected that breast cancer patients would express more optimism about the future after using the IMP in comparison with those who used pamphlets. Optimism was measured with a previously developed eight-item instrument. The results did not confirm their hypothesis; scores in both groups were almost the same before and after the DA as well as after the consultation (p = 0.78). Comparison of optimism scores between groups did not reach statistical significance, p = 0.34.

#### Nonrandomized Controlled Trials

Molenaar and colleagues^69^ assessed the effect of an interactive computer program designed to assist women with early stage breast cancer in deciding between mastectomy and lumpectomy plus radiation. Participants in the intervention group (n=92) used the interactive computer program after attending their surgical oncology consultation. Participants in the control group (n=88) received an information pamphlet (designed to promote recall and further deliberation of their preliminary treatment choice) after their surgical oncology consultation. The purpose of the study was to determine whether the interactive computer program affected participants' treatment decisions, satisfaction, and quality of life.

#### Nonrandomized Controlled Trial Outcomes

##### Decision

There was no significant difference between the intervention and control groups in actual decision. In the intervention group, 69 women chose lumpectomy plus radiation therapy, and 23 women opted for mastectomy. In the control group, 60 women chose lumpectomy plus radiation therapy, and 28 women decided to have a mastectomy.

##### Decision conflict

The O'Connor Decisional Conflict Scale^48^ was used to measure decision conflict pre-intervention. Baseline decision conflict was significantly greater in the intervention group compared to the control group. The authors reported that they added decision conflict as a covariate for all subsequent statistical analyses.

##### Satisfaction

The authors measured several aspects of satisfaction at both 3- and 9-month followup. At 9-month followup, intervention group participants were significantly more satisfied than were control group participants in all of the areas assessed: (1) satisfaction with general information (p<0.01), (2) satisfaction with treatment-specific information (p=0.03), (3) satisfaction with the decisionmaking process (p=0.02), (4) satisfaction with decision (p=0.03), and (5) satisfaction with care (p=0.04).

##### Quality of life

The authors measured both generic and breast cancer specific quality of life at baseline and then at 3- and 9-month followup. Generic quality of life was assessed using the Medical Outcomes Study 20. Breast cancer specific quality of life was measured using the European Organization for Research and Treatment of Cancer Quality of Life Breast Cancer scale. At baseline, there was no significant difference in quality of life between the intervention and control groups. At 9-month followup, however, intervention group participants reported significantly greater quality of life (both generic, p<0.01, and breast cancer specific, p<0.05) compared to control group participants.

#### Case Series

One case series evaluated an interactive videodisk DA designed to help early breast cancer patients with both primary and adjuvant treatment decisions.^75^ The videodisk was developed by the Foundation for Informed Medical Decision Making. It is not clear how many women viewed the primary surgery DA program or the adjuvant program or both.

#### Case Series Outcomes

##### Decision

The authors reported the primary treatment preference of 49 women with breast cancer before and after viewing the surgery program.^75^ Of the 17 women who preferred mastectomy pre-DA, 14 retained this preference post-DA, and 3 women stated they had no treatment preference post-DA. There were 27 women who expressed a preference for lumpectomy plus radiation pre-DA; all 27 retained this preference post-DA. Of the five women who expressed no treatment preference pre-DA, four of them stated a preference for lumpectomy and radiation post-DA, and one woman still did not have a preference.

##### DA Acceptability

Gramlich and colleagues^75^ also reported that 98 percent of patients (N=83) rated the clarity of the surgery program as "excellent" or "very good."

##### Satisfaction with decision

In this study, patients were asked at 6 months post-DA how satisfied they were with their decisions. Pooled data were reported for the surgery and adjuvant interactive videodisks. Of the 57 patients available for followup, 82 percent rated their satisfaction as "excellent" or "very good."

##### Would recommend use of DA with other patients

Ninety-five percent of patients who participated in the interactive videodisk DA study by Gramlich and colleagues^75^ felt "very positive" or "generally positive" about other patients viewing the program.

### Counseling (Evidence Tables 5.24 to 5.28)

Five studies, one RCT and four case series, evaluated counseling interventions.

#### Randomized Controlled Trials

Davison and colleagues^53^ explored whether providing men with additional information about screening for prostate cancer would enable them to assume more active roles in decisionmaking with their family physicians. Men in the control group (n = 50) talked with the investigator about general issues prior to their medical appointment, while those in the intervention group (n = 50) were provided with verbal and written information about controversies surrounding screening for prostate cancer and the pros and cons of having a DRE and/or a PSA test. Men were encouraged to discuss screening issues with their family doctor.

#### RCT Outcomes

##### Decision

After the intervention, the authors reported that 49 percent of men were screened with a DRE and PSA test: 21 percent from the control group and 28 percent from the intervention group (no statistical analysis was reported). According to Degner's Control Preference Scale,^95^ no significant differences were found between role preferences for the two groups before the intervention (p = 0.398). After the intervention, more men in the intervention group assumed an active role in decisionmaking during the consultation compared to men in the control group (p = 0.00002).

##### Anxiety

Davison^53^ measured the state of anxiety by Spielberg's State Trait Inventory. Before and after the intervention, there were no significant differences in the anxiety scores between the intervention and control groups (p value not reported).

#### Other Outcomes

##### Decisional conflict

Based on O'Connor's Decisional Conflict Scale (O'Connor^48^), Davison and colleagues^53^ evaluated the degree to which men experienced decisional conflict in making prostate screening decisions after the intervention. Men in the intervention group had statistically significant lower levels of decisional conflict (p = 0.0001).

#### Case Series

Three of the four case series explored the use of individual counseling by oncology nurses to help breast cancer patients make primary treatment decisions.^79,80,83^ Two of the studies investigated the surgical choice of mastectomy versus lumpectomy (plus radiation therapy).^79,80^ In both studies, patients were also given information pamphlets to take home. Cotton^79^ studied 20 women with "screen-detected breast cancer," and Cotton and colleagues^80^ studied 91 women with primary operable breast cancer. In the third case series, Sandison and colleagues^83^ presented older women with four primary treatment options (tamoxifen alone; complete local excision and tamoxifen; modified radical mastectomy and tamoxifen; and complete local excision, radiation therapy, and tamoxifen). In this study, 50 women aged 70 years or older were given individual counseling and a take-home information sheet in addition to the usual oncology consultation.

In the fourth case series, conducted in Japan, Okamato and colleagues^88^ evaluated a physician-administered counseling intervention. The intervention was designed to assist patients (n=57) diagnosed with hypopharyngeal cancer (including all stages) in deciding whether to have chemoradiotherapy or surgery. At the initial oncology consultation, the physician described the type and stage of the tumor and outlined the two treatment options available using visual aids. The physician continued to provide each participant with additional counseling sessions to review the risks and benefits of each treatment option until the participant reached a decision.

#### Case Series Outcomes

##### Decision

Cotton and colleagues^80^ reported that, of the 91 patients studied, 50 chose mastectomy and 41 elected to have lumpectomy plus radiation therapy. Cotton also published a similar study in 1995, in which 10 of the 20 women studied chose mastectomy, 9 decided to have lumpectomy plus radiation therapy, and 1 woman did not perceive she was given a choice.^79^ In the study by Sandison and colleagues,^83^ after the DA intervention, 38 women elected to choose their own treatment and 12 asked the surgeon to decide. Of the 38 women who chose their own treatment, 33 selected lumpectomy (31 with tamoxifen plus radiation therapy and 2 with tamoxifen), 4 women chose mastectomy plus tamoxifen, and 1 patient opted for tamoxifen only.

Okamato and colleagues^88^ reported that, of the 57 hypopharyngeal cancer patients studied, 43 chose chemoradiotherapy, 11 decided on surgery, 2 requested to be transferred to another hospital, and 1 decided not to be treated.

##### Satisfaction with decisionmaking

Cotton^79^ reported that 14 of the breast cancer patients were "glad to make a decision on their own treatment," while 5 patients were "not glad to have a say in the choice of treatment." In the Sandison and colleagues^83^ study of older women with breast cancer, 36 of 38 patients who elected to choose their own treatment reported that they had made the right choice.

##### DA acceptability

Cotton^79^ reported that, of the 19 patients studied, 1 found "discussions with the breast-care nurse" unhelpful, 7 stated they did not read the literature provided until after surgery, and 2 found the "material upsetting."

#### Other Outcomes

##### Patient would make the same decision again

In Cotton's study,^79^ 3 of the 19 women interviewed 12 months post-breast-cancer surgery stated that they would not make the same choice again. All three of these patients had chosen to have mastectomies.

##### Duration from initial visit to start of treatment

Okamato and colleagues^88^ compared the length of time between participants' initial oncology consultation to start of treatment with the duration from initial visit to start of treatment for the 60 hypopharyngeal cancer patients treated before the intervention was implemented. The authors reported that the counseling intervention increased the time to treatment (no statistical analysis was provided).

##### Survival rate

Okamato and colleagues^88^ reported that there was no significant difference in the crude 3-year survival rate of intervention participants compared to the 60 patients seen before the intervention was implemented (no statistical analysis was provided).

### Informal Decision Analysis (Evidence Table 5.29)

#### Case Series

Ashcroft and colleagues^76^ conducted a large study with women who presented to a clinic with breast problems. All of the women completed a battery of psychological measures at multiple points. Within this group, 43 women were diagnosed with breast cancer. In 25 of these patients, a specific medical treatment was indicated. The remaining 18 women were offered the choice of mastectomy, lumpectomy with radiation therapy, or entry into a clinical trial where they would be randomly assigned to one of the two treatments. Four women entered the clinical trial, and 14 women elected to chose their own treatment. An informal decision analysis procedure was used to help these women decide which treatment they would prefer.

#### Case Series Outcomes

##### Decision

Of the 14 breast cancer patients who elected to chose their own treatment, 6 decided on mastectomy and 8 opted for lumpectomy and radiation therapy.^76^

##### Anxiety and depression

In the study by Ashcroft and colleagues,^76^ anxiety and depression were measured at multiple times, both before and after breast cancer surgery, in women who decided their own treatment with the assistance of informal decision analysis. Unfortunately, these results were presented pooled with data from women who were not offered a choice because their condition necessitated a specific treatment.

#### Other Outcomes

Ashcroft and colleagues^76^ also measured body satisfaction, social adaptability, martial adjustment, and self-esteem. Like the anxiety and depression data, this information was not reported separately for those women who received the DA intervention and made their own choice. Ashcroft and colleagues^76^ stated that patients' scores on these tests were comparable to those of the normal population.

### Decision Boards (Evidence Tables 5.30 to 5.33)

Refer to Chapter 4 for a complete description of DB instruments. Four studies evaluated DB interventions (one RCT, two nonconcurrent cohort studies, and one case series).

#### Randomized Controlled Trials

Irwin and colleagues^61^ tested the hypothesis that a different order of presentation of information would influence the choices of breast cancer patients. They developed and evaluated a DB to objectively educate patients about the benefits and risks of adjuvant chemotherapy. There were two options, Adriamycin + Cyclophosphamide (AC) or Cyclophosphamide + Methotrexate + 5-Fluorouracil (CMF). Women were allocated to one of the two versions of the DB; one version displayed CMF first and then AC (n = 23). The other version displayed AC first, followed by CMF (n = 23).

#### RCT Outcomes

##### Decision

After the intervention, the proportion of women who chose AC or CMF was similar between groups. Ten of 23 (43.4 percent) women who were presented with CMF first chose AC, 12 (52.1 percent) chose CMF, and one (4.3 percent) chose no treatment. For women in the other group, 13/23 (56.5 percent) chose AC, 9 (39.1 percent) chose CMF, and 1 (4.3 percent) chose no treatment. The authors reported that there were no significant differences, but no statistical analysis was given.

##### Knowledge

Irwin and colleagues^61^ evaluated learning and comprehension after patients used the DB. They asked women to answer eight multiple-choice questions with three options and quantified the percentages of correct answers. The authors reported responses as pooled data, rather than by intervention group.

##### Acceptability of DA

The authors asked the women with breast cancer to rate the DA. Ninety-eight percent rated it "quite helpful" or "very helpful." Difficulty with decisionmaking was assessed with a 5-point scale, from "very much" to "not at all." Thirty-two percent of the women considered the decisionmaking "not at all" difficult; the rest of the participants indicated some level of difficulty. The data reported also are pooled.

#### Other Outcomes

Irwin and colleagues^61^ were interested in women's reasons for the treatment choice they made. Women who chose AC treatment rated "time" as the most important factor in their decision, whereas the main reason for choosing CMF was the "side effects" (see Evidence Table 5.30b)

#### Nonconcurrent Cohort Studies

Two studies compared the use of a DB in women with breast cancer for treatment decisionmaking among cohorts recruited in consecutive periods of time. Comparisons of the outcomes were performed before and after the DB implementation. Whelan and colleagues^70^ compared the frequency of choosing breast irradiation after lumpectomy in three groups. The cohorts were gathered in consecutive phases. The first cohort was assembled after a standard clinical radiation oncologist consultation (n = 23); the second consisted of women who attended the consultation, but where physicians had a checklist to standardize the content of information they provided (n = 29). The last cohort included breast cancer patients who were exposed to a DB during the consultation (n = 30). In the second study, Whelan and colleagues^71^ determined the proportion of women with breast cancer who chose mastectomy or lumpectomy plus radiation therapy before and after the introduction of a DB. The historical cohort consisted of patients who underwent surgery in the 18-month period before the introduction of the DB (n = 194); women in the intervention cohort (n = 175) were recruited during the following 18-month period.

#### Nonconcurrent Cohort Study Outcomes

##### Decision

In the first study,^70^ Whelan et al. (1995) found that most patients in the three cohorts chose breast irradiation. The proportions of women who made this choice were 96, 97, and 93 percent, respectively; no statistical analysis was reported for this outcome. Results of the second study^71^ showed a significantly lower proportion of women who underwent lumpectomy in the DB cohort (73 percent) than in the historical cohort (88 percent), (p = 0.001).

##### Knowledge

Based on 10 true or false statements regarding information about breast irradiation, Whelan and colleagues^70^ compared patient comprehension among the three cohorts. One statement was significantly different among the groups, and more women in the DB cohort answered this item correctly (p < 0.0001). Whelan and colleagues^71^ also assessed patient comprehension; however, only the DB cohort answered this questionnaire.

##### Satisfaction with decisionmaking

Whelan and colleagues^71^ assessed satisfaction in the DB cohort only. Ninety-seven percent of the women were satisfied with the information received, and 95 percent with the decisionmaking process.

##### Acceptability of DA

Whelan and colleagues^70^ asked 27/30 women of the DB cohort about their perceptions of the DA. All women reported that it was easy to understand, 22 said that it helped them to make a decision and to think of further questions to ask, and 20 patients recommended that the DB be used for other patients. In the study by Whelan and colleagues,^71^ they evaluated this outcome only in women exposed to the DB. The authors reported that 98 percent of the patients found it easy to understand and would recommend its use with other patients. Eighty-one percent said that the DB helped them to make a decision, and 64 percent indicated that it helped them think of questions to ask.

##### Other outcomes

This study^70^ also compared reasons for choosing breast irradiation across groups. The authors measured this outcome with a six-item questionnaire; patients were asked to score each item from 1 to 5 according to its perceived importance. All but one of the mean importance scores were similar. The DB cohort had the significantly lowest score for the physicians' irradiation recommendation in comparison with the other two groups' scores. Patients also reported that radiation oncologists were less likely to make a formal recommendation when the DB was used (p<0.0001; comparison group not reported). The authors also reported that women's perceptions of having been offered a choice was significantly different: 97 percent of the DB cohort versus 70 percent of the other two cohorts (p = 0.02).

Whelan and colleagues^71^ used the Degner's Control Preference Scale.^95^ The DB cohort women were asked about their decisionmaking role postintervention. Fifty-one percent preferred an active role, 36 percent a collaborative role, and 12 percent a passive role.

#### Case Series

Levine and colleagues^78^ explored the use of a DB intervention to help women with node-negative breast cancer decide whether to have adjuvant chemotherapy.

#### Case Series Outcomes

##### Decision

Of the 37 women who used the DB, 34 chose to have adjuvant chemotherapy.

##### DA helps patient decide

Of the 30 women who were asked, 15 patients stated that the DB "definitely helped" them to decide whether to have adjuvant chemotherapy, 11 patients felt the DB "helped," and four patients felt "it did not help."^78^

##### DA acceptability

Levine and colleagues^78^ asked patients whether they found the DB easy to understand. Of the 30 patients surveyed, 19 found the DB was "very easy," 10 patients said it was "easy," and 1 patient reported that the DB was "difficult to understand." The authors also reported that 29 of the 30 patients would recommend that the DB be used with other breast cancer patients. They asked 30 patients if the DB helped them think of further questions to ask the nurse or doctor. Nine responded that the DB "definitely helped," 15 said it "helped," 5 said the DB "did not help," and 1 patient did not answer. In this DB study, patients were also asked if they had shown the take-home version of the DB to anyone else. Twenty-four of the 30 patients studied had shown the DB to someone. In this subset, 10 patients stated that the DB "definitely helped describe treatment choices," 11 said the DB "helped," two stated that the DB did not help, and 1 patient did not answer.

### Complex Decision Aids (Evidence Tables 5.34 to 5.39)

In this section, since the DA interventions consisted of several different components, each study and its outcomes are reported separately. As in previous sections, RCTs will be described first, followed by controlled trials, and then case series.

#### Randomized Controlled Trials

There were two RCTs^50,58^ that included two or more primary components in their DA.

##### Lerman and colleagues.^50^

In this study, two forms of BRCA1 pretest education -- "an educational or informative" approach and a "counseling or interpretative approach" -- were compared. The informative approach was based on the standard medical model of patient decisionmaking and consisted of a DA educational session + printed handouts (n = 114). The other group received the same DA educational session and handouts as well as "nondirective" genetic counseling that was based on behavioral models of decisionmaking (n = 122). Both groups were compared to a nonintervention group (waiting list [n = 164]). The main outcomes were knowledge, perceived risk of having a BRCA1 mutation, perceived benefits, limitations and risks of testing, the intention to undergo a BRCA1 genetic test, and the provision of a blood sample.

##### Decision

Among the three groups, there were no differences in the proportion of participants wanting to undergo a genetic test in the education group, the counseling group, or the wait list control group (57 percent, 61 percent, and 53 percent, respectively). The proportion of women who provided a blood sample was similar in both the education and counseling groups (50.8 percent vs. 51.6 percent). This outcome was not evaluated in the control group.

##### Knowledge

Breast cancer and BRCA1 testing knowledge were assessed in this study at baseline and 1 month after the intervention. The outcome measure was developed based on previously published instruments. Both intervention groups showed increased knowledge from baseline after the DA. No difference was found between intervention groups, but both were statistically different from the control group (p = 0.0001).

##### Risk perception

They also evaluated the perceived personal risk of having a BRCA1 mutation and perceived limitations and risks of the test. There was no demonstrative impact of the interventions on perceived personal risk of having a BRCA1 mutation. However, both interventions improved patient understanding regarding limitations and risks of BRCA1 testing, and the education plus counseling intervention appeared to be better than the educational intervention alone (p < 0.05).

##### Other results

The authors assessed the perceived benefits of genetic testing and the perceived limitations and risks of the genetic test; the results of these outcomes can be found in Evidence Table 5.34b.

##### Davison and colleagues.^58^

..In the other RCT study, Davison and colleagues evaluated a method to assist men newly diagnosed with prostate cancer to obtain information. There were two groups. Men in the control group (n = 30) were provided five DA brochures containing various types of information about prostate cancer (i.e., disease process, treatment options). They were told that it might be helpful to read the information before or after the initial treatment consultation. Men in the intervention group (n = 30) received the DA brochures and then were asked to think about the type of information they needed to assist in deciding the best treatment for them. A list of questions was reviewed with the patients to give them an idea of the types of questions they could ask their physician. Additional questions were added to the list, and a final list was generated. Men were provided with a blank audiotape, and patients were free to tape the consultation. They were also encouraged to participate in the decisionmaking process.

##### Preference for decisionmaking role

To elicit patients' preferences, the Degner Control Preference Scale^95^ was used before the intervention and after the consultation. No significant differences were found in the proportion of the preferred roles (active, collaborative, and passive) before the intervention (p = 0.113). Five to 6 weeks after the consultation, a significantly higher proportion of men in the intervention groups assumed a more active role in treatment decisionmaking (p < 0.001). Two men in the intervention group reported that the audiotape assisted them in making their treatment decision.

##### Anxiety

Using the Speilberger State-Trait Anxiety Inventory, the authors measured anxiety before the intervention and 5 to 6 weeks after the consultation. They reported that men in the intervention group had significantly higher levels of anxiety prior to the intervention. After the intervention, there were no significant differences between groups (p value was not reported). Men in the intervention group had significantly lower levels of anxiety after the intervention (p < 0.005) compared to baseline; this finding was not seen in the control group.

##### Depression

The authors assessed depression with the Center for Epidemiologic Studies Depression Scale (CES-D). The authors reported that there were no significant differences between or within groups before and after the intervention (p value was not reported).

##### Acceptability of DA

Davison and colleagues^58^ asked participants to evaluate the intervention. Four of the 30 participants did not tape their consultation. Of the 26 men who taped the consultation, 22 listened to the tape. The authors reported that 50 percent used the audiotape to review the information provided during the consultation and to share information with their family. In relation to the question list, the majority of men reported that it was helpful in formulating questions to ask their physicians. Several men asked the doctors to answer all of the questions on the list. Regarding the written material, 6 of 30 in the control group did not read the material compared to 3 of 30 in the intervention group. Twenty-two men ranked the three components of the intervention in order of usefulness: the audiotape was ranked as the most useful, the written information package second, and the question list third. Nevertheless, the majority stated that it was difficult to rank them, as all were important to have and one complemented the other.

#### Nonrandomized Controlled Trials

##### Sepucha and colleagues.^68^

In this sequential controlled trial study, two DA interventions designed to improve the quality of treatment decisions, the quality of communication, and the satisfaction of patients and physicians were tested in a group of early breast cancer patients. The authors assigned 12 women into one of the two interventions; both interventions consisted of the usual consultation with a surgeon or a medical oncologist and preconsultation planning. For 30 minutes, patients were prepared for the medical consultation by the researcher, who created a flowchart of patients' questions and concerns. Afterward during the consultation, the researcher performed a "consultation recording" in the intervention group; this five-step intervention (contracting, creating an agenda, mapping, commitments, and debriefing) was intended to help physicians and patients to facilitate their communication. In the control group, the researcher observed the consultation without participation.

To evaluate the intervention, the authors used the Decision Quality Scale, the MD Decision scale, and the University of California at San Francisco Satisfaction with Consultation Scale. The quality of the decision was measured before the intervention, after the consultation planning, and after the consultation. The authors reported the before- and after-the-consultation planning results as pooled data.

##### Decision quality

The scores increased after the consultation in both groups, and the intervention group achieved a significantly higher score in decision quality assessment than did the control group (p = 0.008).

##### Satisfaction with the consultation

The authors did not find any statistically significant differences between groups related to their satisfaction with the consultation (p = 0.073); however the authors reported that, since the intervention group scores were higher, these patients were more satisfied than the control group.

#### Case Series

There were three case series that investigated the use of complex DAs.^72,73,82^ In a one-group pretest/posttest design, Stalmeier and colleagues^72^ explored the use of a DA designed to support women (n= 51), at high risk of carrying a breast cancer susceptibility gene in deciding between PM or BCS (semiannual clinical breast examination and annual mammography).^72^ The DA intervention consisted of individual counseling, a videotape, a DA brochure, and multiple utility assessments. The second study^82^ studied a series of 250 women with primary breast cancer and no evidence of metastatic disease and used a complex DA to assist in deciding between mastectomy and lumpectomy plus radiation therapy. The DA intervention consisted of individual counseling, a videotape, and a bottom-line sheet. The third study^73^ also used a pretest/posttest design to evaluate the use of a treatment tradeoff DA in patients with locally advanced non-small-cell lung cancer (n= 25) in deciding between combined-modality treatment and radiation therapy.

##### Stalmeier and colleagues.^72^

See previous section for a description of the study.

##### Decision

Of the 12 women identified as carriers of a breast cancer susceptibility gene, 8 chose to undergo PM, and 4 opted to have BSC. The authors also asked an additional 36 women who had used the DA, but whose genetic testing results were not yet available, to make a hypothetical decision assuming a positive carrier status. Under these conditions, 21 women said they would choose PM, 11 women would have BCS, 2 women could not decide, and 2 women did not answer. A hypothetical choice was not elicited from three women who found out during the study that they were noncarriers.

##### Knowledge

Knowledge was assessed by asking all of the women to rate their knowledge of both PM and BCS before and after the DA (10-point scales). Patients rated their knowledge of both PM and BCS significantly higher post-DA (p < 0.001 for PM; and p < 0.01 for BCS).

##### Decision burden

All 51 women who completed the intervention rated how much of a burden they felt the choice between PM and BCS was both pre- and post-DA (7-point scale). Decision burden was significantly lower post-DA (p < 0.01).

##### Decision uncertainty

All 51 women were asked both before and after the DA intervention how certain they were about their choice (7-point scale). The authors reported that decision uncertainty was significantly lower post-DA (p < 0.05).

##### Wolberg and colleagues.^82^

In this study, a complex DA was used to assist breast cancer patients in deciding between mastectomy and lumpectomy plus radiation therapy. The DA intervention consisted of individual counseling, a slide-tape presentation, and a bottom-line sheet.

##### Decision

Wolberg and colleagues^82^ reported that, of the 250 women given a choice, 128 decided on mastectomy and 122 opted for lumpectomy plus radiation therapy.

##### Anxiety and depression

Wolberg and colleagues^82^ used the Profile of Mood States (POMS) to measure patients' moods pre- and post-DA. The authors reported that women who chose mastectomy were more anxious (p < 0.01) and felt more depressed (p<0.05) than those who selected lumpectomy with radiation.

##### Satisfaction with decisionmaking

When Wolberg and colleagues^82^ interviewed women 2 weeks after undergoing breast-cancer surgery, 20 of the 22 women said they had participated "as much as they desired" in making the treatment decision.

##### Other outcomes

Wolberg and colleagues^82^ measured baseline psychosexual adjustment prior to patients' deciding between mastectomy and lumpectomy plus radiation therapy. Women who chose mastectomy reported significantly more predecision problems with sexual relationships than did women who elected to have lumpectomy with radiation therapy (p<0.05).

##### Brundage and colleagues.^73^

In the third case series study, a complex DA was used to assist patients with advanced non-small-cell lung cancer in deciding between combined-modality treatment (CMT) and radiation therapy only. The DA intervention consisted of the usual oncology consultation plus a structured individual interview using a display board and treatment-trade-off exercises, as well as a take-home DA information package.

##### Decision

Of the 18 patients who used the DA, 16 decided on CMT and 2 patients opted for radiation therapy only.

##### Knowledge

The authors also measured the patients' knowledge of the two treatment options before and after the DA in 13 of the 18 patients. They reported that the number of patients correctly answering questions about the direction and magnitude of survival benefit increased post-DA (raw data; no statistical analysis reported).

##### DA acceptability

All of the lung cancer patients who used the DA to decide on treatment for advanced cancer either "strongly agreed" or "agreed" that the decision support was useful in making the decision. The authors also measured patients' treatment preferences before and after the DA. Three patients who reported no preference at baseline all chose CMT after the DA. In 5 patients, the DA increased the strength of their treatment preference and, in the remaining 10 patients, the DA did not alter the strength of their treatment preference. The 13 lung cancer patients who used the DA to decide on treatment for advanced cancer and who completed the followup questionnaire either "strongly agreed" or "agreed" that the decision support should be used with other patients.

##### Decision uncertainty

The authors also measured decision uncertainty (a subscale of the Decision Conflict Scale) in 13 of 18 lung cancer patients both before and after DA. Post-DA, decision uncertainty decreased in 12 patients and increased in 1 patient.

The authors asked physicians to evaluate the decision support. In 12 of 13 cases, the physicians reported that the DA was useful in helping the patient understand the risks and benefits of each treatment. None of the physicians felt that the DA interfered with their relationship with the patient.

## Summary

This chapter summarized 39 published studies that evaluated DAs to assist cancer patients to make prevention, screening, or treatment decisions. The majority of the studies involved decisions related to treatment rather than prevention or screening and focused on breast or prostate cancer. All studies were conducted with adult patients from developed countries. Most of the included patients were Caucasian with more than 12 years of education. The DAs that were evaluated varied from DA brochures and educational scripts to interactive computerized programs. Few studies directly compared different types or modes of DA delivery (i.e., DA brochure vs. interactive computer program). There were relatively few studies involving novel approaches such as computer-based applications.

Only 20 of the 39 evaluations used study designs involving a concurrent comparison group. Quality assessment scores across all the studies were low, but studies published in recent years achieved higher scores. Inadequate randomization, lack of blinding of outcome assessors, and lack of adequate followup were the most common methodological problems.

Few studies reported the development process of the DA. Of the 16 RCTs that evaluated the effectiveness of a DA in a clinical context with actual patients, only 3 studies reported the details of the developmental process. Two other studies reported that the DA had been pretested, but the results were not published.

We attempted to classify the models or frameworks of decisionmaking used in each study by independently assessing the information presented by the authors. Since our assessment often differed from the framework stated, we attribute this disparity to lack of available details in the published report and differences in definitions. The lack of consistency in frameworks might explain the variability in the selection of the primary outcome measures across studies. The outcome measures reported most frequently were the decision itself, knowledge (and recall), acceptability of the DA, satisfaction, anxiety, and depression. However, for many of the outcome measures, their psychometric properties (reliability and validity) were not reported, making it difficult to judge the impact of the DA.

If we consider the results of studies that included a concurrent comparison, some similarities emerged. For example, DAs appeared to increase knowledge (about the disease and the pros and cons of different options), did not increase anxiety, decreased decisional conflict or uncertainty, and increased satisfaction with the decision. In general, all DAs seemed to be acceptable to the users. Regarding decisionmaking, in some studies the DA clearly influenced peoples' decisions by changing their choice after the intervention or by helping them feel more comfortable with their choice. However, in other studies, the DA did not seem to influence decisionmaking.

Prostate cancer screening DAs seemed to help men (especially among older men) to choose not to have the PSA test. Studies about breast cancer treatment DAs showed that (younger) women chose breast conservation rather than radical surgery. Among women at risk of breast and ovarian cancer who faced genetic testing, the DA seemed to be more useful than was the standard genetic counseling.

For decisions about prevention or screening, DAs appear to be a useful addition to standard practice, but there is insufficient evidence to indicate which type of decision aid might be more effective. With respect to decisions involving treatment, at the present time there is insufficient evidence about the effectiveness of DAs.