# Results

## Results of the Literature Search

The results of the searches of electronic databases and reference lists are found in Table 3. Our search of the eight databases yielded a total of 22,279 hits and, after applying the selection criteria, there were 10,772 unique citations. The greatest yield from the search came from the MEDLINE database (6,309), followed by EMBASE with 2,159 unique citations. The search of the MEDLINE database also resulted in the largest number (496) of potentially relevant titles and abstracts, followed by EMBASE with 172 citations.

Table 3. Search yield

| MEDLINE ^a^ | Health STAR | CANCERLIT | CINAHL | Sociological Abstracts | PsycINFO | EMBASE | Cochrane Library | Experts | Reference Lists ^b^ | Contact With Author | Totals
# Titles and abstracts:; - original yield ^c^ | 6,373 | 5,909 | 4,542 | 1707 | 119 | 447 | 2,931 ^d^ | 251 | | | | 22,279
# Titles and abstracts:; - unique yield | 6,309 | 249 | 0 | 1,394 | 84 | 438 | 2,159 | 75 | | | | 10,772
# Articles requested ^e^ | 496 | 32 | 0 | 112 | 3 | 31 | 172 | 19 | 12 | 190 | 1 | 1,068
# Articles that could not be located | 2 | 0 | 0 | 7 | 0 | 1 | 2 | 0 | 0 | 0 | 0 | 12
# Articles in languages other than English | 32 | 0 | 0 | 0 | 0 | 0 | 5 | 0 | 0 | 1 | 0 | 38
# Articles reviewed | 494 | 32 | 0 | 105 | 3 | 30 | 170 | 19 | 12 | 190 | 1 | 1056
# Articles excluded ^e^ | 384 | 28 | 0 | 91 | 2 | 22 | 143 | 16 | 5 | 157 | 1 | 849
# Articles included ^e^ | 110 | 4 | 0 | 14 | 1 | 8 | 27 | 3 | 7 | 33 | 0 | 207

a MEDLINE search was updated to April 2001.

b Total number of citations identified in the reference lists of included studies, review articles, and background articles. Many of these already belonged to the main database.

c These figures contain some duplication of citations.

d Results of the search of EMBASE from 1995 to 2000.

e Figures reported represent the results of the preliminary screening of full text articles.

Overall, 1,068 full text articles were requested from the library. Twelve articles could not be located, resulting in 1,056 full text articles that were retrieved and screened by two reviewers.

## Results of the Screening Process

The results of the screening process are found in Table 4. Of the 1,056 full text articles screened, 207 were included after the preliminary screening process was completed and 849 were excluded. The citations for all included and excluded articles are found in the Bibliography Section of this Evidence Report. The reasons for exclusion are found in Table 4. Fifty-three percent were excluded because they did not describe a decision aid, 39 percent were not primary studies, and the remainder were excluded for other reasons that are specified in Table 4.

Table 4. Results of the preliminary full text screening

Total number of full text articles screened | 1,056
Total number of excluded articles | 849
Reasons for exclusion General education Not a primary study Not related to cancer Informed consent Mathematical model | 450 334 51 8 6
Total number of articles included on preliminary screening of full text articles | 207

Three studies published after 1995 in abstract format only were excluded, and their citations are found in Table 5. The screening of 38 articles required assistance from translators, and two of these were included. Of the 207 articles selected following the preliminary screening process, 39 were considered to be "companion" to other studies, leaving 168 unique studies. Table 6 lists the studies that were considered as "primary" and the "companion" studies are listed after each primary study.

Table 5. Excluded abstracts published after 1995

1. Molenaar S, Sprangers M, Oosterveld P, et al. The evaluation of an interactive computer programme on treatment options in early stage breast cancer: preliminary results. Med Decis Making 1998 Oct;18(4):482.; 2. Molenaar S, Sprangers M, de Haes JC. An interactive computer programme on breast cancer: reactions of patients and surgeons. Psycho Oncol 1998 7(3):175.; 3. Wilkins E, Lowery J, Hamill J. The impact of shared decision-making in prostate specific antigen (PSA) screening. Med Decis Making 1999;19:525.

Table 6. Citations for companion papers of included studies

Ashcroft JJ, Leinster SJ, and Slade PD. Breast cancer patient choice of treatment: preliminary communication. J R Soc Med 1985;78(1): 43-6.; - Owens RG, Ashcroft JJ, Leinster SJ, et al. Informal decision analysis with breast cancer patients: an aid to psychological preparation for surgery. J Psychosocial Oncol 1987;5(2):23-33.; - Leinster SJ., Ashcroft JJ, Slade PD, et al. Mastectomy versus conservative surgery: Psychosocial effects of the patient's choice of treatment. Journal of Psychosocial Oncology 1989;7(1-2):179-92.; - Ashcroft JJ, Leinster SJ, Slade PD. Psychosocial issues in malignant disease; mastectomy versus breast conservation. Psychological effects on patients' choice of treatment. BPOS Proceedings 1984;7-8.
Brundage MD, Feldman SD, Dixon P, et al. A treatment trade-off based decision aid for patients with locally advanced non-small cell lung cancer. Health Expectations 2000;3(1):55-68.; - Brundage MD, Cosby RH, Feldman-Stewart D, et al. A pilot study of decision aid for patients with locally-advanced non-small cell lung cancer. Med Decis Making 1998;18(4):483.; - Brundage MD, Groome PA, Feldman-Stewart D, et al. Decision analysis in locally advanced non-small-cell lung cancer: is it useful? J Clin Oncol. 1997 Mar;15(3):873-883.; - Brundage MD, Feldman-Stewart D, Cosby R, et al. Phase I study of a decision aid for patients with locally advanced non-small-cell lung cancer. J Clin Oncol 2001;19:1326-1335.
Brundage MD, Davidson JR, Mackillop WJ. Trading treatment toxicity for survival in locally advanced non-small cell lung cancer. J.Clin.Oncol. 1997 Jan;15(1):330-340.; - Brundage MD, Davidson JR, Mackillop WJ, et al. Using a treatment-tradeoff method to elicit preferences for the treatment of locally advanced non-small-cell lung cancer. Med.Decis.Making 1998 Jul 18(3):256-67.
Carrère MO, Moumjid-Ferdjaoui N, Charavel M, et al. Eliciting patients' preferences for adjuvant chemotherapy in breast cancer: development and validation of a bedside decision-making instrument in a French Regional Cancer Centre. Health Expectations 2000:97-113.; - Ferdjaoui N, Carrere MO, Charavel M, et al. Integrating patients' preferences in therapeutic decisions in cancer: Development of a decision board. J d'Economie Medicale 1999;17(5):327-42.
Davison BJ, Degner LF. Empowerment of men newly diagnosed with prostate cancer. Cancer Nurs 1997;20(3):187-96.; - Pasacreta JV. An empowerment information intervention improved participation in treatment decision making in men with recently diagnosed prostate cancer. Evidence-Based Nursing 1998;1(2):49.
Flood AB, Wennberg JE, Nease RF Jr, et al. The importance of patient preference in the decision to screen for prostate cancer. Prostate Patient Outcomes Research Team. J Gen Intern Med 1996;11(6):342-9.; - Anonymous. Educating patients about prostate screening and treatment influences their medical decisions. Research Activities 1996;198:7-8.
Goel V, Sawka CA, Thiel EC, Gort EH, O'Connor AM. Randomized trial of a patient decision aid for choice of surgical treatment for breast cancer. Med Decis Making 2001;21:1-6.; - Goel V, Sawka C, Thiel E, Gorl E, O'Connor A. A randomized trial of a decision aid for breast cancer surgery. Med Decis Making 1998;18:482.
Gustafson D, Wise M, McTavish F, et al. Development and pilot evaluation of a computer-based support system for women with breast cancer. J Psychosocial Oncol 1993;11(4):69-93.; - Owens BH, Robbins KC. CHESS: comprehensive health enhancement support system for women with breast cancer. Plast Surg Nurs 1996;16(3):172-5.; - Gustafson DH, Taylor JO, Thompson S et al. Assessing the needs of breast cancer patients and their families. Qual Manag Health Care 1993:2(1):6-17.; - Taylor JO, Gustafson DH, Hawkins R, et al. The comprehensive health enhancement support system. Qual Manag Health Care 1994;2(4):36-43.
Iglehart JD, Miron A, Rimer BK, et al. Overestimation of hereditary breast cancer risk. Ann Surg 1998;228:375-384.; - Miron A, Schildkraut JM, Rimer BK, et al. Testing for hereditary breast and ovarian cancer in the southeastern United States. Ann Surg 2000;231:624-634.; - Bluman LG, Rimer BK, Berry DA, et al. Attitudes, knowledge, and risk perceptions of women with breast and/or ovarian cancer considering testing for BRCA1 and BRCA2. J Clin Oncol 1999;17:1040-1046.
Irwin E, Arnold A, Whelan TJ, et al. Offering a choice between two adjuvant chemotherapy regimens: A pilot study to develop a decision aid for women with breast cancer. Patient Educ Couns 1999;37(3):283-291.; - Irwin E, Arnold A., Rath D, et al. Offering a choice between two adjuvant chemotherapy regimens: What factors affect treatment decision making for women with breast cancer? Proc Annu Meet Am Soc Clin Oncol 1995:14:A1646.
Lerman C, Biesecker B, Benkendorf JL, et al. Controlled trial of pretest education approaches to enhance informed decision-making for BRCA1 gene testing. J Natl Cancer Inst 1997 Jan;89(2):148-57.; - Lerman C, Hughes C, Benkendorf JL, et al. Racial differences in testing motivation and psychological distress following pretest education for BRCA1 gene testing. Cancer Epidemiol.Biomarkers Prev. 1999;8(4 II):361-7.
Maslin AM, Baum M, Walker JS, et al. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. Nt Research 1998;3(6):444-55.; - Maslin AM, Baum M, Walker JS, et al. Using an interactive video disk in breast cancer patient support. Nurs Times 1998;94(44):52-55.
McTavish FM, Gustafson DH, Owens BH, et al. CHESS (Comprehensive Health Enhancement Support System): an interactive computer system for women with breast cancer piloted with an underserved population. J Ambulatory Care Manage 1995;18(3), 35-41.; - Taylor JO, Gustafson DH, Hawkins R, et al. The comprehensive health enhancement support system. Qual Manag Health Care 1994;2(4):36-43.; - Gustafson D, Wise M, McTavish F, et al. Development and pilot evaluation of a computer-based support system for women with breast cancer. Journal of Psychosocial Oncology 1993;11(4):69-93.; - Owens BH, Robbins KC. CHESS: comprehensive health enhancement support system for women with breast cancer. Plast Surg Nurs 1996;16(3):172-5.
Stalmeier P, Unic I, Verhoef L, et al. Evaluation of a shared decision making program for women suspected to have a genetic predisposition to Breast Cancer. Med Decis Making 1999;19:230-41.; - Unic I, Stalmeier PF, Verhoef LC, et al. Assessment of the time-tradeoff values for prophylactic mastectomy of women with a suspected genetic predisposition to breast cancer. Med.Decis.Making 1998 Jul;18(3):268-77.; - Unic I, Verhoef LC, Stalmeier PF, et al. Prophylactic mastectomy or screening in women suspected to have the BRCA1/2 mutation: a prospective pilot study of women's treatment choices and medical and decision-analytic recommendations. Med.Decis.Making 2000;20(3):251-62.
Street RL Jr, Voigt B, Geyer C Jr, et al. Increasing patient involvement in choosing treatment for early breast cancer. Cancer 1995;76(11):2275-85.; - Street RL Jr, Voigt B. Patient participation in deciding breast cancer treatment and subsequent quality of life. Med Decis Making 1997;17(3):298-306.
Volk RJ, Cass AR, Spann SJ. A randomized controlled trial of shared decision making for prostate cancer screening. Arch Fam Med 1999 Jul;8(4):333-40.; - Volk RJ, Spann SJ, Cass AR. A randomized, comparative trial of shared decision making for prostate cancer screening: one-year follow-up. Med Decis Making 1998 Oct;18(4):477.
Wolberg WH, Tanner MA, Romsaas EP, et al. Factors influencing options in primary breast cancer treatment. J Clin Oncol 1987 Jan;5(1): 68-74.; - Wolberg WH, Romsaas EP, Tanner MA, et al. Psychosexual adaptation to breast cancer surgery. Cancer 1989 Apr;63(8):1645-55.; - Wolberg WH. Surgical options in 424 patients with primary breast cancer without systemic metastases. Arc Surg 1991 Jul;126(7):817-9.; - Ward S, Heidrich S, Wolberg W. Factors women take into account when deciding upon type of surgery for breast cancer. Cancer Nursing 1989 Dec:12(6):344-51.
Wolf AM, Nasser JF, Schorling, J. B. The impact of informed consent on patient interest in prostate-specific antigen screening. Arch Intern Med 1996 Jun;156(12):1333-6.; - Wolf AM, Schorling JB. Preferences of elderly men for prostate-specific antigen screening and the impact of informed consent. J Gerontol A Biol Sci Med Sci 1998 May;53(3), M195-M200.; - Wolf AM, Philbrick JT, Schorling, J. B. Predictors of interest in prostate-specific antigen screening and the impact of informed consent: what should we tell our patients? Am J Med 1997 Oct;103(4), 308-14.

As indicated in the methods, a final screening process was undertaken, and the results are reported in Table 7. After considering multiple reports and completing several levels of screening, there were 61 unique studies forming the basis of the Evidence Report. There were 22 studies of the development of a decision aid and 39 studies that evaluated a decision aid in a clinical context. Table 8 lists the location of each study in the Evidence Report.

Table 7. Results of the final full text screening

Screening categories | Number of unique studies (n = 168) ^a^
Include
Effectiveness of a Decision Aid | 39
Development of a Decision Aid | 22
Total | 61
Exclude Research Use Only Usual Care Clinical Trial Entry Outcome Measure Other Intervention Palliative Care Other Focus (e.g., education, mathematical model, not cancer related) Abstract Only | 37 28 9 7 9 4 11 2
Total | 107

a Of the 207 articles included on the initial screening of full text, 39 articles have been considered companion articles to 168 unique studies.

Table 8. Location of included studies in report

Author | Related articles | Citation | Chapter | Evidence Table
Adler K. 1999 | | Adler K. Research in brief. Chemotherapy: the patient's choice. Eur J Oncol Nurs 1999 Jun;3(2):102-4. | Effectiveness | 5.4 a, b
Ashcroft JJ. 1985 | Ashcroft JJ. 1984 Owens RG. 1987 Leinster SJ. 1987 | Ashcroft JJ, Leinster SJ, Slade PD. Breast cancer--patient choice of treatment: preliminary communication. J R Soc Med 1985 Jan;78(1):43-6. | Effectiveness | 5.29 a, b
Brundage MD. 1997 | Brundage MD. 1998 | Brundage MD, Davidson JR, Mackillop WJ. Trading treatment toxicity for survival in locally advanced non-small cell lung cancer. J Clin Oncol 1997 Jan;15(1):330-40. | Development | 4.10 a, b
Brundage MD. 2000 | Brundage MD. 1998 Brundage MD. 1997 Brundage MD. 2001 | Brundage MD, Feldman SD, Dixon P, et al. A treatment trade-off based decision aid for patients with locally advanced non-small cell lung cancer. Health Expect 2000;3(1):55-68. | Effectiveness | 5.39 a, b
Carrère M. 2000 | Ferdjaoui N. 1999 | Carrère M, Moumjid-Ferdjaoui N, Charavel M et al. Eliciting patients' preferences for adjuvant chemotherapy in breast cancer: development and validation of a bedside decision-making instrument in a French Regional Cancer Centre. Health Expect 2000;97-113. | Development | 4.18 a, b
Cassileth BR. 1989 | | Cassileth BR, Soloway MS, Vogelzang NJ, et al. Patients' choice of treatment in stage D prostate cancer. Urology 1989 May;33(5 Suppl):57-62. | Effectiveness | 5.3 a, b
Chapman GB. 1995 | | Chapman GB, Elstein AS, Hughes KK. Effects of patient education on decisions about breast cancer treatments: a preliminary report. Med Decis Making 1995 Jul;15(3):231-9. | Development | 4.7 a, b
Cotton T. 1995 | | Cotton T. Patient choice in breast cancer treatment. Nurs Times 1995;91(17):12 | Effectiveness | 5.26 a, b
Cotton T. 1991 | | Cotton T, Locker AP, Jackson L, et al. A prospective study of patient choice in treatment for primary breast cancer. Eur J Surg Oncol 1991 Apr;17(2):115-17. | Effectiveness | 5.25 a, b
Davison BJ. 1997 | Pasacreta JV. 1998 | Davison BJ, Degner LF. Empowerment of men newly diagnosed with prostate cancer. Cancer Nurs 1997 Jun;20(3):187-96. | Effectiveness | 5.35 a, b
Davison BJ. 1999 | | Davison BJ, Kirk P, Degner LF, et al. Information and patient participation in screening for prostate cancer. Patient Educ Couns 1999;37 July(3):255-63. | Effectiveness | 5.24 a, b
Dolan JG. 1995 | | Dolan JG. Are patients capable of using the analytic hierarchy process and willing to use it to help make clinical decisions? Med Decis Making 1995 Jan;15(1):76-80. | Development | 4.6 a, b
Elit LM. 1996 | 2 studies in 1 article | Elit LM, Levine MN, Gafni A, et al. Patients' preferences for therapy in advanced epithelial ovarian cancer: development, testing, and application of a bedside decision instrument. Gynecol Oncol 1996 Sepa;62(3):329-35. | Development | 4. 14 a, b
Elit LM. 1996 | 2 studies in 1 article | Elit LM, Levine MN, Gafni A, et al. Patients' preferences for therapy in advanced epithelial ovarian cancer: development, testing, and application of a bedside decision instrument. Gynecol Oncol 1996 Sepb;62(3):329-35. | Development | 4.15 a, b
Fiset V. 2000 | 2 studies in 1 article | Fiset V, O'Connor AM, Evans W, et al. Development and evaluation of a decision aid for patients with stage IV non-small cell lung cancer. Health Expect 2000;3(2):125-36. | Effectiveness | 5.13 a, b
Fiset V. 2000 | 2 studies in 1 article | Fiset V, O'Connor AM, Evans W, Graham I, DeGrasse C, Logan J. Development and evaluation of a decision aid for patients with stage IV non-small cell lung cancer. Health Expect 2000;3:125-36. | Development | 4.21 a, b
Flood AB. 1996 | Anonymous 1996 2 studies in 1 article | Flood AB, Wennberg JE, Nease RFJ, et al. The importance of patient preference in the decision to screen for prostate cancer. Prostate Patient Outcomes Research Team. J Gen Intern Med 1996 Juna;11(6):342-49. | Effectiveness | 5.16 a, b
Flood AB. 1996 | Anonymous 1996 2 studies in 1 article | Flood AB, Wennberg JE, Nease RFJ, et al. The importance of patient preference in the decision to screen for prostate cancer. Prostate Patient Outcomes Research Team. J Gen Intern Med 1996 Junb;11(6):342-9. | Effectiveness | 5. 17 a, b
Goel V. 2001 | Goel V. 1998 | Goel V, Sawka CA, Thiel EC, et al. Randomized trial of a patient decision aid for choice of surgical treatment for breast cancer. Med Decis Making 2001;21(1):1-6. | Effectiveness | 5.12 a, b
Gramlich EP. 1998 | | Gramlich EP, Waitzfelder BE. Interactive video assists in clinical decision making. Methods Inf Med 1998 Jun;37(2):201-5. | Effectiveness | 5.23 a, b
Gustafson D. 1993a | Owens BH. 1996 Gustafson DH. 1993 Taylor JO. 1994 2 studies in 1 article | Gustafson D, Wise M, McTavish F, et al. Development and pilot evaluation of a computer-based support system for women with breast cancer. J Psychosoc Oncol 1993a;11(4):69-93. | Development | 4.2 a, b
Gustafson D. 1993b | 2 studies in 1 article | Gustafson D, Wise M, McTavish F, et al. Development and pilot evaluation of a computer-based support system for women with breast cancer. J Psychosoc Oncol 1993b;11(4):69-93. | Development | 4.3 a, b
Hack TF. 1999 | | Hack TF, Pickles T, Bultz BD, et al. Feasibility of an audiotape intervention for patients with cancer: A multicenter, randomized, controlled pilot study. J Psychosoc Oncol 1999;17(2):1-15 | Effectiveness | 5.10 a, b
Iglehart JD. 1998 | Miron A. 2000 Bluman LG. 1999 | Iglehart JD, Miron A, Rimer BK, et al. Overestimation of hereditary breast cancer risk. Ann.Surg. 1998;228:375-384. | Effectiveness | 5.2 a, b
Irwin E. 1999 | Irwin E 1995 | Irwin E, Arnold A, Whelan TJ, et al. Offering a choice between two adjuvant chemotherapy regimens: A pilot study to develop a decision aid for women with breast cancer. Patient Educ Couns 1999;37(3):283-91. | Effectiveness | 5.30 a, b
Jenkinson J. 1998 | | Jenkinson J, Wilson-Pauwels L, Jewett MA, et al. Development of a hypermedia program designed to assist patients with localized prostate cancer in making treatment decisions. J Biocomm 1998;25(2):2-11. | Development | 4.8 a, b
Klass W. 1992 | | Klass W, Varenhorst E, Hjertberg H, et al. A study on prostatic cancer. The patient can decide himself: medical or surgical treatment. Lakartidningen 1992 May;89(19):1659-61. | Effectiveness | 5.6 a, b
Lawrence VA. 2000 | | Lawrence VA, Streiner D, Hazuda HP, et al. A cross-cultural consumer-based decision aid for screening mammography. Prev Med 2000;30(3):200-8. | Development | 4.17 a, b
Lerman C. 1997 | Lerman C. 1999 | Lerman C, Biesecker B, Benkendorf JL, et al. Controlled trial of pretest education approaches to enhance informed decision-making for BRCA1 gene testing. J Natl Cancer Inst 1997 Jan;89(2):148-57. | Effectiveness | 5.34 a, b
Levine MN. 1992 | 2 studies in 1 article | Levine MN, Gafni A, Markham B, et al. A bedside decision instrument to elicit a patient's preference concerning adjuvant chemotherapy for breast cancer. Ann Intern Med 1992 Jula;117(1):53-8. | Effectiveness | 5.33 a, b
Levine MN. 1992 | 2 studies in 1 article | Levine MN, Gafni A, Markham B, et al. A bedside decision instrument to elicit a patient's preference concerning adjuvant chemotherapy for breast cancer. Ann Intern Med 1992 Julb;117(1):53-8. | Development | 4.11 a, b
Maslin AM. 1998 | Maslin AM. 1998 | Maslin AM, Baum M, Walker JS, et al. Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. Nt Research 1998 Nova;3(6):444-55. | Effectiveness | 5.20 a, b
McTavish FM. 1995 | Taylor JO. 1994 Gustafson D. 1993 Owens BH. 1996 | McTavish FM, Gustafson DH, Owens BH, et al. CHESS (Comprehensive Health Enhancement Support System): an interactive computer system for women with breast cancer piloted with an underserved population. J Ambulatory Care Manage 1995;18(3):35-41. | Development | 4.4 a, b
Molenaar S. 2001 | | Molenaar S, Sprangers MA, Rutgers EJ, et al. Decision support for patients with early-stage breast cancer: effects of an interactive breast cancer CDROM on treatment decision, satisfaction, and quality of life. J Clin Oncol 2001;19(6):1676-87. | Effectiveness | 5.22 a, b
North N. 1992 | | North N, Cornbleet MA, Knowles G, et al. Information giving in oncology: a preliminary study of tape-recorder use. Br.J.Clin.Psychol. 1992 Sep;31(3):357-9. | Effectiveness | 5.11 a, b
Okamato M. 1999 | | Okamato M, Takahashi HO, Yao K, et al. A prospective study of introducing self-determined treatment policy for the patients with hypopharyngeal cancer. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan] 1999 Jul;102(7):918-24. | Effectiveness | 5.28 a, b
Onel E. 1998 | | Onel E, Hamond C, Wasson JH, et al. Assessment of the feasibility and impact of shared decision making in prostate cancer. Urology 1998 Jan;51(1):63-6. | Effectiveness | 5.18 a, b
Pignone M. 2000 | | Pignone M, Harris R, Kinsinger L. Vidoetape-Based Decision Aid for Colon Cancer Screening. Ann Intern Med 2000;133:761-9. | Effectiveness | 5.15 a, b
Protiere C. 2000 | | Protiere C, Viens P, Genre D, et al. Patient participation in medical decision-making: a French study in adjuvant radio-chemotherapy for early breast cancer. Ann Oncol 2000 Jan;11(1):39-45. | Effectiveness | 5.5 a, b
Ravdin PM. 2001 | | Ravdin PM, Siminoff LA, Davis GJ, et al. Computer program to assist in making decisions about adjuvant therapy for women with early breast cancer. J ClinOncol 2001;19(4):980-91. | Development | 4.9 a, b
Rolnick SJ. 1999 | | Rolnick SJ, Owens B, Botta R, et al. Computerized information and support for patients with breast cancer or HIV infection. Nurs Outlook 1999 Mar;47(2):78-83. | Development | 4.5 a, b
Sandison AJ. 1996 | | Sandison AJ, Gold DM, Wright P, et al. Breast conservation or mastectomy: treatment choice of women aged 70 years and older. Br J Surg 1996 Jul;83(7):994-6. | Effectiveness | 5.27 a, b
Sawka C. 1998a | 2 studies in 1 article | Sawka C, Goel V, Mahut C, et al. Development of a patient decision aid for choice of surgical treatment for breast cancer. Health Expect 1998a;1:23-36. | Development | 4.19 a, b
Sawka C. 1998b | 2 studies in 1 article | Sawka C, Goel V, Mahut C, et al. Development of a patient decision aid for choice of surgical treatment for breast cancer. Health Expect 1998b;1:23-36. | Development | 4.20 a, b
Schapira MM. 1997 | | Schapira MM, Meade C, Nattinger AB. Enhanced decision-making: the use of a videotape decision-aid for patients with prostate cancer. Patient Educ Couns 1997 Feb;30(2):119-27. | Development | 4.1 a, b
Schapira MM. 2000 | | Schapira MM, VanRuiswyk J. The effect of an illustrated pamphlet decision-aid on the use of prostate cancer screening tests. J Fam Pract 2000;49(5):418-24. | Effectiveness | 5.1 a, b
Sebban C. 1995 | | Sebban C, Browman G, Gafni A, et al. Design and validation of a bedside decision instrument to elicit a patient's preference concerning allogenic bone marrow transplantation in chronic myeloid leukemia. Am J Hematol 1995 Apr;48(4):221-7. | Development | 4.13 a, b
Sepucha KR. 2000 | | Sepucha KR, Belkora JK, Tripathy D, et al. Building bridges between physicians and patients: Results of a pilot study examining new tools for collaborative decision making in breast cancer. J Clin Oncol 2000;18(6):1230-8. | Effectiveness | 5.36 a, b
Stalmeier P. 1999 | Unic I. 1998 Unic I. 2000 | Stalmeier P, Unic I, Verhoef L, et al. Evaluation of a shared decision making program for women suspected to have a genetic predisposition to Breast Cancer. Med Decis Making 1999;19:230-41. | Effectiveness | 5.37 a, b
Street RLJ. 1995 | Street RL. 1997 | Street RLJ, Voigt B, Geyer CJ, et al. Increasing patient involvement in choosing treatment for early breast cancer. Cancer 1995 Dec;76(11):2275-85. | Effectiveness | 5.21 a, b
Unic I. 1998 | Stalmeier P. 1999 Unic I. 2000 | Unic I, Stalmeier PF, Verhoef LC, et al. Assessment of the time-tradeoff values for prophylactic mastectomy of women with a suspected genetic predisposition to breast cancer. Med Decis Making 1998 Jul;18(3):268-77. | Development | 4.22 a, b
Volk RJ. 1999 | Volk RJ. 1998 | Volk RJ, Cass AR, Spann SJ. A randomized controlled trial of shared decision making for prostate cancer screening. Arch Fam Med 1999 Jul;8(4):333-40. | Effectiveness | 5.14 a, b
Watson M. 1998 | | Watson M, Duvivier V, Wade WM, et al. Family history of breast cancer: What do women understand and recall about their genetic risk? J Med Genet 1998;35(9):731-8. | Effectiveness | 5.9 a, b
Whelan T. 1999 | 2 studies in 1 article | Whelan T, Levine M, Gafni A, et al. Mastectomy or lumpectomy? Helping women make informed choices. J Clin Oncol 1999 Juna;17(6):1727-35. | Effectiveness | 5.32 a, b
Whelan T. 1999 | 2 studies in 1 article | Whelan T, Levine M, Gafni A, et al. Mastectomy or lumpectomy? Helping women make informed choices. J Clin Oncol 1999 Junb;17(6):1727-35. | Development | 4.16 a, b
Whelan TJ. 1995 | 2 studies in 1 article | Whelan TJ, Levine MN, Gafni A, et al. Breast irradiation postlumpectomy: development and evaluation of a decision instrument. J Clin Oncol 1995 Apra;13(4):847-53. | Effectiveness | 5.31 a, b
Whelan TJ. 1995 | 2 studies in 1 article | Whelan TJ, Levine MN, Gafni A, et al. Breast irradiation postlumpectomy: development and evaluation of a decision instrument. J Clin Oncol 1995 Aprb;13(4):847-53. | Development | 4.12 a, b
Wilson RG. 1988 | | Wilson RG, Hart A, Dawes PJ. Mastectomy or conservation: the patient's choice. BMJ 1988 Nov;297(6657):1167-9. | Effectiveness | 5.19 a, b
Wolberg WH. 1987 | Wolberg WH. 1989 Wolberg WH. 1991 Ward S. 1989 | Wolberg WH, Tanner MA, Romsaas EP, et al. Factors influencing options in primary breast cancer treatment. J Clin Oncol 1987 Jan;5(1):68-74. | Effectiveness | 5.38 a, b
Wolf AM. 1996 | Wolf AM. 1998 Wolf AM. 1997 | Wolf AM, Nasser JF, Schorling JB. The impact of informed consent on patient interest in prostate-specific antigen screening. Arch Intern Med 1996 Jun;156(12):1333-6. | Effectiveness | 5.7 a, b
Wolf AM. 2000 | | Wolf AM, Schorling JB. Does informed consent alter elderly patients' preferences for colorectal cancer screening? Results of a randomized trial. J Gen Intern Med 2000 Jan;15(1):24-30. | Effectiveness | 5.8 a, b

## General Characteristics of All Included Studies

The following section describes the general characteristics of the included studies. The most salient characteristics of all the studies included (Tables 9 to 17) were the following:

- The number of studies has more than doubled during the 5 years from 1996 to 2001.
- Thirty-eight percent of the studies did not report any information about the source of funding for the research.
- Seventy-four percent of studies were centered in North America.
- Ninety-seven percent of studies were published in English.
- Case series designs (28) accounted for 46 percent of all included reports. There were 16 RCTs, four non-RCTs, and the remaining studies were a mix of other designs.
- Sixty-one percent of studies (37) included patients with breast cancer. Twenty-one percent included patients with prostate cancer, 7 percent ovarian cancer, and the remaining studies included patients with a mix of different types of cancer.
- In nearly all studies (99 percent), the participants were over age 18.
- Across all studies, the most common context of the decision was treatment (71 percent), followed by screening and prevention (28 percent). However, when only RCTs were considered, in 44 percent (7/16) of studies, decisions were made in a treatment context, and in 56 percent (9/16) of studies, the context was screening.
- Thirty-six percent (22/61) reported the developmental process of a decision aid, and 64 percent (39/61), the effectiveness of a decision aid.
- Of the 39 studies investigating the effectiveness of a decision aid, only 1 study focused on a special population (women over 70 years). Only 2 studies of 22 developed a decision aid for special populations (Spanish-speaking Mexican-American women and low-income African-American women).

Table 9. Year of publication

Year of Publication | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
1981-1985 | 1 (1.6) | 1 (2.6) | 0 (0.0)
1986-1990 | 3 (4.9) | 3 (7.7) | 0 (0.0)
1991-1995 | 16 (26.2) | 7 (17.9) | 9 (40.9)
1996-2001 | 41 (67.2) | 28 (71.8) | 13 (59.1)
Total ^a^ | 61 (99.9) | 39 (100.0) | 22 (100.0)

a Not exactly 100% due to rounding error.

Table 10. Language of publication

Language of Publication | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
English | 59 (96.7) | 37 (94.9) | 22 (100.0)
Japanese | 1 (1.6) | 1 (2.6) | 0 (0.0)
Swedish | 1 (1.6) | 1 (2.6) | 0 (0.0)
Total ^a^ | 61 (99.9) | 39 (100.1) | 22 (100.0)

a Not exactly 100% due to rounding error.

Table 11. Country where study was centered

Country Where Study Was Centered (more than one possible) | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
United States | 25 (41.0) | 16 (41.0) | 9 (41.0)
Canada | 20 (32.8) | 10 (25.6) | 10 (45.5)
Australia | 1 (1.6) | 1 (2.6) | 0 (0.0)
United Kingdom | 7 (11.5) | 7 (18.0) | 0 (0.0)
France | 3 (4.9) | 1 (2.6) | 2 (9.1)
Japan | 1 (1.6) | 1 (2.6) | 0 (0.0)
Netherlands | 3 (4.9) | 2 (5.1) | 1 (4.6)
Sweden | 1 (1.6) | 1 (2.6) | 0 (0.0)
Not Clear | 1 (1.6) | 1 (2.6) | 0 (0.0)

Table 12. Source of funding

Source of Funding | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
Industry | 2 (3.3) | 0 (0.0) | 2 (9.1)
Other | 35 (57.4) | 24 (61.5) | 11 (50.0)
Not reported | 23 (37.7) | 14 (35.9) | 9 (40.9)
Not clear | 1 (1.6) | 1 (2.6) | 0 (0.0)
Total | 61 (100.0) | 39 (100.0) | 22 (100.0)

Table 13. Design of primary study

Design of Primary Study (more than one possible) | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
Case series | 28 (45.9) | 16 (41.0) | 12 (54.6)
Randomized controlled trial | 18 (29.5) | 16 (41.0) | 2 (9.1)
Other | 9 (14.8) | 2 (5.1) | 7 (31.8)
Controlled trial | 5 (8.2) | 4 (10.3) | 1 (4.6)
Survey | 1 (1.6) | 0 (0.0) | 1 (4.6)
One group pre/post design | 2 (3.3) | 1 (2.6) | 1 (4.6)

Table 14. Focus of the study -- Focal disease

Focus of the Study: Focal Disease (more than one possible) | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
Breast cancer | 37 (60.7) | 23 (59.0) | 14 (63.6)
Colorectal cancer | 3 (4.9) | 2 (5.1) | 1 (4.6)
Leukemia | 1 (1.6) | 0 (0.0) | 1 (4.6)
Lung cancer | 4 (6.6) | 2 (5.1) | 2 (9.1)
Oral/Pharyngeal cancer | 1 (1.6) | 1 (2.6) | 0 (0.0)
Ovarian cancer | 4 (6.6) | 2 (5.1) | 2 (9.1)
Prostate cancer | 13 (21.3) | 11 (28.2) | 2 (9.1)
Not specified | 1 (1.6) | 1 (2.6) | 0 (0.0)
Other | 1 (1.6) | 0 (0.0) | 1 (4.6)

Table 15. Focus of the study -- Type of decision

Focus of the Study: Type of Decision (more than one possible) | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
Prevention | 2 (3.2) | 1 (2.6) | 1 (4.6)
Screening | 15 (24.6) | 12 (30.8) | 3 (13.6)
Treatment | 47 (77.1) | 28 (71.8) | 19 (86.4)
Other | 1 (1.6) | 0 (0.0) | 1 (4.6)

Table 16. Characteristics of sample

Characteristics of Sample (more than one possible) | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
Patients with focal disease | 41 (67.2) | 28 (71.8) | 13 (59.1)
Patients with noncancer disease | 1 (1.6) | 0 (0.0) | 1 (4.6)
Healthy people at risk for cancer | 14 (23.0) | 11 (28.2) | 3 (13.6)
Health care volunteers | 6 (9.8) | 1 (2.6) | 5 (22.7)
Nonhealth care volunteers | 6 (9.8) | 0 (0.0) | 6 (27.3)

Table 17. Age category

Age Category (more than one possible) | Overall n (%) | Effectiveness of a Decision Aid n (%) | Development of a Decision Aid n (%)
Adults (18 years or older) | 61 (100.0) | 39 (100.0) | 22 (100.0)
Adolescents (age 13-17) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Children (<13 years) | 0 (0.0) | 0 (0.0) | 0 (0.0)