# Methodology

## Players and Key Stakeholders

### Local Expert and Research Team

To conduct the systematic review, a local expert and research team was assembled. This team consisted of members of the MU-EPC whose areas of expertise include medical and professional aspects of cancer care and patient support; models and theoretical understanding of decisionmaking processes; systematic reviews; and other health research methodology. Highly trained research assistants and administrative support staff augmented this team.

### Task Order Officer and Partners

A second organizational sector of those involved in this systematic review include our partner, the NCI (represented by Drs. Barbara Rimer and Michael Stefanek), who commissioned the report, and Margaret Coopey, our Task Order Officer (TOO), who represented the Agency for Healthcare Research and Quality (AHRQ) and consulted with our team.

### Technical Expert Panel and Peer Review Process

The Technical Expert Panel (TEP) for this Task Order was composed of individuals whose collective expertise represented several of the major components in the delivery of cancer care, including health services researchers, health care providers, and consumers (see Appendix A). These individuals are recognized as national and international leaders in the area of cancer-related consumer information and were selected in consultation with our local research team experts, AHRQ, and our partners at NCI. The main function of the TEP was to provide an external review of this project at various stages throughout its course.

## Topic Assessment and Refinement

Questions to be addressed in the task order were identified by the NCI. Refined questions and project scope were negotiated and achieved through consensus between the local research team and the NCI. Results of this process yielded an operational definition of a decision aid and a specific series of questions to be answered in this systematic review.

For the purposes of this systematic review, a definition was sought that was broad enough to encompass and be inclusive of the broad range of thinking in this area. Specifically, a "decision aid" was defined as: An intervention designed primarily to help patients or patients and clinicians together, with making cancer-related health care decisions, when options are available for prevention, screening and treatment. At a minimum, it should target some component of decisionmaking (e.g., information exchange, involvement in the decision process).

A decision aid was considered an "intervention" when it involved some process or instrument that was above and beyond "usual or standard care." For the purpose of this Evidence Report, usual care was defined as standard practice as indicated by the primary study authors. We expected that the components of usual care would vary from study to study depending on the clinical context, but, most of the time, would involve some discussion of risks and benefits of options. Patients must have been involved in the use of the instrument (i.e., patient alone, patient together with significant others). Those tools designed purely for clinicians (e.g., clinical guideline algorithms to standardize care pathways) that provided some form of decision assistance were excluded. The definitive set of questions negotiated between the local research team, the NCI, and AHRQ addressed various themes in the decision aids literature, including the development process of these tools; their effectiveness, including outcomes emerging from their use; and future research directions. The specific questions included:

### Types of Decision Aids

- What models of decisionmaking (e.g., informed, shared) underpin decision aids that have been used?
- What clinical contexts (e.g., prevention, screening, and treatment) have been investigated?
- What has been the clinical focus of the decision aids (e.g., type of cancer and extent of disease)?
- What has been the mode of delivery (e.g., print, interactive video)?

### Populations Using Decision Aids

- On what populations has the research been conducted?
- Have decision aids been developed for or used by members of special populations (e.g., the elderly, ethnic groups, and people with a low level of education)?

### Decision Aids and Outcomes

- What outcomes have been evaluated (e.g., increase in knowledge, satisfaction, and behaviors)?
- Are there any key outcomes that are associated with specific characteristics of decision aids?

### Effectiveness of Decision Aids

- What is the effectiveness of decision aids?
- What is the effectiveness of decision aids in different clinical contexts?
- What is the effectiveness of different modes of delivery?
- What is the effectiveness of decision aids on special populations?

### Future Directions

- What specific direction is needed in future research on cancer-related decision aids?

## Literature Search Strategies

A health science librarian on the local research team assisted with designing and pretesting the literature search strategies for electronic databases. The search strategy for the MEDLINE search is found in Appendix B. Studies were identified using MEDLINE, HealthSTAR, CANCERLIT, CINAHL, Sociological Abstracts, PsycINFO, and the Cochrane Library electronic databases (January 1977 to August 2000) without language restrictions. EMBASE was searched from 1995-2000. The MEDLINE search was subsequently updated to the end of April 2001. In addition to searching major electronic databases, citations of relevant references from published reviews on decision aids, from reference lists of primary articles selected for inclusion, and from suggestions made by members of the local research team and the TEP were also reviewed. Unpublished studies were not included because of concerns about potential threats to internal validity and lack of a peer review process.

### Selection Criteria

#### Inclusion Criteria

A range of inclusion criteria were chosen to reflect methodological, conceptual, and clinical considerations:

- primary human studies
- studies of any design
- interventions that met our definition of a decision aid and involved a decision along the cancer care continuum.

There were no restrictions by the type of outcome measures used by the primary study authors to evaluate the impact of the decision aid.

#### Exclusion Criteria

- news articles, letters, or editorials;
- tools designed solely for clinicians;
- interventions focused on benign prostatic hyperplasia, hormone replacement therapy, and smoking cessation;
- interventions advocating a particular course of action; and
- interventions evaluated after a decision was made.

## Study Screening and Study Selection

### Initial Screening of Title and Abstract Citations

Three criteria were used in the initial screening. The article had to: (1) be a primary study, systematic review, or useful support document; (2) demonstrate evidence that the clinical context was cancer; and (3) meet the definition of a decision aid or describe the development or validation of an outcome measure (see Appendix C). Those articles that met the eligibility criteria were retrieved in full text and subject to the secondary review.

Seven trained reviewers participated in the initial screening process. Each reviewer received a block of citations. There was approximately a 10 percent overlap in citations from one reviewer to the next, resulting in 10 percent of the initial 10,772 citations being screened by at least two independent reviewers. Discrepancies were resolved by consensus and, where consensus could not be reached, the opinions of a third reviewer were requested.

## Screening of Full Text Articles

To ensure systematic application of inclusion and exclusion criteria and to document the process of full-text screening, a "relevance form" was developed (see Appendix D) for this phase. Articles considered in this phase were allocated to the reviewers following a randomization schedule implemented by an unblinded project assistant. Two reviewers rated each article independently. For each article, the "relevance form" was completed and a rating of "Include," "Exclude" or "Uncertain" was made. A consensus process that was documented on the "consensus" relevance form resolved discrepancies. In circumstances in which articles were rated as "Uncertain" or where consensus between the two initial reviewers could not be reached, a third reviewer or members of the local research team were called in to resolve the discrepancy.

Exceptions to this protocol were made for articles published in a language other than English; only one reviewer who was proficient in the language of publication assessed the article for eligibility and completed the relevance form.

## Data Extraction

Three data extraction forms were developed, pilot-tested, and revised by members of the local research team. One form was designed for each of general study characteristics, study outcomes, and study quality. Two reviewers completed data extraction independently of all the articles. Discrepancies were resolved by consensus, and the final forms were scanned into a Microsoft Access database using Teleform software (TELEform Standard version 6.0, Cardiff Software Incorporated, San Marcos, CA, USA).

## Quality Criteria

The quality assessment of the randomized controlled trials (RCTs) was based on three scales: Jadad, et al. scale,^21^ Downs and Black scale,^22^ and Guyatt, et al. scale.^23^ For other study designs-such as non-RCTs, nonconcurrent cohort studies, and case series -- in assessing the methodological quality, the Downs and Black scale^22^ was employed only.

## Data Synthesis

Descriptive statistics were calculated for all fields of the database. Evidence tables were constructed to describe the most salient figures of the included studies using the review questions as an organizational framework. Two tables for each study were designed: the general study characteristics and the study results.

The local research team evaluated the overall quantity and quality of the data available. Given the heterogeneity across studies (i.e., type of decision aids; type of cancer; type of decisions [prevention, screening, treatment]; study designs; inconsistency in outcomes measured; inconsistency in theoretical predications about outcomes; and poor study quality), a meta-analysis was not undertaken. Thus, this report represents a systematic qualitative review of the existing evidence, emphasizing the directions that future researchers could take to fill existing knowledge gaps.

## Peer Reviewers

A preliminary list of potential peer reviewers was drafted in July 2000 and sent to our partners. In February 2001, reviewers were contacted to request their assistance in reviewing the draft version of the Evidence Report; 16 of the 29 proposed reviewers agreed to be our peer reviewers (see Appendix E).