# Introduction

## Decisionmaking About Prevention, Screening, and Treatment

Decisionmaking for many chronic medical illnesses is a difficult task. The process requires clinicians and patients to weigh the immediate costs of inconvenience and potential morbidity of a preventive, screening, or treatment option against potential future benefits such as reduction in morbidity or disability. This tradeoff is further complicated by the uncertainty of these outcomes for the individual patient. With the rapid progress of modern health care, this process has become more challenging as clinicians and patients are often confronted with more than one or two options. Many of these new treatments are accompanied by more modest potential benefits and significant side effects, making the decisionmaking process even more difficult.

In the past, clinicians often tended to make decisions for patients with little patient input.^1,2^ More recently, patients have indicated their need for more information about their disease and the desire to be involved in decisions about their care.^3^ Clinicians and policy makers increasingly have realized the importance of including patient's values when making treatment decisions. The principle of informed choice (i.e., disclosure of treatment alternatives rather than merely informed consent) also has been endorsed at several government levels in the United States, Canada, and the United Kingdom.

Decisions are made most often in the context of clinician- (often physician-) patient encounter. Recent research recognizes the complexity of this interaction and the many forms that it may take.^4,5^ In general, the encounter involves several stages, including the exchange of information between the clinician and the patient, deliberation, and decisionmaking.^6^ The encounter also may take several forms based on the preferred type of interaction by the patient and the clinician. One extreme is the older, paternalistic type of interaction where information flows in one direction -- from the clinician to the patient -- and the clinician alone makes the decision. At the other extreme is the "informed" type of interaction where, again, information flows mainly in one direction, but the patient alone makes the decision.^4^ Recently, Charles and colleagues have described the shared model.^5^ The essential characteristic of this model is that both the clinician and the patient share all stages of the decisionmaking process simultaneously. In its purest form, there is a two-way exchange of information where both physician and patient reveal treatment preferences and both agree on the decision and implement it. However, decisionmaking is a dynamic process and, in any particular clinician-patient encounter, approaches may lie between and move between these types of interaction.

Several investigators have suggested problems with the paternalistic type of physician-patient encounter, particularly with the transfer of information between the physician and the patient.^7,8^ Treatment decisionmaking has been found to be particularly problematic for physicians and cancer patients.^7,9-14^ This is perhaps not unexpected given that the cancer patient can be faced with difficult information about a poor prognosis with limited treatment options. Physicians may find it difficult to openly share this type of information and patients may understandably be anxious or depressed, making it increasingly difficult for them to understand the information presented and take part in the decisionmaking.

Siminoff and Fetting^7^ studied 100 consecutive physician-patient encounters regarding adjuvant chemotherapy in women with early breast cancer to assess the consultative approach. They observed that the communication pattern, particularly that of the physician, was independent of the characteristics of the patient and severity of her disease. The risks and benefits of treatment were discussed, but the physician exchanged little in the way of specific information. The impact of treatment on the patient's lifestyle and emotional state often was not routinely addressed. Not surprisingly, the majority of patients (60 percent) overestimated their chance of cure by 20 percent or more and underestimated the severity of common side effects by a similar amount. Although patients were given alternative options, physicians, perhaps acknowledging the difficulty in communication, generally recommended one treatment and this had a definite influence on the patient's decision. Similarly, Rimer reviewed 116 consultations between physicians and cancer patients.^9^ Clinicians, on average, told patients less than 70 percent of the information relevant to their disease and treatment and patients, on average, recalled only 40 percent of the information that they were told. Other studies have described similar difficulties with information transfer in the oncology encounter.^15,16^

Aside from these problems in communication, researchers have also identified specific problems in treatment decisionmaking. Degner et al.^13^ examined the experiences of 1,012 women with breast cancer regarding their participation in decisionmaking. Twenty-two percent of women indicated they wanted to select their own treatment (active role); 44 percent wanted to select treatment collaboratively with their physician (shared role), and 34 percent wanted to delegate the responsibility to their physician (passive role). However, only 42 percent of patients were able to achieve their preferred role of decisionmaking, and this was even less for those who preferred a more active or shared role.

## Decision Aids

In light of these problems, researchers have responded by investigating better ways of transferring information to patients and supporting them in decisionmaking. Decision aids have been previously defined as "interventions designed to help people make specific and deliberative choices among options (including the status quo) by providing (at a minimum) information on the options and outcomes relevant to a patient's health."^14^ Decision aids differ from traditional patient education materials that are provided to patients. Decision aids provide an explicit presentation of different treatment options and the associated benefits and risks. The information is often tailored to individual characteristics of the patient and their decision. In addition to providing information, decision aids may support patients in other ways to help them make a decision. Examples of these types of decision aids are written materials, computer-based programs, videotapes, audio-guided workbooks and decision boards.

Recently, a number of decision aids have been developed for cancer patients because of the difficulties in communication and treatment decisionmaking identified in the literature. There has been a marked interest in decision aids for cancer patients and their physicians for several reasons: (1) poor understanding may be due to multiple factors, including poor communication techniques, information overload, patient anxiety, and denial; (2) patients with cancer are especially vulnerable dealing with the distressing and difficult diagnosis of a potentially terminal illness; (3) research suggests that communication can be especially poor when dealing with the ethnically diverse, poorly educated, or elderly, who are often overrepresented in the cancer population; (4) treatment decisionmaking in oncology is particularly problematic with a number of different treatments available and many associated with rather modest benefits and significant side effects; and (5) the cancer continuum identifies a number of areas in prevention, screening, diagnosis, treatment, and end-of-life care where the treatment decisions will vary considerably with respect to options available and associated benefits and risks.

Since 1999, there have been six reports (five systematic reviews^14,15,17-19^ and one review of reviews^20^) on decision aids. For example, O'Connor and colleagues^14^ conducted a systematic review of decision aids in various health conditions. Of the 17 randomized trials included, six studies were related to cancer. A number of different cancer-related decision aids (DA) interventions were identified. The authors conclude that, overall, decision aids improved patient knowledge. In a small subgroup of studies, decision aids also appeared to help patients be more involved in decisionmaking and feel more comfortable about their choices, but decision aids did not appear to have a consistent impact on patient satisfaction or anxiety. Molenaar and colleagues^19^ conducted a DA review that included all study designs (controlled and noncontrolled). Thirty studies of DA interventions were identified, 18 of which were related to cancer. The authors report that decision aids were found to be both feasible and acceptable to patients. Like the O'Connor review,^14^ the authors found that DAs improved patient knowledge of available options. Generally, all of these reviews are consistent, demonstrating a variable impact of decision aids on the specific outcomes evaluated. One reviewer concluded that the variability in the impact observed may be related to the different decision aids evaluated and the different contexts studied.^19^

To date, only one review^15^ has focused on cancer, and none of the reviews have included studies on the development of decision aids. Further, if one considers only the cancer-specific components of these larger projects, there appears to be inconsistency in the cancer studies included in the reviews. These differences cannot be accounted for solely by differences in the inclusion/exclusion criteria used in the different reviews or by the year of publication (see Tables 1 and 2). Thus, although each existing review provides an important contribution, none adequately provides answers regarding the utility and value of decision aids in cancer.

Table 1. List of inclusion/exclusion criteria and time period included in DA systematic reviews

Systematic Review | Inclusion Criteria | Exclusion Criteria | Time period included in literature search
Bekker, H. Health Technology Assessment (1999) Volume 3, Number 1 | - not limited to cancer - real patients making a health decision (decision could be real, intended, or hypothetical) - experimental studies with a comparison group (RCTs, non-randomized concurrent, historical studies, and before/after studies with same sample) | - non-English articles - healthy volunteers as subjects - health professionals making decisions about another's care | Electronic database search (1991 to 1996) Three key journals hand searched from 1986 to 1996
O'Connor, A Journal of the National Cancer Institute Monographs (1999a) 25: 67-80 | - not limited to cancer - before/after studies with patients - randomized trials with patients compared to usual care - randomized experiments comparing DAs (included hypothetical choices) | - none explicitly stated | Start date: 1966 End date: early 1998
O'Connor, A BMJ (1999b) 319: 731-734 | - not limited to cancer - randomized trials of DAs - screening or treatment - subjects > 14 years old | - hypothetical choices - clinical trial entry - compliance - advocates an option | Range: 1966 to 1998 [refer to paper]
Molenaar, S. Medical Decision Making (2000) 20: 112-127 | - not limited to cancer -abstracts | - non-English articles | - two annotated bibliographies: (1) shared decisionmaking; and (2) decision aids - electronic database search of Medline from January 1993 to August 1998
Estabrooks, C. Consumer Decision Aids: Where do we stand? Institute for Clinical Evaluative Sciences March (2000) | - not limited to cancer - decisionmaker must be a consumer | - hypothetical decisions - compliance - education only - clinical trial entry - advanced directives -smoking cessation -did not evaluate the DA -did not report measurement of one or more outcome | Start date: 1992 End date: October 1998 - Medline updated monthly. A few key journals hand searched for 1999
NHS Effective Health Care bulletin, December (2000) volume 6, number 6 | - in the part of the report focused on DAs, three systematic reviews of DAs were identified (all three are included in this table; two are the reviews by O'Connor and the one by Molenaar) - the DA section of the report was limited to participants who had a cancer diagnosis | | - systematic reviews of decision aids were identified by a search of electronic databases (1966 to August 2000) - reran O'Connor (1999a) search strategy with the additional criteria that participants had to have a cancer diagnosis; updated search to October 2000
Whelan, T. Impact of cancer-related Decision Aids: An evidence report Agency for Healthcare Research and Quality (2001) | - cancer-related DAs - abstracts published before 1995 were excluded if no followup paper. Abstracts > 1995: included if author contacted (either if paper to come or no paper); excluded if author not contacted or no further paper. | - advocates a particular option - compliance - BPH or HRT - clinical trial entry, palliative care, usual care, and research use only studies | Electronic database search. Start date: 1977 End date: April 2001

Table 2. Cancer-related RCT studies included in DA systematic reviews

Cancer-related RCT studies included in decision aid systematic reviews ^a^ | | Bekker (1999) | O'Connor (1999a) | O'Connor (1999b) | Molenaar (2000) | NHS Bulletin (2000) | Estabrooks (2000) | Whelan (2001)
Author | Year | Bekker (1999) | O'Connor (1999a) | O'Connor (1999b) | Molenaar (2000) | NHS Bulletin (2000) | Estabrooks (2000) | Whelan (2001)
North | 1992 | | | | | | | [image] (E) ^c^
Butow | 1994 | [image] | [image] | | | | | Exclude ^d^
Llewellyn-Thomas | 1995 | [image] | [image] | | [image] | | | Exclude ^d^
Sebban | 1995 | | [image] | | [image] | | | [image] (D) ^c^
Street | 1995 | [image] | [image] | [image] | [image] | [image] | [image] | [image] (E) ^c^
VanRuiswijk [abstract] ^b^ | 1995 | | [image] | | [image] | | | Exclude ^d^
Whelan | 1995 | [image] [RCT] ^b^ | | | | | | [image] [not RCT] ^b^
Flood | 1996 | | [image] [RCT] ^b^ | [image] [RCT] ^b^ | [image] [CT] ^b^ | | [image] [CT] ^b^ | [image] [CT] ^b^
Wolf | 1996 | [image] | [image] | [image] | [image] | | | [image] (E) ^c^
Davison | 1997 | | [image] | [image] | | [image] | | [image] (E) ^c^
Lerman | 1997 | | | [image] | [image] | | [image] | [image] (E) ^c^
Inglehart | 1998 | | | | | | | [image] (E) ^c^
Maslin | 1998 | | | | | [image] | | [image] (E) ^c^
Watson | 1998 | | | | | | | [image] (E) ^c^
Davison | 1999 | | | [image] | | | | [image] (E) ^c^
Hack | 1999 | | | | | | | [image] (E) ^c^
Irwin | 1999 | | | | | | | [image] (E) ^c^
Rolnick | 1999 | | | | | | | [image] (D) ^c^
Volk | 1999 | | [image] [abs] ^b^ | | | | | [image] (E) ^c^
Pignone | 2000 | | | | | | | [image] (E) ^c^
Schapira | 2000 | | | | | | | [image] (E) ^c^
Wolf | 2000 | | | | | | | [image] (E) ^c^
Goel | 2001 | | [image] [abs] ^b^ | | | [image] [in press] ^b^ | | [image] (E) ^c^

a RCT studies that assessed patient compliance, clinical trial entry or advocated a particular course of action are not reported in the above table.

b [] notation is used when either: (1) the study was reported as an RCT by one review and a different design by another, or (2) to distinguish inclusion of an abstract, in press, or published paper.

c (E) means the RCT included the effectiveness chapter and (D) that the study was included in the development chapter.

d Identified by our search strategy, not included in the review: Butow was excluded as secondary purpose; Llewellyn-Thomas excluded as research use only; and VanRuiswijk was excluded as abstract only.

Given the unique challenges this clinical condition may have on the decisionmaking process, a more comprehensive understanding of the decision aids is warranted. A systematic review of decision aids for cancer patients would provide an overview of what has been developed and determine whether these instruments do improve communication and decisionmaking for cancer patients and clinicians. Such a review would also provide other added benefits not studied in previous reviews, including an opportunity to address the impact of different instruments in a more homogeneous population and to evaluate the impact of different points on the continuum of care on the efficacy of decision aids.

## Commissioning of This Report

The McMaster University Evidence-based Practice Centre (MU-EPC) was notified in March 2000 that it was successful in its bid to undertake the development of an evidence report on the "Impact of Cancer-Related Decision Aids." This topic was nominated by the National Cancer Institute (NCI), Division of Cancer Control and Population Sciences. The goal in this project was to identify and summarize the best available information for each question; to make the results available to patients, clinicians, policymakers, and researchers; and to encourage further evaluation of these instruments in clinical practice.