# Appendix G: Acronyms and Abbreviations

AC | Adriamycin/Cyclophosphamide
AHP | Analytic hierarchy process
AHRQ | Agency for Healthcare Research and Quality
BCIT | Breast Cancer Information Test
BCS | Breast cancer screening
BMT | Bone marrow transplant
CES-D | Center for Epidemiologic Studies Depression Scale
CG | Control group
CHESS | Comprehensive Health Enhancement Support System
CINAHL | Cumulative Index to Nursing & Allied Health Literature^®^
CI | Confidence interval
CMF | Cyclophosphamide/Methotrexate/5-Fluorouracil
CMT | Combined treatment modalities
CPS | Control preference scale
CT | Controlled trial
DA | Cancer-related decision aids
DB | Decision board
DRE | Digital rectal examination
DSFI | Derogatis Sexual Function Inventory
EMBASE | Excerpta Medica Database
GSI | General sheet of information
HNPCC | Hereditary nonpolyposis colorectal cancer
ICP | Interactive Computer Program
IG1 | Intervention group 1
IG2 | Intervention group 2
IG3 | Intervention group 3
IMP | Interactive Multimedia Program
IVDS | Interactive Video Disk System
MAX | Maximum
MCMI | Million Clinical Multiaxial Inventory
MOS-SF36 | Medical Outcome Study -- Short form 36
MU-EPC | McMaster University Evidence-based Practice Center
NA | Not applicable
NC | Not clear
NCI | National Cancer Institute
NR | Not reported
NSCLC | Non-small cell lung cancer
PAIS | Psychosocial Adjustment to Illness Scale
PHE | Periodic health examination
PM | Prophylactic mastectomy
POMS | Profile of Mood States
PSA | Prostate-Specific Antigen test
QPS | Question prompt sheet
RA | Research Assistant
RCT | Randomized controlled trial
RPE | Routine physical examination
RS | Rating scale
RT | Radiotherapy
SAT | Survival advantage threshold
SCCR | Supportive Cancer Care Research
SCLS | Small-cell lung cancer
SD | Standard deviation
SES | Socioeconomic status
SPD | Shared Decisionmaking Program
TEP | Technical Expert Panel
TOO | Task Order Officer
TTO | Time tradeoff
VAS | Visual Analog Scale