# Appendix F: Quality Assessment of Effectiveness and Development Studies

Quality Assessment of Effectiveness RCT Studies with the Validity Component of the Guyatt et al. Scale

| Assignment randomized | Patients entered the trial accounted for at its conclusion | Followup completed | Patients analyzed in the group they were randomized | Patients, health workers, and study personnel blinded to treatment assignment | Groups similar at baseline | Groups treated equally | FINAL SCORE
Volk, 1999 | Y | Y | Y | Y | N | Y | Y | 6
Lerman, 1997 | Y | NR | NR | Y | N | Y | Y | 4
Davison, 1997 | Y | Y | NR | Y | N | Y | Y | 5
Davison, 1999 | Y | Y | NR | Y | N | Y | Y | 5
Hack, 1999 | Y | NR | NR | N | N | NR | Y | 2
Watson, 1998 | Y | NR | NR | N | N | NR | Y | 2
Wolf, 1996 | Y | NR | NR | Y | N | Y | Y | 4
Irwin, 1999 | Y | NR | NR | N | N | NR | Y | 2
Street, 1995 | Y | NR | NR | Y | N | Y | Y | 4
Maslin, 1998 | Y | NR | NR | N | N | NR | Y | 2
North, 1992 | Y | NR | NR | Y | N | NR | Y | 3
Shapira, 2000 | Y | NR | NR | Y | N | NR | Y | 3
Goel, 2001 | Y | Y | Y | Y | N | Y | Y | 6
Wolf, 2000 | Y | NR | NR | Y | N | Y | Y | 4
Pignione, 2000 | Y | Y | Y | Y | Y | Y | Y | 7
Inglehart, 1998 | Y | N | N | N | N | NR | Y | 2

Quality Assessment of the Effectiveness RCT Studies with the Jadad Scale

| Randomized | Appropriate Randomization | Double-blinded | Appropriately Blinded | Dropouts | Points | Qualification
Volk, 1999 | Y | Y | N | N | Y | 3 | Good
Lerman, 1997 | Y | N | N | N | Y | 2 | Poor
Davison, 1997 | Y | Y | N | N | N | 2 | Poor
Davison, 1999 | Y | Y | N | N | N | 2 | Poor
Hack, 1999 | Y | Y | N | N | N | 2 | Poor
Watson, 1998 | Y | N | N | N | Y | 2 | Poor
Wolf, 1996 | Y | N | N | N | N | 1 | Poor
Shapira, 2000 | Y | N | N | N | N | 1 | Poor
Irwin, 1999 | Y | N | N | N | N | 1 | Poor
Street, 1995 | Y | N | N | N | N | 1 | Poor
Maslin, 1998 | Y | N | N | N | N | 1 | Poor
North, 1992 | Y | N | N | N | N | 1 | Poor
Goel, 2001 | Y | Y | N | N | Y | 3 | Good
Wolf, 2000 | Y | N | N | N | N | 1 | Poor
Pignione, 2000 | Y | N | N | Y | Y | 3 | Good
Inglehart, 1998 | Y | N | N | N | N | 1 | Poor

Quality Assessment of Effectiveness RCT Studies with the Downs & Black's Checklist: Reporting

Author (year) | Hypothesis/Aim/Objective | Outcomes measured | Sample characteristics | Intervention | Confounders | Findings | Random variability estimate | Adverse events | Patients lost to followup | Actual probability values
Volk, 1999 | Y | Y | Y | N | Y | Y | N | NA | Y | Y
Lerman, 1997 | Y | Y | Y | N | Y | Y | Y | NA | Y | Y
Davison, 1997 | Y | Y | Y | N | Y | Y | N | NA | N | Y
Davison, 1999 | Y | Y | Y | N | Y | Y | N | NA | N | Y
Hack, 1999 | Y | Y | N | Y | N | N | N | NA | N | N
Watson, 1998 | Y | N | N | N | N | Y | Y | NA | N | Y
Wolf, 1996 | Y | Y | Y | Y | Y | Y | N | NA | N | Y
Irwin, 1999 | Y | Y | Y | Y | N | N | Y | NA | N | Y
Street, 1995 | Y | Y | Y | N | Y | Y | Y | NA | N | Y
Maslin, 1998 | Y | Y | N | N | N | N | N | NA | N | Y
North, 1992 | Y | Y | N | N | N | Y | Y | NA | N | Y
Shapira, 2000 | Y | Y | N | N | Y | Y | Y | NA | N | N
Goel, 2001 | Y | Y | Y | Y | Y | Y | Y | NA | Y | Y
Wolf, 2000 | Y | Y | Y | Y | Y | Y | N | NA | N | Y
Pignione, 2000 | Y | Y | Y | Y | Y | Y | Y | NA | Y | Y
Inglehart, 1998 | y | y | y | Y | N | N | N | NA | N | Y

Quality Assessment of Effectiveness RCT Studies with the Downs & Black's Checklist: External Validity

Author (year) | Included subjects are representative of the entire population | Characteristics of the sample are similar | Staff, places, and facilities are representative of treatment the majority of patients receive
Volk, 1999 | Y | NC | Y
Lerman, 1997 | Y | NC | Y
Davison, 1997 | Y | NC | Y
Davison, 1999 | Y | NC | Y
Hack, 1999 | Y | NC | Y
Watson, 1998 | Y | NC | NC
Wolf, 1996 | Y | NC | Y
Irwin, 1999 | Y | NC | Y
Street, 1995 | Y | NC | NC
Maslin, 1998 | Y | NC | NC
North, 1992 | NC | NC | NC
Shapira, 2000 | Y | NC | Y
Goel, 2001 | Y | Y | Y
Wolf, 2000 | Y | NC | Y
Pignione, 2000 | Y | NC | Y
Inglehart, 1998 | Y | NC | Y

Quality Assessment of Effectiveness RCT Studies with the Downs & Black's Checklist: Internal Validity (bias)

| Blinding in included subjects | Blinding in measuring the outcomes | Results based on "data dredging" | Analysis adjusted for different lengths of followup | Statistical analysis appropriate | Compliance with the intervention | Main outcomes accurate
Volk, 1999 | N | N | N | NA | Y | NC | Y
Lerman, 1997 | N | N | N | NA | Y | NC | NC
Davison, 1997 | N | N | N | NA | Y | Y | Y
Davison, 1999 | N | N | N | NA | Y | N | Y
Hack, 1999 | N | N | Y | NA | Y | N | Y
Watson, 1998 | N | N | NC | NA | Y | Y | NC
Wolf, 1996 | N | N | N | NA | Y | NC | NC
Irwin, 1999 | N | N | Y | NA | Y | NC | NC
Street, 1995 | N | N | N | NA | Y | NC | Y
Maslin, 1998 | N | N | NC | NA | NC | NC | Y
North, 1992 | N | N | N | NA | Y | NC | Y
Shapira, 2000 | N | N | N | NA | Y | NC | NC
Goel, 2001 | N | N | N | NA | Y | NC | Y
Wolf, 2000 | N | N | N | NA | Y | NC | NC
Pignione, 2000 | N | Y | N | NA | Y | NC | NC
Inglehart, 1998 | N | N | N | NA | Y | NC | NC

Quality Assessment of Effectiveness RCT Studies with the Downs & Black's Checklist: Internal Validity (confounding)

Author (year) | Each intervention group selected from the same population | Included subjects in the same period of time | Included subjects randomized | Randomization concealed | Adjustment of confounders | Losses of patients taken into a count | Power
Volk, 1999 | Y | Y | Y | NC | N | Y
Lerman, 1997 | Y | Y | Y | NC | N | NC
Davison, 1997 | Y | Y | Y | NC | N | NC
Davison, 1999 | Y | Y | Y | NC | N | NC
Hack, 1999 | Y | Y | Y | NC | N | NC
Watson, 1998 | Y | Y | Y | NC | N | NC
Wolf, 1996 | Y | Y | Y | NC | Y | NC
Irwin, 1999 | Y | Y | Y | NC | N | NC
Street, 1995 | Y | Y | Y | NC | N | NC
Maslin, 1998 | Y | Y | Y | NC | N | NC
North, 1992 | Y | Y | Y | NC | N | NC
Shapira, 2000 | Y | Y | Y | NC | N | NC
Goel, 2001 | Y | Y | Y | Y | N | Y | (Y)
Wolf, 2000 | Y | Y | Y | NC | N | NC | (Y)
Pignione, 2000 | Y | Y | Y | NC | N | Y | (Y)
Inglehart, 1998 | Y | Y | Y | NC | N | N

Quality Assessment of Effectiveness RCT Studies with the Downs & Black's Checklist: Overall Evaluation

Author (year) | Reporting (max: 9) | External validity (max: 3) | Internal validity: Bias (max: 6) | Internal validity: Confounding (max: 6) | FINAL SCORE (max: 24)
Volk, 1999 | 7 | 2 | 3 | 4 | 16
Lerman, 1997 | 8 | 2 | 2 | 3 | 15
Davison, 1997 | 6 | 2 | 4 | 3 | 15
Davison, 1999 | 6 | 2 | 3 | 3 | 14
Hack, 1999 | 3 | 2 | 3 | 3 | 11
Watson, 1998 | 4 | 1 | 2 | 3 | 10
Wolf, 1996 | 7 | 2 | 2 | 4 | 15
Irwin, 1999 | 6 | 2 | 2 | 3 | 13
Street, 1995 | 7 | 1 | 3 | 3 | 14
Maslin, 1998 | 3 | 1 | 1 | 3 | 8
North, 1992 | 5 | 0 | 1 | 3 | 8
Shapira, 2000 | 5 | 2 | 2 | 3 | 12
Goel, 2001 | 9 | 3 | 3 | 5 | 20
Wolf, 2000 | 7 | 2 | 2 | 3 | 14
Pignione, 2000 | 9 | 2 | 3 | 4 | 18
Inglehart, 1998 | 4 | 2 | 1 | 3 | 10

Quality Assessment of Controlled Trials and Nonconcurrent Cohort Effectiveness Studies with the Downs & Black's Checklist: Reporting

Author (year) | Hypothesis/Aim/Objective | Outcomes measured | Sample characteristics | Intervention | Confounders | Findings | Random variability estimate | Adverse events | Patients lost to followup | Actual probability values
Flood, 1996 ^a^ Study 1 | Y | Y | Y | Y | Y | Y | N | NA | Y | Y
Flood, 1996^a^ Study 2 | Y | Y | N | Y | Y | Y | N | NA | Y | Y
Sepucha, 2000^a^ | Y | Y | N | N | Y | Y | N | NA | N | Y
Whelan, 1995 ^b^ | Y | Y | Y | Y | Y | Y | N | NA | N | Y
Whelan, 1999^b^ | Y | Y | Y | Y | Y | Y | N | NA | N | Y
Molenaar, 2001^a^ | Y | Y | Y | Y | Y | Y | Y | NA | Y | Y

a Controlled trial

b Nonconcurrent cohort

Quality Assessment of Controlled Trials and Nonconcurrent Cohort Effectiveness Studies with the Downs & Black's Checklist: External Validity

Author (year) | Included subjects are representative of the entire population | Characteristics of the sample are similar | Staff, places, and facilities are representative of treatment the majority of patients receive
Flood, 1996^a^ Study 1 | N | NC | N
Flood, 1996^a^ Study 2 | Y | NC | Y
Sepucha, 2000 ^a^ | Y | NC | Y
Whelan, 1995^b^ | Y | NC | Y
Whelan, 1999^b^ | Y | NC | Y
Molenaar, 2001 ^a^ | Y | NC | Y

a Controlled trial

b Nonconcurrent cohort

Quality Assessment of Controlled Trials and Nonconcurrent Cohort Effectiveness Studies with the Downs & Black's Checklist: Internal Validity (bias)

Author (year) | Blinding in included subjects | Blinding in measuring the outcomes | Results based on "data dredging" | Analysis adjusted for different lengths of followup | Statistical analysis appropriate | Compliance with the intervention | Main outcomes accurate
Flood, 1996^a^ Study 1 | N | N | N | NA | Y | N | N
Flood, 1996^a^ Study 2 | N | N | N | NA | Y | N | N
Sepucha, 2000^a^ | N | N | N | NA | Y | N | Y
Whelan, 1995^b^ | N | N | N | NA | Y | N | N
Whelan, 1999 ^b^ | N | N | N | NA | Y | N | Y
Molenaar, 2001^a^ | N | N | N | NA | Y | N | Y

a Controlled trial

b Nonconcurrent cohort

Quality Assessment of Controlled Trials and Nonconcurrent Cohort Effectiveness Studies with the Downs & Black's Checklist: Internal Validity (confounding)

Author (year) | Each intervention group selected from the same population | Included subjects in the same period of time | Included subjects randomized | Randomization concealed | Adjustment of confounders | Loss of patients taken into account | Power
Flood, 1996^a^ Study 1 | Y | Y | NA | NA | N | N
Flood, 1996 ^a^ Study 2 | Y | Y | NA | NA | N | N
Sepucha, 2000 ^a^ | Y | Y | NA | NA | N | N
Whelan, 1995^b^ | Y | N | NA | NA | N | N
Whelan, 1999^b^ | Y | N | NA | NA | N | N
Molenaar, 2001 ^a^ | Y | Y | NA | NA | N | Y

a Controlled trial

b Nonconcurrent cohort

Quality Assessment of Controlled Trials and Nonconcurrent Cohort Effectiveness Studies with the Downs & Black's Checklist: Overall Evaluation

Author (year) | Reporting (max: 9) | External validity (max: 3) | Internal validity: Bias (max: 6) | Internal validity: Confounding (max: 4) | FINAL SCORE (max: 22)
Flood, 1996^a^ Study 1 | 8 | 0 | 2 | 2 | 12
Flood, 1996^a^ Study 2 | 7 | 2 | 2 | 2 | 13
Sepucha, 2000 ^b^ | 5 | 2 | 3 | 2 | 12
Whelan, 1995^b^ | 7 | 2 | 2 | 1 | 12
Whelan, 1999^b^ | 7 | 2 | 3 | 1 | 13
Molenaar, 2001 ^a^ | 9 | 2 | 3 | 3 | 17

a Controlled trial

b Nonconcurrent cohort

Quality Assessment of Case Series Effectiveness Studies with the Downs & Black's Checklist: Reporting

Author (Year) | Hypothesis/Aim/Objective | Outcomes measured | Sample characteristics | Intervention | Confounders | Findings | Random variability estimate | Adverse events | Patients lost to followup | Actual probability values
Adler (1999) | Y | N | Y | N | NA | Y | N | NA | Y | N
Ashcroft (1985) | Y | Y | Y | Y | NA | N | Y | NA | N | N
Brundage (2000) | Y | Y | Y | Y | NA | Y | Y | NA | Y | Y
Cassileth (1989) | Y | Y | Y | Y | NA | Y | N | NA | N | N
Cotton (1991) | Y | Y | Y | Y | NA | Y | N | NA | Y | Y
Cotton (1995) | Y | N | N | N | NA | Y | N | NA | Y | N
Gramlich (1998) | Y | N | N | Y | NA | N | N | NA | N | N
Levine (1992) | Y | Y | N | Y | NA | Y | N | NA | Y | N
Onel (1998) | Y | Y | N | Y | NA | Y | N | NA | Y | N
Protiere (2000) | Y | Y | Y | Y | NA | Y | Y | NA | Y | N
Sandison (1996) | Y | Y | Y | Y | NA | Y | N | NA | Y | N
Stalmeier (1999) | Y | Y | Y | Y | NA | Y | Y | NA | Y | Y
Wilson (1988) | Y | Y | Y | N | NA | Y | N | NA | Y | N
Wolberg (1987) | Y | Y | Y | N | NA | Y | Y | NA | NC | N
Klass (1992) | Y | Y | Y | Y | NA | Y | N | NA | N | Y
Okamoto (1999) | N | Y | Y | Y | NA | Y | N | NA | N | N
Fiset (2000) | Y | Y | Y | Y | NA | Y | Y | NA | Y | Y

Quality Assessment of Case Series Effectiveness Studies with the Downs & Black's Checklist: External Validity

Author (Year) | Included subjects are representative of the entire population | Characteristics of the sample are similar | Staff, places, and facilities are representative of treatment the majority of patients receive
Adler (1999) | Y | NC | Y
Ashcroft (1985) | Y | NC | Y
Brundage (2000) | NC | NC | Y
Cassileth (1989) | Y | Y | Y
Cotton (1991) | Y | Y | Y
Cotton (1995) | NC | NC | Y
Gramlich (1998) | NC | NC | Y
Levine (1992) | NC | NC | Y
Onel (1998) | NC | NC | NC
Protiere (2000) | Y | Y | Y
Sandison (1996) | Y | NC | Y
Stalmeier (1999) | NC | NC | Y
Wilson (1988) | Y | Y | Y
Wolberg (1987) | Y | NC | Y
Klass (1992) | NC | NC | NC
Okamoto (1999) | NC | NC | NC
Fiset (2000) | NC | NC | Y

Quality Assessment of Case Series Effectiveness Studies with the Downs & Black's Checklist: Internal Validity (bias)

Author (Year) | Blinding in included subjects | Blinding in measuring the outcomes | Results based on "data dredging" | Analysis adjusted for different lengths of followup | Statistical analysis appropriate | Compliance with the intervention | Main outcomes accurate
Adler (1999) | N | N | N | NA | Y | N | NC
Ashcroft (1985) | N | N | N | NA | Y | N | Y
Brundage (2000) | N | N | N | NA | Y | N | NC
Cassileth (1989) | N | N | N | NA | Y | N | NC
Cotton (1991) | N | N | N | NA | Y | N | NC
Cotton (1995) | N | N | N | NA | Y | N | NC
Gramlich (1998) | N | N | N | NA | Y | N | NC
Levine (1992) | N | N | N | NA | Y | N | NC
Onel (1998) | N | N | N | NA | Y | N | NC
Protiere (2000) | N | N | N | NA | Y | N | NC
Sandison (1996) | N | N | N | NA | Y | N | NC
Stalmeier (1999) | N | N | N | NA | Y | N | NC
Wilson (1988) | N | N | N | NA | Y | N | NC
Wolberg (1987) | N | N | N | NA | Y | N | Y
Klass (1992) | N | N | N | NA | Y | N | NC
Okamoto (1999) | N | N | N | NA | Y | N | NC
Fiset (2000) | N | N | N | NA | Y | N | Y

Quality Assessment of Case Series Effectiveness Studies with the Downs & Black's Checklist: Internal Validity (confounding)

Author (Year) | Each intervention group selected from the same population | Included subjects in the same period of time | Included subjects randomized | Randomization concealed | Adjustment of confounders | Loss of patients taken into account | Power
Adler (1999) | NA | Y | NA | NA | NA | N | N/A
Ashcroft (1985) | NA | N | NA | NA | NA | NC | N/A
Brundage (2000) | NA | Y | NA | NA | NA | Y | N/A
Cassileth (1989) | NA | Y | NA | NA | NA | N | N/A
Cotton (1991) | NA | Y | NA | NA | NA | Y | N/A
Cotton (1995) | NA | Y | NA | NA | NA | Y | N/A
Gramlich (1998) | NA | Y | NA | NA | NA | N | N/A
Levine (1992) | NA | Y | NA | NA | NA | Y | N/A
Onel (1998) | NA | Y | NA | NA | NA | Y | N/A
Protiere (2000) | NA | Y | NA | NA | NA | Y | N/A
Sandison (1996) | NA | Y | NA | NA | NA | Y | N/A
Stalmeier (1999) | NA | Y | NA | NA | NA | NC | N/A
Wilson (1988) | NA | Y | NA | NA | NA | N | N/A
Wolberg (1987) | NA | N | NA | NA | NA | NC | N/A
Klass (1992) | NA | Y | NA | NA | NA | NC | N/A
Okamoto (1999) | NA | Y | NA | NA | NA | NC | N/A
Fiset (2000) | NA | Y | NA | NA | NA | Y | N/A

Quality Assessment of Case Series Studies with the Downs & Black's Checklist: Overall Evaluation

Author (Year) | Reporting (max: 8) | External validity (max: 3) | Internal validity: Bias (max: 6) | Internal validity: Confounding (max: 2) | FINAL SCORE (max: 19)
Adler (1999) | 4 | 2 | 2 | 1 | 9
Ashcroft (1985) | 5 | 2 | 3 | 0 | 10
Brundage (2000) | 8 | 1 | 3 | 2 | 14
Cassileth (1989) | 5 | 3 | 2 | 1 | 11
Cotton (1991) | 7 | 3 | 2 | 2 | 14
Cotton (1995) | 3 | 1 | 2 | 2 | 8
Gramlich (1998) | 2 | 1 | 2 | 1 | 6
Levine (1992) | 5 | 1 | 2 | 2 | 10
Onel (1998) | 5 | 0 | 2 | 2 | 9
Protiere (2000) | 7 | 3 | 2 | 2 | 14
Sandison (1996) | 6 | 2 | 2 | 2 | 12
Stalmeier (1999) | 8 | 1 | 2 | 2 | 13
Wilson (1988) | 5 | 3 | 2 | 1 | 11
Wolberg (1987) | 5 | 2 | 3 | 0 | 10
Klass (1992) | 6 | 0 | 2 | 1 | 9
Okamoto (1999) | 4 | 0 | 2 | 1 | 7
Fiset (2000) | 8 | 1 | 3 | 2 | 14

Quality Assessment of the Development Studies with the Downs & Black's Checklist: Reporting

Author (year) | Hypothesis/Aim/Objective | Outcomes measured | Sample characteristics | Intervention | Confounders | Findings | Random variability estimate | Adverse events | Patients lost to followup | Actual probability values
Shapira, (1997) ID# 123 | Y | Y | N | Y | NA | Y | N | NA | N | NA
Gustafson, (1993) ID# 1196Study 1 | Y | N | Y | Y | NA | N | N | NA | N | N
Gustafson, (1993) ID# 7538 Study 2 | Y | N | Y | Y | NA | N | N | NA | N | N
McTavish, (1995) ID# 5045 | Y | N | N | Y | NA | N | N | NA | N | N
Rolnock, (1999) ID# 386 | Y | N | N | N | N | N | N | NA | N | N
Dolan, (1995) ID# 4933 | Y | Y | N | Y | NA | Y | N | NA | Y | Y
Chapman, (1995) ID# 116 | Y | Y | N | Y | Y | Y | N | NA | N | Y
Jenkinson, (1998) ID# 814 | Y | Y | N | Y | NA | Y | N | NA | N | NA
Brundage, (1997) ID# 149 | Y | Y | Y | Y | NA | Y | Y | NA | Y | Y
Levine, (1992) ID# 7117 | Y | Y | N | Y | NA | Y | N | NA | N | Y
Whelan, (1995) ID# 7535 | Y | Y | N | Y | NA | N | N | NA | N | NA
Sebban, (1995) ID# 117 | Y | Y | N | Y | NA | Y | Y | NA | Y | Y
Elit, (1996) ID# 119 Study 1 | Y | N | N | Y | NA | N | N | NA | Y | Y
Elit, (1996) ID# 7539 Study 2 | Y | N | Y | Y | NA | N | N | NA | Y | N
Whelan, (1999) ID# 7536 | Y | Y | N | Y | NA | Y | N | NA | N | Y
Lawrence, (2000) ID# 5012 | Y | Y | N | Y | NA | Y | Y | NA | N | Y
Carrere, (2000) ID# 5013 | Y | Y | Y | Y | NA | Y | Y | NA | N | Y
Sawka, (1998) ID# 199 Study 1 | Y | Y | Y | Y | NA | Y | Y | NA | N | NA
Sawka, (1998) ID# 7537 Study 2 | Y | Y | Y | Y | NA | Y | Y | NA | N | NA
Unic, (1998) ID# 872 | Y | Y | Y | Y | NA | Y | Y | NA | Y | Y
Ravdin, (2001) ID# 7852 | Y | Y | N | Y | NA | N | N | NA | N | N
Fisset, (2000) ID# 7873 | Y | Y | N | Y | NA | Y | N | NA | N | N

Quality Assessment of the Development Studies with the Downs & Black's Checklist: External Validity

Author (Year) | Included subjects are representative of the entire population | Characteristics of the sample are similar | Staff, places, and facilities are representative of treatment the majority of patients receive
Shapira, (1997) ID# 123 | NC | NC | N
Gustafson, (1993) ID# 1196 Study 1 | NC | NC | NC
Gustafson, (1993) ID# 7538Study 2 | NC | NC | NC
McTavish, (1995) ID# 5045 | NC | NC | NC
Rolnock, (1999) ID# 386 | NC | NC | NC
Dolan, (1995) ID# 4933 | NC | NC | NC
Chapman, (1995) ID# 116 | NC | NC | N
Jenkinson, (1998) ID# 814 | NC | NC | N
Brundage, (1997) ID# 149 | NC | NC | Y
Levine, (1992) ID# 7117 | NC | NC | N
Whelan, (1995) ID# 7535 | NC | NC | NC
Sebban, (1995) ID# 117 | NC | NC | N
Elit, (1996) ID# 119 Study 1 | NC | NC | N
Elit, (1996) ID# 7539 Study 2 | NC | NC | Y
Whelan, (1999) ID# 7536 | NC | NC | N
Lawrence, (2000) ID# 5012 | NC | NC | NC
Carrere, (2000) ID# 5013 | NC | NC | NC
Sawka, (1998) ID# 199 Study 1 | NC | NC | NC
Sawka, (1998) ID# 7537 Study 2 | NC | NC | NC
Unic, (1998) ID# 872 | NC | NC | Y
Ravdin, (2001) ID# 7852 | NC | NC | NC
Fisset, (2000) ID# 7873 | NC | NC | NC

Quality Assessment of Development Studies with the Downs & Black's Checklist: Internal Validity (bias)

Author (year) | Blinding in included subjects | Blinding in measuring the outcomes | Results based on "data dredging" | Analysis adjusted for different lengths of followup | Statistical analysis appropriate | Compliance with the intervention | Main outcomes accurate
Shapira, (1997) ID# 123 | N | N | N | NA | Y | N | N
Gustafson, (1993) ID# 1196 Study 1 | N | N | N | N | Y | Y | NC
Gustafson, (1993) ID# 7538 Study 2 | N | N | N | N | Y | Y | NC
McTavish, (1995) ID# 5045 | N | N | N | N | Y | Y | NC
Rolnick, (1999) ID# 386 | N | N | N | Y | Y | Y | NC
Dolan, (1995) ID# 4933 | N | N | N | NA | Y | Y | NC
Chapman, (1995) ID# 116 | N | N | N | NA | Y | N | NC
Jenkinson, (1998) ID# 814 | N | N | N | NA | Y | N | NC
Brundage, (1997) ID# 149 | N | N | N | NA | Y | Y | Y
Levine, (1992) ID# 7117 | N | N | N | NA | Y | N | Y
Whelan, (1995) ID# 7535 | N | N | N | NA | NC | N | N
Sebban, (1995) ID# 117 | N | N | N | NA | Y | N | N
Elit, (1996) ID# 119 Study 1 | N | N | N | NA | Y | Y | N
Elit, (1996) ID# 7539 Study 2 | N | N | N | NA | NC | Y | N
Whelan, (1999) ID# 7536 | N | N | N | NA | Y | N | Y
Lawrence, (2000) ID# 5012 | N | N | N | NA | Y | N | Y
Carrere, (2000) ID# 5013 | N | N | N | NA | Y | N | Y
Sawka, (1998) ID# 199 Study 1 | N | N | N | NA | Y | N | Y
Sawka, (1998) ID# 7537 Study 2 | N | N | N | NA | Y | N | Y
Unic, (1998) ID# 872 | N | N | N | NA | Y | Y | Y
Ravdin, (2001) ID# 7852 | N | N | N | NA | NC | N | NC
Fisset, (2000) ID# 7873 | N | N | N | NA | NC | N | NC

Quality Assessment of the Development Studies with the Downs & Black's Checklist: Internal Validity (confounding)

Author (year) | Each intervention group selected from the same population | Included subjects in the same period of time | Included subjects randomized | Randomization concealed | Adjustment of confounders | Loss of patients taken into account | Power
Shapira, (1997) ID# 123 | NA | Y | NA | NA | NA | N
Gustafson, (1993) ID# 1196 Study 1 | NA | Y | NA | NA | NA | N
Gustafson, (1993) ID# 7538Study 2 | NA | Y | NA | NA | NA | N
McTavish, (1995) ID# 5045 | NA | Y | NA | NA | NA | N
Rolnick, (1999) ID# 386 | NC | Y | Y | NC | N | N
Dolan, (1995) ID# 4933 | NA | Y | NA | NA | NA | Y
Chapman, (1995) ID# 116 | Y | Y | NA | NA | Y | N
Jenkinson, (1998) ID# 814 | NA | Y | NA | NA | NA | N
Brundage, (1997) ID# 149 | NA | Y | NA | NA | NA | Y
Levine, (1992) ID# 7117 | NA | Y | NA | NA | NA | N
Whelan, (1995) ID# 7535 | NA | Y | NA | NA | NA | N
Sebban, (1995) ID# 117 | NA | Y | Y | N | N | Y
Elit, (1996) ID# 119 Study 1 | NA | Y | NA | NA | NA | Y
Elit, (1996) ID# 7539 Study 2 | NA | Y | NA | NA | NA | Y
Whelan, (1999) ID# 7536 | NA | Y | NA | NA | NA | N
Lawrence, (2000) ID# 5012 | NA | Y | NA | NA | NA | N
Carrere, (2000) ID# 5013 | NA | Y | NA | NA | NA | N
Sawka, (1998) ID# 199 Study 1 | NA | Y | NA | NA | NA | N
Sawka, (1998) ID# 7537 Study 2 | NA | Y | NA | NA | NA | N
Unic, (1998) ID# 872 | NA | Y | NA | NA | NA | Y
Ravdin, (2001) ID# 7852 | NC | Y | NA | NA | NA | N
Fisset, (2000) ID# 7873 | NC | Y | NA | NA | NA | N

Quality Assessment of Development Studies with the Downs & Black's Checklist: Overall Evaluation

Author (Year) | Reporting | External validity | Internal validity: Bias | Internal validity: Confounding | FINAL SCORE
Shapira, (1997) ID# 123 | 4/7 (57.1%) | 0/3 (0%) | 2/6 (33.1%) | 1/2 (50%) | 7/18 (38.8%)
Gustafson, (1993) ID# 1196 Study 1 | 3/8 (37.5%) | 0/3 (0%) | 3/7 (42.8%) | 1/2 (50%) | 7/20 (35%)
Gustafson, (1993) ID# 7538 Study 2 | 3/8 (37.5%) | 0/3 (0%) | 3/7 (42.8%) | 1/2 (50%) | 7/20 (35%)
McTavish, (1995) ID# 5045 | 2/8 (25%) | 0/3 (0%) | 3/7 (42.8%) | 1/2 (50%) | 6/20 (30%)
Rolnick, (1999) ID# 386 | 1/9 (11.1%) | 0/3 (0%) | 4/7 (57.1%) | 2/5 (40%) | 7/24 (29.1%)
Dolan, (1995) ID# 4933 | 5/8 (62.5%) | 0/3 (0%) | 3/6 (50%) | 2/2 (100%) | 10/19 (52.6%)
Chapman, (1995) ID# 116 | 6/9 (66.6%) | 0/3 (0%) | 2/6 (33.1%) | 3/4 (75%) | 11/22 (50%)
Jenkinson, (1998) ID# 814 | 4/7 (57.1%) | 0/3 (0%) | 2/6 (33.1%) | 1/2 (50%) | 7/18 (38.8%)
Brundage, (1997) ID# 149 | 8/8 (100%) | 1/3 (33.3%) | 4/6 (66.6%) | 2/2 (100%) | 15/19 (78.9%)
Levine, (1992) ID# 7117 | 5/8 (62.5%) | 0/3 (0%) | 3/6 (50%) | 1/2 (50%) | 9/19 (47.3%)
Whelan, (1995) ID# 7535 | 3/7 (42.8%) | 0/3 (0%) | 1/6 (16.6%) | 1/2 (50%) | 5/18 (27.7%)
Sebban, (1995) ID# 117 | 7/8 (87.5%) | 0/3 (0%) | 2/6 (33.1%) | 3/5 (60%) | 12/22 (54.5%)
Elit, (1996) ID# 119 Study 1 | 4/8 (50%) | 0/3 (0%) | 3/6 (50%) | 2/2 (100%) | 9/19 (47.3%)
Elit, (1996) ID# 7539 Study 2 | 4/8 (50%) | 1/3 (33.3%) | 2/6 (33.1%) | 1/2 (50%) | 10/19 (52.6%)
Whelan, (1999) ID# 7536 | 5/8 (62.5%) | 0/3 (0%) | 3/6 (50%) | 1/2 (50%) | 9/19 (47.3%)
Lawrence, (2000) ID# 5012 | 6/8 (75%) | 0/3 (0%) | 3/6 (50%) | 1/2 (50%) | 10/19 (52.6%)
Carrere, (2000) ID# 5013 | 7/8 (87.5%) | 0/3 (0%) | 3/6 (50%) | 1/2 (50%) | 11/19 (57.8%)
Sawka, (1998) ID# 199 Study 1 | 6/7 (85.7%) | 0/3 (0%) | 3/6 (50%) | 1/2 (50%) | 10/18 (55.5%)
Sawka, (1998) ID# 7537 Study 2 | 6/7 (85.7%) | 0/3 (0%) | 3/6 (50%) | 1/2 (50%) | 10/18 (55.5%)
Unic, 1998 | 8/8 (100%) | 1/3 (33.3%) | 4/6 (66.6%) | 2/2 (100%) | 15/19 (78.9%)
Ravdin, (2001) ID# 7852 | 3/8 (37.5%) | 0/3 (0%) | 1/6 (16.6%) | 1/3 (33.3%) | 5/20 (25%)
Fisset, (2000) ID# 7873 | 4/8 (50%) | 0/3 (0%) | 1/6 (16.6%) | 1/2 (50%) | 6/19 (31.5%)