# Appendix E: Peer Reviewers for the Cancer Related Decision Aid Systematic Review

## Criticism Editor

- Patricia Huston, MD, MPH. Scientific Communications International, Inc. Ottawa, Ontario, Canada

## Reviewers

- Angela Coulter, PhD. Chief Executive, Picker Institute Europe, King's Mead House Oxpens Road, United Kingdom
- Hanneke de Haes. Department of Medical Psychology, Academic Medical Center, Amsterdam, The Netherlands
- Baruch Fischhoff. Department of Social and Decision Sciences, Carnegie Mellon University, Pittsburgh, Pennsylvania
- Neil A. Hagen MD, FRCPC. Tom Baker Cancer Center, Calgary, Canada
- Val Lawrence, MD. Ambulatory Care, Audie Murphy VA Hospital, San Antonio, Texas
- Jeffrey C. Lerner, PhD. Vice President for Strategic Planning Center Director, AHRQ Evidence-based Practice Center ECRI, a nonprofit agency, Plymouth Meeting, Pittsburgh, Pennsylvania
- Arabella Melville, PhD. Bryn Derwen, Cymru/Wales, United Kingdom
- Sjaak Molenaar, MA. Department of Medical Psychology, Academic Medical Center, Amsterdam, The Netherlands
- Nora Moumjid, GRESAC, Centre L?on B?rard, Lyon, France
- Annette O'Connor RN, PhD. Professor, University of Ottawa School of Nursing and Faculty of Medicine, Acting Director, Clinical Epidemiology Unit Loeb Health Research Institute at the Ottawa Hospital, Ottawa, Ontario, Canada
- Debra Roter, PhD. Professor and Associate Chair, Department of Health Policy and Management, Johns Hopkins School of Public Health, Baltimore, Maryland
- Trevor A Sheldon, Head of Department of Health Studies, University of York Innovation Center, York, United Kingdom
- Amanda J. Sowden, Associate Director, NHS Center for Reviews and Dissemination, University of York, York, United Kingdom
- Hazel Thornton, Rowhedge, Colchester, United Kingdom
- Steven Woloshin, MD, MS, and Lisa Schwartz, VA Outcomes Group, VA Medical Center White River Junction, Vermont