# Appendix C: Algorithm and Descriptive Guidelines for Initial Screening of Title and Abstract Citations

[image]

## Guidelines for Citation Retrieval

DEFINITION OF A DECISION AID
An intervention designed primarily to help patients or patients and clinicians together, with making cancer-related health care decisions when options are available for prevention, screening, and treatment. At a minimum, it should target some component of decision-making (e.g., information exchange, involvement in the decision process). The following interventions will be excluded:; - Interventions designed to support informed consent (they do not involve decision making).; - Interventions designed for general education (they may not offer options, may advocate a particular action or may not ask for any decision to be made).

### Primary Study

- It must be a report of an experiment or investigation of an intervention, or validation of an outcome tool related to an explicit decision-making process.
- It must not be a position paper or any type of review.

### Decision Aid

Tools/Interventions to assist decision-making must have the following characteristics:

- Must explicitly present more than one option (of which one can be take no action or maintain status quo).
- Must not advocate/advise a particular course of action or present information in a manner biased towards one or another option.
- Must target some phase of the decision making process (i.e. structuring the patient-physician encounter, information elicitation or transfer, deliberation, etc.) and occur prior to the actual decision.
- Interventions designed to counsel patients to communicate with clinicians will be treated as uncertain and will be retrieved.
- Interventions designed to counsel clinicians only will be excluded.
- Must be cancer-related, which means the intervention or decision must primarily target the prevention, detection, treatment or management of cancer, unless the article is regarding the development or validation of a decision aid.

### Outcome Measure

a. Outcome measures must be instruments that would be used to assess decision-making or to evaluate decision-making interventions. For example, a study validating the "Decisional Conflict Scale" would be retrieved because this scale is used to evaluate some decision aid interventions.
b. Such studies may not be specifically cancer related.

### Background Articles

We will retrieve any article for background that meets the following criteria:

1) Any review dated 1990 or more current OR
2) Any seminal paper dated 1990 or more current
AND
If and only if it is clearly cancer related
AND
If and only if it focuses on one of the following topics:; a. decision aids/interventions; b. patient or patient and physician decision making; c. information transfer (patient ←→ clinician); d. clinician-patient communication; e. clinician-patient relations; f. decision-related needs of patient populations; g. definitions of decision aid interventions; OR
3) Any literature dated 1995 or more current that investigates or describes the decision-related needs of patient populations, including special patient populations (e.g., children, ethnic minorities, low SES groups, clinical trial participants). We will NOT retrieve general interviews/surveys investigating patients' perceptions or experiences unless they are explicitly related to a decision or the creation of a tool. ALSO, any abstracts or collection thereof from presentations given at cancer meetings or from any meetings relevant to cancer-related decision aids (where relevance can not be established from a title or abstract) will be retrieved if dated 1998 or more current.