# Appendix B: Search Strategy (Medline)^a^

1 | exp decision making/
2 | decision support techniques/
3 | patient education/
4 | patient participation/
5 | exp professional-patient relations/
6 | 1 or 2 or 3 or 4 or 5
7 | exp neoplasms/
8 | 6 and 7
9 | limit 8 to human
10 | limit 9 to yr=1977-2000
11 | exp biopsy/
12 | exp sunscreening agents/
13 | exp mammography/
14 | exp tamoxifen/
15 | tamoxifen.tw.
16 | exp vaginal smears/
17 | brca1.tw.
18 | brca2.tw.
19 | exp occult blood/
20 | exp hormone replacement therapy/
21 | exp prostate-specific antigen/
22 | 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23 | 22 and 6
24 | 23 not 8
25 | limit 24 to human
26 | limit 25 to yr=1977-2000
27 | 10 or 26
28 | exp colonoscopy/
29 | exp bronchoscopy/
30 | exp sigmoidoscopy/
31 | exp colposcopy/
32 | exp conization/
33 | 28 or 29 or 30 or 31 or 32
33 | 33 and 6
34 | 34 not 8
35 | limit 35 to human
36 | limit 36 to yr=1977-2000
37 | 27 or 37
38 | 38 not letter.pt.
40 | 39 not editorial.pt.
41 | 40 not news.pt.

a This search strategy has been slightly modified for the databases different from Medline, according to different indexing of the articles.