# Appendix A: McMaster Research Team

Timothy J. Whelan, BM, BCh, MSc (Task Order Leader): Dr. Whelan is an Associate Professor, Department of Medicine, and Associate Member, Department of Clinical Epidemiology & Biostatistics (CE&B), at McMaster University. He is currently Director of the Supportive Cancer Care Research Unit (SCCR) at McMaster University, which is a health system-linked research unit focusing on supportive care needs of cancer patients. He is a practicing radiation oncologist at the Hamilton Regional Cancer Centre and is co-Chair of the Breast Disease Site Group for the National Cancer Institute of Canada, Clinical Trials Group. Dr. Whelan obtained his medical degrees at University of Oxford Medical School and was a recipient of the Rhodes Scholarship and Terry Fox Fellowship for Physician Scientists. Since obtaining his Master's in CE&B, he has been actively involved in research focusing on health services research and clinical trials related to the management of breast cancer. One of his main areas of interest is information exchange and physician-patient decisionmaking. He is currently principal investigator on several projects evaluating the use of treatment decision aids for women with breast cancer.

Mary Ann O'Brien, MSc, BHSc (PT), (Task Order Coordinator): Ms. O'Brien is an Assistant Clinical Professor in the School of Rehabilitation Sciences at McMaster University. She was the Task Order Coordinator for the Management of Chronic Central Neuropathic Pain Following Traumatic Spinal Cord Injury Task Order. Ms. O'Brien has graduate training in the science of conducting systematic reviews and is a licensed physical therapist with extensive clinical experience in rehabilitation. She is a member of the Board of Examiners for the Canadian Physical Therapy Examination. She is also a member of the Cochrane Collaboration Effective Professional Practice and Organization of Care Review Group. Ms. O'Brien has extensive experience in coordinating the production of systematic reviews. Recently, she coordinated the production of 13 systematic reviews of public health interventions for the Ontario government. In addition, she is the author or co-author of 10 systematic reviews in the areas of health professional behavior change, public health, and rehabilitation. She is responsible for the overall coordination of the Task Order, supervision of other research staff, and drafting of the Evidence Report and associated manuscripts.

Cathy Charles, PhD: Dr. Charles is an Associate Professor in the Department of Clinical Epidemiology & Biostatistics; a Member of the Centre for Health Economics & Policy Analysis; and an Associate Member, Department of Sociology at McMaster University. She is also an Investigator in the Supportive Cancer Care Research Unit, which is cosponsored by the Hamilton Regional Cancer Centre and McMaster University. She is an Honorary Research Associate in the Department of Behavioural Sciences, University of Sydney, Sydney, Australia. She received a B.A. and M.A. in Sociology at the University of Toronto and an M.Phil. and Ph.D. in Sociomedical Sciences from Columbia University. Her research interests include: public and patient participation in health care decisionmaking, the use of research information to improve the organization and delivery of health care, the health professions and public policy, and resident classification systems for long-term care. She is currently undertaking a collaborative study, funded by the Canadian Breast Cancer Research Initiative, on shared treatment decisionmaking among women with early stage breast cancer and among physicians who specialize in this area. Dr. Charles has been a health policy consultant to several provincial governments as well as to the federal government.

Amiram Gafni, DSc: Dr. Gafni is a Professor in the Department of CE&B, a member of the Centre for Health Economics and Policy Analysis and the Supportive Cancer Care Research Unit. His research interests are in the areas of economic evaluation of health care programs (both methods development and empirical applications), modeling of consumers' and providers' health care behavior, policy analysis, and risk and decision analysis in health. Dr. Gafni is heavily involved in research in the areas of decision aids and the physician-patient encounter. He is one of the developers of the decision board (DB) approach (i.e., a method for helping patients to reveal their preferences regarding treatment). The method was first applied for the case of adjuvant chemotherapy for early stage breast cancer and since then has been used in several cancer applications. In addition, Dr. Gafni is involved in both conceptual and empirical research regarding the physician-patient encounter. This research has resulted in the first conceptual definition of the shared treatment decisionmaking model as well as a comprehensive conceptual framework to describe all potential types of encounters and their components. He has also published extensively on these topics.

Mark Levine, MD: Dr. Levine is the Director of the new Clinical Research Institute recently established by the Faculty of Health Sciences, McMaster University. He is a Professor of Medicine and Clinical Epidemiology & Biostatistics at McMaster University. He served as CEO of the Cancer Care Ontario Hamilton Regional Cancer Centre between 1992 and 1999. Since 1982, Dr. Levine has been on staff at the Hamilton Regional Cancer Centre and a member of the Faculty of Health Sciences at McMaster University. He received an MD degree from McGill University followed by a Master's degree in health research methods from McMaster University. Dr. Levine completed his residency in internal medicine at McMaster University and his hematology and oncology training at Duke University Medical Centre. He has been an investigator in breast cancer clinical trials and venous thromboembolism clinical trials and has conducted research in quality-of-life issues and treatment decisions in breast cancer. Dr. Levine is on the Steering Committee of the Ontario Practice Guidelines Initiative and chairs the Steering Committee on Clinical Practice Guidelines for Breast Cancer in Canada. He received the 1999 O. Harold Warwick Prize from the National Cancer Institute of Canada in recognition of research excellence in cancer control within the past decade. He was recently appointed as the first recipient of the Buffett Taylor Chair in Breast Cancer Research at McMaster University.

Andy Willan, PhD: Dr. Willan is a statistician and clinical trial methodologist with a wide variety of interests including oncology, ophthalmology, urology, obstetrics, antiemetics, and cardiology. He has held the posts of head of Biometry of the Clinical Trials Programme at the National Cancer Institute of Canada and Head of Clinical Trials and Epidemiology for the Cancer Programme at Sunnybrook Medical Centre. His contributions to statistical methodology include publications in the areas of health economics, management trials, crossover trials, non-nested regression analysis, bivariate response models and meta-analysis. Dr. Willan currently serves on the steering committee for a number of large multicentre clinical trials in obstetrics and is on the data monitoring and safety committee for the National Cancer Institute of Canada Clinical Trials Programme. He also serves on review panels for the National Cancer Institute of Canada and the Medical Research Council of Canada. Dr. Willan plays an active role in the graduate program in Health Research Methodology in the Department of Clinical Epidemiology and Biostatistics.

Melissa Brouwers, PhD: Dr. Brouwers is an Assistant Professor in the Department of Clinical Epidemiology & Biostatistics and an Assistant Director of the Cancer Care Ontario Program in Evidence-based Care, for which she manages a provincially funded program dedicated to bridging the gap between quality cancer care research and current clinical care options with the most up-to-date evidence-based information for patients, families, and health care providers. Her responsibilities include creating and implementing strategic and operational plans, developing a research agenda, coordinating projects, facilitating and maintaining relationships with Program partners, supervising and training Program staff, and administering the Program budget. She is involved with the Cancer Care Ontario Program in Evidence-Based Care Practice Guidelines Coordinating Committee, Disease Site Chairs Committee, and the Methods Work Group. Dr. Brouwers earned a Ph.D. from the University of Western Ontario, London, Ontario, Department of Psychology. Her areas of interest include: program design and evaluation, attitudes and behavior change, research design and measurement, personality styles and cross cultural variations, stress, coping and health, health psychology, social psychology, and abnormal psychology. She has coordinated two federally funded initiatives dedicated to developing evidence-based information tools and to disseminating health care information to various health care consumers, including clients/patients, health care providers, researchers, and policymakers/government.

Anne Snider, MEd, (EPC Coordinator): Ms. Snider, as EPC Coordinator, is responsible for overall coordination of the Task Order. Her responsibilities include staffing; monthly reporting to the AHRQ Contracts Office; financial management; liaison internally at McMaster University with administrative and financial bodies; liaison with external bodies, including technical experts and the AHRQ; and review and editing of the Evidence Report.

Miguel Villasis-Keever, MD, MSc: Dr. Villasis-Keever is a Pediatrician and Clinical Researcher at the Pediatric Hospital of the Mexican Social Security Institute. He received an MD degree from the University of San Luis Potosi, Mexico, followed by a Master's degree in Medical Sciences from the Universidad Nacional Autonoma de Mexico. In June 2000, he started a Fellowship Research year on Systematic Reviews at McMaster University. He has been involved in all the stages of this systematic review.

Paula Robinson, MD, MSc: Dr. Robinson obtained both her medical degree and her Masters of Science (Biology) degree from McMaster University. She has been involved in the screening process, data extraction, and writing of the evidence report.

Aimee Skye, BA, PhD Student in Cognitive Psychology: Ms. Skye graduated from McMaster University in 2000 with a Bachelor's degree in Honors Psychology. She is currently pursuing her Ph.D. in Cognitive Psychology at McMaster University. Aimee's primary area of research concerns the psychology of judgment, reasoning, and decisionmaking, with particular focus on the domains of health and medicine.

Christopher Sigouin, Biostatistician, PhD student: Mr. Sigouin is a Ph.D. student, Health Research Methodology Programme, Faculty of Health Science, McMaster University. He is responsible for database design, data integrity, and data analysis.

Mary Gauld, BA: Ms. Gauld is a Research Coordinator in the Department of Clinical Epidemiology and Biostatistics, McMaster University. She has participated in numerous systematic reviews, including the AHRQ Task Order on the Treatment of Attention-Deficit/ Hyperactivity Disorder.

Fulvia Baldassarre, MSc, BScN: Ms. Baldassarre completed a Bachelor in Nursing at the University of Chieti (Italy) and graduated in June 2000 from McMaster University with a Masters of Science (Nursing) degree. She is a Research Assistant/Coordinator in the Department of Clinical Epidemiology and Biostatistics, McMaster University.

## Technical Expert Panel

Laura Siminoff, PhD: Dr. Laura Siminoff is an Associate Professor of Internal Medicine and Health Care Research at the Case Western Reserve University School of Medicine and Associate Director of the Behavioral Cancer Control Program at the Ireland Cancer Center, University Hospitals, Cleveland, Ohio. She is also a member of the National Breast Cancer Coalition Action Plan. Dr. Siminoff received her training in public health at the Johns Hopkins University where she completed her Ph.D. She is also a trained anthropologist. Dr. Siminoff has written widely about how breast cancer patients make treatment decisions about adjuvant therapy. She is interested in how to promote informed treatment decisionmaking and patient participation in treatment decisions. Dr. Siminoff has conducted studies examining the treatment decisionmaking process of breast cancer patients and oncologists, how physicians recruit breast cancer patients into clinical trials, and is currently conducting an NCI-funded clinical trial of a decision aid designed to promote joint decisionmaking about adjuvant therapy between stage I-III breast cancer patients and their medical oncologists.

Vikki Entwistle, PhD: Dr. Entwistle is a senior research fellow at the Health Services Research Unit, University of Aberdeen, Scotland. Her research interests include: the development and assessment of consumer health information materials, the measurement and evaluation of participation in clinical decisionmaking, consumer involvement in health care, and media coverage of health and medical issues. Vikki serves on the editorial teams of Health Expectations, an international journal of public participation in health care, and of the Cochrane group on Consumers and Communication.

Carol Sawka, MD: Dr. Sawka is a medical oncologist, CEO of the Toronto-Sunnybrook Regional Cancer Centre and the Cancer Care Ontario Central East Region, and an Associate Professor, Departments of Medicine and Public Health Science at the University of Toronto. She is an Adjunct Senior Scientist at the Institute for Clinical Evaluative Sciences in Ontario, where she has been conducting breast cancer-related health services research. Her research is aimed at improving breast cancer quality of care and outcomes through information provision, shared decisionmaking, and the use of practice guidelines to promote consistent patterns of care. She developed and evaluated a patient decision aid for breast cancer surgery and has conducted a population-based study that evaluated the role of provincewide guidelines in consistency of breast cancer care.

Martin Tattersall, MD, PhD: Dr. Tattersall is a Professor in the Department of Cancer Medicine, University of Sydney, and a cancer physician at the Royal Prince Alfred Hospital in Sydney, Australia. He is a member of the Editorial Board for the journal Cancer Strategy. Regarded as an international clinical cancer expert, Professor Tattersall is Chair of Australia's peak advisory body on drug evaluation, the Australian Drug Evaluation Committee (ADEC). He also has worked on World Health Organization and National Health and Medical Research Council working parties on cancer.