# Appendixes

Appendix A: McMaster Research Team

Appendix B: Search Strategy (Medline)^a^

Appendix C: Algorithm and Descriptive Guidelines for Initial Screening of Title and Abstract Citations

Appendix D: Guidelines for Decision Aid Relevance Form

Appendix E: Peer Reviewers for the Cancer Related Decision Aid Systematic Review

Appendix F: Quality Assessment of Effectiveness and Development Studies

Appendix G: Acronyms and Abbreviations