# Evidence Tables

Evidence Table 3.1: Electronic Database Search Yield^a^

| MEDLINE (to May 2000) | CINAHL (to November 1999) | EMBASE (to May 2000) | Cochrane Library (to November 1999) | PsycINFO (to May 2000) | Sociological Abstracts (to November 1999) | HEALTHStar (to November 1999) | Reference Lists ^b^
# Titles and Abstracts Reviewed | 577 | 88 | 784 | 32 | 71 | 0 | 195 | -
# Articles Requested | 361 | 47 | 279 | 15 | 34 | - | 120 | 90
# Articles Retrieved | 353 | 47 | 273 | 15 | 32 | - | 120 | 63
# Foreign Language | 58 | 0 | 28 | 1 | 0 | - | 15 | 0
# Articles Reviewed | 353 | 47 | 273 | 15 | 32 | - | 120 | 37
# Meeting Inclusion Criteria ^c^ | 129 (101/132) | 23 (1/31) | 110 (25/30) | 10 (0/5) | 14 (2/5) | - | 48 (0/3) | 7 (3/3)

a The same article may be tallied in two or more columns.

b Some of the articles requested by our screeners were to provide background information only, were unretrievable, or were judged inappropriate to screen for our study.

c Fractions represent unique studies: The numerator equals the number of unique articles found by that particular search. The denominator equals the number of articles not found by previous searches (all columns to the left). Total studies = 132.

Evidence Table 3.1a: Sensitivity and Specificity of Electronic Database Searches

| MEDLINE | EMBASE | HealthSTAR | PsycINFO | Cochrane Library
Sensitivity ^a^ | 98% | 83% | 36% | 11% | 8%
Specificity ^b^ | 22% | 14% | 25% | 20% | 31%

a Sensitivity defined as total number of included studies identified by the search divided by the total number of included studies.

b Specificity defined as the total number of included studies identified by the search divided by the total number of potentially relevant studies from the search.

Evidence Table 3.2: Results of Screening Process

Screening of Full Text Articles (n=549) | | Total
1. Total # of unique articles included for any of the five key questions:; - Report of a primary study in humans:; - TSCI in the study sample:; - All subjects; - Some subjects; - In those with TSCI, CNP was present in:; - All subjects; - Some subjects; - In those with TSCI and CNP, their age groups included:; - Adults (18 years and older); - Adolescents (13-17 years); - Children (<13 years); - Type of Primary Study:; - Randomized controlled trial; - Observational study; - Qualitative study | 132 77 55 74 58 131 19 1 6 126 0 | 132
2 Total # of articles excluded on any of the five key questions:; - Not a primary study in humans; - None had TSCI; - None had CNP; - No data in paper | 198 95 92 1 | 386
3 Total Excluded at data extraction:; - Focus of the article was not about the management of TSCI; - Results not reported separately for TSCI and CNP patients; - Abstract only; - Article does not address any key research questions | 14 6 3 4 | 27
4 Unable to Obtain through InterLibrary Loan | | 4

Citations of Articles Not Located

Akman MN, Ersoy Y. Chronic pain and its management in spinal cord injured patients. Fizik Tedavi Rehabilitasyon Dergisi 1995;3.

Ammer K, Rathkolb O. Biofeedback treatment in neurological and head diseases -- Literature survey. Rehabilitacia. Supplementum 1997;30(4):237-42.

Kowaluk EA, Arneric SP, Williams M. Opportunities in pain therapy: Beyond the opioids and NSAIDs. Emerg Drugs 1998;3:1-37.

Ozyurt M, Hizmetli S, Nacitarhan V, Elden H, Kant B, Goker I. The relationship between different variables and prognosis in paraplegic patients. Fizik Tedavi Rehabilitasyon Dergisi 1997;21(1):16-9.

Evidence Table 3.3: Screening of Articles in Languages Other Than English Requiring Translation

Language | Number Screened | Number Excluded | Number Included | Author and Date | Key Question (s) Addressed
Russian | 6 | 3 | 3 | Livshits, 1988 | 1
Russian | 6 | 3 | 3 | Virozub, 1990 | 5
Russian | 6 | 3 | 3 | Livshits, 1990 | 5
Japanese | 12 | 10 | 2 | Tsuda, 1985 | 5
Japanese | 12 | 10 | 2 | Nagaro, 1995 | 4
Turkish | 2 | 0 | 2 | Erzurumlu, 1996 | 4, 5
Turkish | 2 | 0 | 2 | Ozerbil, 1997 | 4
French | 16 | 14 | 2 | Lazorthes, 1978 | 5
French | 16 | 14 | 2 | Rhein, 1995 | 1, 2
German | 16 | 14 | 2 | Paeslack, 1990 | 3
German | 16 | 14 | 2 | Wiegand, 1985 | 5
Croatian | 1 | 0 | 1 | Cobeljic, 1998 | 1
Danish | 1 | 0 | 1 | Svendsen, 1993 | 3
Norwegian | 1 | 0 | 1 | Gronning, 1997 | 4, 5
Spanish | 5 | 5 | 0 | NA | NA
Italian | 3 | 3 | 0 | NA | NA
Swedish | 1 | 1 | 0 | NA | NA
Hebrew | 1 | 1 | 0 | NA | NA

Evidence Table 3.4: Studies with Multiple Citations^a^

Beric A, Dimitrijevic MR, Lindblom U. Central dysesthesia syndrome in spinal cord injury patients. Pain 1988;34(2):109-116.; - Beric A, Dimitrijevic MR. Central dysesthesia syndrome in spinal cord injury patients. Pain 1987; Supp 4:S349.; - Beric A, Dimitrijevic MR, Light JK. Pain in spinal cord injury with occult caudal lesions. European Journal of Pain 1992;13(1):1-7.; - Beric A. Dimitrijevic MR, Wall PD, Lindblom U, editors. Altered Sensation and Pain. Basel, Switzerland: Karger; 1990; 4, Altered sensation and pain in spinal cord injury. p. 27-36.
Davis R, Lentini R. Transcutaneous nerve stimulation for treatment of pain in spinal-cord-injured patients. Bull Prosthet Res 1974;298-301.; - Davis R, Lentini R. Transcutaneous nerve stimulation for treatment of pain in patients with spinal cord injury. Surg Neurol 1975;4(1):100-101.
Davidoff G, Guarracini M, Roth E, et al. Trazodone hydrochloride in the treatment of dysesthetic pain in traumatic myelopathy: a randomized, double-blind, placebo-controlled study. Pain 1987;29(2):151-161.; - Davidoff G, Roth E, Guarracini M, et al. Function-limiting dysesthetic pain syndrome among traumatic spinal cord injury patients: a cross-sectional study. Pain 1987;29(1):39-48.
Kumar K, Toth C, Nath RK. Deep brain stimulation for intractable pain: a 15-year experience. Neurosurgery 1997;40(4):736-746.; - Kumar K, Wyant GM, Nath R. Deep brain stimulation for control of intractable pain in humans, present and future: a ten-year follow-up. Neurosurgery 1990;26(5):774-781.
Kumar K, Toth C, Nath RK, et al. Epidural spinal cord stimulation for treatment of chronic pain -- some predictors of success. A 15-year experience. Surg Neurol 1998;50(2):110-120.; - Lang P. The treatment of chronic pain by epidural spinal cord stimulation -- a 15 year follow up; present status. Axone 1997;18(4):71-73.
Lenz FA, Kwan HC, Martin R, et al. Characteristics of somatotopic organization and spontaneous neuronal activity in the region of the thalamic principal sensory nucleus in patients with spinal cord transection. J Neurophysiol 1994;72(4):1570-1587.; - Lenz FA, Tasker RR, Dostrovsky JO, et al. Abnormal single-unit activity recorded in the somatosensory thalamus of a quadriplegic patient with central pain. Pain 1987;31(2):225-236.; - Lenz FA, Kwan HC, Dostrovsky JO, et al. Characteristics of the bursting pattern of action potentials that occurs in the thalamus of patients with central pain. Brain Res 1989;496(1-2):357-360.
Levi R, Hultling C, Nash MS, Seiger A. The Stockholm spinal cord injury study: 1. Medical problems in a regional SCI population. Paraplegia 1995;33(6):308-315.; - Westgren N, Levi R. Quality of life and traumatic spinal cord injury. Arch Phys Med Rehabil 1998;79(11):1433-1439.; - Levi R, Hultling C, Seiger A. The Stockholm Spinal Cord Injury Study: 2. Associations between clinical patient characteristics and post-acute medical problems. Paraplegia 1995;33(10):585-594.; - Levi R, Hultling C, Seiger A. The Stockholm spinal cord injury study. 3. Health-related issues of the Swedish annual level-of-living survey in SCI subjects and controls. Paraplegia 1995;33(12):726-730.; - Levi R, Hultling C, Seiger A. The Stockholm spinal cord injury study: 4. Psychosocial and financial issues of the Swedish annual level-of-living survey in SCI subjects and controls. Paraplegia 1996;34(3):152-157.
Levy RM, Lamb S, Adams JE. Treatment of chronic pain by deep brain stimulation: long term follow-up and review of the literature. Neurosurgery 1987;21(6):885-893.; - Adams JE, Hosobuchi Y, Fields HL. Stimulation of internal capsule for relief of chronic pain. J Neurosurg 1974;41(6):740-744.
Long DM, Erickson DE. Stimulation of the posterior columns of the spinal cord for relief of intractable pain. Surg Neurol 1975;4(1):134-141.; - Long DM, Erickson D, Campbell J, et al. Gildenberg PL, Long DM, editors. Seminar on Spinal Cord Stimulation for the Control of Pain and other Neurological Disorders. 44 ed. New York: Karger; 1981; 4, Electrical stimulation of the spinal cord and peripheral nerves for pain control. A 10-year experience. p. 207-217.
Meglio M, Cioni B, Prezioso A, et al. Spinal cord stimulation (SCS) in deafferentation pain. Pacing Clin Electrophysiol 1989;12(4 Pt 2):709-712.; - Meglio M, Cioni B, Rossi GF. Spinal cord stimulation in management of chronic pain. A 9-year experience. J Neurosurg 1989;70(4):519-524.; - Cioni B, Meglio M, Pentimalli L, et al. Spinal cord stimulation in the treatment of paraplegic pain. J Neurosurg 1995;82(1):35-39.
Nepomuceno C, Fine PR, Richards JS, Gowens H, et al. Pain in patients with spinal cord injury. Arch Phys Med Rehabil 1979;60(12):605-609.; - Richards JS, Meredith RL, Nepomuceno C, et al. Psycho-social aspects of chronic pain in spinal cord injury. Pain 1980;8(3):355-366.; - Nepomuceno C, Gowens H, Stover SL, et al. Pain in the spinal cord injured. Arch Phys Med Rehabil 1977;58:532-533.; - Richards JS, Nepomuceno C, Riles M, Suer Z. Assessing pain behavior: the UAB Pain Behavior Scale. Pain 1982;14(4):393-398.
North RB, Ewend MG, Lawton MT, Piantadosi S. Spinal cord stimulation for chronic, intractable pain: superiority of "multi-channel" devices. Pain 1991;44(2):119-130.; - North RB, Kidd DH, Zahurak M, et al. Spinal cord stimulation for chronic, intractable pain: experience over two decades. Neurosurgery 1993;32(3):384-394.
Rath SA, Seitz K, Soliman N, et al. DREZ coagulations for deafferentation pain related to spinal and peripheral nerve lesions: indication and results of 79 consecutive procedures. Stereotact Funct Neurosurg 1997;68(1-4 Pt 1):161-167.; - Richter, HP, Seitz, K. Dorsal Root Entry Zone Lesions for the Control of Deafferentation Pain: Experiences in Ten Patients. Neurosurgery 1984;15(6):956-959.; - Rath SA, Braun V, Soliman N, et al. Results of DREZ coagulations for pain related to plexus lesions, spinal cord injuries and postherpetic neuralgia. Acta Neurochir 1996;138(4):364-369.
Richardson, RR. Posterior spinal cord stimulation for treatment of sequela spinal injury. Journal of Orthopaedic Surgical Techniques 1987;3(3-4):165-173.; - Richardson, RR. Posterior spinal cord stimulation for treatment of spinal cord injury sequelae. Journal of Neurological & Orthopaedic Medicine & Surgery 1988;9(1):67-73.
Siddall PJ, Taylor DA, McClelland JM, et al. Pain report and the relationship of pain to physical factors in the first 6 months following spinal cord injury. Pain 1999;81(1-2):187-197.; - Sved P, Siddall PJ, McClelland J, et al. Relationship between surgery and pain following spinal cord injury. Spinal Cord 1997;35(8):526-530.
Taira T, Kawamura H, Tanikawa T, Kawabatake H, Iseki H, Ueda A, Takakura K. A new approach to the control of central deafferentation pain--spinal intrathecal baclofen. Acta Neurochir Suppl 1995;64:136-138.; - Taira T, Kawamura H, Tanikawa T, Iseki H, Kawabatake H, Takakura K. A new approach to control central deafferentation pain: spinal intrathecal baclofen. Stereotact Funct Neurosurg 1995;65(1-4):101-105.

a Bulleted citations relate to the unbulleted "primary" citation above them. Data extraction was performed on articles of primary citations only.

Evidence Table 3.5: Citations of Studies Excluded During Data Extraction

Citation | Reason for Exclusion
Aisen PS, Aisen ML. Shoulder-hand syndrome in cervical spinal cord injury. Paraplegia 1994;32(9):588-592. | Article did not address any of the five key research questions.
Anson CA, Stanwyck DJ, Krause JS. Social support and health status in spinal cord injury. Paraplegia; 31(10):632-638. | Focus of the article was not about the management of TSCI/CNP.
Attal N, Gaudé V, Brasseur L, Dupuy M, Parker F, Bouhassira D. Intravenous lidocaine in central pain: a double-blind, placebo-controlled, psychophysical study (in Process Citation). Neurology 2000;54(3):564-574. | Results are not reported separately for TSCI and CNP patients.
Bravo P, Labarta B, Garcia C. Pain in people suffering marrow injuries and its treatment. Rehabilitacion 1988;22(2):181-189. | Article did not address any of the five key research questions.
Bridle MJ. Evaluation of Virginia Regional Spinal Cord Injury System Follow-up Care. J Rehabil Res Dev 1991;28(1):417. | Abstract only: Complete report not available.
Doll M, Baum H. Retained intraspinal bullet -- an illustrative case report. Neurosurg Rev 1989;12(1):67-70. | Focus of the article was not about the management of TSCI/CNP.
Gerhart KA, Johnson RL, Whiteneck GG. Health and psychosocial issues of individuals with incomplete and resolving spinal cord injuries. Paraplegia 1992;30(4):282-287. | Results are not reported separately for TSCI and CNP patients.
Hansebout RR, Blight A.R. Fawcett S. et al. 4-Aminopyridine in chronic spinal cord injury: a controlled, double-blind, crossover study in eight patients. J Neurotrauma 1993;10(1):1-18. | Focus of the article was not about the management of TSCI/CNP.
Kakulas BA, Smith E, Gaekwad U, et al. Dimitrijevic MR, Wall PD, Lindblom, U, editors. Altered Sensation and Pain. Basel, Switzerland: Karger, 1990; The neuropathology of pain and abnormal sensations in human spinal cord injury derived from the clinicopathological database at the Royal Perth Hospital, 37-41. | Focus of the article was not about the management of TSCI/CNP.
Kewman DG, Tate DG. Suicide in SCI: A psychological autopsy. Rehabilitation Psychology 1998;43(2):143-151. | Focus of the article was not about the management of TSCI/CNP.
Knutsdottir S. Spinal cord injuries in Iceland 1973-1989. A follow up study. Paraplegia 1993;31(1):68-72. | Results are not reported separately for TSCI and CNP patients.
Landells CD, Van Peteghem, PK. Fractures of the Atlas: Classification, Treatment and Morbidity. Spine 13(5):450-452. | Focus of the article was not about the management of TSCI/CNP.
Lazorthes Y, Siegfried J, Verdie JC, Casaux J. Chronic spinal cord stimulation in the treatment of neurogenic pain. Cooperative and retrospective study on 20 years of follow-up. Neurochirurgie 1995; 41(2):73-86. | Results are not reported separately for TSCI and CNP patients.
Manolescu R. Lidocaine Infusion to Control Post Transection Spinal Pain. Reg Anesth 1991;16(1 Suppl):55. | Abstract only: Complete report not available.
Meyerson B, Linderoth B, Lind G. Spinal cord stimulation in chronic neuropathic pain. Lakartidningen 1991;88(9):727-732. | Focus of the article was not about the management of TSCI/CNP
Moossy JJ, Nashold BSJ. Suicide in SCI: A psychological autopsy. Rehabilitation Psychology 1998;43(2):143-151. | Focus of the article was not about the management of TSCI/CNP.
Morse JM, Mitcham C. The experience of agonizing pain and signals of disembodiment. J Psychosom Res 1998;44(6):667-680. | Focus of the article was not about the management of TSCI/CNP.
Notake M, Takata M. The usefulness of CoSPANrho microcatheter for pain relief of the patient with incomplete lumbar spinal cord injury. Hokuriku Journal of Anesthesiology 1996; 30(1):45-47. | Focus of the article was not about the management of TSCI/CNP.
Ohry A, Heim A, Steinbach TV, Rozin R. The needs and unique problems facing spinal cord injured persons after limb amputation. Paraplegia 1983;21(4):260-263. | Focus of the article was not about the management of TSCI/CNP.
Radwanski M. Self-medicating practices for managing chronic pain after spinal cord injury. Rehabil Nurs 1992;17(6):312-317. | Article did not address any of the five key research questions.
Rintala DH, Hart KA, Fuhrer MJ. Self-reported pain in persons with chronic spinal cord injury. J Am Paraplegia Soc 1991;14:83. | Abstract only: Complete report not available.
Robinson LR, Little JW. Motor-evoked potentials reflect spinal cord function in porst-traumatic syringomyelia. Am J Phys Med Rehbil 1990;69(6):307-310. | Focus of the article was not about the management of TSCI/CNP.
Schvarcz JR. Chronic self-stimulation of the medial posterior inferior thalamus for the alleviation of deafferentation pain. Acta Neurochir Suppl 1980;30:295-301. | Results are not reported separately for TSCI and CNP patients.
Sipski ML, Delisa JA, Schweer S. Functional electrical stimulation bicycle ergometry: patient perceptions. Am J Phys Med Rehabil 1989;68(3):147-149. | Focus of the article was not about the management of TSCI/CNP.
Tasker RR, DeCarvalho GT, Dolan EJ. Intractable pain of spinal cord origin: clinical features and implecations for surgery. J Neurosurg 1992;77(3):373-378. | Results are not reported separately for TSCI and CNP patients.
Yanagida H, Fukuda Y, Suwa K, Trouwborst A. Alcohol-induced pituitary neuroadenolysis in anaesthesia dolorosa. Pain Clinic 1988;(4):229-230. | Focus of the article was not about the management of TSCI/CNP.
Young RF, Jacques DS, Rand RW, Copcutt, BR. Medial thalamotomy with the Leksell Gamma Knife for treatment of chronic pain. Acta Neurochir Suppl 1994;62:105-110. | Article did not address any of the five key research questions.

Evidence Table 3.6.1: Year of Publication

Year of Publication | Frequency | Percent
1965-1969 | 1 | 0.8
1970-1974 | 4 | 3.0
1975-1979 | 9 | 6.8
1980-1984 | 13 | 9.9
1985-1989 | 20 | 15.2
1990-1994 | 37 | 28.0
1995-1999 | 48 | 36.4
Total | 132 | 100.0

Evidence Table 3.6.2: Source of Funding

Source of Funding | Frequency | Percent Yes ^a^
Government agency | 17 | 19.5
Charity | 7 | 8.0
Professional organization | 7 | 8.0
Consumer organization | 4 | 4.6
Industry | 4 | 4.6
Other | 2 | 2.3
Not available | 46 | 60.5

a Total sample with general characteristic information available N=76

Evidence Table 3.6.3: Country of Publication

Country of Publication | Frequency | Percent
Australia | 3 | 2.2
Belgium | 2 | 1.5
Canada | 5 | 3.8
Denmark | 2 | 1.5
France | 5 | 3.8
Germany | 7 | 5.3
Greece | 1 | 0.8
India | 1 | 0.8
Israel | 2 | 1.5
Italy | 5 | 3.8
Japan | 5 | 3.8
Norway | 4 | 3.0
Russia | 3 | 2.3
Serbia | 1 | 0.8
Spain | 1 | 0.8
Sweden | 2 | 1.5
Switzerland | 2 | 1.5
Taiwan | 1 | 0.8
Turkey | 3 | 2.3
United Kingdom | 12 | 9.1
United States | 68 | 48.5
Yugoslavia | 1 | 0.8
Total | 132 | 100.0

Evidence Table 3.6.4: Study Design

Study Design | Frequency | Percent
Case reports | 56 | 42.4
Case series (10 pts) | 47 | 35.6
Survey | 10 | 7.6
RCT, crossover | 4 | 3.0
Non-RCT, contemporaneous controls | 4 | 3.0
Validation | 4 | 3.0
RCT, parallel | 2 | 1.6
Case controls | 3 | 2.3
Other | 2 | 1.5
Total | 132 | 100.0

Evidence Table 3.6.5: Direction of Investigation

Direction of Investigation | Frequency | Percent
Prospective | 48 | 63.1
Retrospective | 23 | 30.3
Not Clear | 5 | 6.6
Total | 76 | 100.0

Evidence Table 3.6.6: Patients in Study Sample

Patients in Study Sample | Frequency | Percent
9 | 1 | 1.3
10 | 2 | 2.6
11-15 | 10 | 13.2
16-20 | 4 | 5.3
21-25 | 6 | 7.9
26-30 | 4 | 5.3
31-40 | 7 | 9.2
41-50 | 9 | 11.8
51-75 | 10 | 13.2
76-100 | 6 | 7.9
101-200 | 11 | 14.5
>200 | 6 | 7.9
Total | 76 | 100.0

Evidence Table 3.6.7: Patients in Study Sample With TSCI/CNP

Patients in study sample with TSCI/CNP | Frequency | Percent
9 | 6 | 7.9
10 | 3 | 3.9
11-15 | 14 | 18.4
16-20 | 12 | 15.8
21-25 | 10 | 13.2
26-30 | 5 | 6.6
31-40 | 5 | 6.6
41-50 | 8 | 10.5
51-75 | 5 | 6.6
76-100 | 4 | 5.3
101-200 | 4 | 5.3
Unclear | 1 | 1.3
Total | 76 | 100.0

Evidence Table 3.6.8: Health Care Setting

Health Care Setting | Frequency | Percent Yes ^a^
Tertiary care | 62 | 81.6
Not reported | 10 | 13.2
Community | 6 | 7.9
Home | 4 | 5.3
Other | 1 | 1.3

a Total sample with general characteristic information available N=76

Evidence Table 3.6.9: Eligibility Criteria Reported

Eligibility Criteria Reported | Frequency | Percent
Not explicit | 27 | 35.5
Explicit | 26 | 34.2
No | 23 | 30.1
Total | 76 | 100.0

Evidence Table 3.6.10: Study Duration Preplanned

Study Duration Preplanned | Frequency | Percent
Yes | 37 | 48.7
No | 18 | 23.7
Not available | 21 | 27.6
Total | 76 | 100.0

Evidence Table 3.6.11: Preplanned Study Duration for One Patient

Study Duration Preplanned | Frequency | Percent
< 4 weeks | 3 | 3.9
5 weeks - 10 weeks | 4 | 5.3
11 weeks - 1 year | 7 | 9.2
> 1 year | 4 | 5.3
Other duration | 29 | 38.2
Not available | 29 | 38.2
Total | 76 | 100.0

Evidence Table 3.6.12: Number of Groups

Number of Groups | Frequency | Percent
1 | 56 | 73.7
2 | 11 | 14.5
3 | 6 | 7.9
4 | 3 | 3.9
Total | 76 | 100.0

Evidence Table 3.6.13: Interventions

Interventions | Frequency | Percent Yes ^a^
No intervention | 36 | 47.4
Alfentanil | 1 | 1.3
Amitriptyline | 1 | 1.3
Anterior decompression | 1 | 1.3
Arterior decompression | 1 | 1.3
Back surgery | 4 | 5.3
Brain stimulation | 1 | 1.3
Buprenorphine | 1 | 1.3
Carbamazepine | 1 | 1.3
Cordectomy | 1 | 1.3
DREZ | 6 | 7.9
DREZ CO_2_ laser | 2 | 2.6
DREZ Computer assisted | 1 | 1.3
DREZ radio frequency method | 1 | 1.3
Electroacupuncture | 1 | 1.3
Evacuation of cyst | 1 | 1.3
Flumpenthinol (neuroleptic) | 1 | 1.3
Gabapentine | 1 | 1.3
Intrathecal baclofen | 1 | 1.3
Intrathecal clonidine | 2 | 2.6
Intrathecal lidocaine | 1 | 1.3
Intrathecal morphine | 1 | 1.3
Ketamine | 1 | 1.3
Melitracen (antidepressive tricyclic) | 1 | 1.3
Mexiletine | 1 | 1.3
Multiple drugs | 1 | 1.3
Myclography | 2 | 2.6
Other narcotics | 2 | 2.6
Other nonpharmacological | 3 | 3.9
Other self management | 1 | 1.3
Placebo | 6 | 7.9
Spinal stimulation | 5 | 6.6
TENS | 3 | 3.9
Trazone | 1 | 1.3
Usual care | 1 | 1.3
Valproate | 1 | 1.3

a Total sample with general characteristic information available N=76

Evidence Table 3.6.14: Level of Injury

Level of Injury: (total sample) | Frequency | Percent Yes ^a^
Cervical | 32 | 42.1
Lumbar | 32 | 42.1
Sacral | 7 | 9.2
Thoracic | 37 | 48.7
Paraplegic | 20 | 26.3
Tetraplegic | 14 | 18.4
Not available | 15 | 19.7

a Total sample with general characteristic information available N=76

Evidence Table 3.6.15: Completeness of Injury

Completeness of Injury: (total sample) | Frequency | Percent
Both complete and incomplete | 25 | 32.9
Complete | 4 | 5.3
Incomplete (not specified) | 3 | 3.9
Not available | 44 | 57.9
Total | 76 | 100.0

Evidence Table 3.6.16: Classification

Specification of Injury: (total sample) | Frequency | Percent Yes ^a^
A Complete | 10 | 13.2
B Incomplete | 10 | 13.2
C Incomplete | 10 | 13.2
D Incomplete | 11 | 14.5
E Normal | 2 | 2.6

a Total sample: (N=11)

Evidence Table 3.6.17: Cause of Injury

Cause of Injury: (total sample) | Frequency | Percent Yes ^a^
Road traffic accident | 22 | 28.9
Falls | 19 | 25.0
Gunshot wounds | 19 | 25.0
Sports | 14 | 18.4
Other | 21 | 27.6
Not available | 49 | 64.5

a Total sample with general characteristic information available N=76

Evidence Table 3.6.18: Surgical Stabilization

Surgical Stabilization: (total sample) | Frequency | Percent
All | 4 | 5.3
Some | 18 | 23.7
None | 1 | 1.3
Not available | 53 | 69.7
Total | 76 | 100.0

Evidence Table 3.6.19: Time Since Injury

Time Since Injury: (total sample) | Frequency | Percent
> 6 months | 5 | 6.6
> 6 months to 1 year | 4 | 5.3
> 1 year to 5 years | 4 | 5.3
> 5 years to 10 years | 7 | 7.2
> 10 years | 15 | 19.7
Not available | 41 | 53.9
Total | 76 | 100.0

Evidence Table 3.6.20: Age

Age: (total sample) | Frequency | Percent
> 20 to 30 years | 3 | 3.9
> 30 to 40 years | 13 | 17.1
> 40 to 50 years | 21 | 27.6
> 50 to 60 years | 8 | 10.5
Not available | 31 | 40.8
Total | 76 | 100.0

Evidence Table 3.6.21: Gender

Gender: (total sample) | Frequency | Percent
> 50 to 60% male | 2 | 2.6
> 60 to 70% male | 7 | 9.2
> 70 to 80% male | 12 | 15.8
> 80 to 90% male | 17 | 22.4
> 90% male | 10 | 13.2
Not available | 28 | 36.8
Total | 76 | 100.0

Evidence Table 3.6.22: Neuropathic Pain Defined by Authors

Authors Define Neuropathic Pain: | Frequency | Percent
Yes | 29 | 38.2
No | 47 | 61.8
Total | 76 | 100.0

Evidence Table 3.6.23: Cause of Injury

Cause of Injury: (total sample) | Frequency | Percent Yes ^a^
Allodynia | 6 | 7.9
Anesthesia dolorosa | 1 | 1.3
Burning | 40 | 52.6
Causalgia | 1 | 1.3
Central pain | 9 | 11.8
Deafferentation pain | 13 | 17.1
Dysesthesia | 18 | 23.7
Electric | 7 | 9.2
Hyperesthesia | 7 | 9.2
Hyperalgesia | 6 | 7.9
Hypersensitivity | 1 | 1.3
Neurogenic | 7 | 9.2
Paraplegic pain | 1 | 1.3
Phantom | 5 | 6.6
Sharp | 13 | 17.1
Shooting | 15 | 19.7
Stabbing | 16 | 21.1
Tingling | 17 | 22.4
Other | 31 | 40.8

a Total sample with general characteristic information available N=76

Evidence Table 3.6.24: Start of Pain After Injury

Start of Pain After Injury: (total sample) | Frequency | Percent
> 6 months | 9 | 11.8
> 6 months to 1 year | 2 | 2.6
> 1 year | 2 | 2.6
Not available | 63 | 82.9
Total | 76 | 100.0

Evidence Table 3.6.25: Duration of Pain

Duration of Pain: (total sample) | Frequency | Percent
> 1 year | 5 | 6.6
> 1 year to 5 years | 4 | 5.3
> 5 years | 5 | 6.6
Not available | 62 | 81.6
Total | 76 | 100.0

Evidence Table 3.6.26: Area of Body Affected by Pain

Area of Body Affected by Pain: | Frequency | Percent Yes ^a^
Lower body | 31 | 40.1
Trunk | 17 | 22.4
Upper extremities | 14 | 18.4
Back | 10 | 13.2
Other | 7 | 9.2
Not available | 43 | 56.6

a Total sample with general characteristic information available N=76

Evidence Table 3.6.27: Temporal Properties of Pain

Temporal Properties of Pain: | Frequency | Percent Yes ^a^
Continuous, steady, constant | 17 | 22.4
Rhythmic, periodic, intermittent | 11 | 14.5
Mixed | 7 | 9.2
Worsening | 5 | 6.6
Brief, momentary, transient | 4 | 5.3
Not available | 50 | 65.8

a Total sample with general characteristic information available N=76

Evidence Table 3.6.28: Siddall Classification of Pain

Siddall Classification of Pain: | Frequency | Percent Yes ^a^
Neuropathic | 44 | 57.9
At level | 23 | 30.1
Radicular | 5 | 6.6
Central | 9 | 11.8
Below level | 37 | 48.7
Musculoskeletal | 9 | 11.8
Visceral | 6 | 7.9
Other | 1 | 1.3
Not available | 32 | 42.0

a Total sample with general characteristic information available N=76

Evidence Table 3.6.29: Outcome Measures

Outcome Measures: | Frequency | Percent Yes ^a^
ADL | 1 | 1.3
Amplitudes | 1 | 1.3
Barthel | 1 | 1.3
Beck Depression (BDI) | 2 | 2.6
Binary - number improved | 3 | 4.0
Binary - number with >50% pain relief | 4 | 5.3
Binary - other | 7 | 9.2
Categorical - number with pain | 3 | 4.0
Categorical - number with pain relief | 2 | 2.6
Categorical - other | 6 | 7.9
CESD | 1 | 1.3
Coping Strategies (COPE) (CSQ) | 2 | 2.6
Descriptor Differential Scale (DDS) | 1 | 1.3
EMG potentials | 1 | 1.3
Functional Independence (FIM) | 2 | 2.6
Global Subjective assessment - MD | 3 | 4.0
Heat Pain Threshold | 1 | 1.3
Interview about pain/narrative/words | 22 | 28.9
Klekamp and Sami Scoring System | 1 | 1.3
Latinen test | 3 | 4.0
Likert type - number with pain | 1 | 1.3
McGill Pain Questionnaire | 12 | 15.8
Pain Rating Index | 6 | 7.9
Present Pain Intensity | 5 | 6.4
Number of Words Chosen | 5 | 6.4
McGill Pain Questionnaire Short Form | 2 | 2.6
Medical Record Review | 1 | 1.3
MMPI | 2 | 2.6
MPI (Multidimentional Pain Inventory) | 1 | 1.3
MRI | 1 | 1.3
Neurophysiologic measurements (battery of tests) | 5 | 6.4
Numerical scales | 5 | 6.4
Pain drawing | 4 | 5.1
Percent (%) pain reduction | 1 | 1.3
Physical examinations | 4 | 5.1
PIS (Pain Inventory Scale) | 1 | 1.3
Quality of Life (QOL) | 1 | 1.3
Radiographs | 2 | 2.6
Roentgliogram | 2 | 2.6
SCIIS (Spinal Cord Injury Inventory Scale) | 1 | 1.3
State Anxiety Inventory (STAI) | 3 | 3.9
Sternbach Pain Intensity | 3 | 3.9
Thermographs | 2 | 2.6
Use of drugs | 1 | 1.3
Visual Analogue Scale (mm) | 9 | 11.8
Visual Analogue Scale (other unit) | 11 | 14.5
Zung Pain and Distress Scale | 2 | 2.6

a Total sample with general characteristic information available N=76

Evidence Table 3.1.30: Relaxation Techniques

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Grzesiak, 1977 Country: USA Setting: Tertiary Care Refman ID: 836 | Design: 4 single case reports Followup: complete Reliable/valid outcome measures: NR Length of study: varied - minimum 1 year | Gender: 3 men, 1 woman Age: min 22 y - max 36 y Level of injury: T12, C4/5, T10, T10/11 Completeness of injury: NR Cause of injury: GSW, diving, MVA, compression fracture Time since injury: min 1.5 y - max 3.5 y Duration of pain: NR Onset of pain: NR Pain description: sharp, itching, stabbing, severe, constant; pain below level of lesion | Intervention: muscle relaxation and cognitive alteration of attentiveness to pain using the French and Tupin approach - muscle relaxation exercises, mental imagery, relaxation | Outcome measures: patient's subjective report, staff observation Adverse Effects: NR Comments:; - patients report less pain and improved mood; - staff reports include better program attendance and improved mood; - advantages include easily learned technique, only requires one to several sessions, with optional followup
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 3.1.31: Laughing

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Henderson, 1993 Country: USA Setting: NC Refman ID: 1513 | Design: one group pre/post, 12 subjects Followup: NR Reliable/valid outcome measures: NR - MPQ Length of study: 1 session | Gender: 75% male Age: min 20 y, max 58 y Level of injury: 5 quadriplegic, 7 paraplegic Completeness of injury: NR Cause of injury: 8 MVA, 2 falls, 1 GSW, 1 unknown Time since injury: mean 11.4 y, min 9 m, max 38 y Duration of pain: min 6 m, max 25 y Onset of pain: Pain description: throbbing, shooting, stabbing, sharp, cramping, gnawing, burning, aching, tiring, sickening | Intervention: exposure to a comedian Frequency: 1 session | Outcome measures: MPQ given as a pretest (before the performance); MPQ given again as a posttest Findings: pain decreased in 13 of 15 different pain types defined by McGill Adverse Effects: NR Comments:; - results are limited by the small numbers and the lack of a control group; - study was conducted to suggest the possibility that humor therapy programs could be developed to relieve pain.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 4.1: Characteristics of Studies Assessing Central Neuropathic Pain

Author | Study Design/Quality | Patient Description | Outcome Measures & Findings
Author: Beric, 1992 Country: USA Setting: Tertiary care Refman ID: 980 | Purpose: To describe the presence, quality, and distribution of altered sensation and pain in chronic SCI patients to determine if pain originates from an occult caudal lesion n = 8/188 consecutive patients met the inclusion criteria Study design: Prospective validation study Eligibility criteria: Explicit Appropriate spectrum of patients: Yes Adequate description of setting and referral filter: No Length of study: N/A Reliability/validity of outcome measures: attempted to assess validity Reference standard: No | Gender: 83% male Age: mean 33 y, min 17 y- max 59 y Level of injury: 72% cervical; 28% thoracic Completeness of injury: 83% complete; 17% incomplete Cause of injury: 45% MVA; 33% falls; 5% GSW; 17% sports Time since injury: mean 42.6 m Onset of pain: mean 17.7 m Duration of pain: NC Pain description: ache, burning, dull, electric, pinch, pricking, pulling, sharp, squeezing, stabbing, stinging | Assessment Tools:; - VAS; - Pain drawing; - Physical examination; - Lumbosacral evoked potentials (LSEP); - Polyelectromyography; Findings:; - 14/17 (82%) had LSEP consistent with double lesion syndrome (incomplete cervical or high thoracic injury and occult caudal lesion); - 17/18 (94%) had clinical findings plus one of two positive findings in either LSEP or electromyography
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Cohen, 1988 Country: USA Setting: Pain Clinic for SCI patients Refman ID: 285 | Purpose: To assess the quality and intensity of SCI pain n = 49 TSCI with pain and 98 non-TSCI patients with other types of chronic pain (CPC) from a pain clinic Study design: Retrospective validation study Eligibility criteria: Not explicit Appropriate spectrum of patients: NC Adequate description of setting and referral filter: No Reliability/validity of outcome measures: NR Reference standard: No | Gender: 95% male Age: mean 52 y, min 25 y - max 73 y Level of injury: NR Completeness of injury: 19/49 complete; 30/49 incomplete Cause of injury: NR Time since injury: NR Onset of pain: NR Duration of pain: min 6 m history of pain Pain description: burning, drilling, fearful, lancinating, pricking, pulling, shooting, sickening, stabbing, wrenching, wretched | Outcomes:; - McGill Pain Questionnaire (MPQ); - Minnesota Multiphasic Personality Inventory (MMPI); Findings:; - CPC scores higher than SCI-C for NWC, rank sum, affective subscales of MPQ (p<0.05); - MMPI scores elevated in CPC and SCI-C; less elevated in SCI-I; - CPC>SCI-I for Hs,Hy,Pt subscales of MMPI (p<0.05); - SCI-C>SCI-I for Hy, Pd subscales of MMPI (p<0.05); - No differences between SCI-C and CPC; - MMPI cannot distinguish individuals with SCI and severe pain from those with no pain
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Phantom dysesthesia below the level of the spinal cord lesion
Author: Davidoff, 1987a, b Country: USA Setting: Rehab Center Refman ID: 287,288 | Purpose: To examine the disabling, diffuse dysesthetic pain syndrome experienced by SCI patients n=19 patients who completed the first phase of an RCT Compared to 147 SCI patients in database Study design: Retrospective validation study Eligibility criteria: Explicit Appropriate spectrum of patients: No Adequate description of setting and referral filter: Yes Reliability/validity of outcome measures: NR Reference standard: No | Gender: 90% male Age: mean 36.6 y, min 25 y - max 69 y Level of injury: 16% tetraplegic; 85% paraplegic Completeness of injury: 26% complete; 74% incomplete Cause of injury: 11% MVA; 21% falls; 5% sports; 53% GSW; 11% other Time since injury: NC Onset of pain: < 1 y post SCI Duration of pain: mean 46.8 m (10.2) Pain description: burning, cutting, cruel, nagging, radiating, tight | Outcomes: McGill Pain Questionnaire Number of Words Chosen (NWC) Pain Rating Index (PRI) and components Sternbach Pain Index (SPI) (day and week) Zung Pain and Distress Scale (PAD) Findings:; - Most described CNP as "cutting," "burning," "piercing," "radiating," and "tight," involved lower extremities and felt internally; - All measures equal or greater in severity in CNP patients versus other pain syndromes; - No relation between pain scale scores and symptom duration; Correlations between:; - NWC and PRI-T (p<0.001); - PRI-A and PRI-T (p<0.01); - PRI-A and NWC (p<0.05); - SPI-day and SPI-week (p<0.001); - PAD and NWC (p<0.05); CNP patients more likely to be:; - paraplegic than quadriplegic (p<0.01); - incomplete sensory (73.7% vs. 51.4%, p<0.05); - gunshot wound (52.6% vs. 15.7%, p<0.01); CNP patients less likely to be:; - surgically stabilized (33.6% vs. 66.4%, p<0.01); Comments: population is part of a larger RCT - results taken from Davidoff 87. Also see Table 5.1.10
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Diffuse burning dysesthetic sensations distal to the level of spinal injury
Author: Frisbie, 1990 Country: USA Setting: SCI service in VA Center Refman ID: 117 | Purpose: To distinguish central, musculoskeletal, and syringomyelia pain by two points in history compared with physical examination and radiographic imaging n= 24 with CNP/66 SCI patients Study design: Prospective validation study Eligibility criteria: explicit Appropriate spectrum of patients: Yes Adequate description of setting and referral filter: Yes Reliability/validity of outcome measures: NR Reference standard: No | Gender: NR Age: mean 55 y, min 33 y - max 89 y Level of injury: NR Completeness of injury: 26/51(51%) complete; 25/51 (49%) incomplete Cause of injury: NR Time since injury: mean 16 y, min 2 y - max 45 y Onset of pain: median 3 m post SCI, min 1 d - max 16 m Duration of pain: NR Pain description: burning, causalgia, central pain, neurogenic, stabbing, numbness, pins & needles | Assessment Tools:; - Standardized interview: pain quality, pain location; - Confirmed by: physical exam and radiography; Findings:; - Diagnosis of CNP by history was confirmed in 24/24 cases; - Diagnosis of syrinx pain by history confirmed in 8/11 (73%)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Pain originating from the spinal cord
Author: Quigley, 1996 Country: USA Setting: SCI service in VA Center Refman ID: 341 | Purpose: To explore whether the McGill-Melzack Pain Questionnaire (MMPQ) adequately assesses pain in patients with altered neurological pathways due to SCI n= 27 SCI patients Study design: Prospective validation study Eligibility criteria: NC Appropriate spectrum of patients: NC Adequate description of setting and referral filter: Yes Reliability/validity of outcome measures: NR Reference standard: No | Gender: NR Age: mean 47 y; 27 y min - 76 y max Level of injury: 50% tetraplegic; 50% paraplegic Completeness of injury: NR Cause of injury: NR Time since injury: mean 18.6 y Onset of pain: NR Duration of pain: NR Pain description: 20 words chosen from MPQ | Assessment Tools:; - MMPQ; - Pain Drawing; - VAS 10 cm; Findings:; - Study had inadequate power with duration of injury as a covariate; - Patients with quadriplegia and paraplegia responded differently; - Patients with quadriplegia rated their pain intensity as higher than patients with paraplegia; - Authors concluded that the MPQ was adequate to assess SCI pain
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 4.1: Other Studies Addressing the Prevalence of and Factors Associated with Neuropathic Pain: Shoulder Hand Syndrome (SHS)

Author | Study Design/Quality | Patient Description | Outcome Measures and Findings
Author: Aisen, 1995 Country: USA Setting: Tertiary Care Refman ID: 912 | Design: case control 14 subjects; 7 consecutive cervical spinal cord injury, 7 patients with similar injuries but no SHS Eligibility Criteria: NR Followup: NA Reliability/validity of outcome measures: NA Length of study: NA | Gender: 78% male Age: mean 48 y, min 17 y - max 70 y Level of injury: 100% cervical Completeness of injury: 6/14 complete, 8/14 incomplete Cause of injury: NR Time since injury: mean 2.4 y, min 2 m to max 12 y Duration of pain: NR Onset of pain: NR Pain description: SHS diagnosed on presence of diffuse upper extremity pain with a burning quality, edema, osteoporosis evident on radiographs and dystrophic skin and nail changes (Kozin et al, 1981) | Outcome measures: SSR recorded on the arm with greater pain, measurements of latency and amplitude were obtained from analysis of individual traces Findings:; - mean amplitude more than 3 times greater in patients with SHS (p=0.0252); - in six patients with SHS, symptoms improved following steroid treatment, amplitude falling significantly (p=0.0491); Comments:; - clarification still required of increased outflow and upregulation of receptors
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 4.1: Other Studies Addressing the Prevalence of and Factors Associated With Neuropathic Pain (continued): Reflex Sympathetic Dystrophy

Author | Study Design/Quality | Patient Description | Outcome Measures & Findings
Author: Gellman 1988 Country: USA Setting: Tertiary Care Refman ID: 678 | n=7/60 SCI Study design: Case series Eligibility criteria: Explicit Followup: 100% Length of study: NC Reliability/validity of outcome measures: Authors refer to previous work that reported 96% sensitivity and 98% specificity for three phase radionuclide scintigraphy (TPRS) (series did not include patients with SCI). | Gender: Group 1: 77% male Group 2: 100% male Age: (mean) Group 1: 37 y, Group 2: 25 y Level of injury: Group 1: cervical (5); thoracic (2) Group 2: cervical (3) Completeness of injury: Group 1: complete (2); incomplete (5); Group 2: complete (2); incomplete (1) Cause of injury: Group 1: falls (2); GSW (5) Group 2: MVA (1); falls (1); GSW (1) Time since injury: Group 1: 9 m Group 2: 3 m Onset of pain: NR Duration of pain: NR Pain description: diffuse hand pain, swelling, stiffness | Assessment Tools: Pain interview, physical examination Three-phase radionuclide scintigraphy Findings: 7/60 had upper extremity pain Group 1: TPRS positive for 6/7 Group 2: TPRS positive for 1/3
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 4.2: Characteristics of Studies Evaluating Outcome Tools for Central Neuropathic Pain

Author | Study Design/Quality | Patient Description | Outcome Measures & Findings
Author: Sherman, 1987 Country: USA Setting: VA Medical Center Refman ID: 158 | Purpose: To determine the usefulness of thermography for evaluation of chronic pain of different causes. n= 22 SCI /125 with chronic pain Study design: Prospective, validation study Eligibility criteria: Not explicit Response rate: 100% Length of study: Single evaluation Reliability/validity of outcome measures: Interrater reliability was determined by averaging the correlations between the raters. Thermography assessors were blinded. | Gender: NE Age: NE Level of injury: NR Completeness of injury: 68% complete; 32% incomplete Cause of injury: NR Time since injury: NR Onset of pain: NR Duration of pain: NR Pain description: burning, throbbing, tingling, cramping | Assessment tools: Thermography VAS (0-10) Pain drawing Findings: Blind panel using only thermography could not differentiate intact from incomplete SCI patients; were able to differentiate all but one case of complete versus incomplete SCI Average "validity"=0.67 "Interrater reliability"=0.63 "Efficiency" = 0.87 Efficiency of the test was defined as: % of patients correctly classified as diseased or healthy (number of true positives plus true negatives divided by the number of test times 100)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN: - Phantom pain (pain below level at which normal sensation stops)
Author: Sherman, 1986 Country: USA Setting: VA Center Refman ID:300 | Purpose: To visualize abnormal blood flow patterns in phantom pain. n= 10 Study design: Prospective, validation study Eligibility criteria: explicit Response rate: 100% Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: 100% male Age: mean 52 y, min 27 y - max 63 y Level of injury: 30% cervical; 50% thoracic; 10% cervical and thoracic; 10% thoracic and lumbar Completeness of injury: 100% complete Cause of injury: 90% MVA; 10% GSW Time since injury: mean 13.6 y, min 3 m - max 39 y Onset of pain: NR Duration of pain: NR Pain description: burning, tingling | Assessment tools:; - Video thermography; Findings:; - 1 to 3°C drop just below sensory level in 10/10 cases; - Temperature changes occurred in a similar pattern to sensory change (either abruptly or gradually) at or below the sensory level in all cases; - Elevated temperature and blood flow in areas reported to be painful below sensory level in all cases
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN: - Phantom pain; authors refer to "pain below the level of normal sensations"

Evidence Table 4.3: Characteristics of Studies Addressing the Prevalence of and Factors Associated With CNP

Author | Study Design/Quality | Patient Description | Prevalence | Outcome Measures & Findings
Author: Anke, 1995 Country: Norway Setting: Rehabilitation Facility Refman ID: 55 | Purpose: To assess pain prevalence and quality of life in SCI n= 46 eligible Study design: Prospective, interview (for those with pain), physical examination Sampling frame: Rehabilitation hospital (consecutive admissions) Eligibility criteria: Not explicit Response rate: 100% Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: 78% male Age: median = 32 y, min 15 y - max 76 y Level of injury: tetraplegia: 23 (50%) (those with pain 11 (48%)); paraplegia: 23 (50%) (those with pain 10 (43%)). Frankel classification: A 18(39%) (those with pain 10 (56%)); B-E 28 (61%) (those with pain 11 (39%)) Completeness of injury: NR Cause of injury: NR Time since injury: median 32 w, min 14 w - max 104 w Onset of pain: immediate to 6 m post SCI Duration of pain: median 23 w, min 3 w - 66 w Pain description: constant 16/21 (80%) | Prevalence: Moderate - unbearable pain: 21 (46%) Musculoskeletal: 1 (2%) "Neurogenic": 20 (43%) Diffuse: 8 Segmental: 12 Location of pain: NR Time of day: pain was worse in the evening than in the morning (p= 0.010) | Outcome Measures:; - Pain intensity was rated by patients during the last week of rehab on a 6-point scale (none, slight, moderate, severe, very severe, unbearable). Those with moderate to unbearable pain received a pain interview (pain drawing, assessment of duration and intensity of pain). Pain intensity was measured on a 0-10 cm VAS, 3 times daily for 2-7 days.; - Quality of life: General Health Questionnaire (GHQ 20); Predictors:; - Patients with pain were more likely to be older (median age 40 y vs. 24 y, p= 0.034); - Level of injury, Frankel classification, gender were not significant predictors; Quality of life:; - Patients with pain were more likely to have a pathological score on the GHQ (70% vs. 24%), p=0.003
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Neurogenic pain: a) diffuse or phantom body pain (multifarious, characterized by constant, diffuse, generalized, burning, pricking, tingling pain in paralytic & anesthetic areas; b) root pain (asymmetric, segmental localized pain, sharp with paroxysmal occurrence; c) segmental pain (often bilateral symmetric occurrence within 2-3 spinal segments of the zone of injury, spontaneous, burning character, hyperalgesic border reaction (dysesthesia)); d) visceral pain (deep, diffuse, spastic pain in central abdomen, provoked by bladder or bowel distention) (from Christensen and Jensen 1991)
Author: Burke, 1973 Country: Australia, USA Setting: Two rehabilitation facilities Refman ID: 874 | Purpose: To determine the "incidence" of pain in two SCI centers n = Austin 156; Rancho 214 Study design: Chart review supplemented with information from ward staff Sampling frame: Inpatients at SCI centers; one each in Australia and USA Eligibility criteria: NR Response rate: NR Length of study: 3 1-day "surveys" about 1 m apart Reliability/validity of outcome measures: NR | All data refer to patients with pain Gender: Austin 76% male; Rancho 61% male Age: Austin mean = 38 y; Rancho mean = 33 y Ethnicity: Austin: 100% Caucasian; Rancho: 67% Caucasian Level of injury: NE Completeness of injury: NR Cause of injury: Austin: fracture or fracture/dislocation 71%; stab wound 6%; GSW 6%; nontrauma 18% Rancho: fracture or fracture/dislocation 61%; GSW 18%; nonspecific injury 4%; nontrauma 18% Time since injury: Austin: 10/14 < 24 hours; Rancho: min 1 w, max 1y Onset of pain: immediate to 6 m post SCI Duration of pain: median 23 w, min 3 w - 66 w Pain description: constant 80% | Prevalence: Number with pain*: Austin: 17/156 (11%) Rancho 57/214 (27%) Number with pain of probable spinal origin: Austin 12/156 (7.7%) Rancho 45/214 (21%) Location of pain: NR * Includes 3 patients in Austin and 10 patients in Rancho with nontraumatic spinal cord injuries. The number with pain differs within the report. | Outcome Measures: Prevalence of pain was determined by the author from a chart review, supplemented with information from ward staff.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Neurogenic pain: a) diffuse or phantom body pain (multifarious, characterized by constant, diffuse, generalized, burning, pricking, tingling pain in paralytic & anesthetic areas; b) root pain (asymmetric, segmental localized pain, sharp with paroxysmal occurrence; c) segmental pain (often bilateral symmetric occurrence within 2-3 spinal segments of the zone of injury, spontaneous, burning character, hyperalgesic border reaction (dysesthesia)); d) visceral pain (deep, diffuse, spastic pain in central abdomen, provoked by bladder or bowel distention) (from Christensen and Jensen 1991)
Author: Cairns, 1996 Country: USA Setting: Large public hospital Refman ID: 342 | Purpose: To assess the relationship between pain and depression n = 68/121 eligible Study design: Repeated measures assessing subjects at admission and discharge from hospital Sampling frame: consecutive admissions; part of a larger group of 121 admissions. Eligibility criteria: Not explicit Response rate: 56% Length of study: time between admission and discharge Reliability/validity of outcome measures: CESD, NRS | Gender: 86% male Age: mean = 26 y, min 16 y - max 58 y Level of injury: 34% tetraplegic; 65% paraplegic Completeness of injury: 55% complete, 45% incomplete Cause of injury: 16% MVA, 2% falls, 71% GSW, 6% sports, 5% unspecified Time since injury: mean 19 days Onset of pain: NR Duration of pain: NR Pain description: burning, electric, shooting, aching, cramping throbbing | Prevalence: at admission, 76% of the subjects reported pain - 71% reported that their pain was problematic | Outcome Measures: 101 point Numerical Rating Scale, Center for Epidemiological Studies (CESD) mean pain rating: at admission: 71, at discharge: 53 (p<.001) mean CESD scores: at admission: 22, at discharge: 19 (p<.01) Findings:; - pain and depression were independent at admission; - at discharge, pain and depression were significantly related; - reduced pain will have a greater effect on reducing depression than reduced depression will have on pain
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - A classification scheme describing 3 categories of SCI pain: mechanical, radicular, and dysesthetic pain is used.
Author: Cobeljic, 1998 Country: Serbia Setting: Tertiary care setting Refman ID: 1029 | Purpose: To categorize types of pain in patients with spinal cord injury n= 40 TSCI, 29 with pain Study design: Case series Sampling frame: consecutive cases Eligibility criteria: Explicit Response rate: NR Length of study: NA Reliability/validity of outcomes measures: NR | Gender: % male NR Age: mean 34.3 y Level of injury: Total sample: 11 Cervical, 20 Thoracic, 4 Lumbar, 5 Cauda equina. Of those with pain: 8 Cervical, 13 Thoracic, 3 Lumbar, 5 Cauda equina Completeness of Injury: Frankel scale: Total sample: 29/40 A, 4/40 B, 4/40 C, 3/40 D. Cause of injury: NR Time since injury: 20/40 < 1 y, 8/40 1-2 y, 13/40 > 2 y; 12/29 < 1 y, 6/29 1-2 y, 11/29 > 2 y Onset/Duration of pain: NR Pain description: clearly defines central, radicular, border zone, and mechanical pain | Prevalence:; - 29/40 (73%) had a pain syndrome; - Of the 29 with pain, 59% had a central pain, 24% radicular pain, 7% central & mechanical, 7% central & border zone pain, 3% border zone pain | Outcome Measures; - a test to compare demographic data, neurological levels of injury, and degrees of completeness of injury with the data about types and characteristics of pain; - VAS and Latinen test used for quantification of pain; Findings:; - greater the time since injury, the more likely to have chronic pain; - 21% paresthetic pain (VAS score 0-2), 62% intermediate pain (VAS score 3-6), 17% strong pain (VAS score 8-10); Article published in Croatian
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Authors use a modified classification according to Donovan-Dimitrijevic with a neurophysiological concept of pain. Five categories of pain are provided (1) Central pain described as constant, burning, pins and needles above the lesion; (2) Radicular pain described as stabbing, burning in waves, starting immediately after injury, lessening with activity; (3) Border zone pain starts weeks or months postinjury, provoked by touch, stabbing pain; (4) Mechanical pain described as dull, deep visceral pain starting at various times after injury, exaggerated by activity, relieved by rest; (5) Psychogenic pain is described as persistent chronic pain, resistant to treatment, with an unclear etiology, resulting in dysfunction; (6) Visceral pain is described as a constant, burning starting weeks or months after injury, with no precise location.

Evidence Table 4.3: Characteristics of Studies Addressing the Prevalence of and Factors Associated With CNP(con't.)

Author | Study Design/Quality | Patient Description | Outcome Measures & Findings
Author: Davidoff 1987a, b Country: USA Setting: Rehab Center Refman ID: 287, 288 | n=19 Compared to 147 patients in database Study design: Retrospective validation study Eligibility criteria: Explicit Response rate: 100% Length of study: N/A Reliability/validity of outcome measures: NR | Gender: 90% male Age: mean 36.6 y, min 25 y - max 69 y Level of injury: 16% tetraplegic; 85%paraplegic Completeness of injury: 26% complete; 74% incomplete Cause of injury: 11% MVA; 21% falls; 5% sports; 53% GSW; 11% other Time since injury: NC Onset of pain: < 1y post SCI Duration of pain: mean 46.8 m (10.2) Pain description: burning, cutting, cruel, nagging, radiating, tight | Outcomes: McGill Pain Questionnaire Number of Words Chosen (NWC) Pain Rating Index (PRI) and components Sternbach Pain Index (SPI) (day and week) Zung Pain and Distress Scale (PAD) Findings:; - Most described CNP as "cutting," "burning," "piercing," "radiating," and "tight," involved lower extremities and felt internally; - All measures equal or greater in severity in CNP patients versus other pain syndromes; - No relation between pain scale scores and symptom duration; Correlations between:; - NWC and PRI-T (p<0.001); - PRI-A and PRI-T (p<0.01); - PRI-A and NWC (p<0.05); - SPI-day and SPI-week (p<0.001); - PAD and NWC (p<0.05); CNP patients more likely to be:; - paraplegic than quadriplegic (p<0.01); - incomplete sensory (73.7 vs. 51.4%, p<0.05); - gunshot wound (52.6% vs. 15.7%, p<0.01); CNP patients less likely to be:; - surgically stabilized (33.6% vs. 66.4%, p<0.01); Comments: population is part of a larger RCT - results taken from Davidoff 87. Also see Table 5.1.10
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Diffuse burning dysesthetic sensations distal to the level of spinal injury

Evidence Table 4.3: Characteristics of Studies Addressing the Prevalence of and Factors Associated With CNP(con't.)

Author | Study Design/Quality | Patient Description | Prevalence | Outcome Measures & Findings
Author: Demirel, 1998 Country: Turkey Setting: Istanbul PM&R centre RefMan ID: 296 | Purpose: To investigate the prevalence and characteristics of SCI-related pain n=47 eligible Study Design: Case series Sampling frame: PM&R Centre; denominator unknown Eligibility Criteria: Not Stated Response rate: NR Length of study: 1 w Reliability/validity of outcomes measures: NR | Gender: 61.7% male Age: min 15 to max 67 y; mean 31.4 y (10.7) Level of injury: 77% paraplegic, 23% tetraplegic, C1-C7 23%, T2-T6 14%, T7 - L2 59%, below L2 4% Completeness of injury: 32% complete (24% paraplegic), 68% incomplete (53% paraplegic) Cause of injury: 51% MVA, 24% falls, 10% sports, 11% GSW, 4% other Time since injury: 18 w, min 8 w - max 120 w Onset of pain: 7% immediate onset; 24% within 1 m; 28% within 3 m; 41% within 6 m (of the 29 reporting pain) Duration of pain: NR Pain description: not described | 62% of sample reported pain 61% of patients experienced pain of moderate to severe intensity Approximately 28% had diffuse pain and 49% had segmental pain | Outcome measures:; - VAS assessed 3 times daily for 7 d; Findings:; - patients reporting pain were older than those without pain (median 41y versus 23 y; p<.05); - incidence of pain greater in patients with incomplete lesions (values not extractable; p<0.05); Article published in Turkish
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Fenollosa, 1993 Country: Spain Setting: Community RefMan ID: 84 | Purpose: To assess the prevalence of chronic pain in people with SCI and treatment characteristics n= 95/145 eligible Study design: postal survey Sampling frame: All members of the national association of SCI living in Valencia, Spain Eligibility criteria: Not explicit Response rate: 202/380 (53.2%); 145/202 questionnaires judged acceptable; final response rate = 145/380 (38.2%) Length of study: Single evaluation Reliability/validity of outcomes measures: NR | Of the 95 patients reporting pain lasting more than 6 months: Gender: 80% male (76/95) Age: NE; mean = 37 y for entire group of 145 Level of injury: NE; 26.2% cervical; 15.8% upper thoracic; 46.2% lower thoracic;11.7% lumbar for entire group of 145 Completeness of injury: NE; 58% complete; 32% incomplete for entire group of 145 Cause of injury: NR Time since injury: NE Onset of pain: NR Duration of pain: 95/145 (66%) more than 6 m Area of Body Affected: NR Temporal properties: continuous (52%) Pain description: burning; deafferentation pain; other (numbness, "like electricity") | Prevalence: 65.5% chronic pain Of these:; - 52% deafferentation pain; - 32% poorly defined; - 9% "electric" pain; - 7% "pressure" | Outcome measures:; - Visual analogue scale; - Lattinen scale; Findings:; - No relationship between gender, type of lesions, or etiology of trauma to pain prevalence; - pain more frequent in cervical and lumbar lesions; those > 50 y; and in patients with spasticity; Also see Table 5.1.3.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Jung, 1990 Country: USA Setting: community, rehab hospital Refman ID: 1480 | Purpose: To investigate the prevalence and characteristics of SCI-related pain n = 37/37 eligible Study Design: Case series, mail survey Sampling frame: recruited through chapters of a national organization and through a rehab hospital; denominator unknown Eligibility Criteria: Not Stated Response rate: NR Length of study: 1 survey Reliability/validity of outcomes measures: Yes, MPQ, CSQ | Gender: 70% male Age: mean 41.8 y (13.7) Level of injury: 46% cervical, 41% thoracic; 14% lumbar Completeness of injury: 27% complete, 73% incomplete Cause of injury: 38% MVA, 16% falls, 19% sports, 8% GSW, 19% other Time since injury: 111.3 m (103.92); min 2 m to max 474 m Onset of pain: 7% immediate onset; 24% within 1 m; 28% within 3 m; 41% within 6 m (of the 29 reporting pain) Duration of pain: NR Pain description: not described | all patients participating reported pain (inclusion criteria) 36% were not on any drugs for their pain | Outcome measures:; - MPQ - PRI, NWC, PPI; - Coping Strategies Questionnaire (CSQ); Findings:; - patients reporting pain were older than those without pain (median 41 y versus 23 y; p<.05); - incidence of pain greater in patients with incomplete lesions (values not extractable; p<0.05); - pain coping strategies found to be important predictors of pain after SCI; - no relationship between pain and time from injury was shown
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Kennedy, 1997 Country: UK Setting: Tertiary Care Refman ID: 339 | Purpose: To assess the prevalence of chronic pain after SCI, the relationships between 1) acute and chronic pain and 2) pain and psychological well-being n= 76/115 eligible Study Design: Prospective Sampling frame: SCI Center; consecutive admissions Eligibility criteria: Not explicit Response rate: 66% at 6 w; 39% at 1 y Length of study: 1 y for 59% of the participants Reliability/validity of outcome measures: NR | Gender: 76% male at 6 w; 85% male at 1 y post hospital discharge Age: min 16 y to max 65 y Level of injury: 32% tetraplegic, 68% paraplegic at 6 w; 59% tetraplegic, 41% paraplegic at 1 y post hospital discharge Completeness of injury: NR Cause of injury: NR Time since injury: within 3 m post SCI Onset of pain: 80% at 6 w; 63% at 1 y Duration of pain: NR Temporal properties: worsening for some - at 6 w 24% severe pain; at 1 y 41% severe pain Pain description: Not described | Prevalence:; - 80% pain at 6w (24% severe); - 63% pain at 1y (41% severe) | Outcome measures:; - Visual analogue scale - 6 point measure of pain intensity; - FIM; - Beck Depression Inventory; - State Anxiety Inventory; - COPE; Findings:; - Presence of pain at 6 w was associated with the presence of pain at 1 y (p not reported); - Anxiety & depression was associated with increased pain intensity over time (p<0.05); - Severe pain at 1 y was more likely in paraplegics than tetraplegics (p not reported)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Levi 1995 a,b,c; 1996; Westgren 1998 Country: Sweden Setting: Community Refman ID: 054 | Purpose: To assess the medical problems, psychosocial issues, and financial issues (and associated factors) in an SCI population n= 353/379 eligible Study design: Prospective interview Sampling frame: Catchment area of Stockholm Regional SCI Centre Eligibility criteria: Explicit Response rate: 93% Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: 81% male Age: mean 42 y (14) Level of injury: 42% cervical; 36% thoracic; 15% lumbar; 1% sacral; unknown 6% Completeness of injury: 39% complete; 60% incomplete; 1% no information Cause of injury: 46% MVA/transport accidents; 37% falls; 8% other accidents; 4% intentional self-harm; 3% assault; 1% operations of war; 1% undetermined or sequelae of external causes of morbidity and mortality Time since injury: 11 y Onset of pain: post SCI Duration of pain: NR Pain description: see definition | Prevalence measured; - 167/353 (47.3%) CNP; - 107/353 (30.3%) CNP only; - 60/353 (17.0%) CNP and other pain | Findings:; - Increased age at injury associated with increased prevalence of CNP (age 3-20: 32%; age 21-40: 49%; age 41-77: 61%) (p=0.004); - Prevalence equal for men and women (p=0.7232); - Duration of injury not associated with prevalence of CNP (p=0.4426); - Level and extent of injury not associated with prevalence of CNP (p=0.7944); - Adjusted odds ratio for CNP presence in SCI versus community controls = 3.72 (p<0.0001)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Pain with burning, stabbing, or sharp shooting quality segmentally at, or diffusely below, the neurological level of lesion
Author: Nepomuceno 1979; Richards 1980 Country: USA Setting: Tertiary care Refman ID: 332, 367 | Purpose: To characterize chronic pain in patients with SCI; to assess factors related to pain n= 200/356 Study Design: Survey Sampling frame: Patients discharged >1 y previously from a regional SCI center Eligibility Criteria: not explicit Response rate: 200/356 (56%) Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: 81% male Age: mean = 33 y Ethnicity: 77% white, 23% black Level of injury: 45% cervical; 48% thoracic; 8% lumbar (at or below L2) Completeness of injury: NR Cause of injury: NR Surgical Stabilization: NR Time since injury: > 1 y post SCI Onset of pain: within 6 m 65%; 7-48 m 25%; at least 5 y 4%; could not recall 6% Duration of pain: at least 12 m Pain description: burning, cramping, stinging, numbness, pulling, pressing | Prevalence: measured at least 1 y post injury: Pain or discomfort:; - All levels: 80%; - Cervical/high thoracic: 75%; - Low thoracic: 89%; Of those with pain: 25% extreme or severe discomfort | Outcome Measures:; - MMPI subscales; - Pain questionnaire; Predictors:; - Increased pain associated with older age, higher verbal intelligence, increased anxiety, & a more negative psychosocial situation (p< 0.01); - Pain interfering with ADLs associated with older age, higher intelligence, more depression, greater level of distress, more negative psychosocial situation (p< 0.0001)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Authors did not define neuropathic pain but used the term "spinal cord injury pain."
Author: New, 1997 Country: Australia Setting: Rehab Center Refman ID: 023 | Purpose: To assess the type and severity of acute pain in SCI and at > 1 y follow-up n = 24 Study Design: Multiple interviews during hospitalization; telephone interviews 13-16 months post-discharge Sampling frame: Rehabilitation center; consecutive admissions Eligibility Criteria: Not stated Response rate: 24/24 at admission; 24/24 at discharge; 22/24 at >1 y f/u Length of Study: 13 m - 16 m Reliability/validity of outcome measures: NR | Gender: 92% male Age: 41.2 y; min 15, max 76 y Level of injury: 54% tetraplegia; 34% conus or cauda lesion Completeness of injury: 37% complete; 63% incomplete (ASIA B, C, or D) Cause of injury: 79% "trauma" Time since injury: 31 d; min 12 d - max 76 d from acute ward admission to transfer to rehabilitation center Onset of pain: NR Duration of pain: NR Pain description: see definition | Prevalence: Neuropathic pain:; - approx. 67% at admission; - approx. 55% at discharge; - approx. 70% at followup | Outcome Measures:; - Visual Analog Scale; Findings:; - Overall pain intensity decreased between admission and discharge, but increased to near admission levels when assessed at 13-16 month follow-up. The reasons for this increase were not apparent.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Burning, stabbing, pins and needles, or numbness located at or distal to the level of paralysis
Author: Richards 1990 Country: USA Setting: Rehabilitation Facility Refman ID: 739 | Purpose: To explore the impact of bullet or bullet fragment removal on subsequent pain after SCI due to gunshot would (GSW) n= 56 (3 groups: 12 patients with bullet removed; 12 patients with bullet present, 28 patients with nongunshot wound (NGSW) Study design: Prospective, Interview Sampling frame: Spain Rehabilitation Center; consecutive admissions Eligibility criteria: Explicit Response rate: 100% Length of study: 1 y Reliability/validity of outcome measures: Reliability of pain classification: agreement between two raters 92% | Gender: "distribution equivalent across all groups" Age: NR Level of injury: NR Completeness of injury: NR Cause of injury: 43% GSW; 57% other Time since injury: NR Onset of pain: NR Duration of pain: NR Pain description: burning, stinging | Prevalence: Bullet present:; - Traumatic pain: 1/12; - Root pain: 4/12; - Deafferentation pain: 7/12; Bullet removed:; - Traumatic pain: 0/12; - Root pain: 1/12; - Deafferentation pain: 11/12 | Outcome Measures:; - McGill Pain Questionnaire (MPQ):; - Scale of pain behavior (0-5); - Numerical scale: 0-10; Findings: All results GSW vs. NGSW MPQ: Sensory: 8.4 (1.3) vs. 0.8 (0.4) Affective: 1.3 (0.3) vs. 0 Evaluative: 1.0 (0.2) vs. 0 Miscellaneous: 2.3 (0.4) vs. 0 NWC: 5.4 (0.8) vs. 0.4 (0.2) PPI: 1.1 (0.2) vs. 0.2 (0.1) Pain behavior: 1.2 (0.2) vs. 0.1 (0.1) Numerical scale: 2.7 (0.4) vs. 0.4 (0.2) Predictors: Patients were matched for neurological level and extent of injury (between bullet-wound groups and with a nonbullet-wound group). Results were adjusted for race and education.; - GSW resulted in more neuropathic pain than non-GSW; - Removal of bullet did not reduce pain severity either early or 1 y postadmission
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Authors cite Donovan 1983.
Author: Rintala, 1998 Country: USA Setting: Interviewed in their homes Refman ID: 337 | Purpose: To assess prevalence, severity, and correlates of chronic pain. n= 77 eligible Sampling frame: Random sample derived from 661 SCI patients in 13 counties recruited by media advertising Study Design: survey, interviews Eligibility criteria: explicit Response rate: 77% Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: 100% male Age: mean 41.1 y (12.3) Ethnicity: 64% white; 20% African-American; 13% Hispanic; 4% other Level and completeness of injury: Complete: 67 (87%), 34 tetraplegic; 33 paraplegic - ASIA levels ABC Incomplete: 10 (13%), combined tetraplegic & paraplegic - ASIA level D Cause of injury: 47% MVA; 8% falls; 18% sports; 18% violence; 9% other Time since injury: mean 13.3 y (8.6) Onset/Duration of pain: NR Area of Body Affected: lower body 47%; upper extremities 18%; back 18%; trunk 10%; other 8% Temporal properties: rhythmic 53%; continuous 30%; brief 5%; mixed 12% Siddall Classification: musculoskeletal 51%; visceral 8%; neuropathic 10% (at level - central); Other 32% (segmental, psychogenic) Pain definition: chronic pain lasting or recurring over at least 6 m | Prevalence:; - 75% chronic pain; - 10% CNP; - 32% segmental pain | Outcome Measures:; - McGill Pain Questionnaire; - Zung Pain and Distress Scale; - Binary (presence or absence of chronic pain); - Sternbach Pain Intensity Scale; - Number of chronic pain components; - Classification and description of pain components; Factors Considered: Level of injury and completeness of injury Findings:; - Chronic pain is associated with more depressive symptoms (p<0.05), perceived stress (p<0.05), & poorer self-assessed health (p<0.01); - Greater pain intensity is associated with less paralytic impairment (p<0.05), violent etiology (p<0.05), & more perceived stress (p<0.05); - Upper extremity pain was associated with lower FIM scores (p<0.02) & lower mobility scores (p<0.03)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Authors used Donovan et al. (1982) classification system.
Author: Rose, 1988 Country: UK Setting: community Refman ID: 360 | Purpose: To determine the incidence of chronic pain after SCI n = 615 Study design: Mail survey Sampling frame: Members of Spinal Injuries Association in Britain Eligibility criteria: explicit Response rate: 885/1091 (81%) Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: 75% male Age: median "fourth decade"; min 15 y - max 91 y Level of injury: 33% cervical; 16% high thoracic; 42% low thoracic; 4% L2 or below Completeness of injury: 58% incomplete Cause of injury: NR Time since injury: majority of respondents > 2 y (mode 4 y) Onset of pain: NR Duration of pain: NR Pain description: NR | Prevalence: At some time after injury:; - 615/885 (69%) reported pain at or below the level of the lesion; Of the 615 with pain:; - 18% reported pain in a root distribution; - 43% reported constant pain; - 24% reported daily pain; - 49% severe pain; - 21% mild - moderate pain | Outcome measures: Mailed questionnaire Findings: Authors also reported that 16% stopped work due to pain and 19% stopped social activities due to pain.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Projected pain appears at areas distal to the level of the lesion, starts early, is not related to motion or position and may be felt in any part of the body. Triggered pain is felt in the paraplegic areas, provoked by a stimulus in different skin areas known as trigger zones.
Author: Siddall 1999; Sved 1997 Country: Australia Setting: Rehabilitation Facility Refman ID: 003, 030 | Purpose: To assess the prevalence and predictors of different types of chronic pain; and the relationship of surgery to pain prevalence n= 100/103 eligible Study design: Prospective, longitudinal interviews Sampling frame: Consecutive admissions to SCI unit Eligibility criteria: explicit Response rate: varied at each data collection point from 56 to 86% Length of study: 26 w to 52w Reliability/validity of outcome measures: NR | Gender: 83% male Age: mean 38 y (17) Level of injury: 51% cervical; 25% thoracic; 23% lumbar; 1% sacral Completeness of injury: 36% complete; 64% incomplete Cause of injury: 42% MVA; 24% falls; 18% sports; 16% other Time since injury: within 12 w post SCI Onset of pain: from 2 w to 26 w post SCI Duration of pain: NR Pain description: allodynia, burning, electric, sharp, shooting, stabbing | Prevalence measured at 2,4,8,13,26,52 w following SCI. Pain of any type: at 2 w: 91% at 26 w: 64% (21% of these rated pain as severe) Neuropathic at level pain: at 2 w: 38% at 26 w: 38% at 52 w: 28% Neuropathic below level: at 2 w: 14% at 26 w: 19% at 52 w: 50% | Outcome measures:; - Description of pain severity: none, mild, moderate, severe, excruciating; Findings: Level of injury:; - Allodynia: cervical 39% vs. thoracic 8%, p=0.01; - Neuropathic at level: NS; Completeness of injury:; - Allodynia: incomplete injuries 33% vs. complete 11%, p=0.016; - Neuropathic at or below level: NS; Type of cord injury:; - Allodynia: central cord syndromes 50% vs. other cord lesions 25%, p=0.024; - Neuropathic below level pain: NS; - Neuropathic at level: pain less in anterior cord syndromes 0% vs. other cord lesions 56%, p=0.008; Spine stabilization surgery:; - Surgery associated with increased prevalence of musculoskeletal pain at 2 w but not at other times; - No relationship between surgery and neuropathic pain at or below lesion at any time to 52 w
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Neuropathic at level: sharp, shooting, stabbing, electric, burning pain in the dermatomes at or just above the level of the lesion. Neuropathic below level: burning, stabbing, shooting pain located diffusely below the level of the lesion.
Author: Stensman, 1994 Country: Sweden Setting: Refman ID: 512 | Purpose: To examine the adjustment of persons with complete, irreversible traumatic spinal cord injury 5 years after the injury and their self-reported quality of life n = 17 Study design: interview Sampling frame: Eligibility criteria: explicit Response rate: Length of study: 5 y Reliability/validity of outcome measures: NR | Gender: 88% male Age: mean 29.5 y, min 18 y to max 55 y Level of injury: 59% tetraplegic, 41% paraplegic Completeness of injury: NR Cause of injury: 53% MVA, 24% falls, 18% sports, 6% work related Time since injury: NE Onset of pain: NE Duration of pain: NR Pain description: moderate, severe | Prevalence: 41% subjects reported complications and severe pain | Outcome Measures: semistructured, personal interviews at 6 m; 1, 2, 3, 4, and 5 y postinjury; collecting information on QOL, ADL, medical, psychological and social variables. Findings: Of those with pain:; - 2/7 had good coping scores; - 2/7 reported good QOL
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Stormer, 1997 Country: Germany Setting: Tertiary Care, multicenter Refman ID: 033 | Purpose: To describe and document chronic pain and distressing dysesthesia n= 591 SCI/901 Sampling frame: Study design: Case series (retrospective) Eligibility criteria: Not explicit Response rate: Length of study: N/A Reliability/validity of outcome measures: NR | Gender: 74% male Age: mean 42 y Level of injury: tetraplegia 42%, paraplegia 58% Completeness of injury: NR Cause of injury: NR Time since injury: 58% within 1 y Onset of pain: 34% immediately, 58% within 1 y, 13% > 10 y after injury Duration of pain: NR Pain description: burning, dysesthesia, stabbing, tingling, hardening, cramping, pulling, tearing | Prevalence: 66% (of 901) 50% pain alone, 11% painful dysesthesia, 5% distressing dysesthesia with no pain 75% of pain reported as same or severe distress 41% of 66% had pain/dysesthesias at several sites or of several types | Outcome Measures: pain diary, standardized interviews based on a pain questionnaire and a psychological questionnaire Findings: Coping:; - coping moderately or not well +ve .001; - burdened by paralysis +ve .001; - depression +ve .0001; - no correlations were reported
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Deafferentation pain means the burning infralesional pain or so-called phantom pain characteristic of SCI patients, the causation of which is attributed to the lesion of the spinal cord, medullary cord, and the cauda equina.
Author: Summers 1991 Country: USA Setting: Tertiary care Refman ID: 357 | Purpose: To clarify the relative importance of psychosocial versus physiological factors in chronic pain. n= 54/72 eligible Study Design: Prospective, interview and self-reported questionnaires Sampling frame: SCI Clinic at VA Medical Center; consecutive patients Eligibility Criteria: not explicit Response rate: 54/72 (75%) completed questionnaires Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: 85.2% male Age: mean 40.6 y (11.8) Level of injury: 35% tetraplegic, 65% paraplegic Time since injury: > 1 y post SCI Onset of pain: mean 12 y (8.0) Duration of pain: mean 8.2 y (6.2) Completeness of injury: NR Cause of injury: NR Pain description: NR | Prevalence: Chronic pain: 44/54 (81.5%) Central pain was not specifically reported. Reliability/validity of outcomes measures: Authors report adequate validity/reliability for: Multidimensional pain inventory (MPI), Beck Depression Inventory (BDI), Profile of Mood States (POMS), State-Trait Anxiety Inventory (STAI); none of these evaluations were specifically for neuropathic pain in SCI. Authors report acceptable test-retest reliability for the Pain Experience Scale (PES); this was not performed in patients with neuropathic pain and SCI. | Outcome Measures:; - Likert type - 7pt - 2 scales; - MPI; - BDI; - POMS; - STAI; - Acceptance of Disability Scale (ADS); - PES; - Spinal Cord Injury Interference Scale (SCIIS); Findings:; - Results were adjusted for gender and veteran status; - Greater pain severity was associated with patients who were more angry, were less accepting of disability, perceived significant other expressing punishing responses; - Pain was associated with emotional distress over and above SCI itself; - Level of lesion (p=0.977), completeness (p=0.941), surgical intervention (0.461), and veteran status were not associated with pain severity
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Svendsen, 1993 Country: Denmark Setting: 2 Tertiary Care centers Refman ID: 346 | Purpose: to document the severity and course of chronic pain following SCI n = 63 Study design: Community survey Sampling frame: Eligibility criteria: NE Response Rate: Length of study: NA Reliability/validity of outcome measures: NR | Gender: 73% male Age: mean 36 y, min 18 y - max 75 y Level of injury: 33% tetraplegic, 66% paraplegia Completeness of injury: Frankel classification 40% A, 22% B, 13% C, 24% D, 2% E Cause of injury: 52% MVA, 48% unspecified Time since injury: NC Onset of pain: median 4 m Duration of pain: median 3 y Pain description: stabbing, tingling | Prevalence:; - 92% of respondents have daily pain; - 56% graded their pain as strong or unbearable; - pain worsened in 43% and improved in 16% since its start | Outcome Measures: Findings:; - pain seriously affects daily living in 38%; - sleep disturbed in 48%; Article published in Danish.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Turner, 1999 Country: USA Setting: Community Refman ID: 333 | Purpose: To investigate the prevalence of chronic pain problems in SCI and their severity, characteristics, and associated factors n= 164/171 SCI Study design: Mailed survey Sampling frame: Individuals on a mailing list for an SCI newsletter Eligibility criteria: Explicit Response rate: 171/464 total (37%) Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: 77% male Age: mean 43.3 y (12.7) Ethnicity: 88% white; 4% Native-American; 2% African-American; 3% Hispanic; 2% Asian Level of injury: 47% cervical; 16% high thoracic; 34% low thoracic; 3% L2 or below Completeness of injury: 43% complete; 44% not complete; 13% did not know Cause of injury: MVA 43%; fall 15%; sports 10%; GSW 4%; Other 3% Time since injury: mean 12.1 y (9.5) Onset of pain: (n=164) 1 w post injury 41%; 1-4 w post injury 19%; 1-3 m post injury 23% Duration of pain: NR Pain description: burning, lancinating, pressing, tingling | Of 164 respondents:; - 70% reported persistent bothersome pain after hospital rehabilitation; - 81% reported a current pain problem (and 40% of these reported more than 3 pain problems); - 35% reported pain below level of injury; 29% reported pain at level of injury; 22% reported pain above level of injury; - 75% reported current unpleasant but not painful sensations | Outcome measures: Questionnaire that included:; - McGill Pain Questionnaire (short form); - Pain intensity; Findings:; - MPQ SF; Affective scale: 3.00 (3.16, range 0-12) Sensory scale: 11.31 (6.96, range 0-29) Total: 14.31 (9.48, range 0-41); - Pain intensity:; Characteristic pain: 53.16 (23.37, range 0 -100); - Authors also report pain interference with social activities or work; disability score; and number of days kept from usual activities due to pain.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Projected pain appears at areas distal to the level of the lesion, starts early, is not related to motion or position, and may be felt in any part of the body. Triggered pain is felt in the paraplegic areas, provoked by a stimulus in different skin areas known as trigger zones.
Author: Waisbrod, 1987 Country: USA Setting: VA Medical Center Refman ID: 752 | Purpose: To classify chronic pain in paraplegics n=27 Study design: Prospective, patients completed a standard pain questionnaire Sampling frame: NR Eligibility criteria: Not explicit Response rate: 100% Length of study: NR Reliability/validity of outcome measures: NR | Gender: NR Age: NR Level of injury: 70% above L1; 30% below L1 - unclear if these patients had additional cauda equina lesions Completeness of injury: NR Cause of injury: NR Time since injury: NR Onset of pain: NR Duration of pain: NR Pain description: burning, lancinating, pressing, tingling | Prevalence: "Projected pain" in 100% Type of pain in those with lesions above L1:; - Burning: 42%; - Tingling: 37%; - Dragging: 32%; - Cutting: 21%; - Drilling: 21%; - Tearing: 21%; - Pounding: 16%; - Pressing: 5% | Outcome measures: Standard pain questionnaire (clinic-specific) Findings:; - Projected pain more frequent in the lower limbs for lesions below L1; - 33% of patients with lesion above L1 had projected pain in their fingers; - 63% patients with lesions above L1 had "trigger zones" that provoked pain elsewhere; none of the patients with lesions below L1 had trigger zones
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Projected pain appears at areas distal to the level of the lesion, starts early, is not related to motion or position, and may be felt in any part of the body. Triggered pain is felt in the paraplegic areas, provoked by a stimulus in different skin areas known as trigger zones.
Author: Wang, 1996 Country: UK Setting: Sample from patients discharged from one rehab hospital Refman ID: 1440 | Purpose: To identify chronic spinal cord pathology by magnetic resonance imaging n=153/241 Study design: Prospective Sampling frame: "Comprehensively evaluated" patients from a dataset of 832 patients (source and denominator not reported). Selected by home address. Eligibility criteria: Not explicit Response rate: 153/241(63.5%) Length of study: Single evaluation Reliability/validity of outcome measures: NR Clinical evaluator was blind to results of MRI | Gender: 82% male Age: mean 54 y, min 37 y, max 89 y Level of injury: 38% cervical; 29% thoracic; 33% thoracolumbar Completeness of injury: NR Cause of injury: NR Time since injury: 29 y, min 21 y to max 48 y Onset of pain: NR Duration of pain: NR Pain description: neurogenic pain | Of 153 respondents: 14% reported "Neurogenic" pain | Outcome measures:; - MRI spine; Findings:; - Proportion of patients with each MRI finding that had CNP:; - Proportion of patients with syrinx extension that had CNP, by direction of extension: Rostral only: 0/5 (0%) Caudal only: 3/5 (60%) Rostral and caudal: 2/4 (50%) Within bounds of Vertebral injury: 1/1 (100%)
  Extended atrophy: (16.8%) | 16/95
  Malacia: (15.3%) | 13/85
  Syrinx: | 6/32 (18.8%)
  Cyst: | 3/14 (21.4%)
  Disruption: | 0/6 (0%)
  Tethering: | 1/6 (16.7%)
  No pathology | 0/12 (0%)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Woolsey, 1986 Country: USA Setting: Rehabilitation Facility Refman ID: 718 | Purpose: To determine the incidence, varieties, causes, and management of chronic pain in SCI n = 100 randomly selected patients Study design: Prospective, Interview Sampling frame: SCI patients at rehabilitation center. Denominator not reported. Eligibility criteria: Explicit Response rate: NR Length of study: Single evaluation Reliability/validity of outcome measures: NR | Gender: NR Age: NR Level of injury: quadriplegia 48%; paraplegia 52% Completeness of injury: NR Cause of injury: NR Time since injury: at least 1 y Onset of pain: NR Duration of pain: NR Pain description: NC | Prevalence: Burning pain below level of injury: 38 Pain at fracture site: 24 Radicular pain: 12 Abdominal pain: 2 Muscular pain: 2 "Chronic pain" reported in 67%. Severe pain:; - Paraplegic 15/52 (29%); - Quadriplegic 3/48 (6%); Mild-moderate pain:; - Paraplegic 26/52 (50%); - Quadriplegic 23/48 (48%) | Outcome Measures: Pain interview mild: aware of pain but did not require any modification in behavior or medication; moderate: annoying to the extent that the patient would modify their behavior and would try and alleviate it with medication; and severe: difficult to bear, patient was unable to divert attention from it, was unable to pursue daily activities, and sought immediate relief)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Authors cite other reports; burning pain in SCI patients is considered to be a variety of deafferentation pain.

Supplemental Evidence Table 4.3: Other Studies Addressing the Prevalence of and Factors Associated with Neuropathic Pain: Shoulder Hand Syndrome (SHS)

Author | Study Design/Quality | Patient Description | Outcome Measures and Findings
Author: Aisen, 1995 Country: USA Setting: Tertiary Care Refman ID: 912 | Design: case control 14 subjects; 7 consecutive cervical spinal cord injury, 7 patients with similar injuries but no SHS Eligibility Criteria: NR Followup: NA Reliability/validity of outcome measures: NA Length of study: NA | Gender: 78% male Age: mean 48 y, min 17 y - max 70 y Level of injury: 100% cervical Completeness of injury: 6/14 complete, 8/14 incomplete Cause of injury: NR Time since injury: mean 2.4 y, min 2 m to max 12 y Duration of pain: NR Onset of pain: NR Pain description: SHS diagnosed on presence of diffuse upper extremity pain with a burning quality, edema, osteoporosis evident on radiographs and dystrophic skin and nail changes (Kozin et al, 1981) | Outcome measures: SSR recorded on the arm with greater pain; measurements of latency and amplitude were obtained from analysis of individual traces Findings:; - mean amplitude more than 3 times greater in patients with SHS (p=0.0252); - in six patients with SHS, symptoms improved following steroid treatment, amplitude falling significantly (p=0.0491); Comments:; - clarification still required of increased outflow and upregulation of receptors
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 4.3: Other Studies Addressing the Prevalence of and Factors Associated with Neuropathic Pain: Post-traumatic Syringomeylia

Author | Study Design/Quality | Patient Description | Prevalence/Incidence | Outcome Measures & Findings
Author: Gellad, 1988 Country: USA Setting: Tertiary care Refman ID: 684 | n= 11 SCI /11 Study design: Case series Eligibility criteria: Length of study: 24 m Reliability/validity of outcome measures: NR | Gender: 73% male Age: mean 26 y, min 18 y, max 33 y Level of injury: 11 cervical Completeness of injury: 11 complete Cause of injury: 11 GSW Time since injury: 6.6 w mean Onset of pain: NR Duration of pain: NR Pain description: burning, dysesthesia | Prevalence: posttraumatic syringomyelia is a rare but well-documented complication of blunt spinal injury, usually occurring 2 to 20 y after injury Procedure: Myelography 10 mL of metrizamide, concentration of 300 mg iodine/mL | Outcome measures: clinical, radiologic and surgical findings Adverse effects: NR Findings:; - surgical findings correlated with radiographic findings 100% of the time; - all patients had relief of the burning and dysesthetic pain immediately after surgery; - all have remained free of symptoms up to 24 months followup
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Kramer, 1997 Country: USA Setting: Tertiary care Refman ID: 105 | n= 21 subjects; 17 available for telephone followup Study design: Case series Eligibility criteria: explicit Followup: 80-100% complete Reliability/validity of outcome measures: NR Length of study: chart review, single telephone interview | Gender: 81% male Age: mean 28.4 y, min 16 y - max 67 y (at time of injury - NE for followup) Level of injury: 7 cervical, 14 thoracic Completeness of injury: complete 16; incomplete 4 Cause of injury: 6 MVA; 6 Falls; 9 GSW Time since injury: NR Onset of pain: mean 26.2 m, min 1 m, max 23 y; within 1 y for 65% of patients, within 5 y for 19 patients Duration of pain: NE Pain description: dysesthesia, hyperesthesia, paresthesias, dysesthesia | Prevalence: information collected represents new patient reports of symptoms and physical findings (different from those of the original neurologic injury) Most common symptoms were radicular pain (11 patients); spasticity (10 patients) and sensory loss (8 patients) | Outcome measures: personal telephone interview Findings:; - radicular pain and sensory disturbances response most predictable to surgical intervention; spasticity responds least favorably; - 6/8 subjects having syrinomotomy report lasting relief of myelopathic symptoms
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Milhorat 1996 Country: USA Setting: Tertiary Care Refman ID: 046 | n= 15/137 patients with syringomyelia Study design: Retrospective case series Followup: NR Eligibility criteria: NR Reliability/validity of outcome measures: NR Length of study: NC | Gender: NR Age: NR Level of injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Onset of pain: NR Duration of pain: NR Pain description: burning, causalgia, dysesthesia, hyperesthesia, pins and needles, pressure | Prevalence: NC | Outcome measures: Neurological examination MRI of spinal cord Findings:; - 51/137 (37.2%) pts with syringomyelia had burning pain and hyperesthesia. Unclear how many had SCI; - 15 SCI/155 pts had dorsolateral quadrant, eccentric cavitation pattern on MRI
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Dysesthetic pain was described as an intensely disturbing phenomenon characterized by a variety of sensations, including burning, pricking, stretching, and pressure of the skin.
Author: Shannon, 1981 Country: United Kingdom Setting: Tertiary Care Refman ID: 202 | n= 13 SCI /20 with syringomyelia Study design: Case series (retrospective) Eligibility criteria: Not explicit Reliability/validity of outcome measures: NR Length of study: N/A | Gender: 85% male Age: mean 40.8 y Level of injury: Tetraplegia (1), Paraplegia (12) Completeness of injury: complete (6); incomplete (7) Cause of injury: MVA (7); Falls (2); GSW (2); Sports (1); Industrial (1) Time since injury: 12 y Onset of pain: NR Duration of pain: NE; min 6 m, max 6 y; <18 m in 5 cases Pain description: dysesthesia, hyperesthesia | Prevalence: NC | Outcome measures: Clinical examination, Radiological examination Findings: Authors reported that pts who initially sustained incomplete sensory motor spinal cord damage had better symptomatic response to surgery than pts with a complete lesion. In 10 pts with severe pain, surgery completely relieved their symptoms.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Vernon, 1982 Country: Israel Setting: Tertiary care Refman ID: 376 | n= 40 patients with pain and syringomyelia Study design: Case series (retrospective) Eligibility criteria: Not explicit Followup: N/A Reliability/validity of outcome measures: NR Length of study: NR | Gender: NR Age: mean (at injury) 24.8 y Level of injury: cervical 15%; thoracic 68%; lumbar 18% Completeness of injury: complete 55%; incomplete 45% Cause of injury: GSW, "violence" Time since injury: mean 13.5 y Onset of pain: 2 m to 18 y Duration of pain: NR Pain description: burning, stabbing, tingling, dull ache | Authors reported that the incidence was "at least 1.6% of traumatic injuries" | Outcome measures: Clinical examination, neuroradiological investigations, or post-mortum examination Findings:; - 40 patients had clinical diagnosis of syringomelia; - 26/40 had diagnosis confirmed by neuroradiological investigations, surgery or postmortum examination; Comments:; - Authors reported that pain was the most common presenting symptom. The most common clinical sign was sensory disturbance.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 4.3: Other Studies Addressing the Prevalence of and Factors Associated with Neuropathic Pain: Reflex Sympathetic Dystrophy Syndrome (RSDS)

Author | Study Design/Quality | Patient Description | Prevalence/Incidence | Outcome Measures and Findings
Author: Cremer, 1989 Country: USA Setting: Tertiary Care Refman ID: 272 | n= 5 SCI Study design: Case reports Eligibility criteria: explicit Reliability/validity of outcome measures: NR Length of study:8 w | Gender: 3 males Age: min 23 y, max 55 y Level of injury: 5 cervical Completeness of injury: 2 complete, 3 incomplete Cause of injury: 1 MVA, 2 GSW, 2 falls Time since injury: NR Onset of pain: 1 m Duration of pain: NR Pain description: burning, dysesthesia, hyperesthesia | Prevalence: RSDS is a less common cause of diffuse upper extremity pain associated with recent SCI than radicular or dysesthetic (CNP) pain - clinical diagnostic criteria has been proposed in by Kozin and associates (1976) | Outcome measures: objective measures obtained before and after treatment - including measurements of distal joint pain, limb volume, and active digit range of motion at baseline and at 8 w Findings: no recurrence of pain noted in 3 of 5 patients after 6 m of followup Conclusions:; - 3 phase technetium bone scan (TPBS) shown to be useful as an adjunct to the diagnosis of RSDS; - early diagnosis and treatment are critical to a successful outcome
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author : Wainapel, 1984 Country : USA Setting : Tertiary Care Refman ID: 375 | n= 2 SCI Study design: Case reports Eligibility criteria: NC Reliability/validity of outcome measures: NR Length of study:1 y, 5 m | Gender: 2 males Age:16 y, 53 y Level of injury: Tetraplegic, temporarily tetraplegic Completeness of injury: both incomplete Cause of injury: Sports injuries Time since injury:1 y, 5 m Onset of pain:21 d, 3 m Duration of pain: < 1 y, 1 m Pain description: sharp, burning | Prevalence: Rarely documented | Outcome measures: patient report, physician observation Findings: Patient #1: at 1 y postinjury, no recurrence of symptoms reported after conservative treatment of whirlpool baths, gentle range of motion, and protection of right hand from unexpected, cutaneous stimulation. Patient #2: treatment not clearly defined; 1 m after onset of symptoms, pain is slightly improved but left hand function still slightly limited. Conclusions: Possible that RSD may be an overlooked cause of unexplained pain complaints in patients with SCI.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 4.3: Other Studies Addressing the Prevalence of and Factors Associated with Neuropathic Pain: Hyperpathia

Author | Study Design/Quality | Patient Description | Prevalence/Incidence | Outcome Measures & Findings
Author: Hopkins, 1973 Country: UK Setting: Tertiary care Refman ID: 8105 | n= 7 SCI Study design: Case series Eligibility criteria: NC Length of study: NR Reliability/validity of outcome measures: NR | Gender: 7 male Age: 52.4 y mean Level of injury: 7 cervical Completeness of injury: NR Cause of injury: MVA (1); Falls (5); Industrial (1) Time since injury: 11.4 w mean Onset of pain: NC Duration of pain: NC Pain description: burning, stinging, hyperalgesia, paresthesia | Prevalence: syndrome of acute central cervical cord injury is more common than previously recognized and can follow relatively minor extension or flexion injuries of the neck | Outcome Measures: clinical observation Findings:; - 6/7 subjects had burning or stinging sensations over the chest or upper limbs - felt to be an important clinical point; - severe pain in shoulders and arms was a major symptom in 6/7 subjects, even those with relatively minor injuries
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 4.3: Other Studies Addressing the Prevalence of and Factors Associated with Neuropathic Pain: Phantom Pain

Author | Study Design/Quality | Patient Description | Outcome Measures & Findings
Author: Paeslack, 1990 Country: Germany Setting: Tertiary care Refman ID: 277 | 2 case reports Eligibility criteria: NR Length of study: NR Reliability/validity of outcome measures: NR | Gender: 2 male Age: 38 y, 49 y Level of injury: 1 paraplegic, 1 tetraplegia Completeness of injury: both 1 complete Cause of injury: both MVA Time since injury: NR Onset of pain: 4 w, 7 w Duration of pain: NR Pain description: burning, icing | Outcome measures: physician observation Findings:; - authors conclude that phantom pain shows a side by side increase with psychosocial phases in the critical stage of the trauma; Article published in German.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN -: No definition provided.

Supplemental Evidence Table 4.3: Other Studies Addressing the Prevalence of and Factors Associated with Neuropathic Pain: Chronic Cyclical Pain

Author | Study Design/Quality | Patient Description | Prevalence/Incidence | Outcome Measures & Findings
Author: Rhein, 1995 Country: France Setting: Tertiary care Refman ID: 442 | n= 6 SCI Study design: Case series Eligibility criteria: explicit Length of study: NA Reliability/validity of outcome measures: Yes; MPQ | Gender: % male NR Age: mean 39 y, min 25 y, max 52 y Level of injury: 5 thoracic, 1 lumbar Completeness of injury: 6 complete Cause of injury: NR Time since injury: mean 4 y Onset of pain: < 1 y Duration of pain: 6 m min Pain description: continuous, stable, constant, | Prevalence: chronic cyclical pain in SCI | Outcome measures: MPQ Findings:; - used the MPQ to compare scores with patients suffering from other pain syndromes, including arthritis, cancer, dental, backache, menstrual; - intensity is comparable to other types of chronic pain; Article published in French.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 4.4: Estimates of Prevalence of CNP in a Community Sample

Author | Study Design | Prevalence | Definition of Neuropathic Pain
Author: Levi 1995 a,b,c; 1996; Westgren 1998 Country: Sweden Refman ID: 54 | n = 353/379 eligible Study design: Prospective interview Sampling frame: Catchment area of Stockholm Regional SCI Centre | 167/353 (47.3%) CNP 107/353 (30.3%) CNP only 60/353 (17.0%) CNP and other pain Increased age at injury associated with increased prevalence of CNP (age 3-20:32%; age 21-40:49%; age 41-77:61%) (p=0.004) Prevalence equal for men and women (p=0.7232) Duration of injury not associated with prevalence of CNP (p=0.4426) Level and extent of injury not associated with prevalence of CNP (p=0.7944) Adjusted odds ratio for CNP presence in SCI versus community controls = 3.72 (p<0.0001) | Pain with burning, stabbing, or sharp shooting quality segmentally at, or diffusely below, the neurological level of lesion
Author: Rintala, 1998 Country: USA Refman ID: 337 | n = 77 eligible Study design: survey and interview Sampling frame: Random sample derived from 661 SCI patients in 13 counties recruited by media advertising | 58/77 chronic pain 8/77 (10.4%) CNP 25/77 (32.4%) segmental pain Chronic pain is associated with more depressive symptoms (p<0.05), perceived stress (p<0.05), & poorer self-assessed health (p<0.01) Greater pain intensity is associated with less paralytic impairment (p<0.05), violent etiology (p<0.05), & more perceived stress (p<0.05) Upper extremity pain was associated with lower FIM scores (p<0.02) & lower mobility scores (p<0.03) | Authors used Donovan et al. (1982) classification system.
Author: Rose, 1988 Country: UK Refman ID: 360 | n = 615 Study design: Mail survey Sampling Frame: Members of Spinal Injuries Association in Britain | At some time after injury:; - 615/885 (69%) reported pain at or below the level of the lesion; - 110/615 (18%) reported pain in a root distribution; - 43% reported constant pain; - 24% reported daily pain; - 301/615 (49%) severe pain; - 129/615 (21%) mild-moderate pain; - Authors also reported that 16% stopped work due to pain and 19% stopped social activities due to pain | Definition: Projected pain appears at areas distal to the level of the lesion, starts early, is not related to motion or position, and may be felt in any part of the body. Triggered pain is felt in the paraplegic areas, provoked by a stimulus in different skin areas known as trigger zones.
Author: Turner, 1999 Country: USA Refman ID: 333 | n = 164/171 SCI Study design: Mailed survey Sampling frame: Individuals on a mailing list for an SCI newsletter | 114/164 (70%) reported persistent bothersome pain after hospital rehabilitation 132/164 (81%) reported a current pain problem (and 40% of these reported more than 3 pain problems) 35% reported pain below level of injury; 29% reported pain at level of injury; 22% reported pain above level of injury 123/164 (75%) reported current unpleasant but not painful sensations Authors also report pain interference with social activities or work, disability score, and number of days kept from usual activities due to pain. | Projected pain appears at areas distal to the level of the lesion, starts early, is not related to motion or position, and may be felt in any part of the body. Triggered pain is felt in the paraplegic areas, provoked by a stimulus in different skin areas known as trigger zones.

Evidence Table 4.5: Studies Generating or Testing Hypotheses About Chronic Neuropathic Pain in SCI

Author | Patient Description | Study Hypothesis
Author: Aisen, 1995 Country: USA Refman ID: 912 | # patients: 14 TSCI - 7 with SHS, 7 with SHS Level of injury: cervical | To determine the utility of the sympathetic skin response (SSR) in studying sympathetic outflow in cervical spinal cord injury patients developing RSD and SHS Findings/Conclusions: Conclude that SHS complicating TSCI is associated with increased amplitude of the SSR, supporting the theory that sympathetic hyperactivity is important in the pathophysiology of RSD
Author: Beric, 1988 Country: USA Refman ID: 143 | # patients: 13 with diffuse dysesthesia below lesion/102 with SCI Level of injury: 9 cervical; 4 thoracic | To define the dysesthesia syndrome in SCI by comparing clinical findings and results of quantitative sensory and neurophysiological tests Findings/Conclusions: Laboratory testing revealed relative preservation of dorsal column function compared to absence of spinothalamic function. Authors speculate that this imbalance may underlie generation of dysesthesias due to misperception of residual peripheral input.
Author: Bowsher D, 1996 Country: United Kingdom Refman ID: 049 | # patients: 6 SCI (plus 3 with syrinx)/156 with pain syndromes Level of injury: NR | To study the clinical and pathophysiological features of central pain due to damage to the CNS. Findings/Conclusions: Author generated hypothesis that upregulation or down-regulation of neurotransmitter receptors, possibly mainly noradrenergic, over time, underlies central neuropathic pain.
Author: Cheng, 1997 Country: Taiwan Refman ID: 878 | # patients: 61 SCI (36 with dysesthetic pain and 25 without) Level of injury: 27 at or above C5; 34 below C5 | To investigate the correlation between the presence of spontaneous EMG potentials and dysesthetic pain in cervical cord injured patients Findings/Conclusions: Spontaneous EMG potentials associated with dysesthetic pain (p<0.001) and injury severity (p<0.05) but not age, gender, injury level, duration of injury, operation, and spasticity
Author: Cohen, 1996 Country: United States Refman ID: 343 | # patients: 26 SCI/52 Level of injury: 13 SCI (T2-L2) with pain; 13 SCI (T3-L3) without pain; 13 low back pain; 13 controls | To determine whether dysesthetic pain syndrome resulted in changes in somatosensory perception and processing using two-point discrimination thresholds Findings/Conclusions: SCI-pain group had lower pain and sensory detection thresholds rostral to injury level; SCI-no pain group had higher thresholds. Authors conclude that differences in somatosensory processing occur when DPS is or is not a consequence of SCI.
Author: Defrin, 1999 Country: Israel Refman ID: 242 | # patients: 53 SCI/71 Level of injury: paraplegia T4-L3 21 complete SCI chronic pain (CSCIP); 10 complete SCI no chronic pain; 15 incomplete SCI chronic pain (ISCIP); 7 incomplete SCI no chronic pain | To investigate the perception of acute pain using the heat-pain threshold in SCI pts with chronic pain following partial or complete spinal cord damage Findings/Conclusions: Higher thresholds above level in CSCIP versus all other groups; this was reversed after complete pain relief from DREZ. CSCIP had more intense pain and larger area of body affected. Authors concluded that a critical level of chronic pain must be perceived to induce acute pain threshold elevation.
Author: Donovan, 1982 Country: USA Refman ID: 366 | # patients: 7 SCI / 8 with pain syndromes Level of injury: 2 segmental nerve; 2 SCI; 2 visceral; 1 muscle/mechanical; 1 psychogenic | To correlate five clinical pain types (peripheral, central, visceral, mechanical, psychic) with neurophysiological data Findings/Conclusions: The authors conclude that pain following spinal cord injury can be classified into one or more of the five pain types and distinguished by clinical and neurophysiological means.
Author: Dressler, 1994 Country: United Kingdom Refman ID: 081 | # patients: 1 TSCI (GSW) subject of 23 subjects investigated Level of injury: T12, L1 | To describe the signs and symptoms of "painful legs and moving toes syndrome" as described by Spillane et al. (1971). No a priori hypothesis stated. Findings/Conclusions: Treatment of this syndrome is notoriously difficult -- benefits of medications are often inadequate. Lumbar sympathetic blockade sometimes offers transient relief.
Author: Eide, 1996 Country: Norway Refman ID: 047 | # patients: 16 with SCI and central dysesthesia pain Level of injury: 8 cervical; 4 thoracic; 2 lumbar | To investigate if central pain is only dependent on lesioning of spinothalamic pathways, using somatosensory testing Findings/Conclusions: Thermal and tactile thresholds were changed in denervated skin (but not different in painful versus nonpainful areas); reductions in touch, vibration, and joint position were similar in painful and nonpainful areas; allodynia and wind up-like pain were more common in painful areas. Authors concluded that central pain is not only dependent upon lesioning of either dorsal column-medial lemniscal or spinothalamic pathways; allodynia and wind up-like pain may be consistent with hyperexcitability in nociceptive spinothalamic tract neurons.
Author: Lenz, 1989 Country: USA Refman ID: 165 | # patients: 5 Level of injury: NR | No a priori hypothesis stated. Findings/Conclusions: Authors report that somatosensory thalamic neurons of patients with central pain after SCI fire in bursts of action potentials more frequently than do similar neurons in patients without pain; the bursting pattern has characteristics similar to that associated with an underlying calcium spike; authors conclude that these findings may have relevance to etiology and treatment of central pain.
Author: Livshits, 1988 Country: Russia Refman ID: 675 | # patients: case series 25 of 50; consecutive patients admitted to hospital for surgery Level of injury: NE; cervical, thoracic, lumbar | To determine if there is an association between SSEP waves under median carpal nerve stimulation Findings/Conclusions: Late SSEP waves were more pronounced in TSCI cases with pain syndrome than in SCI patients without pain and normal subjects. SSEP is not a treatment, measures reactions in patients with pain. Found to be an association between SSEP waves and neurotic triad of the MMPI test (depression, hypochondria and hysteria). Article published in Russian.
Author: Loeser, 1968 Country: USA Refman ID: 893 | # patients: 1 Level of injury: L1 sensory and motor level | Many of the central pain states that occur after nerve or spinal cord injury may be due to chronic deafferentation and subsequent hyperactivity at the segmental level. Findings/Conclusions: Neuronal activity adjacent to the lesion was unusual and resembled that seen in chronic deafferentation of the cat spinal cord or the primate cortical epileptic focus.
Author: Melzack, 1978 Country: Canada Refman ID: 216 | # patients: 5 with phantom pain Level of injury: All thoracic | To examine the properties of phantom body pains in paraplegics and to propose a theoretical concept to explain them Findings/Conclusions: Authors conclude that mechanisms underlying phantom pain must be sought central to the level of cord transection and that loss of input to central structures after deafferentiation may contribute to pain production; authors propose a central "pattern generating mechanism" hypothesis for pain generation.
Author: Ness, 1998 Country: USA Refman ID: 247 | # patients: 1 Level of injury: paraplegia T4/L1 incomplete | To determine whether there was evidence of differential brain activity (by measuring regional cerebral blood flow (rCBF) with brain SPECT) in an individual with cyclic, chiefly unilateral, dysesthetic pain Findings/Conclusions: During pain, rCBF increased in the anterior cingulated gyrus, the thalamus bilaterally, and the contralateral somatosensory cortex but decreased in the caudate bilaterally. Gabapentin reduced the patient's pain.
Author: Roelcke, 1997 Country: Switzerland Refman ID: 904 | # patients: 11 SCI / 23 patients (12 controls) Level of injury: 7/11 paraplegic, 4/11 tetraplegic (C5 and C6 (n=2 each)) | To investigate if the deafferentation state after SCI may be followed by an altered pattern of cerebral glucose metabolism, as measured by positron emission tomography (PET), in paraplegic and tetraplegic patients Findings/Conclusions: Global cerebral glucose metabolism was reduced in patients with SCI and pain versus healthy controls; metabolism was increased in the supplementary motor area, anterior cingulated, and putamen and decreased in the midbrain, cerebellar hemispheres, and temporal cortex. Authors conclude that cerebral deafferentation due to reduction or loss of sensorimotor function lowers absolute cerebral glucose metabolism in SCI patients; relatively increased levels in certain brain regions involved in attention and movement initiation may be related to their secondary disinhibition.
Author: Sherman, 1986 Country: USA Refman ID: 300 | # patients: 9/10 have pain Level of injury: all complete; 4/9 cervical; 6/9 thoracic | To examine the relationships between near surface blood flow and altered sensations in TSCI patients in order to determine objective evidence of where phantom body pain is generated Findings/Conclusions: Results demonstrated a consistent decrease in termperature corresponding to the level at which normal sensations ceased. Changes in blood flow patterns correlate highly with the level at which sensations changed from normal to abnormal.
Author: Sherman, 1987 Country: USA Refman ID: 158 | # patients: 22 SCI /125 with chronic pain Level of injury: NR | To determine the usefulness of thermography for the evaluation of chronnic pain of different causes. Findings/Conclusions: Blind panel using only thermography could not differentiate intact from incomplete SCI patients; were able to differentiate all but one case of complete versus incomplete SCI.
Author: Song, 1993 Country: USA Refman ID: 085 | # patients: 15 with SCI and dysesthetic pain; 15 with SCI and no pain; 16 controls Level of injury: at or below T1 | To investigate if dysesthetic pain syndrome (DPS) patients would show increased cortical reogranization, measured using two-point discrimination thresholds (2PDTs), because of high levels of sensory stimulation following injury Findings/Conclusions: SCI pain group had smaller 2PDTs, especially over neck and spine; SCI pain group had inverse correlation between perceived pain severity and 2PDT in spinal skin area; authors conclude that SCI patients with severe DPS have a higher sensitivity to somatosensory stimuli, particularly in skin areas with projections to primary somatosensory cortex areas adjacent to the deafferentiated region; increase in 2PDT may be due to increase in size of somatosensory cortical areas allotted to the corresponding skin areas.
Author: Woodward, 1991 Country: USA Refman ID: 109 | # patients: 2 case reports Level of injury: tetraplegia, paraplegia | To investigate the response to light touch or tapping over areas rostral to the level of injury -- proximal tap or "central Tinel" sign Findings/Conclusions: The authors speculated that the proximal tap sign relates to the functional reorganization of central nociceptor systems.

Studies of Pharmacological Interventions

Evidence Table 5.1.1: Opioids (Alfentanil), Ketamine

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Eide, 1995 Country: Norway Setting: Tertiary care Refman ID: 62 | RCT crossover, (repeated measures design, all same subjects) Allocation concealment: NR Adequate randomization: Latin square design Blinding: Yes (patients), NC for therapy & outcome assessment Followup complete: Yes (80-100%) Reliable/valid outcome measures: VAS, intensity of continuous pain, allodynia and wind-up-like pain Heat Pain Threshold (HPT) Compliance assessed? NC Length of study: I d | n=9 Gender: 89% Male Age: mean 41 y, min 21 y - max 72 y Level of injury: Cervical, thoracic, lumbar Completeness of injury: ASIA classification: 5 A complete, 4 BCD incomplete. Cause of injury: 3 MVA, 3 falls, 2 sports, 1 crush Time since injury: NR Duration of pain: mean 33.7 (23.8) m, min 14 m - max 94 m Onset of pain: 6 immediate, 3 2 to 6 m post injury Pain description: central pain, allodynia, burning, dysesthesia, sharp, shooting, stabbing, tingling | Drug: Group 1: placebo Group 2: ketamine Group 3: alfentanil Dose: ketamine: bolus 60 µg/kg, 6µg/kg/min alfentanil: bolus 7 µg/kg, 0.6µg/kg/min Route: I.V. infusion Frequency: Not assessed | Outcome measures: VAS 0-100mm Continuous pain: markedly reduced by both drugs - measured 64mm VAS (median), 34 (25^th^ percentile) - 70 (75^th^ percentile) - 7/9 patients felt ketamine most affective - ketamine vs placebo p= 0.04 - alfentanil vs placebo p= 0.01 - ketamine vs alfentanil p= 0.19 Allodynia: markedly reduced by both drugs - measured 49mm VAS (median), 29 (25^th^ percentile) - 82 (75^th^ percentile) - ketamine vs placebo p= 0.014 - alfentanil vs placebo p= 0.03 - ketamine vs alfentanil p= 0.93 Wind-up-pain: reduced by ketamine and alfentanil - measured 55mm VAS (median), 42 (25^th^ percentile) - 90 (75^th^ percentile) - ketamine vs placebo p= 0.07 - alfentanil vs placebo p= 0.014 - ketamine vs alfentanil p= 0.37 HPT: thresholds remained unchanged - measured 44.5mm VAS (median), 39 (25^th^ percentile) - 49 (75^th^ percentile) - ketamine vs placebo p= 0.64 - alfentanil vs placebo p= 0.24 - ketamine vs alfentanil p= 0.95 Adverse effects: nausea, fatigue, dizziness, changes in mood, change in heart rate, itching, restless thoughts, reduced visual acuity, changes in hearing, general discomfort, feeling of unreality Severity of adverse effects: Reported as weak, medium, bothersome
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 5.1.2: Opioids (Morphine), Buprenorphine, Clonidine

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Glynn, 1986 Country: UK Setting: Tertiary care Refman ID: 163 | Non-RCT Adequate randomization: NA Blinding: Single Followup complete: Yes (80-100%), Unable to determine if losses to followup were taken into account Reliable/valid outcome measures: NC Binary scale: + = an effect or pain relief 0 = no effect or no pain relief Length of study: NC | n=15 Gender: 80% Male Age: mean 47.9 y Level of injury: cervical (5), thoracic (6), and lumbar (4) Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: mean 9.9 y Onset of pain: NR Pain description: Central pain, deafferentation pain | Drug: Drug 1: clonidine Drug 2: morphine Drug 3: buprenorphine Dose: Clonidine: 150 µg in 5 ml saline Morphine: 5mg in 5 ml water Buprenorphine: 0.3 mg in 5 ml saline Route: lumbar epidural catheter Frequency: "at least 24 hours" | Outcome measures: Drug 1: 10/15 had an effect or pain relief Drug 2: 5/14 had an effect or pain relief, 7 who didn't respond to clonidine Drug 3: 2/5 had an effect or pain relief Adverse effects: - none of the patients experienced any respiratory depression, no pruritus, nausea, or vomiting - 1 patient stopped the drug because of severe depression - 2 patients did not get satisfactory relief but did not stop as the pain was worse without the drug Severity of adverse effects: reported Comments: - Buprenorphine was given to patients who received no pain relief after administration of either clonidine or morphine. - 2 subjects had some effect or relief was felt with buprenorphine but not with either clonidine or morphine. - 1 subject did not find pain relief with any of the drugs. - clonidine provided the best relief in 7 subjects. - 3 subjects had relief with both clonidine and morphine.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 5.1.3: Opioids (Morphine), Amitriptyline, Clonazepam, Others

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Fenollosa 1993 Country: Spain Setting: Tertiary care Refman ID: 84 | Case series & a postal survey Adequate randomization: NA Blinding: NR Followup complete: Yes (80-100%). Assessment at 3, 6,12, 18, 24 & 36 m Reliable/valid outcome measures: NC Lattinen Test (subjective intensity, frequency, analgesics intake, disability due to pain & sleep) Score 0-20 Compliance assessed? Unable to determine Length of study: 3 y | n=28/33 (TSCI/SCI, 5 musculoskeletal pain) Gender: 70% Male; Survey N=145 80.6% Male Age: mean 32.5 y Survey: 37 y (13-70) Level of injury: cervical 42%, thoracic 30%, lumbar 27% Completeness of injury: Complete 48%, Incomplete 52% Cause of injury: Traumatic: 23 patients Medical: 10 patients Time since injury: More than 6 m (from survey) Duration of pain: NE Onset of pain: NR Pain description: From survey data: continuous, burning, numbness, "like electricity, pressure" | Drug: 4 regimens ("step programme") 1. amitriptyline + clonazepam +NSAID 2. amitriptyline + clonazepam +5-OH-tryptophane + TENS 3. amitriptyline + clonazepam + spinal cord stimulation 4. morphine (intrathecal continuous infusion) Dose: Amitriptyline 30mg/d increased to 75 mg/d at day 10, Clonazepam 0.6-1.5 mg/d 5OH-tryptophane 300 mg/d Morphine 0.6 mg initially and 0.3-1mg according to the response. Permanent infusion 0.6 mg/d Route: Oral for drug in regimens (1-3) Intrathecal (morphine) Frequency: Waiting period between stages 35 d (15-90). | Outcomes: Improvement (Satisfactory pain relief) Regimen 1: 6/33 (18%) Regimen 2: 16/27 (59%) Regimen 3: 3/7 (43%) Regimen 4: 8/12 (67%) Adverse effects: Catheter displacement in 3 patients (out of 12) in regimen 4; 2 cases of respiratory depression (from survey) Severity of adverse effects: NR Comments: - Some patients taking Baclofen for spasticity. - SCS technique implanted permanently after waiting period of 2-3 m. Recommended only for patients with radicular pain. - None of the 8 pts in morphine developed tolerance after 3 y of treatment. - Not clear if patients who responded to the survey are the same ones that were treated with the different therapeutic regimens.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 5.1.4: Anticonvulsants (Valproate)

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Drewes, 1994 Country: Denmark Setting: Tertiary care and home Refman ID: 345 | RCT Crossover Adequate randomization: NR Blinding: Yes (patient and outcome assessment) Followup complete: NC Reliable/valid outcome measures: NC McGill Pain Questionnaire (MPQ) - PRI, PPI, NWC, pain localization drawing Compliance assessed? NC Length of study: 8 w | n=20 Gender: 75% male Age: 32.5 y mean Level of injury: tetraplegic, paraplegic Completeness of injury: NR Cause of injury: 19/20 Traumatic; 1/20 Spinal Stenosis Time since injury: median 79.5 m, min 4 m to max 122 m Duration of pain: NE Onset of pain: NR Pain description: shooting, tingling, agonizing, cutting, cruel | Drug: valproate Double blind, crossover study first treatment/placebo period of 3 w, 2 w washout, new 3 w treatment period Dose: 600 mg (individually increased) Median dose 1,800 mg (600-2,400mg) Route: Oral Frequency: b.i.d. | Outcome measures: MPQ, PPI, PRI, NWC, Area (% of total body area) Mean improvement after 3 weeks of treatment: Placebo: PPI -01; PRI-1.7; NWC NR; Area 0.2% Treatment: PPI -0.2; PRI-1.6; NWC NR; Area 2.1% Adverse effects: Gastroenteritis, dizziness, more pain Severity of adverse effects: NR Placebo: 4 pts improved and 1 pt had worsening of the pain. Valproate: 6 pts improved and 2 pts were worse. Comments: - Findings were not clearly reported. - No significant differences between the two groups were reported, although a positive trend was observed in the valproate treatment phase. One patient excluded from analysis
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Pain distal to the level of injury in an area with loss of normal feeling. Central pain described in the introduction.

Evidence Table 5.1.5: Anticonvulsants (Gabapentine)

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Epstein, 1998 Country: USA Setting: Tertiary care Refman ID: 36 | Case Series Adequate randomization: NA Blinding: NR Followup complete: Yes (80-100%) Reliable/valid outcome measures: NC Numerical scale (0-10, verbal pain intensity) Percent pain reduction Compliance assessed? NC Length of study: Until relief of pain or occurrence of side effects | n=10 SCI/29 Gender: 70% male Age: mean 47 y, min 20 - max 76 y Level of injury: NR Completeness of injury: 4 complete, 6 incomplete Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: burning, hyperaesthesia, lancinating, paraesthesias | Drug: gabapentine Dose: 600 to 2,700 mg/d (daily increases of 200 to 300 mg) Route: Oral Frequency: b.i.d or t.i.d | Outcome measures: - mean pain reduction: 72% in SCI - at least 50% pain reduction reported in 10 SCI patients. Adverse effects: based on 10 SCI patients - 2 patients reported no side effects - drowsy and fatigue (5), diarrhea (3), nightmares/hallucinations (2), dysarthria (1), nausea (2), somnolence (based on all) Severity of adverse effects: NR Comments: - Main findings not clearly described. - Suggestive that gabapentin may be beneficial in the treatment of neuropathic pain
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 5.1.6: Local Anesthetics and Drugs With Anesthetic Properties (Mexiletine)

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Chiou-Tan, 1996 Country: USA Setting: Tertiary care Refman ID: 51 | RCT Crossover Adequate randomization: NC Blinding: NR Followup complete: Yes (73%) Reliable/valid outcome measures: NC McGill Pain Questionnaire (MPQ) NWC VAS linear pain scale (0-10) Barthel index (measure of functional ability) Compliance assessed? NC Length of study: 10 w | n=15 SCI enrolled, 11 completed Gender: 82% Male Age: 44 y mean (11.0) Level of injury: cervical (3), thoracic (6), and lumbar (2) Completeness of injury: Complete (9) and incomplete (2) Cause of injury: MVA (2), falls (3), GSW (3), surgery (2), other (1) Time since injury: 7 y mean Duration of pain: NC (> 6 m by inclusion criteria) Onset of pain: NR Pain description: burning, dysesthesia, neuropathic | Drug: Mexiletine (lidocaine) Dose: 450 mg/d Route: Oral Frequency: 10-week crossover design: 1 week washout, 150 mg t.i.d for 4 w (drug) or placebo, 1 w washout, 4 w drug or placebo | Outcome measures: mean, (SD), Wilcoxon P Placebo: McGill Pain Questionnaire 103.0 (63) to 60 (31.0) (internal pain) p=0.31 51.0 (60.0) to 18.0 (16.0) (external pain) p=.044 NWC 11.0 (9.0) to 5.0 (8.0) p=0.16 PRI 1.0 (0.0) to 1.0 (0.0) insufficient data PPI 5.0 (0.0) to 5.0 (0.0) p=0.23 Visual Analog Scale 7.8 (1.7) to 8.7(1.5) p=0.06 Mexiletine: McGill Pain Questionnaire 56.0 (40) to 44.0 (35) (internal pain) p=0.69 30.0 (48) to 32.0 (40.0) (external pain) p=0.38 NWC 9.0 (7.0) to 6.0 (7.0) p= 0.16 PRI 7.0 (1.0) to 5.0 (1.0) p=1.0 PPI 6.0 (6.0) to 3.0 (4.0) p=0.34 Visual Analog Scale 8.1 (2.2) to 7.7 (2.4) p=0.88 Barthel: no change in level of function from baseline at any point in the study Adverse effects: NR Severity of adverse effects: NR Comments: - No significant effect of mexiletine on SCI dysesthetic pain scales or the Barthel index - Did not decrease injury-related dysesthetic pain - Mexiletine not found to be helpful in treating TSCI dysesthetic pain
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Chronic dysesthetic SCI pain - pain at or below level of lesion present after SCI > 6 m duration limiting functional ability.

Evidence Table 5.1.7: Local Anesthetics and Drugs With Anesthetic Properties (Lidocaine)

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Loubser, 1991 Country: USA Setting: Tertiary care Refman ID: 358 | RCT Crossover, double-blind study Adequate randomization: NR Blinding: Yes (patients and therapy delivery) Followup complete: Yes (80-100%) Reliable/valid outcome measures: NC; VAS 10mm, pain diagram Compliance assessed? NC Length of study: I d | n=21 SCI Gender: 81% Male Age: 42 y mean, 18 y min, 58 y max Level of injury: cervical (5), thoracic (14), and lumbar (2) Completeness of injury: Complete and incomplete (not specified) Cause of injury: NR Time since injury: At least 18 m Duration of pain: At least 6 m Onset of pain: NR Pain description: burning, sharp, aching, throbbing, pressure, dull; neuropathic at or below level. Most described pain as constant with minor fluctuation following activity or bedrest. | Drug: lidocaine 5% in dextrose Dose: 100 mg; Mean 80 (20.8) mg Route: intrathecal injection (lumbar subarachnoid catheter) Frequency: Intermittent: Titration every 5 minutes in 25 mg aliquots | Outcome measures: Decrease in pain (intensity and duration), VAS repeated every 15 to 30 minutes - Placebo 4/21 - Treatment 13/21 P<0.01 Pain response to subarachnoid lidocaine: Mean reduction of pain intensity: 37.8% (37) Mean duration of response: 123.1 minutes (95.3) Adverse effects: Hypotension, pain intensification. No headache, infection reported. Severity of adverse effects: No major side-effects reported. Comments: - Authors conclude that individual interpretation to the response of spinal anesthesia is required. - Long-term followup is recommended in order to determine the impact of this intervention.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Pain regarded as severe, "function-limiting" (Davidoff, 1987), and refractory to traditional rehabilitative therapies.

Evidence Table 5.1.8: Adrenergics and Cholinergic Agonists (Clonidine)

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Glynn, 1992 Country: UK Setting: Tertiary care Refman ID: 96 | Case Series Adequate randomization: NA Blinding: NA Followup complete: Yes (80-100%) Unable to determine losses of pts to follow-up. Reliable/valid outcome measures: NC VAS: 0-10 (10/10 no pain) Compliance assessed? NC Length of study: I d | n=10 Gender: 70% Male Age: 50.5 y mean Level of injury: cervical (5), thoracic (2), lumbar (2), and sacral (1) Completeness of injury: NR Cause of injury: NR Time since injury: mean 15.0 y Duration of pain: NR Onset of pain: NR Pain description: Deafferentation pain | Drug: clonidine Dose: 150 µg in 5 ml saline Route: epidural lumbar catheter Frequency: single dose | Outcome measures: Decrease in pain (intensity and duration) 3.4 (2.8) 7/10 obtained analgesia Adverse effects: - hypotension (minor), drowsiness, headache (none) - no "untoward" adverse effects noted Severity of adverse effects: NR Comments: - 6 patients included in pharmacokinetics analysis because the catheters were not in the epidural space in the remaining 4 patients - Most of the patients (8) experienced drowsiness. - 5 of 6 patients with muscle spasms obtained good to total relief after injection of clonidine. - 1 failure following parenteral injection
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Chronic dysesthetic SCI pain. Pain at or below level of lesion present after SCI > 6 m duration limiting functional ability.

Evidence Table 5.1.9: Baclofen

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Loubser, 1996 Country: USA Setting: Tertiary care Refman ID: 045 | Case Series Adequate randomization: NA Blinding: NA Followup complete: Yes (80-100%) Reliable/valid outcome measures: NC - VAS (mm) - Use of analgesic medication Compliance assessed? NC Length of study: 12 m | n=9/12 SCI Gender: 89% Male Age: 39.7 y mean (14.1) Level of injury: cervical (5), thoracic (4) Completeness of injury: Frankel's classification: 3 A Complete, 3 B incomplete, & 3 C incomplete Cause of injury: NR Time since injury: NR Duration of pain: At least 6 m (inclusion criteria) Onset of pain: NR Pain description: Allodynia, burning, dysaethesia, neurogenic, diffuse, stinging, paresthesias | Drug: baclofen Dose: NR Route: intrathecal pump (lumbar subarachnoid catheter) Frequency: NR | Outcome measures: VAS 0-10: Baseline mean 5.60 (1.65); 6 m posttreatment mean 6.09 (1.67); 12 m posttreatment mean 6.11 (1.74) - 7 patients with neurogenic pain (78%) had no significant change in pain severity at both 6 and 12 m. - 2 patients (22%) had increase in pain severity both at 6 and 12 m. Oral analgesic medication usage: All 6 patients continued oral analgesic medication with no change in dosage or type of medication. Adverse effects: Not assessed Severity of adverse effects: NR Comments: - Findings suggest that intrathecal baclofen does not decrease chronic neurogenic spinal cord pain.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - The authors reference Merskey and Bogduk, 1994. Classified as neurogenic or musculoskeletal

Evidence Table 5.1.10: Trazodone Hydrocloride

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Davidoff, 1987a; Davidoff, 1987b Country: USA Setting: Tertiary care Refman ID: 287 | RCT Parallel, double blind, placebo controlled Adequate randomization: NR Blinding: Yes (patient and therapy delivery) Followup complete: Yes; Group 1: 80-100%; Group 2: <60% Reliable/valid outcome measures: McGill Pain Questionnaire (MPQ) Pain Rating Index (PRI) Present Pain Intensity (PPI) Number of Words Chosen (NWC) Sternbach Pain Intensity (SPI) Zung Pain and Distress Scale (PAD) Compliance assessed? Yes Length of study: 8 w | n=19 Gender: 90% male Age: 38.8 y (placebo group 1); 39.4 y (treatment group 2) Level of injury: 16% tetraplegic, 85% paraplegic Completeness of injury: 26% complete, 74% incomplete Cause of injury: 11% MVA, 21% falls, 53% GSW, 5% sports, 11% other Time since injury: NR Duration of pain: mean 51.0 m (19.2 m) placebo, mean 47.6 m (9.7 m) treatment Onset of pain: within first post-injury year (inclusion criteria) Pain description: Neuropathic below level, burning, cutting, cruel, nagging, radiating, tight | Drug: trazodone hydrocloride Dose: 150 mg/d Route: Oral Frequency: 6 w course 1 capsule/d for 3 d; 2 capsules/d for next 4 d; & 3 capsules/d for the remaining 5 w | Outcome measures: Group 1 (Placebo) baseline to intervention PRI 34.7 (4.4) to 32.1 (3.5) PPI 2.4 (0.3) to 1.7 (0.2) NWC 13.9 (1.5) to 13.2 (1.5) SPI (d) 55.7 (10.4) to 63.4 (8.4) SPI (w) 65.6 (9.6) to 68.3 (6.9) PAD 59.0 (4.9) to 53.0 (3.2) Group 2 (Treatment) baseline to intervention PRI 33.0 (5.5) to 33.5 (2.4) PPI 2.1 (0.3) to 2.6 (0.2) NWC 13.2 (1.9) to 14.0 (1.0) SPI (d) 57.9 (11.1) to 61.7 (6.8) SPI (w) 69.7 (8.7) to 73.9 (4.7) PAD 56.9 (4.6) to 67.2 (3.8) Subjective assessment of pain by MD: 2/9 (group 1), 5/9 (group 2) effective relief by patient: 3/9 (group 1), 4/9 (group 2) effective relief Adverse effects: Drowsiness, dry mouth, urinary tract infection, increased spasticity, urinary retention Severity of adverse effects: NR Comments: - Premature termination of study due to side effects in the treatment group (4 pts) - There were no significant differences in the pain measures over time & between drug & placebo groups.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Pain following traumatic myelopathy, characterized by diffuse burning and tingling sensations distal to level of spinal injury.

Evidence Table 5.1.11: Combination -- Pharmacological (Amitriptyline + Carbamazepine) and Nonpharmacological Treatment (Electroacupuncture)

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Erzurumlu, 1996 Country: Turkey Setting: Tertiary care Refman ID: 1062 | Non-RCT Contemporaneous controls 2 groups, before/after within each group. Multidisciplinary pain treatment approach Adequate randomization: NA Blinding: No Followup complete: Yes (80-100%) Unable to determine if losses of patient to followup were taken into account Reliable/valid outcome measures: NR VAS (1-10) Compliance assessed? No Length of study: 2 m (60 d) | n=28 Gender: 92.3% Male Age: mean 22.9 y (3.8) Level of injury: Group 1: tetraplegic & paraplegic Group 2: paraplegic Completeness of injury: Group 1: cervical complete Group 2: caudal incomplete Cause of injury: NR Time since injury: Total sample: mean 8.6 m (4.2) Duration of pain: NR Onset of pain: NR Pain description: Central pain, stabbing, atypical, visceral, diffuse, psychological | Drug: Group 1: amitriptyline & carbamazepine Group 2: 4Hz frequency electroacupuncture, 20 minute sessions for 10 d Dose: amitriptyline 50 mg/d carbamazepine 600 mg/d Route: Oral Frequency: Group 1: daily Group 2: NC | Outcome measures: VAS 1-10 Group 1 Baseline mean 5.29 (1.2) Posttreatment (10 d) mean 3.29 (0.8) Followup (60 d) mean 2.71 (0.8) Group 2 Baseline mean 6.07 (1.3) Posttreatment (10 d) mean 2.14 (0.8) Followup (60 d) mean 3.5 (1.4) Adverse effects: No complications reported. Severity of adverse effects: NR Comments: - Group 1 reached a plateau in pain scores at day 15. - Group 2 reached plateau at day 7. - Article published in Turkish.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 5.1.12: Combination -- Pharmacological (Melitracen + Flupenthixol) and Nonpharmacological Treatment (TENS)

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Heilporn, 1977-78 Country: Belgium Setting: NR Refman ID: 828 | Case Series, Multidisciplinary approach Study direction: retrospective Adequate randomization: NA Blinding: NA Followup complete: Yes (80-100%); Characteristics of patients lost to followup not described Reliable/valid outcome measures: Categorical NC, "distinctly better," "a certain improvement," "no improvement" Compliance assessed? NC Length of study: 2 w to 3 m | n=12 (11 SCI) Gender: 91% Male Age: NR Level of injury: thoracic (10), lumbar (1) Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: Dysaesthesia | Group 1: Drug: Group 1: melitracen + flupenthixol Group 2: TENS + melitracen + flupenthixol Dose: Melitracen 3x50 mg/day Flupenthixol 3x1 mg/day Route: Oral Frequency: t.i.d Group 2: transcutaneous nerve stimulation | Outcome measures: Global subjective assessment by MD Group 1 5/11 "distinctly better," 3/11 "no improvement," 3/11 "a certain improvement" Adverse effects: (3 pts) ocular problems, micturition difficulties Severity of adverse effects: NR Group 2 1/3 "no improvement," 2/3 "a certain improvement" Adverse effects: none mentioned Severity of adverse effects: NR Patients not convinced by the treatment and felt that it hindered their independence. Comments: - Authors feel that stubborn pain may benefit from a trial of the drug combination of melitracen-flupenthixol.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Diffuse sublesional pain localized in an anaesthetical region

Supplemental Evidence Table 5.1.1: Opioids (Morphine) and Clonidine

Author | Patients Description | Intervention | Findings & Comments
Author: Siddall, 1994 Country: Australia Setting: Tertiary care Refman ID: 73 | Case Report Gender: male Age: 27 y Level of injury: tetraplegic Completeness of injury: complete Cause of injury: fall Surgical stabilization: Time since injury: 4 y Duration of pain: 1 y Onset of pain: 3 y Length of followup: 9 m Outcome measures: NR Pain description: burning, tearing, with intermittent shooting, stabbing pain radiating to left heel | Intervention: - 7 mg/day morphine over 2 weeks - started intrathecal morphine (5 mg/day) and clonidine (8 µg/day); increased to infusion rate of 10/day morphine and 17 µg/day clonidine over a 1 week period Previous treatment: - Analgesics did not provide adequate relief of pain. - Intrathecal baclofen | Outcomes: - Morphine alone did not control pain. - 2 weeks after combination treatment began, patient reports reduction of pain to 50% of previous levels. Continues to experience good relief of pain after 9 m. Adverse effects: NR Severity of Adverse effects: NR Comments: - Morphine did not relieve the pain but did relieve the muscle spasm, equal to that of the intrathecal baclofen - Intrathecal administration of clonidine was thought to be important in avoiding undesirable side effects, - Suggest further studies to determine most effective concentration of clonidine and to measure the analgesic effect of its influence in combination with opioids.
Author's description of pain - No definition provided.

Supplemental Evidence Table 5.1.2: Aminopyridine

Author | Patient Description | Intervention | Findings & Comments
Author: Potter, 1998 Country: Canada Setting: Tertiary care Refman ID: 1218 | 3 case reports Gender: 2/3 male Age: 45 y, 42 y, 40 y Level of injury: 1 ASIA C, 2 ASIA D; 3/3 incomplete tetraplegia Cause of injury: 2/3 MVA, 1 diving accident Surgical stabilization: NR Time since injury: 16 y, 17 m, 3 y Frequency of pain: NR Onset of pain: NR Outcome measures: Modified Ashworth Scale Pain description: spasm | 4 - Aminopyridine 10 mg bid or tid orally over a 4 m interval Previous treatment: Effective: 4 AP i.v (immediate release) Ineffective: 12 y of cross section of analgesics modalities and wheelchair positioning | Outcome: - Marked and sustained reductions in upper or lower extremity spasticity as soon as 2 hours of the first dose of 4-AP - Improvement in gait and sexual functions Pt #1 experienced "appreciable reductions in dysesthetic lumbar pain" Other benefits: reduced pain (n=1), restored muscle strength (n=3), improved sensation (n=2), voluntary control of bowel function (n=1), and sustained penile tumescence (n=2). Improved quality of life Adverse effects: transient light headedness. No evidences of renal or hepatic toxicity with prolonged use Pt#3: irritability and wakefulness at night (eliminated by reduction from t.i.d to b.i.d administration) Severity of Adverse effects: NR Comments: - Sensory analgesics and antispastic effects tended to appear 1-2 hours after the first dose consistent with the peak serum levels. - All three patients experienced regression to previous pain and functional state after discontinuation of the drug at 4 m.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 5.1.3: Baclofen

Author | Patient Description | Intervention | Findings & Comments
Author: Herman, 1992 Country: USA Setting: Tertiary care Refman ID: 095 | 42 y old male Level of injury: C5-6 Cause of injury: NR Surgical stabilization: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Length of followup: NR Outcome measures: VAS (0-100) Pain description: severe dysesthesia & complete sensor motor impairment. Patient also had lower back pain. | Intrathecal Baclofen 50 µg in ml normal saline (bolus dose) | Baclofen abolished dysesthetic pain (VAS 83) Adverse effects: marked sensitivity to the drug Severity of adverse effects: NR Comments: - Report of this patient comes from an RCT of 9 patients with chronic, dysesthetic, and spasm-related pain with spinal spasticity (Multiple sclerosis, spinal cord injury and transverse myelitis)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition of pain provided.

Supplemental Evidence Table 5.1.4: Baclofen

Author | Patient Description | Intervention | Findings & Comments
Author: Taira, 1995 Country: Japan Setting: Tertiary care Refman ID: 057 | N= 6 TSCI /14 Gender: 100% Male Age: (mean) 55.2 y (9.1) Level of injury: cervical (2), thoracic (3), lumbar (1) Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: 15.8 y Onset of pain: NR Length of followup: NR Outcome measures: numerical scale Pain description: Allodynia, hyperalgesia | Drug: Baclofen Dose: Bolus 50-100 µg Route: Intrathecal (lumbar catheter) Frequency: 3-5 times over 1 w - normal saline used once in each patient | Numerical Scale (posttreatment): 6.33 (4.08), 3/6 TSCI subjects reported "substantial pain relief" Adverse Effects: Unsteady gait, urinary retention, mild headache Severity of Adverse Effects: transient Comments: - Patients with signs of partial spinal lesions reported pain relief; whereas patients with complete lesions of the spinal cord did not benefit.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition of pain provided.

Supplemental Evidence Table 5.1.5: Carbamazepine

Author | Patient Description | Intervention | Findings & Cpomments
Author: Gibson, 1971 Country: USA Setting: Tertiary care Refman ID: 8090 | 2 case reports Gender: 2/2 male Age: 34 y, 37 y Level of injury: paraplegic Cause of injury: Fracture dislocation, GSW Surgical stabilization: Patient #1 - Yes. Decompressive laminectomy. Patient reported 50% decrease in his pain after the operation but the pain returned after 6 m. Patient #2 - no Time since injury: 7 y, 35 y Duration of pain: 6 y, 28 y (approximately) Onset of pain: 3 m, 20 y Outcome measures: Descriptive narration Duration of observation: 4 m, 8 m Pain description: severe burning and deep in the bones, radiating, aching, severe, sharp, lancinating in the lower body. Intractable pain associated with muscle spasms. | Carbamazepine Patient #1: 200 mg 4X/d, reduced to 700 mg/d Patient #2: 600 mg per d, reduced to 500 mg due to nausea Previous treatment: Patient #1: analgesics, laminectomy Patient #2: Spinal anesthesia, subarachnoid alcohol blocks. Trial of dilantin and valium for 1 w (not effective) | Patient #1: deep aches remain but tolerable Patient #2: "marked relief" Relief persisted with only occasional burning sensations. Adverse effects: Patient #1: gastrointestinal disturbance Patient #2: nausea Lancinating complaints in these two patients are similar to that seen in classical trigeminal neuralgia. Severity of Adverse effects: NR Comments: Relief of pain with carbamazepine suggests a central origin of severe atypical pain following afferent denervation of the spinal cord.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 5.1.6: Local Anesthetics (Lidocaine)

Author | Patients Description | Intervention | Findings & Comments
Author: Nagaro, 1995 Country: Japan Setting: Tertiary care Refman ID: 64 | 4 of 89 subjects were TSCI Gender: 55% of total sample male; NR for 4 TSCI Age: mean 51.6 y for total population; NR for 4 TSCI Level of injury: NR Completeness of injury: 2 complete, 2 incomplete Cause of injury: NR Surgical stabilization: NR Time since injury: NR Duration of pain: 6.4 y (6.6) for 4 TSCI; 3.9 y (6.1) total population Onset of pain: NR Length of followup: NR Outcome measures: VAS 0-10 mm; 0 = no pain; 10 = most painful Pain description: NR | Previous treatment: NR Intervention: Lidocaine 1.5 mg/kg infused iv for 1 minute | Outcomes: TSCI patients (4 patients) - Baseline VAS pain score 7.0 (1.8) - After treatment: 1 excellent, 2 fair, 1 no change Total Sample (89 patients) - Baseline VAS pain score 5.8 (2.3) - After treatment: 44 (49%) excellent; 13 (15%) good; 17 (19%) fair; 15 (17%) no effect. Adverse effects: NR Severity of Adverse effects: NR Comments: - Pain score lowest immediately after infusion - Authors suggest that systemic local anesthetics are most effective in neuropathy due to cancer pain, postherpetic or trigeminal neuralgia, low back pain with root pain or stenosis, peripheral nerve injury, and thalamic pain. - Article published in Japanese.
Author's description of pain - No definition provided.

Supplemental Evidence Table 5.1.7: Local Anesthetic (Midazolam)

Author | Patients Description | Intervention | Findings & Comments
Author: Ozerbil, 1997 Country: Turkey Setting: Tertiary care Refman ID: 1204 | 4 case reports Gender: male Age: 47, 51, 28, 31 Level of injury: 4 paraplegic; 4 thoracic Completeness of injury: 2 Frankel Class A, 2 Frankel Class C Cause of injury: 2 MVA, 1 fall, 1 other Surgical stabilization: NC Time since injury: mean 26 m, min 18 m to max 32 m Duration of pain: mean 22.5 m, min 16 m to max 29 m Onset of pain: NR Length of followup: 2 w min Outcome measures: VAS, modified Ashworth, face scale Pain description: chronic central pain and spasticity in lower regions | Epidural administration of midazolam 6 times daily Dose: 40 µg/kg dissolved in 10 ml normal saline via lumbar epidural catheter Previous treatment: NC | Outcomes: - baseline VAS 7-8; at 1 day 0-1; at 15 days 0 - baseline face 15-17; at 1 day 1-2; at 15 days 1 - baseline modified Ashworth hip 3-4; at 1 day 0-2; at 15 days 1 - baseline modified Ashworth foot 3-4; at 1 day 1-2; at 15 days 1-2 Adverse effects: none observed Severity of Adverse effects: NA Comments: - Midazolam provided relief for both central pain and spasticity. - Efficacy on central pain more pronounced - No significant side effects in any patient - Article published in Turkish.
Author's description of pain - No definition provided.

Supplemental Evidence Table 5.1.8: Amitriptyline, Carbamazepine

Author | Patient Description | Intervention | Findings & Comments
Author: Sandford, 1992 Country: USA Setting: Tertiary care Refman ID: 219 | 33 y old female Level of injury: burst fracture of C7 Cause of injury: MVA Surgical stabilization: at time of accident Time since injury: about 10 w Duration of pain: NR Onset of pain: about 1 m postinjury Length of followup: NR Outcome measures: patient report Pain description: intermittent dull, burning pain beginning in feet, to backs of legs into lower back. Light touch caused excruciating pain at times. | amitriptyline: initial dose: 25 mg hs, increased to 200 mg hs final dose: 50 mg tid carbamazepine: initial dose 100 mg bid increased to 200 mg bid final dose: 200 mg bid Previous treatment (ineffective): repeat anterior decompression acetaminophen, ibuprofen, oxycodone, propoxyphene, TENS | - some relief at night with amitriptyline - substantial pain reduction after 10 d treatment when carbamazepine was added Adverse Effects: NR Severity of Adverse Effects: NR Comments: - sustained improvement after 3 y
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition of pain provided.

Supplemental Evidence Table 5.1.9: Amitriptyline Plus Other Nonpharmacologics

Author | Patient Description | Intervention | Findings & Comments
Author: Loubser, 1993 Country: USA Setting: Tertiary care Refman ID: 347 | 53 y old male Level of injury: C6 (MVA) Completeness of injury: Incomplete motor and sensory Time since injury: 2 y Onset of pain: NR Length of followup: NR Outcome measures: VAS (0-10), pain diagram Pain description: Lower extremities - knees to soles of feet bilaterally, radiation to right thigh (cramping) Upper extremities - dysesthesias from elbow to tips of fingers | Combination therapy: - 150 mg amitriptyline b.i.d. - group psychotherapy - biofeedback relaxation Previous therapy: - 50 mg lidocaine in 7.5% dextrose injected via catheter | Combination therapy (amitriptyline and psychotherapy): - some relief of pain that the patient deemed compatible with normal activities of daily living Adverse Effects: NR Severity of Adverse Effects: NR Comments: - Patient refused trial of deep brain stimulation, dorsal column stimulation, and trial of intrathecal opioid.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Central: location within dorsal horn and somatosensory projection systems rostral to the actual spinal cord transection

Supplemental Evidence Table 5.1.10: Amitriptyline Plus Other Nonpharmacologics

Author | Patient Description | Intervention | Findings & Comments
Author: Segatore, 1994 Country: Canada Setting: Tertiary care Refman ID: 074 | 23 y old male Level of injury: C5 fracture dislocation (MVA) Time since injury: NR Onset of pain: within 5 w of surgical stabilization Length of followup: NR Outcome measures: patient report Pain description: burning and numbness throughout his trunk and limbs, episodes of severe lancinating pain into his dominant upper extremity | - 25 mg amitriptyline (Elavil) at bedtime - seen by social worker for support and relaxation training | - within 3 d, significant amelioration of pain Adverse Effects: NR Severity of Adverse Effects: NR Comments: background dysesthesias were reduced to a manageable intensity and fewer paroxysmal bursts
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - From IASP: central pain is pain due to "central mechanisms" or pain that arises following disease or injury to the CNS. Neuropathic pain should be reserved for pain attributed to "peripheral-central mechanisms" that are operative in disease or injury of peripheral nerves.

Supplemental Evidence Table 5.1.11: Carbamazepine, Clonipramine

Author | Patients Description | Intervention | Findings & Comments
Author: Gallien, 1995 Country: France Setting: Tertiary care Refman ID: 388 | 8 RSD case reports Gender: 7/8 male Age: median 35 y, min 29 y, max 59y Level of injury: 4/8 tetraplegic, 4/8 paraplegic; 5/8 Frankel A, 2/8 Frankel C, 1/8 Frankel D Cause of injury: 2/8 MVA, 1/8 fall, 5/8 GSW Surgical stabilization: 4/8 yes Time since injury: mean 7m, min 1 to max 16 m Duration of pain: NR Onset of pain: 7 m Outcome measures: patient self report, "improvement," x-rays Pain description: permanent burning, tingling pain with local hyperesthesia, electricity, stabbing | Formulation of the solution: 7/8 subcutaneous porcine, 160 IU/d or salmon calcitonine 100 IU/d for 10 days, then 3 times a week for 5 weeks Physiotherapy consisting of immersions in hot and cold water included If no improvement occurred at 10 days, carbamazepine (dose NR). clonipramine was introduced at 75 mg/d Previous treatment: NR | Outcomes: Carbamazepine produced an improvement in 2/8 patients, good findings were obtained in the other 6/8 with clonipramine. Adverse effects: None reported as a result of the drugs. All patients had a depression syndrome prior to the study. Severity of Adverse effects: NR Comments: Noticed 2 distinctive clinical phases: a hot phase with diffuse swelling and a cold phase with the disappearance of trophic changes and then the appearance of searing pain without nerve root distribution
Author's description of pain - No definition provided.

Supplemental Evidence Table 5.1.12: Combination (Buprenorphine, Diazepam, Thiamylal)

Author | Patient Description | Intervention | Findings & Comments
Author: Nagaro, 1995 Country: Japan Setting: Tertiary care Refman ID: 320 | 40 y old male Level of injury: fracture dislocation T12/L1 Cause of injury: NR Surgical stabilization: NR Time since injury: 18 y Duration of pain: 18 y Onset of pain: "soon after injury" Length of followup: 6 y Outcome measures: VAS (0-10) Pain description: shooting pain to left medial thigh corresponding to L2 dermatomes lasting for several seconds & occurring several times per hour (VAS 5-10) | phenol block - 0.5ml of 10% phenol in glycerin at T11/12 After block, patient received buprenorphine, diazepam, thiamylal with little or no effect Previous treatments Effective: vigorous rubbing of lower left abdomen Ineffective: acupuncture, dorsal column stimulator, TENS, antidepressants, major tranquilizers, NSAIDs | Outcomes: - block produced anesthesia to T11 on left with resolution of pain for 2 h - subsequent severe (VAS 10) continuous pain Adverse effects: marked worsening of pain Severity of adverse effects: NR Comments: - Block receded after 60 h and pain returned to previous level. - Input above area of deafferentation had an inhibiting effect on the pain in the area of deafferentation.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition of pain provided.

Supplemental Evidence Table 5.1.13: Combination (Gabapentin and Clonazepam)

Author | Patient Description | Intervention | Findings & Comments
Author: Ness, 1998 Country: USA Setting: Tertiary care Refman ID: | 40 y old male Level of injury: T12/L1 fracture dislocation, Incomplete Frankel Cause of injury: traumatic Surgical stabilization: NR Time since injury: approximately 15 y Duration of pain: 8-10 episodes per d Onset of pain: "shortly after injury" Outcome measure: verbal 10-point scoring system (0 absence; 10 maximum pain) Pain description: episodic bursts of "searing" pain, burning | Gabapentin: Titration to 400 mg po t.i.d. Stepwise advancement to 600 mg q.i.d. over a 9 m period Clonazepam: 2400mg/d+ tramadol 100 mg po t.i.d. was added to improve effect on pain Previous treatment: Ineffective: carbamazepine, intravenous lidocaine, oral mexilitine, prolisin and thorazine (no benefit or unacceptable side effects) | Substantial reduction in frequency (5-6 episodes per d) and average intensity of the pain (subjective pain rating of 2-3/10). Benefit persisted for 22 m - pain rating 1-2/10 Adverse effects: tremors, somnolence, and inability to concentrate Severity of adverse effects: Required discontinuation of the drug on two occasions Comments: This report emphasizes the value of regional blood flow (rCBF) using single photon emission computed tomography (SPECT) to "measure" pain.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition of pain provided.

Supplemental Evidence Table 5.1.14: Combination (Gabapentin, Tramadol, Flunitrazepam)

Author | Patient Description | Intervention | Findings & Comments
Author: Mercadante 1998 Country: Italy Setting: Tertiary care Refman ID: 053 | 3 case reports Gender: 3 male Age: 62 y, 67 y, 54 y Level of injury: 2 lumbar, 1 paraplegic Cause of injury: 2 falls, 1 failed back surgery Surgical stabilization: 1 No Time since injury: 10 y, 2 NR Duration of pain: NR Onset of pain: NR Outcome measures: VAS 10 Pain description: allodynia, burning, electric, hyperalgesia, hyperpathia. Rhythmic periodic, intermittent, irradiating, belt pain to the back, shocking pain at the legs Duration of observation: NR | Intervention: Gabapentin: Pt #1: 300 t0 600 mg per d; Pt #2: 300 mg bid increased over 2 w to 1,600 mg d; Pt #3:300 at bedtime to 1,200 mg bid Tramadol: Pt #1: low dose; Pt #3: 400 mg/d Flunitrazepam: Pt #1: 20-30 mg d Previous treatment Pt #1: Laminectomy, Physiotherapy and TENS and flunitrazepam Pt #2: epidural stimulation stimulation, baclofen, NSAIDS, morphine and tramadol Pt #3: tramadol, codeine-paracetamol, NSAIDS, steroids, antidepressants, benzodiazepine. | - Pt #1: gabapentin, tramadol and flunitrazepam. Pain progressively reduced. VAS ranged 4-7, verbal rating: moderate-acceptable. Partial reversal of sympathetic involvement signs. - Pt #2: gabapentin only. VAS <6, acceptable pain relief, myoclonic jerks disappeared. - Pt #3: gabapentin and tramadol. Pain originally VAS 8-10, reduced to VAS 3-6 Adverse effects: - Pt #1: None - Pt #2: severe somnolence and myoclonic jerks with incorrect doses (400 mg bid) - Pt #3: dizziness and somnolence reported during the first days of treatment (progressively disappeared) Severity of Adverse effects: Adverse effects of gabapentin were transient and mild-to-moderate in severity. These may be prevented by gradually increasing the dosage over time. Comments: - Gabapentin potentially useful where conventional analgesics are ineffective.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Central dysesthetic pain defined as the presence of pain caudal to the site of injury for any period of at least 4 w postinjury.

Supplemental Evidence Table 5.1.15: Other (Aspirin in Chloroform)

Author | Patients Description | Intervention | Findings & Comments
Author: Tharion, 1997 Country: India Setting: Tertiary care Refman ID: 098 | 7 case reports Gender: 6 male Age: mean 42 y, min 35 y, max 50 y Level of injury: 2 cervical, 5 thoracic Cause of injury: NR Surgical stabilization: NR Time since injury: NR Duration of pain: mean 6.7 m Onset of pain: NR Outcomes: good, fair, poor relief of pain Pain description: Root pain, central pain legs | Topical application of aspirin in chloroform over the painful areas up to 6 times per d Formulation of the solution: 300mg acetyl salicylic acid dissolved in 15 ml of chloroform Previous treatment: Effective: 4 AP iv (immediate release) Ineffective: 12 y of cross section of analgesics modalities and wheelchair positioning. Outcome measures: Numerical scale (0: no pain-100: as bad as it gets) | - 5 subjects report "good" response, Score 25; - 2 subjects report "fair" response, Score 30-40 - Onset of pain relief started within 10-20 minutes of application. - Duration of relief after each application varies between 2 & 8 hours. Other benefits: sleep no longer disturbed due to pain Adverse effects: None on these patients. One person in the trial showed mild, transient erythema of the skin. Severity of Adverse effects: NR Comments: - The seven patients reported here come from a non-randomized, before-and-after trial of 15 patients with complaints of severe chronic neurogenic pain in whom conventional methods of analgesia were unsuccessful. - All patients scored 100 before the trial started. - One pt with spinal tuberculosis paraplegia (reported as a patient with chronic pain following spinal cord injury) had complete relief of pain after 3 w of repeated application of the solution.
Author's description of pain - "Pain of burning, stabbing, or sharp shooting quality segmentally at or diffusely below the neurological level of lesion"

Evidence Table 5.2: Pharmacologic Studies Sorted by Study Design

Author | Table Number | Study Design | Key Elements | Conclusions
Chiou-Tan, 1996 | 5.1.6 | RCT Crossover design 15 subjects | Local anesthetic - mexiletine, 450 mg/d orally, 1 week washout, 4 week drug or placebo, 10 weeks total study period | - 11 subjects (63%) completed trial - no significant effect of mexiletine on SCI dysesthetic pain scales or the Barthel index - drug did not decrease injury-related dysesthetic pain
Davidoff, 1987a, 1987b | 5.1.10 | RCT double blind, placebo-controlled 19 subjects | Antidepressant - trazodone hydrocloride, 150mg/d over a 6 week course | - premature termination of study due to side effects in treatment group - no significant differences in the pain measure over time and between drug and placebo groups
Drewes, 1994 | 5.1.4 | RCT Crossover design 20 subjects | Anticonvulsant - valproate, 600-2400mg orally 3 week treatment, 2 week washout, 3 week treatment, 8 week total study period | - No significant differences between the two groups were reported, although a positive trend was observed in the valproate treatment phase - some adverse effects noted
Eide, 1995 | 5.1.1 | RCT Crossover design 9 subjects | Opioids, Combination ketamine - bolus 60 µg/kg, 6µg/kg/min, alfentanil - bolus 7 µg/kg, 0.6µg/kg/min - delivered by IV infusion | - continuous pain, allodynia, and windup pain all markedly reduced by both drugs - HPT thresholds not changed by either drug - minimal adverse effects noted
Loubser, 1991 | 5.1.7 | RCT Crossover design 21 subjects | Local anesthetic - lidocaine - subarachnoid catheter, titration every 5 minutes in 25 mg aliquots | - conclude that individual interpretation to the response of spinal anesthesia is required - long term followup is recommended in order to determine the impact of this intervention
Erzurumlu, 1996 | 5.1.11 | non-RCT contemporaneous controls 28 subjects | Combination - pharmacologic, non-pharmacologic Group 1: amitriptyline 50 mg/d, carbamazepine 600 mg/d in combination Group 2: 4Hz frequency electroacupunture | - Group 1 reached a plateau in pain scores at day15 - Group 2 reached plateau at day 7
Glynn, 1986 | 5.1.2 | non-RCT contemporaneous controls 15 subjects | Opioids and Adrenergics - clonidine150 µg in 5 ml saline via epidural lumbar catheter; morphine 5 mg in 5ml water, buprenorphine 0.3 mg in ml saline | - clonidine provided the best relief in 7 subjects - 3 subjects had relief with both clonidine and morphine - 1 subject did not find relief with any of the drugs
Epstein, 1998 | 5.1.5 | Case series 10 TSCI of 29 subjects | Anticonvulsants: gabapentine 600 to 2,700 mg/d orally | - at least 50% pain reduction reported - 20% of patients had no side effects - suggest that gabapentin is beneficial in the treatment of neuropathic pain
Fenollosa, 1993 | 5.1.3 | Case series, postal survey 28 TSCI of 33 surveyed | Opioids - Combination - Other non-pharmaceutical amitriptyline, clonazepam, NSAID, 5-OH-tryptophane, morphine, spinal cord stimulation | - SCS technique implanted permanently after waiting period of 2-3 m. Recommended only for patients with radicular pain - None of the 8 pts on morphine developed tolerance after 3 y of treatment
Glynn, 1992 | 5.1.8 | Case series 10 subjects | Adrenergic Agent - Clonidine 150 µg in 5 ml saline | - 5 of 6 patients with muscle spasms obtained good to total relief after injection of clonidine - 1 failure following parenteral injection - most of the patients (8) experienced drowsiness
Heilporn, 1977-78 | 5.1.12 | Case series Retrospective 11 TSCI subjects | Multi-disciplinary approach - 11 patients were given a combination of melitracen-flupenthixol, 3 patients were subjected to a therapeutic trial of transcutaneous nerve stimulation (2 patients participated in both trials) | - authors feel that stubborn pain may benefit from a trial of the drug combination of melitracen-flupenthixol - transcutaneous stimulation did not provide sedation for root pain in this trial
Loubser, 1996 | 5.1.9 | Case series 9 TSCI subjects | Baclofen - intrathecal pump (lumbar subarachnoid catheter) | - findings suggest that intrathecal baclofen does not decrease chronic neurogenic spinal cord pain - 78% of patients had no significant change in pain severity

Evidence Table 6.1: Characteristics of Studies Using Spinal Cord Stimulation

Author | Study Design/Quality | Patient Description | Intervention | Outcome Measures & Findings
Author: Broggi, 1994 Country: Italy Setting: Tertiary care Refman ID: 432 | Design: case series of 23 SCI /363 in 32 Italian hospitals Followup: unable to determine Reliable/valid outcome measures: NR Length of study: 2 y | Gender: NR Age: NR Level of injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Onset of pain: NR Duration of pain: range 2-40 y for total sample Pain description: NR | Intervention: Epidural spinal cord stimulation Type: unipolar/multipolar Stimulation test: mean 17 d Final implant: radiofrequency/programmable | Outcome measures: VAS categorical (no pain - excruciating), use of stimulator, use of medication, QOL. Authors reported results for TSCI subjects as:; - stimulation efficacy suddenly disappears; - no patients used stimulation at 1 y followup; Adverse Effects:; - displacement of lead leakage 4%; - infection of subcutaneous pocket 1%; - infection of surgical wound 1%; - lead breakage 2%
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Meglio 1989a, Meglio 1989b, Cioni 1995 Country: Italy Setting: Tertiary care Refman ID: 137, 138, 344 | Design: retrospective case series of 16/41 SCI Followup: mean 15.9 m Reliable/valid outcome measures: NR Length of study: 1 to 3 w before permanent device implanted | Gender: 56% male Age: mean 54.9 y Level of injury: cervical (1), thoracic (11), lumbar (4) Completeness of injury: incomplete (not specified) Cause of injury: NR Time since injury: mean 91.1 m Duration of pain: NR Onset of pain: NR Pain description: deafferentation pain, paraplegic pain | Intervention: spinal cord stimulation Dose: rectangular pulses 0.2 msec duration at 85 cps Frequency: 20-30 m, 2-3 times/d (test trial) | Outcome measures:; - VAS reported as % of analgesia; - binary pain relief outcome, number with >50% pain relief at test period: 7/16 at followup: 3/16 patients reported 70%, 75%, and 75% analgesia at 15, 30, and 40 months followup; - 7/16 patients received a permanent device; Adverse Effects: muscle spasms (2), radicular muscle twitches (1); no major complications occurred
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Nielson 1975 Country: USA Setting: NR Refman ID: 227 | Design: retrospective case series of 18 SCI / 130 Followup: complete Reliable/valid outcome measures: NR Length of study: NC | Gender: NE Age: NE Level of injury: paraplegic, level not recorded Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NE Onset of pain: NE Pain description: intractable radicular | Intervention: Spinal cord stimulation Dose: NR Frequency: NR | Outcome measures:; - categorical pain relief (excellent, good, fair, failure); - binary (satisfactory/unsatisfactory); Postcordotomy dysesthesia (n= 12): 5 excellent; 3 good; 1 fair; 3 failure Paraplegia pain (n= 6): 2 satisfactory Adverse effects: unable to determine which adverse effects were present in the 18 SCI patients
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Richardson 1987, 1988 Country: USA Setting: Tertiary care Refman ID: 297, 298 | Design: case series of 15/81 SCI; 20 patients were assessed & 15 had implantation Followup: 1 y Reliable/valid outcome measures: NR Length of study: 1 y | Gender: NR Age: NR Level of injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration, onset of pain: NR Pain description: Other, intractable | Intervention: Spinal cord stimulation Type: percutaneous, epidural stimulator, dorsal column stimulator, spinal cord stimulator Dose: NR Frequency: NR | Outcome measures:; - % of pain relief Post-op - 11/15 responded successfully 1 y - 5/12 still responding successfully; Adverse Effects: Technical malfunctioning (10); no mortalities, some "unusual" morbidities (not specified); no problems with infection - major problems included patient noncompliance in use & care of the equipment & nonreliability of patients in following instructions.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Shimoji, 1993 Country: Japan Setting: NR Refman ID: 88 | Design: Prospective case series of 12 SCI/454 Followup: complete Reliable/valid outcome measures: NR Length of study: NR | Gender: 91% male Age: mean 51 y Level of injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: NR | Intervention: percutaneous spinal cord stimulation Dose: 0.5 to 5.0V for 30 minute time intervals Frequency: 1.6-8.0 Hz Stimulation test: 3-67 d Final implant: <1w to >1 y | Outcome measures: (taken before and after intervention): Binary outcome of pain relief 5/12 had pain relief >50%. Reduction in analgesics/tranquilizers entire study group: 11.5% discontinued drugs; 57.9% reduced drugs; 30.6% no change in drug use; no patient increased drug use. Adverse Effects: CSF leak (6), infection at catheter site (27), displaced electrode (22), catheter break (8)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 6.1: Characteristics of Case Studies Using Spinal Cord Stimulation

Author | Study Design/Quality | Patient Description | Intervention | Outcome Measures & Findings
Author: Buchhaas 1989 Country: Germany Setting: Tertiary care Refman ID: 638 | Design: case series of 7 SCI Followup: complete Reliable/valid outcome measures: NR Length of study: 1 y | Gender: 75% male Age: mean 44.5 y Level of injury: cervical, thoracic Completeness of injury: 2 complete, 5 incomplete Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: causalgia, phantom, vegetative, hyperpathia | Intervention: Spinal cord stimulation at conus or mid-thoracic area Type: unipolar/bipolar Dose: NR Frequency: NR | Outcome measures: Categorical outcome for pain relief Stimulation in mid. thoracic spine (3) postop; - 80-100% relief (1/3); - 50-80% relief (1/3); - 0-30% relief (1/3) at 1y; - 50-80% relief (2/3) removal of electrode (1/3) Stimulation of conus/epiconus (4) postop & 1 y; - 80-100% relief (3/4); - 30-50% relief (1/4); Adverse effects: deterioration in 1 patient
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Cole, 1991 Country: UK Setting: Tertiary Care Refman ID: 271 | Design: Case reports (4) - 3 with TSCI Followup: 4 d to 3 w Reliable/valid outcome measures: NR | Gender: 2 male, 1 female Age: 26, 43, 41 Level of injury: thoracic Completeness of injury: complete Cause of injury: 2 MVA, 1 NR Time since injury: 2 y, 16 y, 3 y Duration of pain: 2 y, 15 y, 3 y Onset of pain: soon after Pain description: sharp, worsening, persistent, present to some extent at all times | Intervention: Spinal Cord Stimulation Dose: varied Frequency: rate 10-100 HZ, ampl 1-10 mA, duration 10-100 us If no effect is found within a reasonable period between one week to a month or so, then the electrode is removed. | Outcome measures: relief of pain Adverse Effects: NR Authors conclusion: SCS is not an effective technique for the relief of chronic deafferentation pain projected below the level of complete SCI.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Intractable central deafferentation pain
Author: Devulder, 1991 Country: Belgium Setting: Tertiary Care Refman ID: 567 | Design: Case series 2/69 Followup: Not specific Reliable/valid outcome measures: NR | Gender: 1 male, 1 female Age: NR Level of injury: paraplegic Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: neurogenic | Intervention: Spinal Cord Stimulation, neurosurgical implantation, unipolar electrode, monopolar stimulation system Dose: NR Frequency: 8.5 mA; 230 us; 60pps RF | Outcome measures: 4 categories: good pain relief, no analgesics; good pain relief, occasional nonnarcotic analgesics; little pain relief, continuing need for narcotic analgesics; discontinuation of stimulation procedure Both TSCI patients had the stimulation device removed. Adverse Effects: (entire sample) technical complications 69; revisions 107; functional complications 12
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Kumar, 1991 Country: Canada Setting: Tertiary care Refman ID: 111 | Design: case series of 2/121 SCI Followup: every 6 m for up to 10 y Reliable/valid outcome measures: VAS, MPQ Length of study: up to 10 y | Gender: NE Age: NE Level of injury: Paraplegic Completeness of injury: Incomplete Cause of injury: GSW Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: burning, deafferentation pain, other-intractable | Intervention: Epidural Spinal Cord Stimulation Implantation within the periventricular grey matter, specific sensory thalamic nuclei, or the internal capsule. | Mean pain reduction:; - early pain relief: 1 successful; - long-term pain relief: 0 successful; Adverse Effects: NC for TSCI patients. For entire sample of 121: displaced electrode, infection, fractured electrode, electrical leak, battery depletion, cerebrospinal fluid leak Comments: All conventional methods of pain control had previously failed in this population.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Lazorthes, 1978 Country: France Setting: Tertiary Care Refman ID: 215 | Design: case series of 2/12 Followup: NR Reliable/valid outcome measures: NR Length of study: NR | Gender: 1 male, 1 female Age: 32 y, 50 y Level of injury: thoracic, both paraplegic Completeness of injury: 1 complete, 1 incomplete Cause of injury: 1 traumatic, 1 postradiotherapeutic Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: causalgia, intractable chronic pain, rebellious pain | Intervention: Percutaneous implantation of pain-relieving stimulator; 1 case anterior stimulation, 1 case posterior stimulation Dose: NR Frequency: NR | Outcome measures: scale 0 to 4; 1 subject had complete relief (4) one subject had initial relief (3) which then deteriorated to no relief (0) Adverse Effects: displacement of electrodes Comments:; - Authors do not conclude that anterior medullary stimulation is better than posterior column stimulation.; Article published in French.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Long, 1975, Long 1981 Country: USA Setting: Tertiary Care Refman ID: 856, 792 | Design: case series 3/69 with TSCI Followup: evaluated post-operatively for more than 30 m Reliable/valid outcome measures: NR Length of study: NC | Gender: NR Age: NR Level of injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: burning, dysesthesia | Intervention: Dorsal column stimulators Dose: as needed Frequency: NR | Outcome measures: Patient statements of pain relief and a combined set of criteria from the protocol adopted by the National Study Group for Dorsal Column Stimulation Adverse Effects: not available for TSCI population. For the entire sample: 1 postop clot, 2 paraparesis, 8 postop cerebrospinal fluid collections, 33 failure of stimulation into a painful part, 2 excessive stimulation in the perineum, 2 primary infections, 2 erosion of equipment, 1 cerebrospinal fluid leak, 1 allergic reaction
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Moraci 1982 Country: Italy Setting: Tertiary Care Refman ID: 309 | Design: 1 case report Followup: NR Reliable/valid outcome measures: NR Length of study: NC | Gender: 1 male Age: 58 Level of injury: cervical Completeness of injury: NR Cause of injury: MVA Time since injury: 2 y Duration of pain: 20 m Onset of pain: 4 m Pain description: intractable pain | Intervention: Spinal cord stimulation, electrodes implanted percutaneously into the epidural space Dose: 1 hour 3 times/d Frequency: 50-60 pulses/second, pulse width 100 to 400 msec, voltage 0.5 to 0.8 volt | Outcome measures: 10 m followup: good relief of pain without drugs Adverse Effects: Hypotonia of the legs
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: North 1991; North 1993 Country: USA Setting: Tertiary Care Refman ID: 591, 514 | Design: 5/62; retrospective case series Followup: mean 2.14 y following implantation Reliable/valid outcome measures: McGill Length of study: NR | Gender: 55% male Age: mean 48.3 y; min 21 y, max 72 y Level of injury: 4 paraplegic Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: 10.6 y; min 1 y, max 40 y Onset of pain: NR Pain description: intractable, chronic pain | Intervention: percutaneous and laminectomy electrodes, single and multichannel devices Dose: NR Frequency: NR | Outcome measures: 2/5 success (success defined as at least 50% reported relief of pain 2 y postoperatively and patient satisfaction with treatment. Patients with spinal cord injury reported slightly longer latency and much shorter persistence of pain relief. Adverse Effects: Lead fracture (13%), electrode migration (0), infection (11%) were all discussed for the entire population.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Richardson, 1980 Country: USA Setting: Tertiary Care Refman ID: 207 | Design: prospective case series; 7/10 TSCI Followup: Diagnostic testing 3 to 5 d after implant, 1 y followup Reliable/valid outcome measures: NR Length of study: 1 y | Gender: NR Age: NR Level of injury: 6 thoracic; 1 lumbar Completeness of injury: 5 complete Cause of injury: 5 GSW, 1 MVA, 1 Other trauma Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: intractable pain | Intervention: percutaneous, epidural, dorsal column & peripheral neurostimulation Dose & Frequency: "as per published techniques" In addition to stimulation, 5 of 7 patients received some form of medication: Diazepam (4); codeine phosphate and acetaminophen (2); oxycodone with aspirin, phenacetin, and caffeine (2) | Outcome measures: % of pain relief Results:; - initial results: 2/10 had significant pain relief (>50%); - 1 y after implantation only 1 patient was still using the stimulator with significant pain relief; Adverse Effects: none mentioned
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Diffuse, nonlocalized, central (or phantom) type of pain is most common, most severe, and the most difficult to treat. It is typically described as "burning," although it is also described as "aching," "cramping," "tingling," and "tightening and often involves the feet."
Author: Simpson, 1991 Country: UK Setting: Tertiary care Refman ID: 593 | Design: case series 2/60 with TSCI Followup: 2 w to 9 y, median 29 m entire sample Reliable/valid outcome measures: NR Length of study: NC | Gender: NR TSCI; 57% male entire sample Age: NR TSCI; median 55 y entire sample Level and Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR TSCI; median 9 y entire sample Onset of pain: NR Pain description: intractable, paraperesis | Intervention: Spinal cord stimulation Dose: NR Frequency: NR | Outcome measures: categorical - made worse (MW), no effect (NE), modest benefit (MB), significant benefit (SB); - 2 TSCI subjects had SB - complete or partial relief; Adverse Effects:; - sustained relief with a significant effect on medication, activity, lifestyle, sleep pattern.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Tsuda, 1985 Country: Japan Setting: Tertiary Care Refman ID: 741 | Design: case series 8/44 TSCI Followup: 1 y Reliable/valid outcome measures: NR Length of study: surveyed 6 m after surgery | Gender: 88% male Age: mean 44 y Level of Injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: mean 4.6 y Onset of pain: NR Pain description: burning, deafferentation | Intervention: percutaneously inserted spinal cord electrical stimulation Dose: NC Frequency: NC | Outcome measures: good, fair, poor relief of pain.; - at 6 m: 2 fair, 6 poor; Adverse Effects: NR Article published in Japanese.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Urban, 1978 Country: USA Setting: Tertiary care Refman ID: 825 | Design: 3/20 case series Followup: up to 2 y Reliable/valid outcome measures: No - subjective patient report Length of study: 2 w observation period, followup up to 2 y | Gender: 1 male, 2 female Age: 42, 69, 39 y Level of injury: L2, T11, L3/T12 Completeness of injury: NC Cause of injury: trauma Time since injury: NR Duration of pain: 14 y, 2 y, 12 y Onset of pain: NR Pain description: intractable | Intervention: percutaneous epidural stimulation Dose: NR Frequency: 9 v battery-powered radio transmitter, pulse width 200 to 300 msec, frequency between 7 and 200 Hz, voltage 0 and 15 V. | Outcome measures: 4 categories of pain relief - 0% to 24% poor; 25% to 49% fair; 50% to 74% good; 75% to 99% excellent. Positive results were noted only if pain relief was constant and persistent over several months.; - 1 subject had no relief of pain (poor); - 1 subject had decreased pain (fair) for up to 1 y; - 1 subject had some relief (fair) for up to 6 m; Adverse Effects: not reported for TSCI population: in general, cessation of stimulation, skin erosion, infection Comments:; - All patients were suffering from chronic pain that had failed to respond to extensive prior treatment.; - Authors state overall poor results in controlling chronic pain with electrical stimulation of the spinal cord are confirmed with this study.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 6.2: Characteristics of Studies Using Brain Stimulation

Author | Study Design/Quality | Patient Description | Intervention | Outcome Measures & Findings
Author: Levy 1987, Adams 1974 Country: USA Setting: Tertiary care Refman ID: 149, 870 | Design: case series of 11/141 SCI Followup: NC; initial followup within 6 w of implantation; mean long-term followup 80 m Reliable/valid outcome measures: NR Length of study: NC | Gender: NR Age: mean 50.1 y Level of injury: paraplegic Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: 95.9 m Onset of pain: NR Pain description: allodynia, aching, burning, deafferentation pain, hyperesthesia, hyperalgesia, intractable | Intervention: Deep brain stimulation Fourteen electrodes, 7 sensory thalamic and 7 PAG/PVG, implanted in 11 patients with pain secondary to spinal cord injury. Two of each class of electrodes were internalized. | Long-term success defined as continued regular use of the stimulator with reported pain relief. Mean pain reduction:; - # patients with pain relief at treatment 36% (4/11); - at followup: none (0/11); Adverse Effects: NC for TSCI patients. For entire sample of 141:; - infection 12%; erosion of hardware 7%; foreign body reaction 5%; intracranial hemorrhage 3.5%; psychosis 2%
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Pain that occurs after the nervous system has been damaged

Supplemental Evidence Table 6.2: Characteristics of Case Studies Using Brain Stimulation

Author | Study Design/Quality | Patient Description | Intervention | Outcome Measures & Findings
Author: Hosobuchi, 1975 Country: USA Setting: Tertiary care Refman ID: 228 | Design: case reports, 1/11 TSCI Followup: NR Reliable/valid outcome measures: NC Length of study: NR | Gender: NR Age: NR Level of injury: NR Completeness of injury: paraplegic Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: dysesthesia | Intervention: thalamic electrical stimulation Dose: acute stimulation of the posterior portion of the ipsilateral internal capsule | Outcome measures: "remarkable pain relief"; now has chronically implanted internal capsular electrodes that can be activated from an external system and continue to provide satisfactory relief from dysesthesia Adverse Effects: None reported.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Pain below the sensory level
Author: Kumar, 1997; Kumar, 1990 Country: Canada Setting: Tertiary care Refman ID: 37, 1573 | Design: case series of 3/68SCI Followup: every 6 m for up to 15 y Reliable/valid outcome measures: VAS, MPQ Length of study: NC | Gender: NE Age: NE Level of injury: Paraplegic Completeness of injury: Incomplete (not specified) Cause of injury: GSW Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: burning, deafferentation pain, other-intractable | Intervention: Deep brain stimulation Implantation within the periventricular grey matter, specific sensory thalamic nuclei, or the internal capsule. | Outcome measures: VAS, modified MPQ, categorical (poor, good, excellent) Mean pain reduction:; - early pain relief: 1/3 successful; - long-term pain relief: 0 successful; Adverse Effects: NC for TSCI patients. For entire sample of 68: infection, fractured electrode, hardware malfunction, electrical leak seizures, intracerebral haematoma, blurred vision, headache like pain Comments:; - Patients with SCI did poorly, whereas patients with failed back syndrome, trigeminal neuropathy, and peripheral neuropathy fared well.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Neuropathic pain originates from injury to the nervous system, anywhere from peripheral nerves to supraspinal structures "characterised by a localised burning pain felt on the surface of the body and is most often unilateral."
Author: Nguyen, 1999 Country: France Setting: Tertiary Care Refman ID: 006 | Design: Prospective, case series, 3/32 patients had TSCI Followup: mean 27.3 m Reliable/valid outcome measures: VAS, MQS, ADL Length of study: NC | Gender: NR for TSCI; 18/32 (56%) Age: NR for TSCI; mean 54 y sample Level of injury: paraplegia 3/3 Completeness of injury: NR Cause of injury: NR Time since injury: NE Duration of pain: NR for TSCI; 7.8 y entire sample Onset of pain: NR Pain description: allodynia, central pain, dysaesthesia, paraplegic pain | Intervention: chronic motor cortex stimulation Frequency: 40Hz (25-55) Pulse width 82.5 us (60-80), amplitude 2.1V (1.3-4) | All patients had previously proven resistant to extensive pharmacotherapy. Outcome measures: VAS, MQS, ADL. Results NE for TSCI patients. Adverse Effects: NC for TSCI patients. For entire sample of 32: subcutaneous infection 1/32; partial dehiscence of stimulator pocket scar 1/32; headache 3/32; asymptomatic epidural hematoma 1/32. Possible overlap of subjects with Nguyen, Keravel, Feve, et al., 1997. Unable to clearly determine.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Nguyen, 1997 Country: France Setting: Tertiary Care Refman ID: 29 | Design: prospective followup of 20 patients; 2/20 TSCI Followup: 18 m Reliable/valid outcome measures: VAS Length of study: NC | Gender: 100% male Age: 39, 35 Level of injury: 1 paraplegia, 1 tetraplegia Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: constant, severe, burning pain, deafferentation, deep visceral | Intervention: chronic stimulation of the motor cortex, site located based on MRI, verified by teleradiography Frequency: 40.8 Hz (25-55 Hz), duration 90 microseconds (60-180), amplitude 2.4 volts | Outcome measures: VAS graded from 0 to 100; 1 patient reported excellent results (80-100 VAS); 1 was recorded as a failure (<40% reduction of pain) Adverse Effects: none in TSCI patients; In complete sample: 3 dysesthesia, 1 speech disorder; 1 extradural haematoma (spontaneous resolution); no induced motor activation or epilepsy; no technical problems or infections were observed Possible overlap of subjects with Nguyen, Lefaucheur, Decq, et al., 1999. Unable to clearly determine.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Diffuse pain situated below the level of the lesion and deep visceral pain
Author: Young, 1992 Country: USA Setting: Tertiary care Refman ID: 212 | Design: case reports; 1/6 TSCI Followup: 2 y Reliable/valid outcome measures: NR Length of study: 7 y | Gender: female Age: 36 y Level of injury: cervical spine Completeness of injury: NR Cause of injury: MVA Time since injury: 20 y Duration of pain: 18 y Onset of pain: 2 y Pain description: severe, persistent, deafferentation | Intervention: chronic electrical stimulation of the Kolliker-Fuse nucleus region Frequency: 50-60 Hz, pulse width 0.1 msec, amplitudes 3-6 V | Outcome measures: excellent pain relief Adverse Effects: Initial electrodes removed because of ineffectiveness.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 6.3: Characteristics of Studies Using Transcutaneous Electrical Nerve Stimulation (TNS) for Treatment of Pain

Author | Study Design/Quality | Patient Description | Intervention | Outcome Measures & Findings
Author: Davis, 1974, 1975 Country: USA Setting: Tertiary care Refman ID: 866, 368 | Design: case series, 31 patients; 11/31 with Type C pain (see definition) Followup: 100% Reliable/valid outcome measures: No Length of study: 1 w to 1 m | Gender: NR Age: min 23 y, max 68 y Level of injury: 13% cervical, 35% thoracic, 48% conus/cauda equina Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: central, neuropathic at level (radicular, central), neuropathic below level | Intervention: TNS Dose: solid state battery-operated pulse generators delivering variable electrical spikes to a pair of electrodes Frequency: as needed Additional treatments: Almost all patients required analgesics such as pentazocine, carbamazepine and oxycodon for relief. | Outcome measures:; - success - 36% (11/31) enough relief to warrant wearing the TNS whenever pain was present and reduction in dosage of analgesics noted; - partial success - 6% (2/31) some relief, but not enough to want to bother taping on the electrodes and keeping device with them; - failure - 58% (18/31) no relief at all; Relief according to type of pain: Type A pain (11): 7 successes, 1 partial, 3 failures Type B pain (9): 2 successes, 1 partial, 6 failures Type C pain (11): 2 successes, 9 failures Relief according to injury site: Cervical (4): 4 failures Thoracic (11): 5 successes, 6 failures Conus, cauda equina (16): 6 successes, 2 partial, 8 failures Adverse Effects: none mentioned
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Type C pain due to damage to the spinal cord itself, sometimes called central pain and is "referred" from the patients' anesthetic areas
Author: Doctor, 1996 Country: USA Setting: Tertiary care, community Refman ID: 1455 | Design: RCT, double blind, placebo controlled. 40 subjects, 50% neurogenic pain, 50% musculoskeletal pain Followup: NR Reliable/valid outcome measures: yes Length of study: 1.5 hours | Gender: 88% male Age: mean 46 y Level of injury: 50% Cervical, 38% Thoracic, 13% Lumbar Completeness of injury: 42% complete, 58% incomplete Cause of injury: NR Time since injury: mean 12.4 y Duration of pain: mean 9.4 y Onset of pain: NR Pain description: below level of injury, tingling, radiating, cold, squeezing | Intervention: TNS, Epix-XL continuous square wave pulse stimulation Dose: individually tailored for each subject, 100 ppi Frequency: 30 minutes | Outcome measures: MPQ, STAI, DDS Adverse Effects: Results: Pain unpleasantness ratings:; - Placebo- positive expectation 7.9 (3.5); - neutral expectation 7.8 (3.7); - Active- positive expectation 8.8 (1.7); - neutral expectation 4.9 (2.0); Posttreatment pain intensity means:; - Placebo-positive expectation 9.0 (5.2); -neutral expectation 12.9 (3.2); - Active-positive expectation 8.7 (3.0); -neutral expectation 7.8 (2.0); Comments: neurogenic pain subjects generally ended with more pain than musculoskeletal subjects
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - The result of direct damage to the spine, originating from nerve tissue; centrally mediated pain resulting in sensations of pain experienced below the level of injury; pain system not working properly = chronic pain.

Evidence Table 7.1: Characteristics of Studies for Dorsal Root Entry Zone (DREZ) Interventions

Author | Study Design/Quality | Patient Description | Intervention | Findings & Results
Author: Edgar, 1993 Country: USA Setting: NR Refman ID: 091 | case series of 46 computer assisted (CA) DREZ/112 CA DREZ or standard DREZ Followup: 91% complete (n=112) Reliable/valid outcome measures: NR Length of study: 44 m average follow up; min 2 m, max 96 m | Gender: NR Age: NR Level of injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration & Onset of pain: NR Onset of pain: NR | DREZ: Radiofrequency, computer assisted 85°C, 30 s/lesion, 1 lesion/mm | Outcome measures: Binary outcome for pain relief Pain relief: 92% (50-100% pain relief) 84% (100% pain relief) Adverse Effects: Reported for complete sample (n=112) neurological deficit (5), sensory deficit (2), motor deficit (3), CSF leak (3), pulmonary embolus (2), posttraumatic autogenic myelopathic myoclonus (5), wound infection (0) Comments: Number of CA DREZ followed up unclear
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - burning, shock-like, or sharp lightning-like pain, at and distal to the cor injury site in a nondermatomal pattern in anesthetized or partially anesthetized areas
Author: Friedman 1986 Country: USA Setting: Tertiary Care Refman ID: 362 | case series of 54 SCI/56 SCI and spinal tumors Followup: 100% complete Reliable/valid outcome measures: NR Length of study: 6 m to 60 m | Gender: 85% male (n=47) Age: min 27 y- max 72 y Level of injury: NR Completeness of injury: NR Cause of injury: 33% GSW, 67% other causes (blunt trauma) Time since injury: NR Duration of pain: > 8 m Onset of pain: < 2 m postinjury (90% patients) < 120 m postinjury (10% patients) Pain description: burning, aching, throbbing, diffuse | DREZ: Radiofrequency Earliest patients: 60mA, 15 s, spaced several mm apart Later patients: 75° C, 15 s, 1 mm spacing of lesions | Outcome Measures: Categorical outcome for pain relief Pain relief: include range if reported as n=54; - 26-28/54 good (pain free; no analgesic use; no limitation of activity by pain); - 3-5/54 fair (nonnarcotic usage for pain); - 21-23/54 poor (narcotic usage; limitation of activity by pain); Adverse Effects: CSF leak (9), epidural hematoma (1), weakness (2), transient urinary incontinence (2), new dysesthesias (2) Patient description and adverse effects data reported for n=56. Unable to exclude two spinal tumors from sample. Comments: Possible overlap of subjects with Sampson, 1995
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Nashold. 1981 Country: USA Setting: Tertiary Care Refman ID: 799 | case series of 9 SCI/13 SCI (including cauda equina) Followup: 100% complete Reliable/valid outcome measures: NR Length of study: 5 -38 m | Gender: 78% male Age: mean 47 y; (min 17 y - max 74 y) Level of injury: 33% thoracic; 56% thoraco-lumbar; 11% lumbar Completeness of injury: 78% complete; 22% incomplete motor Cause of injury: 11% road traffic accident; 11% GSW; 78% NR Time since injury, Duration of pain: NR Onset of pain: within 12 y Pain description: burning, sharp, stabbing, tingling, diffuse | DREZ: Radiofrequency (no other parameters reported) | Outcome measures: Categorical outcome for pain relief Pain relief: 4/9 excellent (total pain relief); 3/9 good (50% pain relief); 2/9 poor (no significant pain relief) Adverse Effects: lost effective hand motor function (1)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - Pain is characteristically severe, diffuse, and continuous with periods of exacerbation. Described as burning or tingling in nature, and hyperesthesia may be present in the affected region.
Author: Nashold. 1990 Country: USA Setting: Tertiary Care Refman ID: 612 | case series of 16 SCI/18 total SCI (nontraumatic included) Followup: 100% complete Reliable/valid outcome measures: NR Length of study: 3.5 years average follow-up (n=18) | Gender: 56% male Age: 39.8 y (min 25 y - max 61 y) Level of injury: 94% paraplegic, 6% tetraplegic Completeness of injury: NR Cause of injury: 31% MVA, 11% falls, 31% GSW, 11% sports, 11% other Time since injury: NR Duration & Onset of pain: NR Pain description: burning, electric, sharp, aching, shock, radiating | DREZ: Radiofrequency 75° C, 15 s/lesion, 1 mm lesion spacing Drainage of spinal cyst | Outcome measures: Categorical outcome for pain relief Pain relief:; - 12/16 good - no analgesics, no limitation of activity by pain; - 4/16 fair - no narcotics, no limitation of activity by pain; - 0/16 poor - narcotics required and/or activity limited by pain; Adverse Effects: NR
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Powers, 1988 Country: USA Setting: NR Refman ID: 144 | case series of 9 SCI/40 with deafferentation pain Followup: 100% complete Reliable/valid outcome measures: NR Length of study: NR | Gender: NR Age: NR Level of injury: 100% thoracic; 100% paraplegic Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration & Onset of pain: NR Pain description: burning, diffuse, deafferentation, indescribable | DREZ: Variety of lasers used (type used per patient not reported) CO_2_ laser: 5 W, 0.5 s pulse exposure, 0.325-0.45 mm diameter beam spot size Argon laser: 7 W, 1.0 s pulse exposure, 0.15-0.20 mm diameter beam spot size Nd: YAG laser (frequency doubled): 532 nm wavelength | Outcome Measures: Binary outcome for pain relief Pain Relief: 5/9 good (>50% pain relief; no narcotic analgesic use); 4/9 failure Adverse Effects: Reported for SCI sample only (n=9) ipsilateral lower extremity weakness (1), wound infection/CSF leak (1)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Rath 1997, Rath 1996, Richter 1984 Country: Germany Setting: Tertiary Care Refman ID: 019 | case series of 23 SCI/68 with deafferentation pain Followup: 100% complete Reliable/valid outcome measures: NR Length of study: 58 m average followup 58 m; range 10-157 m | Gender: 83% male Age: 47 y (min 17 y - max 74 y) Level of injury: 91% thoracic, 19% lumbar; 91% paraplegic Completeness of injury: complete, incomplete motor, incomplete sensory (% NR) Cause of injury: NR Time since injury: NR Duration & Onset of pain: NR Pain description: deafferentation pain, endzone pain, diffuse pain | DREZ: Radiofrequency 75°C, 15 s, 1-2 mm spacing of lesions 5 patients required cyst evacuation/drainage in addition to DREZ | Outcome measures: Categorical outcome for pain relief Pain relief:; - DREZ only: 11/23 good (relief >75%); 2/23 fair (relief = 25% to 75%); 9/23 poor (relief <25%); 1/23 recurrence (8 m post-Rx) after initial 60% relief; - DREZ + cyst evacuation: 1/5 satisfactory pain relief 4/5 unsatisfactory pain relief; Adverse Effects: temporary gait ataxia, slight paresis of foot, hyperesthesia below lesion, temporary bladder dysfunction, paresthesias, disturbed wound healing (n not reported). All adverse effects reported for complete sample (n=68).
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Sampson 1995 Country: USA Setting: Tertiary Care Refman ID: 430 | case series of 23-29 SCI (6 possible avulsions)/39 SCI and cauda equina and avulsions Followup: 100% complete Reliable/valid outcome measures: NR Length of study: NC | Gender: NE Age: NE Level of injury: 100% thoraco-lumbar Completeness of injury: complete, incomplete (% NE) Cause of injury: GSW, blunt trauma, avulsion (% NE) Time since injury: NR Duration & Onset of pain: NE Pain description: burning, electric, cramping | DREZ: Radiofrequency; - Prior to 1982: 60mA, 15 s, spaced several mm apart; - Post 1982: 75° C, 15 s, 1 lesion/mm | Outcome Measures: Categorical outcome for pain relief Pain relief: 12-15/29 good (no analgesic use); 7/29 fair (nonnarcotic usage for pain; no interference with ADLs); 4-7/29 poor (all others) Adverse Effects: weakness (4 permanent, 1 transient), CSF leak (2), sexual or bladder dysfunction (3), wound/urinary tract infection (2), parathesias (1), perioperative death (0) Reported for spinal cord sample - unable to exclude 6 avulsion injuries from sample Possible overlap of subjects with Friedman, 1986
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Wiegand, 1985 Country: Germany Setting: Tertiary Care Refman ID: 178 | case series of 15 TSCI /35 patients with deafferentation pain Followup: 100% complete Reliable/valid outcome measures: NR Length of study: NC | Gender: 88% male Age: mean 46 y Level of injury: see note Completeness of injury: see note Cause of injury: NR Time since injury: 9 y Duration & Onset of pain: see note Pain description: deafferentation, phantom | DREZ: Radiofrequency; - 40-50 mA, 15 s | Outcome Measures: 8/15 had 100% improvement Adverse Effects: none in the TSCI sample Article published in German.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Young, 1990 Country: USA Setting: Tertiary Care Refman ID: 123 | case series of 20 SCI / 78 with deafferentation pain Followup: 100% complete Reliable/valid outcome measures: NR Length of study: NR | Gender: NR Age: NR Level of injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: burning, deafferentation pain | DREZ: Group 1: Radiofrequency 0.5 x 2mm stainless steel electrode, 30-40mA, 15-20 s Group 2: CO_2_ laser, 5-10 W, 0.1-0.2 s, 0.2 mm spot size Group 3: Radiofrequency 0.25 x 2mm stainless steel electrode, 70-75°C, 15 s In all groups lesions were placed "virtually abutting" each other | Outcome Measures: Binary outcome for pain relief Satisfactory Pain Relief: (defined as a reduction of 50% or more of pain, cessation of narcotic analgesic usage and improvement in functional capacity) Group 1: 3/6 (50%) Group 2: 3/6 (50%) Group 3: 5/9 (56%) Adverse Effects: Reported for SCI patients only (n=20) (group 1, group 2, group 3) leg weakness (4,1,2), loss of proprioception (5,1,1), loss of sphincter control (1,0,0), delayed myelopathy (1,0,0), increased leg spasticity (0,1,0)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 7.1: Characteristics of Studies for Dorsal Root Entry Zone (DREZ) Interventions

Author | Patients Description | Intervention | Findings & Comments
Author: Gronning, 1997 Country: Norway Refman ID: 039 | case report Gender: male Age: 56 y Level of injury: C12 Completeness of injury: paraplegic Cause of injury: fall Surgical stabilization: yes Time since injury: 4 y Duration of pain: 3 y Onset of pain: 1 y Length of followup: 3 y Pain description: burning in the buttock area, icing in the rectum and lancinating pain to the lower extremities | Previous treatment: - combination of amitryptilin and morphine - dextropropoxyphen, ketobemidone alone or in combination with tricyclic antidepressants, carbamazepine or baclophen - trancutaneous nerve stimulation and acupuncture had no effect Current treatment: - DREZ - 2.5 y after trauma | Outcomes: - amitryptilin and morphine had a slight short-term effect - no response to treatment with simple analgesics alone or in combination with tricyclic antidepressants - trancutaneous nerve stimulation and acupuncture had no effect - DREZ had good relief according to patient Adverse effects: NR Severity of Adverse effects: NR Comments: - burning in dorsal area and piercing in legs disappeared immediately after microcoagulation - 1 y after surgery still has icing pain in rectum and sometimes in feet
Author's description of pain - IASP definition of neurogenic, chronic pain (Merskey, Boduk, 1994)
Author: Levy, 1983 Country: USA Refman ID: 1392 | 34 year old male Level of injury: T11 (GSW) Completeness of injury: Complete paraplegia Time since injury: 2 y Duration of pain: About 2 y (not reported) Onset of pain: Several m post injury Pain description: Low lumbar area, radiating to both upper legs, chiefly on right. Burning dysesthetic quality reported, not helped by "medication" NOS | Bilateral laser DREZ lesion. T8 to L1 | - Good pain relief for 1m, narcotic free; - New onset pain 1m post operatively in left hip requiring narcotics; Comments:; - Prior extensive history of drug use and psychological problems; - Followup not possible
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Samii 1984 Country: Germany Setting: Tertiary Care Refman ID: 180 | case series of 5 SCI / 35 non-SCI pathology Gender: NR Age: NR Level of injury: NR Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NC Pain description: burning, needles | DREZ: Radiofrequency 45-55 mA, 15 s, 2-3 mm spacing per lesion | Outcome measures: Categorical outcome for pain relief Pain relief: 2/5 very good (70-100% pain relief); 2/5 good (50-70% pain relief); 1/5 fair (<50% pain relief) Adverse Effects: Reported for entire sample (n=35) transient sensory deficit (9), transient motor deficit (1), transient motor and sensory deficit (8)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Author | Study Design/Quality | Patient Description | Intervention | Findings & Results
Author: Spaic, 1999 Country: Yugoslavia Setting: NR Refman ID: 17 | case series of 6 TSCI patients with deafferentation pain Followup: 100% complete Reliable/valid outcome measures: NR Length of study: 9.1 m average followup | Gender: 100% male Age: 25-35 y Level of injury: 5 thoracic, 1 lumbar Completeness of injury: 1 complete, 5 incomplete Cause of injury: GSW Time since injury: 2-5 y Duration & Onset of pain: NR Pain description: burning, chronic, constrictive, paroxysmal, diffuse | Microsurgical DREZ (MDT): an incision and bipolar coagulations performed ventrolaterally at the entrance of the rootlets into the dorsolateral sulcus. 2mm lesion made at a 45° medially and ventrally | Outcome Measures: Binary outcome for pain relief; - 4/6 100% pain relief; - 2/6 80% pain relief; Adverse Effects: infection (0), CSF leak (0), motor deficit (0) Article published in Serbo-Croatian.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - persistent, severe, incapacitating pain in the regions corresponding to the injured segments which became anaesthetic and with partial or complete loss of motor function

Author | Patients Description | Intervention | Findings & Comments
Author: Strangalis, 1997 Country: Greece Refman ID: 268 | 62 year old female Level of injury: T4 Crush with complete cord transection and neurological deficit (Fall) Time since injury: Approximately 5 y Duration of pain: 5 y Onset of pain: 3 m post injury Pain description: Burning pain in both legs initially responding to analgesics (NOS) gradually developing refractory dysaesthesias with "intense" psychological suffering | Bilateral DREZ lesioning utilizing Nd:YAG laser T2-T5 laminectomy, Lesioning to 3 cm above and below injury to depth of 2 mm (1200 Joules) | - Immediate "significant" relief of dysesthesias; Comments:; - Sensory deficit ascended by two dermatomes; - No return of pain reported; - Length of followup: NR
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Evidence Table 7.2: Characteristics of Studies Evaluating Other Spinal Surgical Procedures

Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Bohlman, 1994 Country: USA Setting: Tertiary care Refman ID: 469 | Design: case series of 45 patients Followup: 44/45 Reliable/valid outcome measures: NR Length of study: mean 50 m | Gender: 64% male Age: mean 43 y, min 16 y - max 72 y Level of injury: thoracic 13%, lumbar 18%, thoro-lumbar 69% Completeness of injury: NR Cause of injury: NR Time since injury: mean 4.5 y, min 3 m - 21 y Duration of pain: NR Onset of pain: NR Pain description: chronic pain that altered activities of daily living | Anterior decompression: costotransversectomy in 4 subjects, transthoracic in 7, and retroperitoneal in 33. | Outcome measures: neurologic examination and grading Pain relief: Neurologic exam: 21/25 improved Interview, patient assessment:; - 30/44 stated complete relief; - 11/44 stated partial relief; - 3/44 reported no change; Adverse Effects: Acute complications occurred in two patients. 1 patient died of pulmonary embolus postoperatively, 1 patient developed a partial bowel obstruction that resolved with nonsurgical supportive measures. Late complications developed in 6 patients: kyphosis (3), refracture of spine at another level (3). No loss of neurologic function from anterior thoraco lumbar decompression.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN- chronic pain that altered activities of daily living
Author | Study Design/Quality | Patient Description | Intervention | Findings & Comments
Author: Falci, 1999 Country: USA Setting: NR Refman ID: 009 | Design: retrospective case series of 59 subjects, 31 with TSCI/CNP Followup: 24/31 completed the questionnaire Reliable/valid outcome measures: NR Length of study: 1 y | Gender: % male NE Age: NE Level of injury: NR Completeness of injury: NE Cause of injury: NR Time since injury: NE Duration of pain: NR Onset of pain: NR Pain description: deafferentation pain, hypersensitivity, neurogenic | Spinal cord untethering or cyst shunting | Outcome measures: subjective patient assessment of pain Pain relief: 13/24 respondents reported substantial improvement in neurogenic pain Adverse Effects: wound infection (1), CSF leak (3), pseudomeningocele (2), cyst recurrence (1)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Jefferson, 1983 Country: United Kingdom Setting: Tertiary care Refman ID: 8010 | Design: case series 20/21 Followup: NR Reliable/valid outcome measures: NR Length of study: mean 4 to 6 y | Gender: 90% male Age: mean 37 y Level of injury: paraplegic Completeness of injury: Cause of injury: NR Time since injury: mean 8.9 y Duration of pain: mean 3.1 y Onset of pain: mean 5.8 y Pain description: electric, hyperesthesia, shooting, diffuse, electric shock, intractable | Cordectomy - excision of a section of the spinal cord for the control of pain. | Outcome measures: % relief Pain relief:; - patients with knee pain pattern (6/20) 30%; - patient with thigh pain pattern (3/20) 15%; - patient with leg pain pattern (6/20) 30%; - patient with injury T10 or higher (4/20) 20%; Adverse Effects: loculation of subcutaneous CSF (1); further surgery for CSF leak (3)
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Livshits, 1990 Country: Russia Setting: Tertiary care center Refman ID: 622 | Design: prospective case series of 28 TSCI patients or 41 subjects with CNP Followup: complete Reliable/valid outcome measures: NR Length of study: followed 1 day, 3 m, and up to 14 y | Gender:70% male Age: min 23 y, max 73 y Level of injury: cervical Completeness of injury: NR Cause of injury: NR Time since injury: NR Duration of pain: NR Onset of pain: NR Pain description: NR | 65 surgical interventions were carried out on the 41 subjects -including uni- and bilateral chordotomy, commissurotomy, posterior longitudinal myelotomy, coagulation of posterior root entry zones, percutaneous chordotomy, percutaneous rhizotomy all subjects were on medications (narcotics) that were not providing adequate relief | Outcome measures: subjective patient assessment of pain Pain relief: 83% reported relief in the immediate postoperative period and 75% in long term period Adverse Effects: NR Article published in Russian.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Schaller, 1999 Country: Switzerland Setting: Tertiary care Refman ID: 012 | Design: retrospective case series of 12 subjects with TSCI and syringomyelia Followup: complete Reliable/valid outcome measures: NC Length of study: NC | Gender: 8/12 male Age: mean 43 y (± 11 y) Level of injury: lumbar 1/12, thoracic 9/12, cervical 2/12 Completeness of injury: 10/12 complete, 2/12 incomplete Cause of injury: NR Time since injury: mean 6.8 y Duration of pain: NR Onset of pain: NR Duration of followup: mean 44 m (± 25 m) Pain description: central pain, dysesthesia | Goal of surgical treatment was to prevent further deterioration. Evaluation of various surgical treatments - laminectomy with arachnoid lysis and dural grafting (LLG) performed in 2 of 12 patients and syringoperitoneal shunting (SPS) performed in 10 of 12 patients | Outcome measures: Klekamp and Samii scoring system − 0 − 2: disabled or incapacitated function, 3 − 5: satisfactory, normal function level Pain relief: improved by 1.2 points after SPS and by 2.0 points after LLG, with a slightly better outcome in LLG Adverse Effects: NR Comments:; - age, duration of clinical history, or spinal level did not influence outcome; - pain improved in 9 of 12 patients, sensory deficits decreased in 3 of 12 patients, and motor weakness decreased in 1 of 12 patients; - shunt placement may increase arachnoid scarring and lead to a higher rate of failure
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - central or function-limiting dysesthetic pain syndromes
Author: Transfeldt, 1990 Country: USA Setting: Tertiary care Refman ID: 730 | Design: retrospective case series of 49 subjects Followup: complete Reliable/valid outcome measures: NC, MPQ Length of study: NC, mean 5.7 y, min 1 y - max 19 y | Gender: 59% male Age: mean 35 y, min 15 - max 61 Level of injury: L1 39%, T12 22%, L4 8%, other 31% Completeness of injury: 12% complete, 88% incomplete. Frankel grade A 12%, B 10%, C 20%, D 57% Cause of injury: MVA 47%, falls 27%, motorcycle 16%, other 10% Time since injury: mean 6.8 y Duration of pain: NR Onset of pain: NR Pain description: central pain, dysaesthesia | followup after Anterior Spinal Decompression | Outcome measures: evaluation of pain, neurologic function, spasticity, and correction of kyphotic deformity Pain relief: 36 patients reported a spinal cord-type pain preoperatively. 83% showed an improvement after surgery, 14% had no change. 36% reported pain had completely resolved, 22% experienced improvement in pain severity and increased pain-free intervals, 22% experienced improvement in severity of pain but no change in pain-free intervals, 11% had continued pain. 1 patient noted that pain was worse postoperatively. Neurologic function was improved postoperatively in 22 patients and remained unchanged in 27 patients. Adverse Effects: 3 dural tears, 5 blood loss > 5 liters, UTI in 4 patients, 4 prolonged ileus, 6 pulmonary complications, 2 pseudarthrosis and 2 wound infections Major benefit appears to be significant improvement in pain patterns.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - central or function-limiting dysesthetic pain syndromes
Author: Virozub, 1990 Country: Russia Setting: tertiary care Refman ID: 359 | Design: case series of 24 patients Followup: complete Reliable/valid outcome measures: NR Length of study: 12 m maximum | Gender: 83% male Age: min 31 y, max 50 y Level of injury: NR Completeness of injury: 100% complete Cause of injury: 16 work, 8 unclear Time since injury: min 1 m, max 12 y Duration of pain: NR Onset of pain: NR Pain description: spasm, dull, spontaneous | Operative interventions on the pain-conducting tracts of the spinal cord Inferior commissurotomy performed on 13 subjects Bilateral chordotomy conducted in 7 patients with intensive central pain syndrome Coagulation of the entry of the posterior roots of the spinal cord carried out in 4 patients | Outcome measures: subjective patient assessment of pain Pain relief: proved effective in cases in which the spinal cord was injured below the level of the 12^th^ thoracic segment Adverse Effects: NR Article published in Russian.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.

Supplemental Evidence Table 7.2: Case Reports of Other Spinal Surgical Technologies

Author | Patient Description | Intervention | Outcome Measures & Comments
Author: Durward, 1982 Country: Canada Setting: Tertiary care Refman ID: 198 | Design: case series 6/10 subjects, 3 syringomyelia, 3 neurogenic leg pain following SCI Level of injury: Cervical (1), Thoracic (5) Completeness of injury: Complete (5), Incomplete (1) Cause of injury: MVA (2), Unspecified (4) Time since injury: mean 13 y, min 6 - max 23 y Duration of pain: mean 5.3 y, min 1 y - max 10 y Onset of pain: mean 8 y, min 1 y - max 15 y Length of followup: Pain description: numbness, hypepathetic | Intervention: Selective spinal cordectomy Cordectomy specimen available for pathological examination. Specimens were removed from or near the site of the spinal cord trauma and showed extensive gliosis, leptomeningeal fibrosis, and schawannosis. | Outcome measures: Pain relief: 3 syringomyelia cases improved, 3 neurogenic leg pain remained unchanged Adverse Effects: NR Comments: Failure to relieve pain in the lower limb neurogenic pain patients supports the hypothesis that the source of pain is located in more rostral sensory centers
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Loeser, 1968 Country: USA Refman ID: 893 | 51 year old male Level of injury: L1 sensory and motor level. Completeness of injury: Complete paraplegia (rear-end MVA) Decompressive laminectomy post-accident did not reverse neurological deficit Previous history: ankylosing spondylitis Time since injury: 18 m Duration of pain: 16 m Onset of pain: 2 m postinjury Length of followup: NR Pain description: Rectal pains, radiating into buttocks and thighs. "Burning" occurring spontaneously, or triggered by thigh or right chest wall stimulation. Augmented by emotional factors. No effect from analgesics, anticonvulsants, and tranquilizers. Minor improvement with intensive psychotherapy. Symptoms intensified with spinal anesthesia. | Cordectomy with excision of distal spinal cord T9-L2 laminectomy Electrophysiologic monitoring from T10-L1 Cord transected at T 10-T11 vertebral interspace | - Pain still present, but no longer triggered by cutaneous stimulation; - Patient felt operation to be a failure; - Subsequent "improvement" of status post physiotherapy; - Electrophysiologic observations noted similarities to those observed in chronically deafferented cat spinal cord; - No adverse effects noted.
AUTHOR'S DEFINITION OF NEUROPATHIC PAIN - No definition provided.
Author: Pagni, 1995 Country: Italy Refman ID: 425 | 43 year old male Level of injury: "low thoraco-lumbar" Completeness of injury: "Seemingly complete cord syndrome" Time since injury: 2-3 y (unclear) Duration of pain: 1-2 y (unclear) Onset of pain: Next calendar year (reported by date) Length of followup: 10 y Pain description: Lower extremities - "Paroxysmal shooting pains lasting a few seconds many times an hour," aggravated by muscle spasm. Feet and perineum - Moderate burning | Cordomyelotomy T10-L1 laminectomy, excision of posterior half of spinal cord T11 to L5-S1, bilateral transection of anterior quadrants and dorsal columns of the cord at T11 | - Shooting pains and muscular spasms eliminated, reduction of burning sensations; - Reflex voiding preserved; - Able to sit comfortably; - Authors report the failure of this technique on a 71 year old male affected by severe spastic flexor paraplegia secondary to a myelopathy of unknown etiology; - Pain control maintained