# Bibliography

Abdennebi B, Furaha K, Chitti M Surgery of the radiculo-spinal cord junction in the treatment of chronic pain and incapacitating spasticity. Report of a series of 29 patients Neurochirurgie 1990 36(5):297 302 2267043
Abdill CK, Rivas DR, Chancellor MB Transurethral placement of external sphincter wire mesh stent for neurogenic bladder SCI Nurs 1994 11(2):38 41 7863317
Adams JE, Hosobuchi Y, Fields HL Stimulation of internal capsule for relief of chronic pain J Neurosurg 1974 41(6):740 744 4609304
Aisen ML, Stallman J, Aisen PS The sympathetic skin response in the shoulder-hand syndrome complicating tetraplegia Paraplegia 1995 33(10):602 605 8848315
Aisen PS, Aisen ML Shoulder-hand syndrome in cervical spinal cord injury Paraplegia 1994 32(9):588 592 7527910
Al-Chaer ED, Feng Y, Willis WD On the brink of the philosophical ether Pain Forum 1998 7(3):141 142
Aminoff MJ Sensory modulation and the spinal cord Ann Neurol 1993 34(4):511 512 8215240
Anke AG, Stenehjem AE, Stanghelle JK Pain and life quality within 2 years of spinal cord injury Paraplegia 1995 33(10):555 559 8848308
Anonymous 1994 SAE-P: Pain rehabilitation Arch Phys Med Rehabil 1994 75(5 Suppl.):S31 S37
Anonymous Post-traumatic cervicodorsal cerebrospinal fluid cyst Rivista di Neuroradiologia 1998 11(5):734 736
Anonymous Cannabis: When will it become a medicine? Pharmaceutical Journal 1999 263(7068):681 682
Anson CA, Stanwyck DJ, Krause JS Social support and health status in spinal cord injury Paraplegia 1993 31(10):632 638 8259325
Arai M A posterior horn syndrome presumably due to direct trauma to the sacral cord: A rare complication of epidural anesthesia Masui 1999 48(6):654 655 10402822
Arnold PM, Baek PN, Stillerman CB, Rice SG, Mueller WM Surgical management of lumbar neuropathic spinal arthropathy (Charcot joint) after traumatic thoracic paraplegia: Report of two cases J Spinal Disord 1995 8(5):357 362 8563155
Asbury AK, Fields HL Pain due to peripheral nerve damage: an hypothesis Neurology 1984 34(12):1587 1590 6095135
Ashton CH Adverse effects of cannabis and cannabinoids Br J Anaesth 1999 83(4):637 649 10673884
Attal N, Gaudé V, Brasseur L, Bupuy M, Guirimand F, Parker F, Bouhassira D Intravenous lidocaine in central pain: a double-blind, placebo-controlled, psychophysical study Neurology 2000 54(3):564 574 10680784
Aziz Q, Thompson DG Brain-gut axis in health and disease Gastroenterology 1998 114(3):559 578 9496948
Backonja MM, Galer BS Pain Assessment and Evaluation of Patients Who Have Neuropathic Pain Neurol Clin 1998 16(4):775 790 9767062
Backonja M, Gombar KA Response of central pain syndromes to intravenous lidocaine J Pain Symptom Manage 1992(3):172 178
Balazy TE Clinical management of chronic pain in spinal cord injury Clin J Pain 1992 8(2):102 110 1633373
Barber DB, Gall NG Osteonecrosis: an overuse injury of the shoulder in paraplegia: case report Paraplegia 1991 29(6):423 426 1896222
Barolat G Experience with 509 plate electrodes implanted epidurally from C1 to L1 Stereotact Funct Neurosurg 1993 61(2):60 79 8197329
Barolat G Current status of epidural spinal cord stimulation Neurosurgery Quarterly 1995 5(2):98 124
Baron R Neuropathic pain -- Pathophysiological concepts, predictors and new therapies Aktuelle Neurologie 1997 24(3):94 102
Basbaum AI Spinal mechanisms of acute and persistent pain Reg Anesth Pain Med 1999 24(1):59 67 9952097
Batier C, Frerebeau P, Kong AS, et al Posterior spinal cord neurostimulation in lumbar radiculitis pain. Apropos of 14 cases Agressologie 1989 30(3):137 138 2526600
Bedbrook G, Beer NI, McLaren RK Preventive measures in the tertiary care of spinal cord injured people Paraplegia 1985 23(2):69 77 4000694
Bedbrook GM. Bedbrook G, editors. Lifetime Care of the Paraplegic Patient. Edinburgh: Churchill-Livingstone. Pain in paraplegia and tetraplegia. 1985:p. 245-256.
Bedbrook G. Bedbrook G, editors. The Care and Management of Spinal Cord Injuries. New York: Verlag. Pain and phantom sensation. 1981:p. 224-229.
Beer S, Kesselring J Leg pain -- the contribution of the neurologist Ther Umsch 1998 55(10):618 623 9828696
Behar M, Magora F, Olshwang D, Davidson JT Epidural morphine in treatment of pain Lancet 1979 1(8115):527 529 85109
Bennett GJ An animal model of neuropathic pain: a review Muscle Nerve 1993 16(10):1040 1048 8413357
Bennett GJ. Wall P, Melzack R, editors. Textbook of Pain. Edinburgh: Churchill Livingstone. Neuropathic pain. 1994:p. 201-224.
Berbrayer D Tethered cord syndrome complicating spina bifida occulta: a case report Am J Phys Med Rehabil 1991 70(4):213 214 1878181
Beric A, Dimitrijevic M Central Dysesthesia Syndrome in Spinal Cord Injury Pain 1987Supp 4:
Beric A, Dimitrijevic MR, Prevec TS Somatosensory dysfunction in chronic neurogenic pain Neurologija 1988 37(3-4):51 57 3251157
Beric A, Dimitrijevic MR, Lindblom U Central dysesthesia syndrome in spinal cord injury patients Pain 1988 34(2):109 116 3174149
Beric A, Dimitrijevic MR, and Light JK. Pain in SCI double lesion syndrome. 1989. [pmcid: 372750].
Beric A, Dimitrijevic MR, Wall P Modification of pain below the level of the SCI Pain 1990Supp. 5:
Beric A. Dimitrijevic MR, Wall PD, Lindblom U, editors. Altered Sensation and Pain. Basel, Switzerland: Karger. 4, Altered sensation and pain in spinal cord injury. 1990:p. 27-36.
Beric A, Dimitrijevic MR, Light JK Pain in spinal cord injury with occult caudal lesions European Journal of Pain 1992 13(1):1 7
Beric A. Illis L, editors. Spinal Cord Dysfunction: Intervention and Treatment. Oxford: Oxford University Press. 2, Pain in spinal cord injury. 1992:p. 156-166.
Beric A Central pain: "new" syndromes and their evaluation Muscle Nerve 1993 16(10):1017 1024 8413354
Beric A Post-spinal cord injury pain states Pain 1997 72(3):295 298 9313269
Berkley KJ Lesions of the dorsal columns: Definitely disturbing Pain Forum 1998 7(3):129 134
Berkowitz M, Harvey C, Greene CG, et al. The economic consequences of traumatic spinal cord injury. New York: Demos. 1992. [pmcid: 402151].
Blesch A, Grill RJ, Tuszynski MH Neurotrophin gene therapy in CNS models of trauma and degeneration Prog Brain Res 1998 117(32):473 484 9932426
Blond S Stimulation techniques in chronic pain secondary to spinal nerve and/or spinal cord injuries Agressologie 1993 34(2):
Bodenhamer E, Coleman C, Achterberg J Self-directed EMG training for the control of pain and spasticity in paraplegia: a case study Biofeedback Self Regul 1986 11(3):199 205 3607087
Bohlman HH, Kirkpatrick JS, Delamarter RB, Leventhal M. Anterior decompression for late pain and paralysis after fractures of the thoracolumbar spine. Clin Orthop. 1994;300:24-29. [pmid: 8131342].
Bohme K, Tryba M Paraspinal opioids and pump systems Z Arztl Fortbild Qualitatssich 1998 92(1):47 52 9553213
Boivie J. Bromm BDJEeal, editors. Pain and the brain: From nociception to cognition. Advances in pain research and therapy. Linkoeping, Sweden: U Hosp, Dept of Neurology. 24, Pain syndromes in patients with CNS lesions and a comparison with nociceptive pain. 1995:p. 367-375.
Bonica JJ. Bonica J, editors. The Management of Pain. 2 ed. Lea & Febiger. Definitions and taxonomy of pain. 1990:p. 18-27.
Bors E. Phantom Limbs of patients with spinal cord injury. Archives of Neurological Psychiatry. 1952;66:610-631.
Bors E. Extinction and synesthesia in patients with spinal cord injuries. Paraplegia. 1979;17:21-31. [pmid: 492748].
Boswell MV, Iacono RP, Guthkelch AN Sites of action of subarachnoid lidocaine and tetracaine: observations with evoked potential monitoring during spinal cord stimulator implantation Reg Anesth 1992 17(1):37 42 1599893
Botterell EH, Callaghan JC, Jousse AT. Pain in paraplegia: clinical management and surgical treatment. Proc R Soc Med. 1953;47:281-288.
Boulton M, Fitzpatrick R, Swinburn C Qualitative research in health care: II. A structured review and evaluation of studies J Eval Clin Pract 1996 2(3):171 179 9238586
Bowsher D Central pain: clinical and physiological characteristics J Neurol Neurosurg Psychiatry 1996 61(1):62 69 8676164
Bowsher D Central pain following spinal and supraspinal lesions Spinal Cord 1999 37(4):235 238 10338341
Bracken MB, Webb SBJ, Wagner FC Classification of the severity of acute spinal cord injury: implications for management Paraplegia 1978 15(4):319 326 625431
Bracken MB, Shepard MJ, Collins WF, Holford TR, Young W, Baskin DS, Eisenberg HM, Flamm E, Leo-Summers L, Maroon J A randomized, controlled trial of methylprednisolone or naloxone in the treatment of acute spinal-cord injury. Results of the Second National Acute Spinal Cord Injury Study [see comments] N Engl J Med 1990 322(20):1405 1411 2278545
Brandstater ME, Brown SE Physical medicine and rehabilitation JAMA 1996 275(23):1843 1844 8642742
Brasil-Neto JP, Cohen LG, Pascual-Leone A, Jabir FK, Wall RT, Hallett Rapid reversible modulation of human motor outputs after transient deafferentation of the forearm: a study with transcranial magnetic stimulation Neurology 1992 42(7):1302 1306 1620338
Bravo P, Labarta B, Garcia C Pain in people suffering marrow injuries and its treatment Rehabilitacion 1988 22(2):181 189
Brena SF, Sammons EE Phantom urinary bladder pain: case report Pain 1979 7(2):197 201 392410
Bridle MJ, Lynch KB, Quesenberry CM Long term function following the central cord syndrome Paraplegia 1990 28(3):178 185
Bridle MJ, Lynch KB, Quesenberry C Evaluation of Virginia Regional Spinal Cord Injury System follow-up care J Rehabil Res Dev 1991 28(1):
Britell CW. Chronic pain in spinal cord injury. Symposium on chronic pain syndrome. Forthcoming.
Britell CW, Mariano AJ. Chronic pain in spinal cord injury. Physical Medicine and Rehabilitation: State of the Art Reviews. 1991;5:71-82.
Broggi G, Servello D, Dones I, Carbone G Italian multicentric study on pain treatment with epidural spinal cord stimulation Stereotact Funct Neurosurg 1994 62(1-4):273 278 7631081
Bromm B The spontaneous and evoked EEG in anesthesia Anasth Internisvthr Notf Med 1992 27(2):76 83
Brooker C, Cousins MJ, Molloy AR Neuropathic pain: A GP's guide Modern Medicine of Australia 1999 42(5):58 68
Broseta J, Maruenda J, Roldan P Traumatic lesions of the thoracolumbar spine Rev Esp Cir Osteortic 1980 15(90):357 379
Broseta J, Garcia-March G, Sanchez MJ, et al Influence of spinal cord stimulation on peripheral blood flow Appl Neurophysiol 1985 48(1-6):367 370 3879798
Bruehlmeier M, Dietz V, Leenders KL, Roelcke U, Missimer J, Curt A How does the human brain deal with a spinal cord injury? Eur J Neurosci 1998 10(12):3918 3922 9875370
Buchhaas U, Koulousakis A, Nittner K Experience with spinal cord stimulation (SCS) in the management of chronic pain in a traumatic transverse lesion syndrome Neurosurg Rev 1989 12(Suppl 1):582 587 2812434
Buckelew SP, Burk JP, Brownlee-Duffeck M, Frank RG, DeGood D Cognitive and somatic aspects of depression among a rehabilitation sample: Reliability and validity of SCL-90-R research subscales Rehabilitation Psychology 1988 33(2):67 75
Buhren V, Potulski M, Jaksche H Surgical management of tetraplegia Unfallchirurg 1999 102(1):2 12 10095401
Burchiel KJ, Anderson VC, Brown FD, Fessler RG, Friedman WA, Pelofsky, Weiner RL, Oakley J, Shatin D Prospective, multicenter study of spinal cord stimulation for relief of chronic back and extremity pain Spine 1996 21(23):2786 2794 8979327
Burke DC Pain in paraplegia Paraplegia 1973 10(4):297 313 4697003
Burke DC. Vinken P, Bruyn G, editors. Handbook of Clinical Neurology. New York: Elsevier. Pain and phantom sensation in spinal paralysis. 1976:p. 489-499.
Burke DS, Woodward JM. Phantom movement and phantom feeling in complete paraplegic patients. Handbook of Clinical Neurology. 1976;26:489-499.
Burke TF, Payne LE, Hurley WT, et al An unusual case of back pain and spinal cord compression Am J Emerg Med 1994 12(6):645 649 7945607
Burnstock G, Wood JN Purinergic receptors: their role in nociception and primary afferent neurotransmission Curr Opin Neurobiol 1996 6(4):526 532 8794102
Cairns DM, Adkins RH, Scott MD Pain and depression in acute traumatic spinal cord injury: origins of chronic problematic pain? Arch Phys Med Rehabil 1996 77(4):329 335 8607754
Calodney A. Pain after spinal cord injury. Pain Digest. 1993;3:112-115.
Calvillo O, Racz G, Didie J, et al Neuroaugmentation in the treatment of complex regional pain syndrome of the upper extremity Acta Orthop Belg 1998 64(1):57 63
Campbell CC, Koris MJ Etiologies of shoulder pain in cervical spinal cord injury Clin Orthop 1996(322):140 145
Campbell JN Examination of possible mechanisms by which stimulation of the spinal cord in man relieves pain Applied Neurophysiology 1981 44(4):181 186 6978676
Canavan AM, Haeske-Dewick H Depression and neurological disabilities Current Opinion in Psychiatry 1995 8(6):407 409
Carlsson AM Assessment of chronic pain. I. Aspects of the reliability and validity of the visual analogue scale Pain 1983 16(1):87 101 6602967
Cassinari V, Petroboni E, Pinto N, Defanti CA Electrostimulation of the spinal cord in the treatment of chronic pain Rivista di Neurobiologia 1982 28(3-4):203 226 6985309
Catchlove RF Phantom pain following limb amputation in a paraplegic. A case report Psychother Psychosom 1983 39(2):89 93 6878596
Cervero F Not all pain is in the spinal cord Pain 1992 51(2):262 263 1484723
Chabal C, Jacobson L, Little J Intrathecal fentanyl depresses nociceptive flexion reflexes in patients with chronic pain Anesthesiology 1989 70(2):226 229 2913859
Chen TY, Lee ST, Lui TN, Wong CW, Yeh TS, Tzaan WC, Hung SY, Al-Mefty O Efficacy of surgical treatment in traumatic central cord syndrome Surg Neurol 1997 48(5):435 441 9352804
Cheng PT, Hong CZ, Liaw MY Spontaneous electromyographic potentials in cervical cord-injured patients are related to dysesthetic pain Am J Phys Med Rehabil 1997 76(5):389 394 9354493
Cherry DA Surgical procedures for the relief of acute and chronic pain The Medical Journal of Australia 1991 155(10):701 704 1682790
Chiou-Tan FY, Tuel SM, Johnson JC, Priebe MM, Hirsh DD, Strayer JR Effect of mexiletine on spinal cord injury dysesthetic pain Am J Phys Med Rehabil 1996 75(2):84 87 8630199
Christensen FL Pain in spinal cord injured patients Int J Rehabil Res 1988 11(3):303 304
Christensen FL, Jensen TS Sensation disorders and pain in spinal cord lesions Ugeskr Laeger 1991 153(49):3466 3469 1776178
Christensen MD, Hulsebosch CE Chronic central pain after spinal cord injury J Neurotrauma 1997 14(8):517 537 9300563
Chu Y-H, Wong C-S, Ho S-T, Watkins WD Epidural coadministration of ketamine and morphine attenuates the neuropathic pain: a case report Pain Clinic 1995 8(3):263 267
Cioni B, Meglio M, Pentimalli L, Visocchi M Spinal cord stimulation in the treatment of paraplegic pain J Neurosurg 1995 82(1):35 39 7815131
Climent JM, Pallares J, Pallares MJ, et al. Tratamiento del dolor cronico en el lesionado medular. Dolor I.C.& T. 1987;2:97-100.
Cobeljic R, Kovacevic S, Vulovic D, Stojanovic A Types of chronic pain in patients with spinal cord injury Acta Orthop Iugosl 1998 29(1):73 77
Issue 4,1999 325679
http://www.jr2.ox.ac.uk:80/Cochrane/. Accessed on July 16, 1999.
Coghill RC, Mayer DJ, Price DD Wide dynamic range but not nociceptive-specific neurons encode multidimensional features of prolonged repetitive heat pain J Neurophysiol 1993 69(3):703 716 8385190
Cohen LG, Topka H, Cole RA, Hallett M Leg paresthesias induced by magnetic brain stimulation in patients with thoracic spinal cord injury Neurology 1991 41(8):1283 1288 1866019
Cohen MJ, McArthur DL, Vulpe M, Schandler SL, Gerber KE Comparing chronic pain from spinal cord injury to chronic pain of other origins Pain 1988 35(1):57 63 3200598
Cohen MJ, Schandler SL, Vulpe M Event-related brain potentials during orienting to auditory and visual stimulation in spinal cord injured humans Paraplegia 1992 30(12):864 871 1287540
Cohen MJ Comments on psychosocial factors in chronic spinal cord injury pain by Summers, Rapoff, Varghese, Porter, and Palmer Pain 1994 58(2):280 282 7816500
Cohen MJ, Ament PA, Schandler SL, et al Changes in the P300 component of the tactile event-related potential following spinal cord injury Paraplegia 1996 34(2):107 112 8835036
Cohen MJ, Song ZK, Schandler SL, Ho WH, Vulpe M Sensory detection and pain thresholds in spinal cord injury patients with and without dysesthetic pain, and in chronic low back pain patients Somatosens Mot Res 1996 13(1):29 37 8725646
Cohen MJ Psychosocial factors in chronic spinal cord injury pain: comment Pain 1994(2):280 281
Cole JD, Illis LS, Sedgwick EM Intractable central pain in spinal cord injury is not relieved by spinal cord stimulation Paraplegia 1991 29(3):167 172
Conant LL A causal analysis of psychological variables associated with chronic spinal cord injury pain Dissertation Abstracts International: Section B: The Sciences and Engineering 1995(6-B):
Conant LL Psychological variables associated with pain perceptions among individuals with chronic spinal cord injury pain Journal of Clinical Psychology in Medical Settings 1998(1):71 90
Consroe P Brain cannabinoid systems as targets for the therapy of neurological disorders Neurobiology of Disease 1998 5(6):534 351 9974182
Cook A, Druckemiller W. Phantom limb in paraplegic patients. J Neurol. 1952;9:505-516.
Cremer SA, Maynard F, Davidoff G The reflex sympathetic dystrophy syndrome associated with traumatic myelopathy: Report of 5 cases Pain 1989 37(2):187 192 2748191
Crim JR, Bassett LW, Gold RH, et al Spinal neuroarthropathy after traumatic paraplegia AJNR AM J Neuroradiol 1988 9(2):359 362 3128083
Cundiff GW, Blair KL, Puckett MJ Group pain management therapy for persons with SCI SCI Psychosocial. Process 1995(2):61 66
Curtis KA, Roach KE, Brooks AE, Amar T, Benbow CS, Genecco TD, Gualano J Development of the Wheelchair User's Shoulder Pain Index (WUSPI) Paraplegia 1995 33(5):290 293 7630657
Curtis KA, Black K Shoulder pain in female wheelchair basketball players J Orthop Sports Phys Ther 1999 29(4):225 231 10322595
Curtis KA, Drysdale GA, Lanza RD, et al Shoulder pain in wheelchair users with tetraplegia and paraplegia Arch Phys Med Rehabil 1999 80(4):453 457 10206610
Dalyan M, Cardenas DD, Gerard B Upper extremity pain after spinal cord injury Spinal Cord 1999 37(3):191 195 10213328
Davidoff G, Guarracini M, Roth E, Sliwa J, Yarkony G Trazodone hydrochloride in the treatment of dysesthetic pain in traumatic myelopathy: a randomized, double-blind, placebo-controlled study Pain 1987 29(2):151 161 3302841
Davidoff G, Roth E, Guarracini M, Sliwa J, Yarkony G Function-limiting dysesthetic pain syndrome among traumatic spinal cord injury patients: a cross-sectional study Pain 1987 29(1):39 48 3588000
Davidoff G, Roth EJ. Casey K, editors. Pain and Central Nervous System Disease: The Central Pain Syndromes. New York: Raven Press. Clinical characteristics of central (dysesthetic) pain in spinal cord injury patients. 1991:p. 77-83. [pmcid: 317473].
Davis L, Martin J. Studies upon spinal cord injuries II The nature and treatment of pain. J Neurosurg. 1947;4:483-491. [pmid: 20267936].
Davis R, Lentini R Transcutaneous nerve stimulation for treatment of pain in spinal-cord-injured patients Bull Prosthet Res 1974(Fall):298 301
Davis R, Lentini R Transcutaneous nerve stimulation for treatment of pain in patients with spinal cord injury Surg Neurol 1975 4(1):100 101 1080891
Davis R Pain and suffering following spinal cord injury Clin Orthop 1975(112):76 80
Davis R Spasticity following spinal cord injury Clin Orthop 1975(112):66 75
Davis RW Phantom sensation, phantom pain, and stump pain Arch Phys Med Rehabil 1993 74(1):79 91 8380543
De Broucker T, Cesaro P, Willer JC, et al Diffuse Noxious Inhibitory Controls in man: involvement of the spinoreticular tract Brain 1990 113(4):1223 1234 2397390
De Jong R Central pain mechanisms JAMA 1978 239(26):
de la Fuente A, Roman F, Tebas P, Perez MR, Masa V, Martinez Lopez de Letona Fever, dorsal pain, and paraplegia Enferm Infec Microbiol Clin 1991 9(1):55 56
De La Porte, Siegfried J Lumbosacral spinal fibrosis (spinal arachnoiditis). Its diagnosis and treatment by spinal cord stimulation Spine 1983 8(6):593 603 6228017
De Seze M, Wiart L, Joseph P-A, Dosque J-P, Mazaux J-M, Barat M Capsaicin and neurogenic detrusor hyperreflexia: A double-blind placebo- controlled study in 20 patients with spinal cord lesions Neurourol Urodyn 1998 17(5):513 523 9776014
De Vivo MJ, Whiteneck G, Charles ED. Stover SL, Whiteneck G, De Lisa J, editors. Spinal cord injury: clinical outcomes from the Model Systems. Gaithersburg, MD: Aspen Publishers. The economic impact of spinal cord injury. 1995:p. 234-271.
Dean BZ, Williams FH, King JC, et al Pain rehabilitation. 4. Therapeutic options in pain management Arch Phys Med Rehabil 1994 75(5 Suppl.):S21 S30 7910453
Defrin R, Ohry A, Blumen N, Urca G Acute pain threshold in subjects with chronic pain following spinal cord injury Pain 1999 83(2):275 282 10534599
Dellemijn P. Are opioids effective in relieving neuropathic pain?. Pain. 1999:80453-462.
Demirel G, Yllmaz H, Gencosmanoglu B, Kesiktas N Pain following spinal cord injury Spinal Cord 1998 36(1):25 28 9471134
DeVivo MJ Causes and costs of spinal cord injury in the United States Spinal Cord 1997 35(12):809 813 9429259
Devor M, Basbaum A, Bennett G, et al. Basbaum A, Besson J-M, editors. Towards a New Pharmacology of Pain. New York: Wiley. Group report: mechanisms of neuropathic pain following peripheral injury. 1991:p. 417-440.
Devor M, Govrin-Lippmann R, Angelides K Na+ channel immunolocalization in peripheral mammalian axons and changes following nerve injury and neuroma formation J Neurosci 1993 13(5):1976 1992 7683047
Devulder J, De CL, Rolly G, Caemaert J, Calliauw L Spinal cord stimulation in chronic pain therapy Clin J Pain 1990 6(1):51 56 2134997
Devulder J, Vermeulen H, De Colvenaer L, Rolly G, Calliauw L, Caemaert J Spinal cord stimulation in chronic pain: evaluation of results, complications, and technical considerations in sixty-nine patients Clin J Pain 1991 7(1):21 28 1809411
Devulder J, Duprez D, De Laat M., et al Epidural spinal cord stimulation does not improve microvascular blood flow in neuropathic pain Angiology 1996 47(12):1145 1149 8956666
Dickenson AH Spinal cord pharmacology of pain Br J Anaesth 1995 75(2):193 200 7577253
Dickenson AH Central acute pain mechanisms Ann Med 1995 27(2):223 227 7632418
Dickenson AH Balances between excitatory and inhibitory events in the spinal cord and chronic pain Prog Brain Res 1996 110(17):225 231 9000728
Dickenson AH Nervous, excited and touchy: NMDA receptors in the spinal cord Neuroreport 1997 8(9-10):
Dickenson AH, Chapman V, Green GM The pharmacology of excitatory and inhibitory amino acid-mediated events in the transmission and modulation of pain in the spinal cord Gen Pharmacol 1997 28(5):633 638 9184794
Dijkhuizen PA, Verhaagen J The use of neurotrophic factors to treat spinal cord injury: advantages and disadvantages of different delivery methods Neuroscience Research Communications 1999 24(1):1 10
Ditunno JFJ Functional outcomes in spinal cord injury (SCI): quality care versus cost containment J Spinal Cord Med 1997 20(1):1 7 9097246
Doctor JN An evaluation of transcutaneous electrical nerve stimulation Dissertation Abstracts International: Section B: The Sciences and Engineering 1996(4-B):
Doll M, Baum H Retained intraspinal bullet -- an illustrative case report Neurosurg Rev 1989 12(1):67 70 2747936
Donovan WH, Bedbrook GM Sensory and motor activity in the posterior primary rami following complete spinal cord injury Arch Phys Med Rehabil 1980 61(3):133 138 7369851
Donovan WH, Dimitrijevic MR, Dahm L, Dimitrijevic M Neurophysiological approaches to chronic pain following spinal cord injury Paraplegia 1982 20(3):135 146 6982450
Donovan WH, Brown DJ, Ditunno JJ, Dollfus P, Frankel HL Neurological issues Spinal Cord 1997 35(5):275 281 9160450
Dooley DM, Sharkey J Electrostimulation of the nervous system for patients with demyelinating and degenerative diseases of the nervous system and vascular diseases of the extremities Appl Neurophysiol 1977 40(2-4):208 217 309312
Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised sutdies of health care interventions. J Epidemiol Community Health. 1998;52:377-384. [pmid: 9764259].
Dressler D, Thompson PD, Gledhill RF, Marsden CD The syndrome of painful legs and moving toes Mov Disord 1994 9(1):13 21 7511213
Drewes AM, Andreasen A, Poulsen LH Valproate for treatment of chronic central pain after spinal cord injury. A double-blind cross-over study Paraplegia 1994 32(8):565 569 7970862
Druckman R, Lende R. Cental pain of spinal origin: Pathogenesis and surgical relief in one patient. Neurology. 1965;15:518-522. [pmid: 14312773].
Dubner R, Bennett GJ. Spinal and trigeminal mechanisms of nociception. Annu Rev Neurosci. 1983;6:381-418. [pmid: 6132587].
Dubner R, Hargreaves KM. The neurobiology of pain and its modulation. Clin J Pain. 1989;5 Suppl 2:S1-S4.
Dubner R Neuropathic pain: New understanding leads to new treatments APS Journal 1993 2(1):8 11
Dubner R, Ren K Endogenous mechanisms of sensory modulation Pain Suppl 1999 6(Aug):S45 S53
Durward QJ, Rice GP, Ball MJ, Gilbert JJ, Kaufmann JC Selective spinal cordectomy: clinicopathological correlation J Neurosurg 1982 56(3):359 367 6948922
Dvorak J, Valach L, Schmid S Injuries of the cervical spine in Switzerland Orthopade 1987 16(1):2 12 3574939
Echols DH The effectiveness of thoracic rhizotomy for chronic pain Neurochirurgia 1970 13(3):69 74 5427052
Edgar RE. The treatment of central deafferentation pain in spinal cord injury. Forthcoming.
Edgar RE, Best LG, Quail PA, Obert AD Computer-assisted DREZ microcoagulation: posttraumatic spinal deafferentation pain J Spinal Disord 1993 6(1):48 56 8439716
Edwards WH Direct versus indirect hypnosis for the relief of chronic pain in spinal cord injured patients Dissertation Abstracts International 1980(10-B):1 85
Eide PK, Stubhaug A, Stenehjem AE Central dysesthesia pain after traumatic spinal cord injury is dependent on N-methyl-D-aspartate receptor activation Neurosurgery 1995 37(6):1080 1087 8584148
Eide PK, Jorum E, Stenehjem AE Somatosensory findings in patients with spinal cord injury and central dysaesthesia pain J Neurol Neurosurg Psychiatry 1996 60(4):411 415 8774406
Eide PK Pathophysiological mechanisms of central neuropathic pain after spinal cord injury Spinal Cord 1998 36(9):601 612 9773443
Eisenach J. Update on spinal cord pharmacology in pain. Acta Anaesthesiol Scand. 1997;Suppl 110:124-126.
El Masry W, Biyani A Incidence, management, and outcome of post-traumatic syringomyelia J Neurol Neurosurg Psychiatry 1996 60(2):141 146 8708641
Elliott TR, Harkins SW. Psychosocial concomitants of persistent pain among persons with spinal cord injuries. Neuro Rehabil. 1991;1:7-16.
Epstein B, Childers MK The use of gabapentin for neuropathic and musculoskeletal pain: a case series J Neurol Rehabil 1998 12(2):81 86
Erdmann KA, Rogers MT Implantable devices for pain Seminars in Anesthesia 1997 16(4):320 327
Erzurumlu A, Dursun H, Gunduz S, Kalyon TA, Apracioglu O The management of chronic pain at spinal cord injured patients. The comparison of effectiveness amitryptiline and carbamazepine combination and electroacupuncture application Journal of Rheumatology & Medical Rehabilitation 1996 7(3):176 180
Esposito S Microsurgery of the spinal cord in the treatment of pain Rivista di Neurobiologia 1982 28(3-4):239 250 7187103
Evans RL, Hendricks RD, Connis RT, Haselkorn JK, Ries KR, Mennet TE. Quality of life after spinal cord injury: a critique and meta-analysis. J Am Paraplegia Soc. 1993;17:60-66.
Falci SP, Lammertse DP, Best L, Starnes CA, Prenger EC, Stavros AT, Mellick D Surgical treatment of posttraumatic cystic and tethered spinal cords J Spinal Cord Med 1999 22(3):173 181 10685382
Farcot JM, Mercky F, Grasser C Thoracolumbar or sacral epidural administration of clonidine in deafferentation pain: possibilities, limits and long-term follow-up Agressologie 1989 30(3):139 142 2751043
Farkash AE, Portenoy RK The pharmacological management of chronic pain in the paraplegic patient J Am Paraplegia Soc 1986 9(3-4):41 50 2878062
Fenollosa P, Pallares J, Cervera J, Pelegrin F, Inigo V, Giner M, Forner V Chronic pain in the spinal cord injured: statistical approach and pharmacological treatment Paraplegia 1993 31(11):722 729 7507585
Ferraz FM, Luessenhop AJ Surgical therapy of chronic pain Neurosurgery 1980 7(4):432 433 6934415
Fields HL Neurophysiology of pain and pain modulation Am J Med 1984 77(3A):2 8 6486128
Fields H. Wall P, Melzack R, editors. Textbook of Pain. New York: Churchill-Livingstone. Peripheral neuropathic pain: an approach to management. 1994:p. 991-996.
Fields H, Rowbotham M. Gebhart G, Hammond D, Jensen T, editors. Proceedings of the 7th World Congress on Pain: Progress in Pain Research and Management. 2nd ed. Multiple mechanisms of neuropathic pain: a clinical perspective. 1994:p. 437-454.
Fitzgerald M Developmental biology of inflammatory pain Br J Anaesth 1995 75(2):177 185 7577251
Fiume D Influence of spinal cord stimulation on peripheral blood flow Appl Neurophysiol 1983 46(5-6):290 294 6610390
Foo D, Subrahmanyan TS, Rossier AB Post-traumatic acute anterior spinal cord syndrome Paraplegia 1981 19(4):201 205 7290729
Fordyce WE, Grzesiak RC, and Dunn ME. Chronic pain management in SCI: assessment, individual treatment and team approaches. Forthcoming.
Forrest DM Spinal cord stimulator therapy J Perianesth Nurs 1996 11(5):349 352 8970301
Freed WJ Neural transplantation: Prospects for clinical use Cell Transplant 1993 2(1):13 31
Freeman LW, Heimburger F. Surgical relief of pain in paraplegic patients. Archives of Surgery. 1947;55:433-440. [pmid: 20270305].
Freeman TB, Campbell JN, Long DM Naloxone does not affect pain relief induced by electrical stimulation in man Pain 1983 17(2):189 195 6606154
Friedman AH, Nashold Jr. BS DREZ lesions for relief of pain related to spinal cord injury J Neurosurg 1986 65(4):465 469 3760955
Friedman AH, Bullitt E Dorsal root entry zone lesions in the treatment of pain following brachial plexus avulsion, spinal cord injury and herpes zoster Appl Neurophysiol 1988 51(2-5):164 169 3389792
Friedman AH, Nashold Jr. BS. Youmans J, editors. Neurological Surgery. 3 ed. Philadelphia: W. B. Saunders. Pain of spinal origin. 1990;Vol. 6:p. 3950-4059.
Frisbie JH, Aguilera EJ Chronic pain after spinal cord injury: an expedient diagnostic approach Paraplegia 1990 28(7):460 465 2250989
Fuentes JM, Vlahovitch B, Negre C Post-traumatic brachial diplegia due to cervical cord lesions Neurochirurgie 1984 30(3):165 170 6462321
Gadsby JG, Flowerdew MW. Transcutaneous electrical nerve stimulation and acupuncture-like transcutaneous electrical nerve stimulation for chronic low back pain. Cochrane Database Syst Rev. 2000;2.
Gaebler C, Maier R, Kukla C, Vecsei V Long-term results of pedicle stabilized thoracolumbar fractures in relation to the neurological deficit Injury 1997 28(9-10):661 666 9624347
Galer BS, Jensen MP Development and preliminary validation of a pain measure specific to neuropathic pain: the Neuropathic Pain Scale Neurology 1997 48(2):332 338 9040716
Galibois P, Copty M, Bouchard R, Noel M, Gionet T A new approach in the treatment of pain, an implanted spinal cord stimulator Infirm Can 1974 16(11):17 21
Gallagher-Lepak S, Chan F, Kates D, Dunlap L, Eiring KM, Cunningham J Medications used in rehabilitation settings: Considerations for therapists and counselors The Hatherleigh guide to treating substance abuse 1996 1(7):25 47
Gallien P, Nicolas B, Robineau S, Lebot MP, Brissot R The reflex sympathetic dystrophy syndrome in patients who have had a spinal cord injury Paraplegia 1995 33(12):715 720 8927411
Garcia J, Altman RD Chronic pain states: invasive procedures Sem Arthritis Rheum 1997 27(3):156 160
Gellad FE, Paul KS, Geisler FH Early sequelae of gunshot wounds to the spine: radiologic diagnosis Radiology 1988 167(2):523 526 3357965
Gellman H, Eckert RR, Botte MJ, Sakimura I, Waters RL Reflex sympathetic dystrophy in cervical spinal cord injury patients Clin Orthop 1988(233):126 131
Genest M; Genest S. Psychology and health. Champaign, IL: USA: Research Press. 1987. [pmcid: 373129].
Gerber S, Sellier N, Lalande G, Kalifa G, Bennet J Painful spine in children. Diagnostic strategy Feuill Radiol 1989 29(2):102 116
Gerhart KA, Johnson RL, Whiteneck GG Health and psychosocial issues of individuals with incomplete and resolving spinal cord injuries Paraplegia 1992 30(4):282 287 1625899
Gerhart KA, Bergstrom E, Charlifue SW, et al Long-term spinal cord injury: Functional changes over time Arch Phys Med Rehabil 1993 74(10):1030 1034 8215852
Gibson JC, White LE, Jr. Denervation hyperpathia: A convulsive syndrome of the spinal cord responsive to carbamazepine therapy. J Neurosurg. 1971;35:287-290.
Gilbert M, Counsell CM, Martin P, Snively C Spinal cord stimulation for chronic intractable pain: nursing implications J Neurosci Nurs 1994 26(6):347 351 7706838
Glennon TP, Madewell JE, Donovan WH, Bontke CF, Spjut HJ Neuropathic spinal arthropathy after spinal cord injury: a report of three cases Spine 1992 17(8):964 971 1523497
Glynn CJ, Jamous MA, Teddy PJ, Moore RA, Lloyd JW Role of spinal noradrenergic system in transmission of pain in patients with spinal cord injury Lancet 1986 2(8518):1249 1250 2878134
Glynn CJ, Jamous MA, Teddy PJ Cerebrospinal fluid kinetics of epidural clonidine in man Pain 1992 49(3):361 367 1408302
Go BK, DeVivo MJ, Richards JS. Stover S, De Lisa J, Whiteneck G, editors. Spinal cord injury: clinical outcomes from the model systems. Gaithersburg: Aspen Publication. The epidemiology of spinal cord injury. 1995:p. 21-55.
Goldstein B, Hammond MC, Stiens SA, et al Posttraumatic syringomyelia: profound neuronal loss, yet preserved function Arch Phys Med Rehabil 1998 79(1):107 112 9440427
Gonzalez-Darder JM, Canela P, Gonzalez-Martinez V, Ortiz E, Gomez R, Celjas F Spinal electrical stimulation. Current indications and results in a series of 46 patients Res Esp Anestesiol Reanim 1992 39(2):86 90
Goodman BS, Jann BB, Haddox JD, et al Subcutaneous bupivacaine for treatment of spasticity: a case report Arch Phys Med Rehabil 1995 76(2):202 204 7848079
Gordh T, Karlsten R, Kristensen J Intervention with spinal NMDA, adenosine, and NO systems for pain modulation Ann Med 1995 27(2):229 234 7632419
Green BA, Edgar RE. Long D, editors. Current therapy in neurological surgery. Philadelphia: BC Decker. 1989;Vol. 2. Spinal cord injury pain.
Gronning M, Ertzgaard P, Myrseth E Central nervous pain in patients with spinal cord injury. Medical and surgical treatment Tidsskr Nor Laegeforen 1997 117(13):1904 1907 9214011
Grundy D, Russell J ABC of spinal cord injury. Later management and complications -- I BMJ 1986 292(6521):677 680 2418908 1339658
Grzesiak RC Relaxation techniques in treatment of chronic pain Arch Phys Med Rehabil 1977 58(6):270 272 67831
Guyatt GH, Sackett DL, and Cook DJ Users' guides to the medical literature. II. How to use an article about therapy or prevention. A. Are the results of the study valid? Evidence-Based Medicine Working Group JAMA 1993 270(21):2598 601 Department of Medicine, McMaster University, Hamilton, Ontario, Canada. Journal Article; 8 8230645
Guyatt GH, Sackett DL, Cook DJ Users' guides to the medical literature. II. How to use an article about therapy or prevention. B. What were the results and will they help me in caring for my patients? Evidence-Based Medicine Working Group JAMA 1994 271(1):59 63 8258890
Gybels JM Indications for neurosurgical treatment of chronic pain Acta Neurochir 1991 116(2-4):171 175
Hachen HJ Psychological, neurophysiological and therapeutic aspects of chronic pain: preliminary results with transcutaneous electrical stimulation [proceeedings] Paraplegia 1977 15(4):353 367 305020
Haldeman SD Indications for clinical neurophysiological testing Bull Hosp Jt Dis Orthop Inst 1996 55(3):122 124
Hansebout RR, Blight AR, Fawcett S, Reddy K 4-Aminopyridine in chronic spinal cord injury: a controlled, double-blind, crossover study in eight patients J Neurotrauma 1993 10(1):1 18 8320728
Harrison P, Kent EA, Lema MJ Interpleural analgesia: Its use, and a complication, in a quadriplegic patient with chronic benign pain J Pain Symptom Manage 1993 8(4):238 241 7963766
He J, Barolat G, Holsheimer J, Struijk JJ Perception threshold and electrode position for spinal cord stimulation Pain 1994 59(1):55 63 7854803
Heilporn A Two therapeutic experiments on stubborn pain in spinal cord lesions: coupling melitracen-flupenthixol and the transcutaneous nerve stimulation Paraplegia 1978 15(4):368 372 305021
Henderson M, Mowry RL A pilot study of the impact of laughter on the experience of chronic pain by people with spinal cord injuries SCI Psychosocial Process 1995 6(4):154 156
Henry JL. Concepts of pain sensation and its modulation. J Rheumatol Suppl. 1989;19:104-112. [pmid: 2481740].
Herman RM, D'Luzansky SC, Ippolito R Intrathecal baclofen suppresses central pain in patients with spinal lesions. A pilot study Clin J Pain 1992 8(4):338 345 1493344
Hess R Neurophysiological mechanisms of pain perception Methods Find Exp Clin Pharmacol 1982 4(7):463 467 6302416
Hillier T, Jadad A. The development of a database on the measurement of pain. Support Care Cancer. 1996;3.
Hirst RA, Lambert DG, Notcutt WG Pharmacology and potential therapeutic uses of cannabis Br J Anaesth 1998 81(1):77 84 9771275
Hodges C, Bender L Phantom pain: a critical review of the proposed mechanisms British Journal of Occupational Therapy 1994 57(6):209 212
Hohmann GW Psychological aspects of treatment and rehabilitation of the spinal cord injured person Clin Orthop 1975(112):81 88
Holsheimer J, Wesselink WA Effect of anode-cathode configuration on paresthesia coverage in spinal cord stimulation Neurosurgery 1997 41(3):654 659 9310984
Hopkins A, Rudge P Hyperpathia in the central cervical cord syndrome J Neurol Neurosurg Psychiatry 1973 36(4):637 642 4731333
Hoppenstein R Percutaneous implantation of chronic spinal cord electrodes for control of intractable pain: preliminary report Surg Neurol 1975 4(1):195 198 1080905
Hosobuchi Y, Adams JE, Rutkin B Chronic thalamic and internal capsule stimulation for the control of central pain Surg Neurol 1975 4(1):91 92 1080907
Hunt WE, Goodman JH, Bingham WG, Jr Stimulation of the dorsal spinal cord for treatment of intractable pain: a preliminary report Surg Neurol 1975 4(1):153 156 1080900
Hunter JP, Ashby P Segmental effects of epidural spinal cord stimulation in humans J Physiol 1994 474(3):407 419 8014902 1160332
Hyndman OR. Lissauer's tract section. A contribution to chordotomy for the relief of pain (preliminary report). J Int Coll Surg. 1942;5:294-400.
Illis LS Disorders of the spinal cord. Overview Curr Opin Neurol Neurosurg 1988 1(4):583 584
Illis LS Lesions of the spinal cord, roots and nerves Curr Opin Neurol Neurosurg 1989 2(4):567 574
Ingold O Pain management from the viewpoint of the anesthetist Schweiz Rundsch Med Prax 1998 87(7):232 237 9540379
http://www.halcyon.com/iasp/sigs.html#SYSTEMATIC REVIEWS IN PAIN RELIEF (In Formation). Accessed on July 16, 2000.
Ioannidis JP, Cappelleri JC, Lau J Issues in comparisons between meta-analyses and large trials JAMA 1998 279(14):1089 1093 9546568
Irwig L, Tosteson AN, Gatsonis C, Lau J, Colditz G, Chalmers TC, and Mosteller F Guidelines for meta-analyses evaluating diagnostic tests Ann Intern Med 1994 120(8):667 76 8135452
Iumashev GS, Lavrov IN, Cherkashina ZA Local hypothermia of the spinal cord in the postoperative period Zhurnal Voprosy Neirokhirurgii Imeni N - N - Burdenko 1982(4):47 49
Jack TM, Lloyd JW. Long term efficacy of surgical cordotomy in intractable nonmalignant pain. Ann R Coll Surg Eng. 1983;65:97-102.
Jadad, A.R. Meta-analysis of randomised clinical trials in pain relief. 1994. University of Oxford. [pmcid: 43273].
Jadad AR, Carroll D, Glynn CJ, McQuay HJ Intravenous regional sympathetic blockade for pain relief in reflex sympathetic dystrophy: a systematic review and a randomized, double-blind crossover study J Pain Symptom Manage 1995 10(1):13 20 7536227
Jadad AR, Carroll D, Moore A, McQuay H Developing a database of published reports of randomised clinical trials in pain research Pain 1996 66(2-3):239 246 8880846
Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, McQuay HJ Assessing the quality of reports of randomized clinical trials: is blinding necessary? Control Clin Trials 1996 17(1):1 12 8721797
Jadad AR, Cook DJ, Jones A, Klassen TP, Tugwell P, Moher M, Moher D Methodology and reports of systematic reviews and meta-analyses: a comparison of Cochrane reviews with articles published in paper-based journals JAMA 1998 280(3):278 280 9676681
Jadad AR, Haynes RB The Cochrane Collaboration -- advances and challenges in improving evidence-based decision making Med Decis Making 1998 18(1):2 9 9456200
Jadad AR and Cepeda MS Clinical trials in pain relief: 10 challenges. Clinical Updates. International Association for the Study of Pain 1999Summer.325679
Jadad A. Neuropathic pain. Refresher Course Syllabus. Seattle: IASP Publications. 1993.
Jadad A. Bruera EPR, editors. Topics in Palliative Care. New York: Oxford University Press. Opioids in the treatment of neuropathic pain: a systematic review of controlled clinical trials. 1998:p. 31-40.
Jaeschke R, Guyatt G, and Sackett DL Users' guides to the medical literature. III. How to use an article about a diagnostic test. A. Are the results of the study valid? Evidence-Based Medicine Working Group JAMA 1994 271(5):389 91 Department of Medicine, McMaster University, Hamilton, Ontario, Canada. Journal Article; 2 8283589
Jaeschke R, Guyatt GH, and Sackett DL Users' guides to the medical literature. III. How to use an article about a diagnostic test. B. What are the results and will they help me in caring for my patients? The Evidence-Based Medicine Working Group JAMA 1994 271(9):703 7 Department of Medicine, McMaster University, Hamilton, Ontario, Canada. Journal Article; 5 8309035
Jarmundowicz W, Radek A Ossification in the area of the spinal cord arachnoid as the cause of a chronic pain syndrome after spinal fracture Neurologia i Neurochirurgia Polska 1988 22(1):78 81 2967923
Jarosz DA Pediatric spinal cord injuries: a case presentation Crit Care Nurs Q 1999 22(2):8 13 10646437
Jeanmonod D, Sindou M, Magnin M, Boudet M Intra-operative unit recordings in the human dorsal horn with a simplified floating microelectrode Electroencephalogr Clin Neurophysiol 1989 72(5):450 454 2469569
Jefferson A. Lipton S, Miles J, editors. Persistent pain, modern methods of treatment. London: Grune & Stratton. 7, Cordectomy for intractable pain in paraplegia. 1983:p. 115-132.
Jensen MP, Karoly P, Braver S The measurement of clinical pain intensity: a comparison of six methods Pain 1986 27(1):117 126 3785962
Johnson RL, Brooks CA, Whiteneck GG Cost of traumatic spinal cord injury in a population-based registry Spinal Cord 1996 34(8):470 480 8856854
Johnson RL, Gerhart KA, McCray J, Menconi JC, Whiteneck GG Secondary conditions following spinal cord injury in a population-based sample Spinal Cord 1998 36(1):45 50 9471138
Jung BF Effect of coping skills and time on pain in spinal cord injury Dissertation Abstracts International 1990(3-B):
Kaelan C, Jacobsen PF, Kakulas BA An investigation of possible transynaptic neuronal degeneration in human spinal cord injury J Neurol Sci 1988 86(2-3):231 237 3221242
Kakulas BA, Smith E, Gaekwad U, et al. Dimitrijevic MR, Wall PD, Lindblom U, editors. Altered Sensation and Pain. Basel, Switzerland: Karger. The neuropathology of pain and abnormal sensations in human spinal cord injury derived from the clinicopathological database at the Royal Perth Hospital. 1990:p. 37-41.
Kalso E, Tramer MR, McQuay HJ, Moore RA. Systemic local-anaesthetic-type drugs in chronic pain: a systematic review. European Journal of Pain. 1998;2:3-14. [pmid: 10700296].
Kannisto M, Sintonen H Later health-related quality of life in adults who have sustained spinal cord injury in childhood Spinal Cord 1997 35(11):747 751 9392045
Kanpolat Y, Akyar S, Caglar S Diametral measurements of the upper spinal cord for stereotactic pain procedures: experimental and clinical study Surg Neurol 1995 43(5):478 482 7660287
Kaplan LI, Grynbaum BB, Lloyd KE, Runsk HA. Pain and spasticity in patients with spinal cord dysfunction. JAMA. 1962:120-127.
Kaplan LI, Grynbaum BB, Lloyd KE, Rusk HA. Pain and spasticity in patients with spinal cord dysfunction. JAMA. 1962;182:918-925.
Kennedy P, Frankel H, Gardner B, Nuseibeh I Factors associated with acute and chronic pain following traumatic spinal cord injuries Spinal Cord 1997 35(12):814 817 9429260
Kennedy R. A new viewpoint toward spinal cord injuries. Ann Surg. 1946;124:1057-1065.
Kerr, FWL. 1966. Lecture given to the Amercan College of Surgeons. [pmcid: 292881].
Kerrigan DC, Janes WW, Martin WA, et al Physical medicine and rehabilitation residents' educational needs assessment Arch Phys Med Rehabil 1993 74(7):687 690 8328887
Kewman DG, Tate DG Suicide in SCI: A psychological autopsy Rehabilitation Psychology 1998 43(2):143 151
Kiriakopoulos ET, Tasker RR, Nicosia S, Wood ML, Mikulis DJ Functional magnetic resonance imaging: a potential tool for the evaluation of spinal cord stimulation: technical case report Neurosurgery 1997 41(2):501 504 9257323
Kitahata LM Pain pathways and transmission Yale J Biol Med 1993 66(5):437 442 7825344
Klingler D, Kepplinger B, Gerstenbrand F, Heinisch W Epidural spinal electrostimulation (ESES) in patients with chronic pain and central motor disturbances Wien Klin Wochenschr 1981 93(22):688 695 7324483
Knutsdottir S Spinal cord injuries in Iceland 1973-1989. A follow up study Paraplegia 1993 31(1):68 72 8446450
Koeze TH, Williams AC, Reiman S Spinal cord stimulation and the relief of chronic pain J Neurol Neurosurg Psychiatry 1987 50(11):1424 1429 3500999
Kolarik J, Nadvornik P, Dvorak M, Andrs M Crossed transvertebral puncture to block spinal ganglion in treatment of pain Zentralbl Neurochir 1988 49(3):185 188 2977250
Kosugi Y, Takakura K, Naito Y Electrical stimulation of the dorsal column of the spinal cord for pain elimination Iyo Denshi to Seitai Kogaku 1976 14(1):33 40 1084934
Krainick JU, Thoden U. Methods of pain modulation by electrical stimulation. Langenbecks Arch Chir. 1976;342:75-81. [pmid: 1086945].
Kramer KM, Levine AM Posttraumatic syringomyelia: a review of 21 cases Clin Orthop 1997 Jan(334):190 199
Krames ES Intraspinal opioid therapy for chronic nonmalignant pain: current practice and clinical guidelines J Pain Symptom Manage 1996(6):333 352
Krassioukov A, Wolfe DL, Hsieh J, et al Quantitative sensory testing in patients with incomplete spinal cord injury Arch Phys Med Rehabil 1999 80(10):1258 1263 10527084
Kremer E, Atkinson JHJ Pain measurement: construct validity of the affective dimension of the McGill Pain Questionnaire with chronic benign pain patients Pain 1981 11(1):93 100 7301404
Kroin JS Intrathecal drug administration. Present use and future trends Clin Pharmacokinet 1992 22(5):319 326 1380410
Krueger EG. Management of painful states in injuries of the spinal cord and cauda equina. Am J Phys Med. 1960;39:103-110. [pmid: 14412210].
Kumar K, Wyant GM Deep brain stimulation for alleviating chronic intractable pain Can J Surg 1985 28(1):20 22 3871656
Kumar K, Wyant GM, Nath R Deep brain stimulation for control of intractable pain in humans, present and future: a ten-year follow-up Neurosurgery 1990 26(5):774 781 2352595
Kumar K, Nath R, Wyant GM Treatment of chronic pain by epidural spinal cord stimulation: a 10-year experience J Neurosurg 1991 75(3):402 407 1869942
Kumar K, Toth C, Nath RK Spinal cord stimulation for chronic pain in peripheral neuropathy Surg Neurol 1996 46(4):363 369 8876718
Kumar K, Toth C, Nath RK Deep brain stimulation for intractable pain: a 15-year experience Neurosurgery 1997 40(4):736 746 9092847
Kumar K, Toth C, Nath RK, et al Epidural spinal cord stimulation for treatment of chronic pain -- some predictors of success. A 15-year experience Surg Neurol 1998 50(2):110 120 9701116
Kuo H-C Quality of life after active urological management of chronic spinal cord injury in Eastern Taiwan Eur Urol 1998 34(1):37 46 9676412
Lacert P, Trottier S, Durand J, Pannier S, Grossiord A Late syringomyelic syndromes in paraplegics Rev Neurol 1977 133(5):325 338 897441
Laffey JG, Murphy D, Regan J, O'Keeffe D Efficacy of spinal cord stimulation for neuropathic pain following idiopathic acute transverse myelitis: a case report Clinical Neurology & Neurosurgery 1999 101(2):125 127 10467910
Lamid S, Chia JK, Kohli A, et al Chronic pain in spinal cord injury: comparison between inpatients and outpatients Arch Phys Med Rehabil 1985 66(11):777 778 4062530
Landells CD, Van PP Fractures of the atlas: classification, treatment and morbidity Spine 1988 13(5):450 452 3187689
Lang E, Krainick JU, Gerbershagen HU Spinal cord transmission of impulses during high spinal anesthesia as measured by cortical evoked potentials Anesth Analg 1989 69(1):15 20 2742163
Lang P The treatment of chronic pain by epidural spinal cord stimulation -- a 15 year follow up; present status Axone 1997 18(4):71 73 9295480
Larson SJ Surgical treatment of pain in patients with spinal cord injury J Am Paraplegia Soc 1986 9(3-4):51 53 3783153
Lau J, Ioannidis JP, Schmid CH Quantitative synthesis in systematic reviews Ann Intern Med 1997 127(9):820 826 9382404
Laupacis A, Wells G, Richardson WS, Tugwell P Users' guides to the medical literature. V. How to use an article about prognosis. Evidence-Based Medicine Working Group JAMA 1994 272(3):234 237 8022043
Lawrence RM Phantom pain: a new hypothesis Med Hypotheses 1980 6(3):234 248
Lazorthes Y, Verdie JC, Arbus L Anterior and posterior medullary analgesic stimulation, using a percutaneous implantation technic Acta Neurochir 1978 40(3-4):277 283
Lazorthes Y, Siegfried J, Verdie JC, Casaux J Chronic spinal cord stimulation in the treatment of neurogenic pain. Cooperative and retrospective study on 20 years of follow-up Neurochirurgie 1995 41(2):73 86 7630466
Lenz FA, Tasker RR, Dostrovsky JO, Kwan HC, Gorecki J, Hirayama T, Murphy JT Abnormal single-unit activity recorded in the somatosensory thalamus of a quadriplegic patient with central pain Pain 1987 31(2):225 236 3501563
Lenz FA, Kwan HC, Dostrovsky JO, Tasker RR Characteristics of the bursting pattern of action potentials that occurs in the thalamus of patients with central pain Brain Res 1989 496(1-2):357 360 2804648
Lenz FA, Kwan HC, Martin R, Tasker R, Richardson RT, Dostrovsky JO Characteristics of somatotopic organization and spontaneous neuronal activity in the region of the thalamic principal sensory nucleus in patients with spinal cord transection J Neurophysiol 1994 72(4):1570 1587 7823087
Levi R, Hultling C, Seiger A The Stockholm Spinal Cord Injury Study: 2. Associations between clinical patient characteristics and post-acute medical problems Paraplegia 1995 33(10):585 594 8848313
Levi R, Hultling C, Nash MS, Seiger A The Stockholm spinal cord injury study: 1. Medical problems in a regional SCI population Paraplegia 1995 33(6):308 315 7644255
Levi R, Hultling C, Seiger A The Stockholm spinal cord injury study. 3. Health-related issues of the Swedish annual level-of-living survey in SCI subjects and controls Paraplegia 1995 33(12):726 730 8927413
Levi R, Hultling C, Seiger A The Stockholm spinal cord injury study: 4. Psychosocial and financial issues of the Swedish annual level-of-living survey in SCI subjects and controls Paraplegia 1996 34(3):152 157 8668355
Levitt M, Ovelmen-Levitt J, Nashold Jr. BS, Yezierski RP Letter to the Editor: Comment on Yezierski, Pain, 68 (1996) 185-194 Pain 1997 73(1):115 119 9414069
Levy RM, Lamb S, Adams JE Treatment of chronic pain by deep brain stimulation: long term follow-up and review of the literature Neurosurgery 1987 21(6):885 893 3325851
Levy WJ, Nutkiewicz A, Ditmore M, et al Laser-induced dorsal root entry zone lesions for pain control. Report of three cases J Neurosurg 1983 59(5):884 886 6194280
Leys D, Petit H, Lesoin F, et al Late posttraumatic syringomyelic syndromes. Pathogenetic theories apropos of 3 cases Acta Neurol Belg 1986 86(1):11 19 3962583
Likavec MJ. Raj P, editors. Practical management of pain. Chicago: Year Book Medical Publishers. Pain secondary to parplegia or quadriplegia. 1986:p. 224-227.
Linderoth B, Meyerson BA Dorsal column stimulation: modulation of somatosensory and autonomic function Seminars in the Neurosciences 1995 7(4):263 277
Little JW, Halar E Temporal course of motor recovery after Brown-Sequard spinal cord injuries Paraplegia 1985 23(1):39 46 3982846
Livshits AV, Sokolova AA, Khazanov IB, Fedorov VI, Kulikov IP Attempt at objective evaluation of pain and analgesia during stimulation of the posterior columns in patients with spinal cord lesions Zhurnal Voprosy Neirokhirurgii Imeni N - N - Burdenko 1984(6):42 47
Livshits AV, Sokolova AA, Demina NA Characteristics of the late components in somatosensory evoked potentials of patients with a pain syndrome in spinal cord involvement Zhurnal Nevropatologii i Psikhiatrii Imeni S - S - Korsakova 1988 88(5):30 34
Livshits AV The algesic syndrome in spinal cord trauma Paraplegia 1992 30(7):497 501 1508564
Livshits LI, Kereselidze SG Surgery of the pain-conducting tract of the spinal cord in the combined treatment of pain syndromes of the trunk and limbs Zhurnal Voprosy Neirokhirurgii Imeni N - N - Burdenko 1990(1):24 26
Loeser JD, Ward AAJ, White LE, Jr Chronic deafferentation of human spinal cord neurons J Neurosurg 1968 29(1):48 50 5244625
Long DM, Erickson DE Stimulation of the posterior columns of the spinal cord for relief of intractable pain Surg Neurol 1975 4(1):134 141 126498
Long DM. Bonica JJ, Albe-Fessard D, editors. Advances in pain research and therapy. New York: Raven Press. 1, Use of peripheral and spinal cord stimulation in the relief of chronic pain. 1976:p. 395-403.
Long DM, Erickson D, Campbell J, North R Electrical stimulation of the spinal cord and peripheral nerves for pain control. A 10-year experience Applied Neurophysiology 1981 44(4):207 217 6978679
Long DM. Stimulation of the peripheral nervous system for pain control. Clin Neurosurg. 1983;31:323-343. [pmid: 6238744].
Loubser PG Chronic spinal cord injury pain Acupunct Electrother Res 1987 12(3-4):266 267
Loubser PG, Donovan WH Diagnostic spinal anaesthesia in chronic spinal cord injury pain Paraplegia 1991 29(1):25 36 1708859
Loubser PG, Clearman RR Evaluation of central spinal cord injury pain with diagnostic spinal anesthesia Anesthesiology 1993 79(2):376 378 8342845
Loubser PG, Donovan WH. Narayan R, Wilberger J, Povlishock J, editors. Neurotrauma. New York: McGraw Hill. Chronic pain associated with spinal cord injury. 1996:p. 1311-1322.
Loubser PG, Akman NM Effects of intrathecal baclofen on chronic spinal cord injury pain J Pain Symptom Manage 1996 12(4):241 247 8898508
Loubser PG Adverse effects of epidural spinal cord stimulation on bladder function in a patient with chronic spinal cord injury pain [letter] J Pain Symptom Manage 1997 13(5):251 252 9185428
Lundqvist C, Siosteen A, Blomstrand C, Lind B, Sullivan M Spinal cord injuries. Clinical, functional, and emotional status Spine 1990 16(1):78 83
Lundqvist C, Andersen O, Blomstrand C, et al Spinal arteriovenous malformations. Health-related quality of life after embolization Acta Neurol Scand 1994 90(5):337 344 7887133
Manolescu R Lidocaine infusion to control post transection spinal pain Reg Anesth 1991 16(1 SUPPL.):
Mansuy L, Sindou M, Fischer G, Gerin P Current concepts on the physiology of pain at the spinal cord level. Neurosurgical applications Nouv Presse Med 1974 3(6):313 317 4362781
Mao J, Chen LL. Systemic lidociane for neuropathic pain relief. Pain. 2000;87:7-17. [pmid: 10863041].
Marchettini P, Lacerenza M, Formaglio F Experimental pain models and clinical chronic pain: Is plasticity enough to link them? Behav Brain Sci 1997 20(3):458 459
Mariano AJ, Britell CW, and Umlauf RL. Chronic pain and the psychosocial functioning of spinal cord injured outpatients. Forthcoming.
Mariano AJ Chronic pain and spinal cord injury Clin J Pain 1992 8(2):87 92 1633387
Maruyama Y, Shimoji K Epidural spinal cord stimulation: its efficacy and mechanisms Gan No Rinsho 1985 31(6 Suppl):729 735 2993694
Matthews JM, Wheeler GD, Burnham RS, Malone LA, Steadward RD The effects of surface anaesthesia on the autonomic dysreflexia response during functional electrical stimulation Spinal Cord 1997 35(10):647 651 9347592
Mattle H Diagnosis and differential diagnosis of back pain from the neurological point of view Schweiz Rundsch Med Prax 1986 Journal Suisse de Medecine 116(45):1550 1560
Maurer M, Henn V, Dittrich A, Hofmann A Delta-9-tetrahydrocannabinol shows antispastic and analgesic effects in a single case double-blind trial Eur Arch Psychiatry Clin Neurosci 1990 240(1):1 4 2175265
Maury M A propos du traitement de la douleur chez les paraplégiques Annales de Médecine Physique 1977 20(4):376 381
Maury M About pain and its treatment in paraplegics [proceedings] Paraplegia 1978 15(4):349 352 625436
Max MB Towards physiologically based treatment of patients with neuropathic pain Pain 1990 42(2):131 137 1701044
Mayer DJ, Price DD, Becker DP Neurophysiological characterization of the anterolateral spinal cord neurons contributing to pain perception in man Pain 1975 1(1):51 58 829276
Maynard FMJ, Bracken MB, Creasey G, Ditunno JFJ, Donovan WH, Ducker TB, Garber SL, Marino RJ, Stover SL, Tator CH, et al International Standards for Neurological and Functional Classification of Spinal Cord Injury. American Spinal Injury Association Spinal Cord 1997 35(5):266 274 9160449
McCormack K The spinal actions of nonsteroidal anti-inflammatory drugs and the dissociation between their anti-inflammatory and analgesic effects Drugs 1994 47(5 Suppl.):28 45 7525183
McKibbon A, Eady A, Marks S. PDQ Evidence-based Principles and Practice. Hamilton: B.C. Decker Inc.; 1999.
McKinley WO, Johns JS, Musgrove JJ Clinical presentations, medical complications, and functional outcomes of individuals with gunshot wound-induced spinal cord injury Am J Phys Med Rehabil 1999 78(2):102 107 10088582
McLachlan EM, Janig W, Devor M, Michaelis M Peripheral nerve injury triggers noradrenergic sprouting within dorsal root ganglia Nature 1993 363(6429):543 546 8505981
McQuay H, Carroll D, Jadad AR, Wiffen P, Moore A Anticonvulsant drugs for management of pain: a systematic review BMJ 1995 311(7012):1047 1052 7580659
McQuay HJ, Tramer M, Nye BA, Carroll D, Wiffen PJ, Moore RA A systematic review of antidepressants in neuropathic pain Pain 1996 68(2-3):217 227 9121808
McQuay H; Moore R. An evidence-based resource for pain relief. Oxford: Oxford University Press; 1998.
Meglio M, Cioni B Influence of spinal cord stimulation on peripheral blood flow Appl Neurophysiol 1982 45(1-2):195 200 6977322
Meglio M, Cioni B, Rossi GF Spinal cord stimulation in management of chronic pain. A 9-year experience J Neurosurg 1989 70(4):519 524 2538588
Meglio M, Cioni B, Prezioso A, Talamonti G Spinal cord stimulation (SCS) in deafferentation pain Pacing Clin Electrophysiol 1989 12(2):709 712 2470055
Melzack R The McGill Pain Questionnaire: major properties and scoring methods Pain 1975 1(3):277 299 1235985
Melzack R Acupuncture and pain mechanisms (author's transl) Anaesthesist 1976 25(5):204 207 183560
Melzack R, Loeser JD Phantom body pain in paraplegics: evidence for a central "pattern generating mechanism" for pain Pain 1978 4(3):195 210 273200
Melzack R Recent concepts of pain J Med 1982 13(3):147 160 6184428
Melzack R Phantom limbs Reg Anesth 1989 14(5):208 211 2486645
Melzack R Phantom limbs and the concept of a neuromatrix Trends Neurosci 1990 13(3):88 92 1691874
Mercadante S Gabapentin in spinal cord injury pain Pain Clinic 1998 10(3):203 206
Merritt JL Management of spasticity in spinal cord injury Mayo Clin Proc 1981 56(10):614 622 7278373
Merskey H; Bogduk N. Merskey H and Bogduk N, editors. Classification of Chronic Pain. 2nd ed. Seattle: IASP Press. 1994. [pmcid: 43273].
Mertens P, Parise M, Garcia-Larrea L, et al. Long-term clinical, electrophysiological and urodynamic effects of chronic intrathecal baclofen infusion for treatment of spinal spasticity. Acta Neurochir Suppl. 1995;64:17-25. [pmid: 8748577].
Meyer RI From the clinic: practice settings for kinesiotherapy -- Aquatics Clinical Kinesiology 1990 44(1):12 13
Meyers AR, Bisbee A, Winter M The "Boston Model" of managed care and spinal cord injury: a cross-sectional study of the outcomes of risk-based, prepaid, managed care Arch Phys Med Rehabil 1999 80(11):1450 1456 10569440
Meyerson B, Linderoth B, Lind G Spinal cord stimulation in chronic neuropathic pain Lakartidningen 1991 88(9):727 732 2002739
Meyerson BA, Cui JG, Yakhnitsa V, Sollevi A, Segerdahl M, Stiller CO, O'Connor WT, Linderoth B Modulation of spinal pain mechanisms by spinal cord stimulation and the potential role of adjuvant pharmacotherapy Stereotact Funct Neurosurg 1997 68(1-4 Pt 1):129 140 9711706
Meythaler JM Rehabilitation of Guillain-Barre syndrome Arch Phys Med Rehabil 1997 78(8):872 879 9344309
Michaelis LS The problem of pain in paraplegia and tetraplegia Bull N Y Acad Med 1970 46(2):88 96 5262937
Middleton JW, Siddall PJ, Walker S Intrathecal clonidine and baclofen in the management of spasticity and neuropathic pain following spinal cord injury: a case study Arch Phys Med Rehabil 1996 77(8):824 826 8702379
Milhorat TH, Kotzen RM, Mu HT, Capocelli ALJ, Milhorat RH Dysesthetic pain in patients with syringomyelia Neurosurgery 1996 38(5):940 946 8727819
Mion G, Ruttimann M, Daniel L Infra-anesthetic ketamine dosage in the treatment of neuropathic-type pain Ann Fr Anesth Reanim 1997 16(1):81 82 9686111
Monsivais JJ, Monsivais DB Managing chronic neuropathic pain with implanted anesthetic reservoirs Hand Clin 1996 12(4):781 786 8953297
Moore JE, Umlauf RL, Britell CB. Physical and psychosocial dysfunction in SCI patients with chronic pain. Pain. 1987;4.
Moossy JJ, Nashold Jr.BS, Osborne D, Friedman AH Conus medullaris nerve root avulsions J Neurosurg 1987 66(6):835 841 3572514
Moraci A, Ambrosio D, Mignini R Spinal cord stimulation in the treatment of post-traumatic intractable pain Rass Int Clin Ter 1982 62(10):649 653
Morley S, Eccleston C, Williams A Systematic review and meta-analysis of randomized controlled trials of cognitive behaviour therapy and behaviour therapy for chronic pain in adults, excluding headache Pain 1999 80(1-2):1 13 10204712
Morse JM, Mitcham C The experience of agonizing pain and signals of disembodiment J Psychosom Res 1998 44(6):667 680 9678748
Mueller AD. Pain study of paraplegic patients. Archives of Neurology (Chicago). 1962;7:117-120.
Mullen JB Acute hyperesthesia after spinal trauma Neurosurgery 1979 5(4):432 436 316505
Munglani R, Hunt SP Molecular biology of pain Br J Anaesth 1995 75(2):186 192 7577252
Myers RR The pathogenesis of neuropathic pain Reg Anesth 1995 20(3):173 184 7547652
Nagahiro S, Matsukado Y, Hirata Y, Saito Y, Hamada J, Fukumura A, Itoyama Y Pathogenesis and the treatment of secondary syringomyelia No to Shinkei 1987 39(2):143 149 3828149
Nagaro T, Shimizu C, Inoue H, Fujitani T, Adachi N, Amakawa K, Kimura S, Arai T, Watanabe T, Oka S The efficacy of intravenous lidocaine on various types of neuropathic pain Masui 1995 44(6):862 867 7637167
Nagaro T, Takaishi K, Kimura S, Arai T Inhibition of pain following spinal cord injury by the stimulation of the region just above deafferentation Pain Clinic 1995 9(2):201 204
Nakamura T, Kadoya S, Emori T, Kwak R, Itoh S, Yamamoto N, Teranaka, Toshima M A case report of post-traumatic syringomyelia No Shinkei Geka 1984 12(11):1325 1331 6514129
Nashold Jr. BS, Ostdahl RH Dorsal root entry zone lesions for pain relief J Neurosurg 1979 51(1):59 69 448420
Nashold Jr. BS, Bullitt E Dorsal root entry zone lesions to control central pain in paraplegics J Neurosurg 1981 55(3):414 419 6167696
Nashold Jr. BS Current status of the DREZ operation: 1984 Neurosurgery 1984 15(6):942 944 6514168
Nashold Jr. BS Influence of spinal cord stimulation on peripheral blood flow Appl Neurophysiol 1988 51(2-5):136 145 3291757
Nashold Jr. BS Deafferentation pain in man and animals as it relates to the DREZ operation Can J Neurol Sci 1988 15(1):5 9 3278779
Nashold Jr. BS, Alexander E. Tollison CDE, et-al., editors. Handbook of chronic pain management. Durham, NC: Duke U Medical Ctr, Div of Neurosurgery, Dept of Surgery, Professor, 1989. Neurosurgical treatment of Deafferentation Pain. p. 125-135.
Nashold Jr. BS, Vieira J, el-Naggar AO Pain and spinal cysts in paraplegia: treatment by drainage and DREZ operation Br J Neurosurg 1990 4(4):327 335 2222879
Nashold BS. Nashold B, Ovelmen-Levitt J, editors. Deafferentation Pain Syndrome: Pathophysiology and Treatment. New York: Raven Press. Paraplegia and pain. 1991:p. 301-319.
Nepomuceno C, Gowens H, Stover SL, et al. Pain in the spinal cord injured. Arch Phys Med Rehabil. 1977;58:532-533.
Nepomuceno C, Fine PR, Richards JS, Gowens H, Stover SL, Rantanuabol U, Houston R Pain in patients with spinal cord injury Arch Phys Med Rehabil 1979 60(12):605 609 518270
Ness TJ, San Pedro E, Richards JS, Kezar L, Liu HG, Mountz JM A case of spinal cord injury-related pain with baseline rCBF brain SPECT imaging and beneficial response to gabapentin Pain 1998 78(2):139 143 9839825
New PW, Lim TC, Hill ST, Brown DJ A survey of pain during rehabilitation after acute spinal cord injury Spinal Cord 1997 35(10):658 663 9347594
Nguyen JP, Keravel Y, Feve A, Uchiyama T, Cesaro P, Le Guerinel C, Pollin B. Treatment of deafferentation pain by chronic stimulation of the motor cortex: report of a series of 20 cases. Acta Neurochir Suppl. 1997;68:54-60. [pmid: 9233414].
Nguyen JP, Lefaucheur JP, Decq P, Uchiyama T, Carpentier A, Fontaine, Brugieres P, Pollin B, Feve A, Rostaing S Chronic motor cortex stimulation in the treatment of central and neuropathic pain. Correlations between clinical, electrophysiological and anatomical data Pain 1999 82(3):245 251 10488675
Nichols PJ, Norman PA, Ennis JR Wheelchair user's shoulder? Shoulder pain in patients with spinal cord lesions Scand J Rehabil Med 1979 11(1):29 32 419395
Nicolle MH, Audic B, Rhein F, Del GN Cyclic dysaesthetic pain syndrome in paraplegic patients Presse Medicale 1941 19(41):
Nielson KD, Adams JE, Hosobuchi Y Experience with dorsal column stimulation for relief of chronic intractable pain: 1968-1973 Surg Neurol 1975 4(1):148 152 1080899
North RB Spinal cord stimulation for intractable pain: long-term follow-up J Spinal Disord 1990 3(4):356 361 2151991
North RB, Ewend MG, Lawton MT, Piantadosi S Spinal cord stimulation for chronic, intractable pain: superiority of "multi-channel" devices Pain 1991 44(2):119 130 2052378
North RB, Fowler K, Nigrin DJ, Szymanski R Patient-interactive, computer-controlled neurological stimulation system: clinical efficacy in spinal cord stimulator adjustment J Neurosurg 1992 76(6):967 972 1588431
North RB, Kidd DH, Zahurak M, James CS, Long DM Spinal cord stimulation for chronic, intractable pain: experience over two decades Neurosurgery 1993 32(3):384 394 8455763
North RB. Spinal cord stimulation for chronic, intractable pain. Adv Neurol. 1993;63:289-301. [pmid: 8279313].
North RB, Roark GL Spinal cord stimulation for chronic pain Neurosurg Clin N Am 1995 6(1):145 155 7696870
Notake M, Takata M The usefulness of CoSPANrho microcatheter for pain relief of the patient with incomplete lumbar spinal cord injury Hokuriku Journal of Anesthesiology 1996 30(1):45 47
Noth J Trends in the pathophysiology and pharmacotherapy of spasticity J Neurol 1991 238(3):131 139 1869888
Oaklander AL The pathology of pain Neuroscientist 1999 5(5):302 310
Ohry A, Heim M, Steinbach TV, Rozin R The needs and unique problems facing spinal cord injured persons after limb amputation Paraplegia 1983 21(4):260 263 6622052
Ohry A Pain syndromes in spinal cord injured patients Harefuah 1986 110(9):470 473 3530921
Ohta Y, Akino M, Iwasaki Y, Abe H Spinal epidural stimulation for central pain caused by spinal cord lesion No Shinkei Geka 1992 20(2):147 152 1371851
Onofrio BM, Yaksh TL Long-term pain relief produced by intrathecal morphine infusion in 53 patients J Neurosurg 1990 72(2):200 209 1688618
Ostrovsky MA Selected cognitive abilities of subpopulations of chronic pain patients and controls Dissertation Abstracts International: Section B: The Sciences and Engineering 1994 1995 Mar(9-B):
http://www.jr2.ox.ac.uk/Bandolier/painres/painpag/index.html. Accessed on July 16, 1999.
Ozerbil OM, Duman A, Yosunkaya A, Bayram A, Ustun ME Epidural administration of midasolam for chronic central pain and spasticity in spinal cord injured patients Journal of Rheumatology & Medical Rehabilitation 1997 8(4):328 330
Paeslack V, Spahn B, Sommer K Pain in paraplegics Fortschr Med 1990 108(4):49 50 2179082
Pagni CA. Wall P, Melzack R, editors. Textbook of Pain. Edinburgh: Churchill Livingstone. 45, Central pain due to spinal cord and brain stem damage. 1989:p. 634-655.
Pagni CA, Canavero S Cordomyelotomy in the treatment of paraplegia pain. Experience in two cases with long-term results Acta Neurol Belg 1995 95(1):33 36 7725895
Parsons KC, Lammertse DP Rehabilitation in spinal cord disorders. 1. Epidemiology, prevention, and system of care of spinal cord disorders Arch Phys Med Rehabil 1991 72(4-S):S293 S294 2003760
Pentland W, McColl M, Rosenthal C The effect of aging and duration of disability on long term health outcomes following spinal cord injury Paraplegia 1995 33(7):367 373 7478724
Pentland WE, Twomey LT The weight-bearing upper extremity in women with long term paraplegia Paraplegia 1991 29(8):521 530 1775358
Pentland WE, Twomey LT Upper limb function in persons with long term paraplegia and implications for independence: Part I Paraplegia 1994 32(4):211 218 8022630
Perrouin-Verbe B, Robert R, Lefort M, Agakhani N, Tadie M, Mathe JF Post-traumatic syringomyelia Neurochirurgie 1999 45Suppl 1:58 66
Pertovaara A Antinociception induced by alpha-2-adrenoceptor agonists, with special emphasis on medetomidine studies Prog Neurobiol 1993 40(6):691 709 8097888
Petersen-Zeitz KR, Basbaum AI. Second messengers, the substantia gelatinosa and injury-induced persistent pain. Pain. 1999;Suppl 6:S5-S12. [pmid: 10491967].
Petros AJ, Wright RM Epidural and oral clonidine in domiciliary control of deafferentation pain Lancet 1987 1(8540):
Philip L. Gildenberg and Donlin M. Long, editors. Seminar on spinal cord stimulation for the control of pain and other neurological disorders. New York, April 1980. 44 ed. New York, NY: S. Karger. 1981. [pmcid: 281528].
Piscol K. Open spinal operations (anterolateral chordotomy and commissural myelotomy) in modern treatment of pain. Langenbecks Arch Chir. 1976;342:91-99. [pmid: 1069182].
Pockett S Spinal cord synaptic plasticity and chronic pain Anesth Analg 1995 80(1):173 179 7802274
Pollock LJ. Pain below the level of injury of the spinal cord. Archives of Neurological Psychiatry. 1951;65:319-322.
Portenoy RK, Foley KM, Inturrisi CE The nature of opioid responsiveness and its implications for neuropathic pain: new hypotheses derived from studies of opioid infusions Pain 1990 43(3):273 286 1705692
Portenoy R. Basbaum A, Besson J-M, editors. Towards a New Pharmacology of Pain. New York: Wiley. Issues in the management of neuropathic pain. 1991:p. 393-414.
Portenoy R. Bruera E, Portenoy R, editors. Topics in Palliative Care. New York: Oxford University Press. Introduction: Neuropathic pain: from unresolved questions to clinical practice. 1998:p. 3-5.
Porter RW, Hohmann GW, Bors E, et al Cordotomy for pain following cauda equina injury Arch Surg 1966 92(5):765 770 5219788
Posner JB Back pain and epidural spinal cord compression Med Clin North Am 1987 71(2):185 205 2950289
Potter PJ, New P Letters to the editor Spinal Cord 1998 36(7):
Potter PJ A survey of pain during rehabilitation after acute spinal cord injury Spinal Cord 1998 36(7):
Potter PJ, Hayes KC, Hsieh JC, Delaney GA, Segal JL Sustained improvements in neurological function in spinal cord injured patients treated with oral 4-aminopyridine: Three cases Spinal Cord 1998 36(3):147 155 9554012
Powers SK, Barbaro NM, Levy RM Pain control with laser-produced dorsal root entry zone lesions Appl Neurophysiol 1988 51(2-5):243 254 3389802
Poynton AR, O'Farrell DA, Shannon F, Murray P, McManus F, Walsh MG Sparing of sensation to pin prick predicts recovery of a motor segment after injury to the spinal cord J Bone Joint Surg Br 1997 79(6):952 954 9393910
Probst C Demand-controlled continuous spinal-cerebral morphine administration via an implanted programmable pump Schweiz Rundsch Med Prax 1991 80(46):1278 1282 1835544
Pruitt SD, Wahlgren DR, Epping-Jordan JE, Rossi AL Health behavior in persons with spinal cord injury: development and initial validation of an outcome measure Spinal Cord 1998 36(10):724 731 9800276
Quigley P, Veit N Interdisciplinary pain assessment of spinal cord injury patients SCI Nurs 1996 13(3):62 68 8900667
Radwanski M Self-medicating practices for managing chronic pain after spinal cord injury Rehabil Nurs 1992 17(6):312 317 1492160
Ragnarsson KT Management of pain in persons with spinal cord injury J Spinal Cord Med 1997 20(2):186 199 9144608
Raj P Complex spinal pain -- Concepts of its management Pain Digest 1995 5(3):143 147
Rath SA, Braun V, Soliman N, Antoniadis G, Richter HP Results of DREZ coagulations for pain related to plexus lesions, spinal cord injuries and postherpetic neuralgia Acta Neurochir 1996 138(4):364 369
Rath SA, Seitz K, Soliman N, Kahamba JF, Antoniadis G, Richter HP DREZ coagulations for deafferentation pain related to spinal and peripheral nerve lesions: indication and results of 79 consecutive procedures Stereotact Funct Neurosurg 1997 68(1-4 Pt 1):161 167 9711710
Ravenscroft A, Ahmed YS, Burnside IG Chronic pain after spinal cord injury: a survey of practice in UK spinal injury units Spinal Cord 1999 37(1):25 28 10025691
Rawlings CE, el-Naggar AO, Nashold Jr. BS The DREZ procedure: an update on technique Br J Neurosurg 1989 3(6):633 642 2697214
Ray CD Electrical stimulation: new methods for therapy and rehabilitation Scand J Rehbil Med 1978 10(2):65 74
Reading AE A comparison of the McGill Pain Questionnaire in chronic and acute pain Pain 1982 13(2):185 192 6889722
Rhein F, Del GN, Audic B, Nicolle MH Chronic cyclical pain in spinal cord injury patients Annales de Readaptation et de Medecine Physique 1995 38(2):65 69
Richards JS, Meredith RL, Nepomuceno C, Fine PR, Bennett G Psycho-social aspects of chronic pain in spinal cord injury Pain 1980 8(3):355 366 7402693
Richards JS, Nepomuceno C, Riles M, Suer Z Assessing pain behavior: the UAB Pain Behavior Scale Pain 1982 14(4):393 398 7162841
Richards JS, Stover SL, Jaworski T Effect of bullet removal on subsequent pain in persons with spinal cord injury secondary to gunshot wound J Neurosurg 1990 73(3):401 404 2384778
Richards JS Chronic pain and spinal cord injury: review and comment Clin J Pain 1992 8(2):119 122 1633375
Richardson RR, Meyer PR, Cerullo LJ Neurostimulation in the modulation of intractable paraplegic and traumatic neuroma pains Pain 1980 8(1):75 84 6966047
Richardson RR, Meyer PRJ, Cerullo LJ Transcutaneous electrical neurostimulation in musculoskeletal pain of acute spinal cord injuries Spine 1980 5(1):42 45 6965811
Richardson RR Posterior spinal cord stimulation for treatment of sequela spinal injury Journal of Orthopaedic Surgical Techniques 1987 3(3-4):165 173
Richardson RR Posterior spinal cord stimulation for treatment of spinal cord injury sequelae Journal of Neurological & Orthopaedic Medicine & Surgery 1988 9(1):67 73
Richter HP, Seitz K Dorsal root entry zone lesions for the control of deafferentation pain: experiences in ten patients Neurosurgery 1984 15(6):956 959 6514172
Riddoch G. The clinical features of central pain. Lancet. 1938;234:1093-1209.
Rintala DH, Hart KA, Fuhrer MJ. Self-reported pain in persons with chronic spinal cord injury. J Am Paraplegia Soc. 1991;14.
Rintala DH, Loubser PG, Castro J, Hart KA, Fuhrer MJ Chronic pain in a community-based sample of men with spinal cord injury: prevalence, severity, and relationship with impairment, disability, handicap, and subjective well-being Arch Phys Med Rehabil 1998 79(6):604 614 9630137
Rish BL, Dilustro JF, Salazar AM, Schwab KA, Brown HR Spinal cord injury: a 25-year morbidity and mortality study Mil Med 1997 162(2):141 148 9038035
Robinson AJ Central nervous system pathways for pain transmission and pain control: issues relevant to the practicing clinician J Hand Ther 1997 10(2):64 77 9188026
Robinson LR, Little JW Motor-evoked potentials reflect spinal cord function in post-traumatic syringomyelia Am J Phys Med Rehabil 1990 69(6):307 310 2264950
Roby-Brami A, Bussel B, Willer JC, et al An electrophysiological investigation into the pain-relieving effects of heterotopic nociceptive stimuli. Probable involvement of a supraspinal loop Brain 1987 110(6):1497 1508 2448000
Rodriguez GP, Claus-Walker J, Kent MC, et al Adrenergic receptors in insensitive skin of spinal cord injured patients Arch Phys Med Rehabil 1986 67(3):177 180 3006630
Roelcke U, Curt A, Otte A, Missimer J, Maguire RP, Dietz V, Leenders KL Influence of spinal cord injury on cerebral sensorimotor systems: a PET study J Neurol Neurosurg Psychiatry 1997 62(1):61 65 9010401
Ronk LL Spinal cord stimulation for chronic, nonmalignant pain Orthop Nurs 1996 15(5):53 58 8954465
Rose M, Robinson JE, Ells P, Cole JD Pain following spinal cord injury: results from a postal survey Pain 1988 34(1):101 102 3405616
Roth EJ. Yarkony G, editors. Spinal Cord Injury: Medical and Rehabilitation Management. Gaithersburg, MD. Pain in spinal cord injury. 1994:p. 141-158.
Rumiantsev IV, Morozov VI The surgical treatment of the chronic pain syndrome in complicated spinal trauma Sovetskaia Meditsina 1991(7):72 76
Salvador S, Montoto A, Juan-Garcia FJ, Rodriguez AR, Rodriguez A Pain and spinal cord injury Dolor 1997 12(3):187 195
Samii M, Moringlane JR Thermocoagulation of the dorsal root entry zone for the treatment of intractable pain Neurosurgery 1984 15(6):953 955 6514171
Sampson JH, Cashman RE, Nashold Jr. BS, Friedman AH Dorsal root entry zone lesions for intractable pain after trauma to the conus medullaris and cauda equina J Neurosurg 1995 82(1):28 34 7815130
Sanchez-Ledesma MJ, Garcia-March G, Diaz-Cascajo P, Gomez-Moreta J, Broseta J Spinal cord stimulation in deafferentation pain Stereotact Funct Neurosurg 1989 53(1):40 45 2472663
Sandford PR, Lindblom LB, Haddox JD Amitriptyline and carbamazepine in the treatment of dysesthetic pain in spinal cord injury Arch Phys Med Rehabil 1992 73(3):300 301 1543437
Sapkas G, Papadakis S, Katonis P, Roidis N, Kontakis G Operative treatment of unstable injuries of the cervicothoracic junction European Spine Journal 1999 8(4):279 283 10483829
Sawynok J Adenosine receptor activation and nociception Eur J Pharmacol 1998 347(1):1 11 9650842
Schaller B, Mindermann T, Gratzl O Treatment of syringomyelia after posttraumatic paraparesis or tetraparesis J Spinal Disord 1999 12(6):485 488 10598990
Schvarcz JR. Chronic self-stimulation of the medial posterior inferior thalamus for the alleviation of deafferentation pain. Acta Neurochir Suppl. 1980;30:295-301.
Schwartz RG, Gall NG, Grant AE Abdominal pain in quadriparesis: myofascial syndrome as unsuspected cause Arch Phys Med Rehabil 1984 65(1):44 46 6691798
Schwartzman RJ, McLellan TL Reflex sympathetic dystrophy. A review Arch Neurol 1987 44(5):555 561 3495254
Schwartzman RJ, Maleki J Postinjury neuropathic pain syndromes Med Clin North Am 1999 83(33):597 626 10386117
Sedan R, Farnarier G, Rossi PP Current indications for inserting a stimulator of the posterior columns of the spinal cord in the treatment of intractable pain Sem Hop 1976 52(18-19):1139 1143 189392
Seemann H, Lang H. Forschungsbericht des gleichnamigen Projektes des Projekttragers GSF -- Forschungszentrum fur Umwelt und Gesundheit. GSF Munchen. 1992;55.
Segatore M Deafferentation pain after spinal cord injury. Part II. Management SCI Nurs 1992 9(3):72 78 1519040
Segatore M Deafferentation pain after spinal cord injury. Part I. theoretical aspects SCI Nurs 1992 9(2):46 50 1626277
Segatore M Understanding chronic pain after spinal cord injury J Neurosci Nurs 1994 26(4):230 236 7814915
Seifert V, Zimmermann M, Stolke D, et al Spondylectomy, microsurgical decompression and osteosynthesis in the treatment of complex disorders of the cervical spine Acta Neurochir 1993 124(2-4):104 113
Shannon N, Symon L, Logue V, Cull D, Kang J, Kendall B Clinical features, investigation and treatment of post-traumatic syringomyelia J Neurol Neurosurg Psychiatry 1981 44(1):35 42 7205304
Shatin D, Mullett K, Hults G Totally implantable spinal cord stimulation for chronic pain: design and efficacy Pacing Clin Electrophysiol 1986 9(4):577 583 2426676
Shen CH, Hung CJ, Wu CC, Huang HW, Ho WM Rhabdomyolysis-induced acute renal failure after morphine overdose -- a case report Acta Anaesthesiologica Sinica 1999 37(3):159 162 10609351
Sherman RA, Ernst JL, Markowski J Relationships between near surface blood flow and altered sensations among spinal cord injured veterans Am J Phys Med 1986 65(6):281 297 3789129
Sherman RA, Barja RH, Bruno GM. Thermographic correlates of chronic pain: analysis of 125 patients incorporating evaluations by a blind panel. Arch Phys Med Rehabil. 1987;68:273-279. [pmid: 3579531].
Sherman RA, Katz J, Marbach JJ, et al. William J. Ray, editors. Phantom pain. New York: Plenum Press. 1997. 1, Locations, characteristics, and descriptions.
Shimoji K, Hokari T, Kano T, Tomita M, Kimura R, Watanabe S, Endoh, Fukuda S, Fujiwara N, Aida S Management of intractable pain with percutaneous epidural spinal cord stimulation: differences in pain-relieving effects among diseases and sites of pain Anesth Analg 1993 77(1):110 116 8317715
Shukhov VS, Sharov NA The psychological-algological characteristics of patients with posttraumatic spinal cord and spinal diseases Zhurnal Nevropatologii i Psikhiatrii Imeni S - S - Korsakova 1993 93(2):47 50
Shukla VK, Lemaire S Non-opioid effects of dynorphins: possible role of the NMDA receptor Trends Pharmacol Sci 1994 15(11):420 424 7855907
Siddall PJ, Cousins MJ. Stanley T, Ashburn M, editors. Anesthesiology and pain management. Amsterdam: Kluwer Academic. Post spinal cord injury pain: mechanisms and treatment options. 1994:p. 237-251.
Siddall PJ, Gray M, Rutkowski S, Cousins MJ Intrathecal morphine and clonidine in the management of spinal cord injury pain: a case report Pain 1994 59(1):147 148 7854795
Siddall PJ, Taylor D, Cousins MJ Pain associated with spinal cord injury Curr Opin Neurol 1995 8(6):447 450 8845929
Siddall PJ, Cousins MJ Recent advances in pain management Aust NZ J Surg 1995 65(9):674 685
Siddall PJ, Taylor DA, Cousins MJ Classification of pain following spinal cord injury Spinal Cord 1997 35(2):69 75 9044512
Siddall PJ, Taylor DA, McClelland JM, Rutkowski SB, Cousins MJ Pain report and the relationship of pain to physical factors in the first 6 months following spinal cord injury Pain 1999 81(1-2):187 197 10353507
Siddall PJ, McClelland J Non-painful sensory phenomena after spinal cord injury J Neurol Neurosurg Psychiatry 1999 66(5):617 622 10209173
Sie IH, Waters RL, Adkins RH, et al Upper extremity pain in the postrehabilitation spinal cord injured patient Arch Phys Med Rehabil 1992 73(1):44 48 1729973
Siegfried J Sensory thalamic neurostimulation for chronic pain Pacing Clin Electrophysiol 1987 10(1 Pt 2):209 212 2436180
Silfverskiold J, Waters RL Shoulder pain and functional disability in spinal cord injury patients Clin Orthop 1991(272):141 145
Simone DA Allodynia, hyperalgesia, and excitability of dorsal horn neurons APS Journal 1993 2(1):34 36
Simpson BA Spinal cord stimulation in 60 cases of intractable pain J Neurol Neurosurg Psychiatry 1991 54(3):196 199 1827648
Sindou M, Rosati C, Millet MF, Beneton C. Selective posterior rhizotomy in the dorsal root entry zone for treatment of hyperspasticity and pain in the lower limb (s). Neurochirurgie. 1987;33:433-454. [pmid: 3328098].
Sindou M The dorsal root entry zone of the spinal cord: the surgical target in the treatment of pain and spasticity Bull Acad Natl Med 1989 173(8):1039 1044 2633855
Sindou M, Jeanmonod D Microsurgical DREZ-otomy for the treatment of spasticity and pain in the lower limbs Neurosurgery 1989 24(5):655 670 2716974
Sindou M Microsurgical DREZotomy (MDT) for pain, spasticity, and hyperactive bladder: a 20-year experience Acta Neurochir 1995 137(1-2):1 5
Sindrup SH, Jensen TS Efficacy of pharmacological treatments of neuropathic pain: an update and effect related to mechanism of drug action Pain 1999 83(3):389 400 10568846
Sipski ML, Delisa JA, Schweer S Functional electrical stimulation bicycle ergometry: patient perceptions Am J Phys Med Rehabil 1989 68(3):147 149 2730783
Sipski ML, Hendler S, Delisa JA Rehabilitation of patients with spinal cord disease Neurol Clin 1991 9(3):705 725 1921954
Sipski ML, Alexander CJ, Harris M Long-term use of computerized bicycle ergometry for spinal cord injured subjects Arch Phys Med Rehabil 1993 74(3):238 341 8439248
Slabaugh PB, Smith TK Neuropathic spine after spinal cord injury. A case report J Bone Joint Surg Am 1978 60(7):1005 1006 701332
Sluka KA, Rees H The neuronal response to pain Physiotherapy Theory & Practice 1997 13(1):3 22
Sollevi A, Belfrage M, Lundeberg T, Segerdahl M, Hansson P Systemic adenosine infusion: a new treatment modality to alleviate neuropathic pain Pain 1995 61(1):155 158 7644239
Song ZK, Cohen MJ, Ament PA, Ho WH, Vulpe M, Schandler SL Two-point discrimination thresholds in spinal cord injured patients with dysesthetic pain Paraplegia 1993 31(8):485 493
Song ZK, Cohen MJ, Schandler SL, Ho WH, and Vulpe M. Tactual pain sensitivity of spinal cord injured patients with and without pain. Forthcoming.
Spaic M, Petkovic S, Tadic R, Minic L DREZ surgery on conus medullaris (after failed implantation of vascular omental graft) for treating chronic pain due to spine (gunshot) injuries Acta Neurochir. (Wien.) 1999 141(12):1309 1312 300905 10672302
Spitzer M Noise-driven neuroplasticity in self-organizing feature maps: a neurocomputational model of phantom limbs MD Comput 1997 14(3):192 199 9151509
Standaert C, Cardenas DD, Anderson P Charcot spine as a late complication of traumatic spinal cord injury Arch Phys Med Rehabil 1997 78(2):221 225 9041906
Stensman R Adjustment to traumatic spinal cord injury. A longitudinal study of self-reported quality of life Paraplegia 1994 32(6):416 422 8090550
Stetkarova I, Halter JA, Dimitrijevic MR Surface and epidural lumbosacral spinal cord evoked potentials in chronic spinal cord injury J Neurotrauma 1993 10(3):315 326 8258844
Stevens JC, Patterson MQ Dimensions of spatial acuity in the touch sense: changes over the life span Somatosens Mot Res 1995 12(1):29 47 7571941
Stiefel F Malignant and non-malignant chronic pain: therapy, opioids and fears Swiss Centre for Paraplegia, Nottwil, 6 May 1993 Support Care Cancer 1993 1(5):279 280 8156242
Stormer S, Gerner HJ, Gruninger W, Metzmacher K, Follinger S, Wienke, Aldinger W, Walker N, Zimmermann M, Paeslack V Chronic pain/dysaesthesiae in spinal cord injury patients: results of a multicentre study Spinal Cord 1997 35(7):446 455 9232750
Stover SL, Fine PR The epidemiology and economics of spinal cord injury Paraplegia 1987 25(3):225 228 3601432
Stranjalis G, Torrens M Dorsal root entry zone lesion performed with Nd:YAG laser Br J Neurosurg 1997 11(3):238 240 9231013
Subbarao JV, Klopfstein J, Turpin R. Prevalence of wrist and shoulder pain in patients with spinal cord injury. J Spinal Cord Med. 1994;18:9-13.
Summers JD, Rapoff MA, Varghese G, Porter K, Palmer RE Psychosocial factors in chronic spinal cord injury pain Pain 1991 47(2):183 189 1762813
Sved P, Siddall PJ, McClelland J, Cousins MJ Relationship between surgery and pain following spinal cord injury Spinal Cord 1997 35(8):526 530 9267918
Svendsen L, Drewes AM, Biering-Sorensen F, et al Chronic pain after spinal cord injury: a descriptive study Ugeskr Laeger 1993 155(39):3118 3122 8212402
Sweet W. Phantom sensations following intraspinal injury. Neurochirurgia. 1975;18:139-154. [pmid: 1105222].
Sweet WH, Wepsic JG. Stimulation of the posterior columns of the spinal cord for pain control: indications, technique, and results. Clin Neurosurg. 1974;21:278-310. [pmid: 4371724].
Sweet WH, Wepsic J Stimulation of the posterior columns of the spinal cord for pain control Surg Neurol 1975 4(1):
Taira T, Kawamura H, Tanikawa T, Iseki H, Kawabatake H, Takakura K A new approach to control central deafferentation pain: spinal intrathecal baclofen Stereotact Funct Neurosurg 1995 65(1-4):101 105 8916336
Taira T, Kawamura H, Tanikawa T, Kawabatake H, Iseki H, Ueda A, Takakura K. A new approach to the control of central deafferentation pain: spinal intrathecal baclofen. Acta Neurochir Suppl. 1995;64:136-138. [pmid: 8748602].
Tanelian DL, Brose WG Neuropathic pain can be relieved by drugs that are use-dependent sodium channel blockers: lidocaine, carbamazepine, and mexiletine Anesthesiology 1991 74(5):949 951 1850581
Tang ST, Chu NK, Wong MK Intracavernous injection of prostaglandin E1 in spinal cord injured patients with erectile dysfunction. A preliminary report Paraplegia 1995 33(12):731 733 8927414
Tani S, Shimizu H, Ishijima B, Hanakago R Our experiences of PISCES (percutaneously inserted spinal cord electrical stimulation) in SMON and other neurologic disorders No to Shinkei 1984 36(4):383 388 6611163
Tanikawa T Electrical stimulation for pain relief--spinal cord stimulation No Shinkei Geka 1983 11(12):1225 1236 6608061
Tarlov IM Deafferentation to relieve spasticity or rigidity: reasons for failure in some cases of paraplegia J Neurosurg 1966 25(3):270 274 5921316
Tasker RR, DeCarvalho GT, Dolan EJ Intractable pain of spinal cord origin: clinical features and implications for surgery J Neurosurg 1992 77(3):373 378 1506884
Tasker RR, Vilela FO Deep brain stimulation for neuropathic pain Stereotact Funct Neurosurg 1995 65(1-4):122 124 8916340
Teasell RW, Arnold JO, Delaney GA Sympathetic nervous system dysfunction in high-level spinal cord injuries Physical Medicine & Rehabilitation: State of the Art Reviews 1996 10(1):37 60
ten Vaarwerk IAM, Staal MJ Spinal cord stimulation in chronic pain syndromes Spinal Cord 1998 36(10):671 682 9800271
Tharion G, Bhattacharji S Aspirin in chloroform as an effective adjuvant in the management of chronic neurogenic pain Arch Phys Med Rehabil 1997 78(4):437 439 9111466
Theuvenet PJ, Dunajski Z, Peters MJ, van RJ Responses to median and tibial nerve stimulation in patients with chronic neuropathic pain Brain Topography 1999 11(4):305 313 10449261
Thoden U, Krainick JU Ambulatory treatment of pain using transcutaneous nerve stimulation Dtsch Med Wochenschr 1974 99(34):1692 1693 4546588
Thoumie P Pain in paraplegic and tetraplegic patients Revue du Praticien 1995 45(16):2037 2039 8578115
Tilsley GN Pain, pains and patients. I Nurs Times 1967 63(18):
Tokunaga A, Senba E Molecular mechanisms of chronic pain Masui 1996 45(5):547 557 8847779
Transfeldt EE, White D, Bradford DS, Roche B Delayed anterior decompression in patients with spinal cord and cauda equina injuries of the thoracolumbar spine Spine 1990 15(9):953 957 2259987
Tronca R, Simon JL, Dumurgier C Retrospective study of paraplegics treated for over 25 years at the Invalides National Institute Annales de Readaptation et de Medecine Physique 1989 32(6):773 782
Tsubokawa T, Yamamoto T, Katayama Y, et al Deep brain stimulation for relief of intractable pain. Clinical results of thalamic relay stimulation Neurol Med Chir 1982 22(3):211 218
Tsubokawa T, Katayama Y, Yamamoto T, et al Deafferentation pain and stimulation of the thalamic sensory relay nucleus: clinical and experimental study Appl Neurophysiol 1985 48(1-6):166 171 3017207
Tsuda T, Tasker RR Percutaneous epidural electrical stimulation of the spinal cord for intractable pain -- with special reference to deafferentation pain No Shinkei Geka 1985 13(4):409 415 3875050
Tunks E. Bloch R, Basbaum M, editors. Management of Spinal Cord Injuries. Baltimore. Pain in spinal cord injured patients. 1986:p. 180-211.
Turner JA, Loeser JD, Bell KG Spinal cord stimulation for chronic low back pain: a systematic literature synthesis Neurosurgery 1995 37(6):1088 1095 8584149
Turner JA, Cardenas DD Chronic pain problems in individuals with spinal cord injuries Semin Clin Neuropsychiatry 1999 4(3):186 194 10498786
Umbach I, Heilporn A Post-spinal cord injury syringomyelia Paraplegia 1991 29(4):219 221 1870887
Umlauf, R. L., Moore, J.E., and Britell, C.W. Prevalence and nature of the pain experience in spinal cord injured. 1987. Paper presented at the 8th annual meeting of the Society of Behavioral Medicine, Washington, DC. [pmcid: 373129].
Umlauf RL Psychological interventions for chronic pain following spinal cord injury Clin J Pain 1992 8(2):111 118 1633374
Urban BJ, Nashold Jr.BS Percutaneous epidural stimulation of the spinal cord for relief of pain. Long-term results J Neurosurg 1978 48(3):323 328 305469
Urban E, Jabbari B, Robles H Concurrent cerebral venous sinus thrombosis and myeloradiculopathy in Sjogren's syndrome Neurology 1994 44(31):554 556 8145932
Urban MO, Gebhart GF Central mechanisms in pain Med Clin North Am 1999 83(3):585 596 10386116
Van de Kelft, De La Porte Long-term pain relief during spinal cord stimulation. The effect of patient selection Qual Life Res 1994 3(1):21 27 8142944
Van de Kelft E, De La Porte C Spinal cord stimulation for chronic, intractable pain: experience over two decades Neurosurgery 1993 33(5):
van den Pol AN Hypothalamic hypocretin (orexin): robust innervation of the spinal cord J Neurosci 1999 19(8):3171 3182 10191330
Vanchieri C Cancer researcher's odyssey benefits many patients J Natl Cancer Inst 1998 90(3):184 186 9462671
Vaquero J, Martinez R, Oya S, Coca S, Salazar FG, Colado MI Transplantation of adrenal medulla into spinal cord for pain relief: disappointing outcome Lancet 1988 2(8623):
Vernon JD, Silver JR, Ohry A Post-traumatic syringomyelia Paraplegia 1982 20(6):339 364 7162844
Vilim FS, Aarnisalo AA, Nieminen ML, Lintunen M, Karlstedt K, Kontinen VK, Kalso E, States B, Panula P, Ziff E Gene for pain modulatory neuropeptide NPFF: induction in spinal cord by noxious stimuli Mol Pharmacol 1999 55(5):804 811 10220558
Villanueva L, Le BD The activation of bulbo-spinal controls by peripheral nociceptive inputs: diffuse noxious inhibitory controls Biol Res 1995 28(1):113 125 8728826
Villavicencio H Quality of life of patients with advanced and metastatic prostatic carcinoma Eur Urol 1993 24(Suppl 2):118 121 8262116
Villoria CM, Hernandez AJ, Fernandez VD Percutaneous epidural stimulation of the spinal cord in the treatment of chronic pain Res Esp Anestesiol Reanim 1985 32(3):119 121
Virozub ID, Bublik LA, Chernovskii VI Treatment of pain in vertebral-spinal cord injury by functional operations on the spinal cord Zh Vopr Neirokhir Im N N Burdenko 1990(1):11 13
Vlaeyen JW, Geurts SM, Kole-Snijders AM, Schuerman JA, Groenman NH, van EH What do chronic pain patients think of their pain? Towards a pain cognition questionnaire Br J Clin Psychol 1990 29(Pt 4):383 394 2149663
Vlahovitch B, Fuentes JM, Choucair Y, Orst G, Asencio JG, Maille B, Verger AC Prognostic elements at early stages of severe spinal cord injuries (value of pain sensitivity) Neurochirurgie 1975 21(6):447 468 1228484
Vogel HP, Heppner B, Humbs N, Schramm J, Wagner C Long-term effects of spinal cord stimulation in chronic pain syndromes J Neurol 1986 233(1):16 18 3485183
Vrabl M Osteochondroma of the cervical spine in combination with chronic posttraumatic bisegmental instability Acta Chirurgica Austriaca 1997 29(3):157 160
Wainapel SF, Freed MM Reflex sympathetic dystrophy in quadriplegia: Case report Arch Phys Med Rehabil 1984 65(1):35 36 6691796
Wainapel SF Reflex sympathetic dystrophy following traumatic myelopathy Pain 1984 18(4):345 349 6728500
Waisbrod H, Hansen D, Gerbershagen HU Chronic pain in paraplegics Neurosurgery 1984 15(6):933 934 6514167
Waldman SD, Donohoe CD, Waldman KA The pharmacologic management of neuropathic pain Progress. in Anesthesiology 1998 12(4):55 64
Walker K, Perkins M, Dray A Kinins and kinin receptors in the nervous system Neurochem Int 1995 26(1):1 16 7787759
Wang D, Bodley R, Sett P, Gardner B, Frankel H A clinical magnetic resonance imaging study of the traumatised spinal cord more than 20 years following injury Paraplegia 1996 34(2):65 81 8835030
Wang D, Jiang H, Wang C Complications of osteotomy of vertebral arch and body in kyphosis Chung-Hua Wai Ko Tsa Chih [Chinese Journal of Surgery] 1997 35(12):722 724
Wantanabe S, Bruera E Corticosteroids as adjuvant analgesics J Pain Symptom Manage 1994(7):442 445
Wasner G, Baron R Central pain -- Clinical characteristics, pathophysiological concepts and therapy Aktuelle Neurologie 1998 25(7):269 276
Waters RL, Adkins RH, Sie I, et al Postrehabilitation outcomes after spinal cord injury caused by firearms and motor vehicle crash among ethnically diverse groups Arch Phys Med Rehabil 1998 79(10):1237 1243 9779677
Watkins ES, Koeze TH Spinal cord stimulation and pain relief BMJ 1993 307(6902):
Watkins LR, Maier SF Implications of immune-to-brain communication for sickness and pain Proc Natl Acad Sci USA 1999 96(14):7710 7713 33606 10393885
Watson C, Watt-Watson J Treatment of neuropathic pain: Focus on antidepressants, opioids and gabnapentin Pain Res Manage 1999 4(4):168 178
Webb SBJ, Berzins E, Wingardner TS, Lorenzi ME Spinal cord injury: epidemiologic implications, costs and patterns of care in 85 patients Arch Phys Med Rehabil 1979 60(8):335 340 157113
Wegener ST, Elliott TR Pain assessment in spinal cord injury Clin J Pain 1992 8(2):93 101 1633388
Westgren N, Levi R Quality of life and traumatic spinal cord injury Arch Phys Med Rehabil 1998 79(11):1433 1439 9821906
Whiteneck GG, Charlifue SW, Frankel HL, Fraser MH, Gardner BP, Gerhart KA, Krishnan KR, Menter RR, Nuseibeh I, Short DJ Mortality, morbidity, and psychosocial outcomes of persons spinal cord injured more than 20 years ago Paraplegia 1992 30(9):617 630 1408338
Widerstrom-Noga EG, Felipe-Cuervo E, Broton JG, et al Perceived difficulty in dealing with consequences of spinal cord injury Arch Phys Med Rehabil 1999 80(5):580 586 10326925
Wiegand H, Winkelmuller W Treatment of deafferentation pain by high-frequency intervention on the dorsal root entry zone Dtsch Med Wochensch 1985 110(6):216 220
Willen JA, Gaekwad UH, Kakulas BA Burst fractures in the thoracic and lumbar spine. A clinico-neuropathologic analysis Spine 1989 14(12):1316 1323 2617361
Willer J-C, De BT, Bussel B, Roby-Brami A, Harrewyn J-M Central analgesic effect of ketoprofen in humans: electrophysiological evidence for a supraspinal mechanism in a double-blind and cross-over study Pain 1989 38(1):1 7 2780057
Willer JC, Bolgert F, Le BD. Ascending and descending pathways involved in diffuse noxious inhibitory controls (DNIC) in man. J Physiol. 1991;435.
Wing PC, Tsang IK, Susak L, Gagnon F, Gagnon R, Potts JE Back pain and spinal changes in microgravity Orthop Clin North Am 1991 22(2):255 262 1826549
Wong JY, Rapson LM Acupuncture in the management of pain of musculoskeletal and neurologic origin Phys Med Rehabil Clin N Am 1999 10(3):531 545 10516974
Woodward KG, Vulpe M The proximal tap or "central Tinel" sign in central dysesthetic syndrome after spinal cord injury J Am Paraplegia Soc 1991 14(3):136 138 1885951
Woolf CJ, Shortland P, Coggeshall RE Peripheral nerve injury triggers central sprouting of myelinated afferents Nature 1992 355(6355):75 78 1370574
Woolf CJ Multiple mechanisms for mechanical allodynia: from increased gain to novel synapse formation APS Journal 1993 2(1):42 45
Woolf CJ, Mannion RJ Neuropathic pain: aetiology, symptoms, mechanisms, and management Lancet 1999 353(9168):1959 1964 10371588
Woolsey RM Chronic pain following spinal cord injury J Am Paraplegia Soc 1986 9(3-4):39 41 3783152
Worz R Phantom-pain -- Still a topic Fortschr Med 1990 108(4):39 46
Wright, L. R. and Sweet, W. H. Intractable pain in traumatic paraplegia. 17th Spinal Cord Injury Conference Sept. 29-30. 1969:76-89. [pmcid: 377891].
Xu XJ, Hao JX, Kupers R, et al Mechanisms of central pain Acta Anaesthesiol Scand 1997Supplementum. 110:127 128
Yaksh TL. Frederick W. L. Kerr comments on his life with notes on his contributions to the understanding of facial neuralgias Appl. Neurophysiol 1988 51(2-5):65 75
Yaksh TL The spinal pharmacology of facilitation of afferent processing evoked by high-threshold afferent input of the postinjury pain state Curr Opin Neurol Neurosurg 1993 6(2):250 256 8097639
Yaksh TL New horizons in our understanding of the spinal physiology and pharmacology of pain processing Semin Oncol 1994 20(2 Suppl.):6 18 8475414
Yaksh TL Physiology and pharmacology of the postinjury pain state Seminars in Anesthesia 1997 16(2):79 91
Yaksh TL, Hua XY, Kalcheva I, Nozaki-Taguchi N, Marsala M The spinal biology in humans and animals of pain states generated by persistent small afferent input Proc Natl Acad Sci USA 1999 96(14):7680 7686 33601 10393880
Yaksh TL Spinal systems and pain processing: Development of novel analgesic drugs with mechanistically defined models Trends Pharmacol Sci 1999 20(8):329 337 10431212
Yamamoto M, Meyer JS, Sakai F, Jakoby R Effect of differential spinal cord transection on human cerebral blood flow J Neurol Sci 1980 47(3):395 406 6775053
Yanagida H, Fukuda Y, Suwa K, Trouwborst A Alcohol-induced pituitary neuroadenolysis in anaesthesia dolorosa Pain Clinic 1988(4):229 230
Yezierski RP Pain following spinal cord injury: the clinical problem and experimental studies Pain 1996 68(2-3):185 194 9121805
Young PA The anatomy of the spinal cord pain paths: a review J Am Paraplegia Soc 1986 9(3-4):28 38 3537211
Young RF Evaluation of dorsal column stimulation in the treatment of chronic pain Neurosurgery 1978 3(3):373 379 84362
Young RF Clinical experience with radiofrequency and laser DREZ lesions J Neurosurg 1990 72(5):715 720 1691282
Young RF, Tronnier V, Rinaldi PC Chronic stimulation of the Kolliker-Fuse nucleus region for relief of intractable pain in humans J Neurosurg 1992 76(6):979 985 1588433
Young RF, Jacques DS, Rand RW, Copcutt BR. Medial thalamotomy with the Leksell Gamma Knife for treatment of chronic pain. Acta Neurochir Suppl. 1994;62:105-110. [pmid: 7717125].
Young RF, Rinaldi PC. Wall P, Melzack R, editors. Textbook of Pain. 3rd ed. Edinburgh: Churchill Livingstone. 66, Brain stimulation for relief of chronic pain. 1994:p. 1225-1233.
Zachariah SB, Borges EF, Varghese R, et al Positive response to oral divalproex sodium (depakote) in patients with spasticity and pain Am J Med Sci 1994 308(1):38 40 8010336