# References

Adams JE, Hosobuchi Y, Fields HL Stimulation of internal capsule for relief of chronic pain J Neurosurg 1974 41(6):740 4 4609304
Aisen ML, Stallman J, Aisen PS The sympathetic skin response in the shoulder-hand syndrome complicating tetraplegia Paraplegia 1995 33(10):602 5 8848315
Anke AG, Stenehjem AE, Stanghelle JK Pain and life quality within 2 years of spinal cord injury Paraplegia 1995 33(10):555 9 8848308
Attal N, Gaudé V, Brasseur L, Bupuy M, Guirimand F, Parker F, Bouhassira D Intravenous lidocaine in central pain: a double-blind, placebo-controlled, psychophysical study Neurology 2000 54(3):564 74 10680784
Backonja MM, Galer BS Pain Assessment and Evaluation of Patients Who Have Neuropathic Pain Neurol Clin 1998 16(4):775 90 9767062
Bedbrook G. Bedbrook G, editors. The Care and Management of Spinal Cord Injuries. New York: Verlag. Pain and phantom sensation. 1981:p. 224-9.
Bennett GJ An animal model of neuropathic pain: a review Muscle Nerve 1993 16(10):1040 8 8413357
Beric A. Dimitrijevic MR, Wall PD, Lindblom U, editors. Altered Sensation and Pain. Basel, Switzerland: Karger. 4, Altered sensation and pain in spinal cord injury. 1990:p. 27-36.
Beric A, Dimitrijevic MR, Light JK Pain in spinal cord injury with occult caudal lesions European Journal of Pain 1992 13(1):1 7
Beric A, Dimitrijevic MR, Lindblom U Central dysesthesia syndrome in spinal cord injury patients Pain 1988 34(2):109 16 3174149
Bohlman HH, Kirkpatrick JS, Delamarter RB, Leventhal M. Anterior decompression for late pain and paralysis after fractures of the thoracolumbar spine. Clin Orthop. 1994;300:24-9. [pmid: 8131342].
Botterell EH, Callaghan JC, Jousse AT. Pain in paraplegia: clinical management and surgical treatment. Proc R Soc Med. 1953;47:281-8.
Boulton M, Fitzpatrick R, Swinburn C Qualitative research in health care: II. A structured review and evaluation of studies J Eval Clin Pract 1996 2(3):171 9 9238586
Bowsher D Central pain: clinical and physiological characteristics J Neurol Neurosurg Psychiatry 1996 61(1):62 9 8676164
Bravo P, Labarta B, Garcia C Pain in people suffering marrow injuries and its treatment Rehabilitacion 1988 22(2):181 9
Britell CW, Mariano AJ. Chronic pain in spinal cord injury. Physical Medicine and Rehabilitation: State of the Art Reviews. 1991;5:71-82.
Broggi G, Servello D, Dones I, Carbone G Italian multicentric study on pain treatment with epidural spinal cord stimulation Stereotact Funct Neurosurg 1994 62(1-4):273 8 7631081
Buchhaas U, Koulousakis A, Nittner K Experience with spinal cord stimulation (SCS) in the management of chronic pain in a traumatic transverse lesion syndrome Neurosurg Rev 1989 12(Suppl 1):582 7 2812434
Burke DC Pain in paraplegia Paraplegia 1973 10(4):297 313 4697003
Burke DC. Vinken P, Bruyn G, editors. Handbook of Clinical Neurology. New York: Elsevier. Pain and phantom sensation in spinal paralysis. 1976:p. 489-99.
Cairns DM, Adkins RH, Scott MD Pain and depression in acute traumatic spinal cord injury: origins of chronic problematic pain? Arch Phys Med Rehabil 1996 77(4):329 35 8607754
Cheng PT, Hong CZ, Liaw MY Spontaneous electromyographic potentials in cervical cord-injured patients are related to dysesthetic pain Am J Phys Med Rehabil 1997 76(5):389 94 9354493
Chiou-Tan FY, Tuel SM, Johnson JC, Priebe MM, Hirsh DD, Strayer JR Effect of mexiletine on spinal cord injury dysesthetic pain Am J Phys Med Rehabil 1996 75(2):84 7 8630199
Cobeljic R, Kovacevic S, Vulovic D, Stojanovic A Types of chronic pain in patients with spinal cord injury Acta Orthop Iugosl 1998 29(1):73 7
Issue 4,1999 325679
http://www. jr2.ox.ac.uk:80/Cochrane/. Accessed on July 16, 2000.
Cohen MJ, McArthur DL, Vulpe M, Schandler SL, Gerber KE Comparing chronic pain from spinal cord injury to chronic pain of other origins Pain 1988 35(1):57 63 3200598
Cohen MJ, Song ZK, Schandler SL, Ho WH, Vulpe M Sensory detection and pain thresholds in spinal cord injury patients with and without dysesthetic pain, and in chronic low back pain patients Somatosens Mot Res 1996 13(1):29 37 8725646
Cole JD, Illis LS, Sedgwick EM Intractable central pain in spinal cord injury is not relieved by spinal cord stimulation Paraplegia 1991 29(3):167 72
Davidoff G, Guarracini M, Roth E, Sliwa J, Yarkony G Trazodone hydrochloride in the treatment of dysesthetic pain in traumatic myelopathy: a randomized, double-blind, placebo-controlled study Pain 1987 29(2):151 61 3302841
Davidoff G, Roth E, Guarracini M, Sliwa J, Yarkony G Function-limiting dysesthetic pain syndrome among traumatic spinal cord injury patients: a cross-sectional study Pain 1987 29(1):39 48 3588000
Davis L, Martin J. Studies upon spinal cord injuries II The nature and treatment of pain. J Neurosurg. 1947;4:483-91. [pmid: 20267936].
Davis R Pain and suffering following spinal cord injury Clin Orthop 1975(112):76 80
Davis R, Lentini R Transcutaneous nerve stimulation for treatment of pain in spinal-cord-injured patients Bull Prosthet Res 1974(Fall):298 301
Defrin R, Ohry A, Blumen N, Urca G Acute pain threshold in subjects with chronic pain following spinal cord injury Pain 1999 83(2):275 82 10534599
Demirel G, Yllmaz H, Gencosmanoglu B, Kesiktas N Pain following spinal cord injury Spinal Cord 1998 36(1):25 8 9471134
Devulder J, Vermeulen H, De Colvenaer L, Rolly G, Calliauw L, Caemaert J Spinal cord stimulation in chronic pain: evaluation of results, complications, and technical considerations in sixty-nine patients Clin J Pain 1991 7(1):21 8 1809411
Doctor JN An evaluation of transcutaneous electrical nerve stimulation Dissertation Abstracts International: Section B: The Sciences and Engineering 1996(4-B):
Donovan WH, Dimitrijevic MR, Dahm L, Dimitrijevic M Neurophysiological approaches to chronic pain following spinal cord injury Paraplegia 1982 20(3):135 46 6982450
Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomized and non-randomized studies of health care interventions. J Epidemiol Community Health. 1998;52:377-84. [pmid: 9764259].
Dressler D, Thompson PD, Gledhill RF, Marsden CD The syndrome of painful legs and moving toes Mov Disord 1994 9(1):13 21 7511213
Drewes AM, Andreasen A, Poulsen LH Valproate for treatment of chronic central pain after spinal cord injury. A double-blind cross-over study Paraplegia 1994 32(8):565 9 7970862
Durward QJ, Rice GP, Ball MJ, Gilbert JJ, Kaufmann JC Selective spinal cordectomy: clinicopathological correlation J Neurosurg 1982 56(3):359 67 6948922
Edgar RE, Best LG, Quail PA, Obert AD Computer-assisted DREZ microcoagulation: posttraumatic spinal deafferentation pain J Spinal Disord 1993 6(1):48 56 8439716
Eide PK, Jorum E, Stenehjem AE Somatosensory findings in patients with spinal cord injury and central dysaesthesia pain J Neurol Neurosurg Psychiatry 1996 60(4):411 5 8774406
Eide PK, Stubhaug A, Stenehjem AE Central dysesthesia pain after traumatic spinal cord injury is dependent on N-methyl-D-aspartate receptor activation Neurosurgery 1995 37(6):1080 7 8584148
Epstein B, Childers MK The use of gabapentin for neuropathic and musculoskeletal pain: A case series J Neurol Rehabil 1998 12(2):81 6
Erzurumlu A, Dursun H, Gunduz S, Kalyon TA, Apracioglu O The management of chronic pain at spinal cord injured patients. The comparison of effectiveness amitryptiline and carbamazepine combination and electroacupuncture application Journal of Rheumatology & Medical Rehabilitation 1996 7(3):176 80
Falci SP, Lammertse DP, Best L, Starnes CA, Prenger EC, Stavros AT, Mellick D Surgical treatment of posttraumatic cystic and tethered spinal cords J Spinal Cord Med 1999 22(3):173 81 10685382
Fenollosa P, Pallares J, Cervera J, Pelegrin F, Inigo V, Giner M, Forner V Chronic pain in the spinal cord injured: statistical approach and pharmacological treatment Paraplegia 1993 31(11):722 9 7507585
Fields H, Wall P, Melzack R, editors. Textbook of Pain. New York: Churchill-Livingstone. Peripheral neuropathic pain: an approach to management. 1994:p. 991-6.
Fields H, Rowbotham M. Gebhart G, Hammond D, Jensen T, editors. Proceedings of the 7th World Congress on Pain: Progress in Pain Research and Management. 2nd ed. Multiple mechanisms of neuropathic pain: a clinical perspective. 1994:p. 437-54.
Friedman AH, Nashold Jr. BS DREZ lesions for relief of pain related to spinal cord injury J Neurosurg 1986 65(4):465 9 3760955
Frisbie JH, Aguilera EJ Chronic pain after spinal cord injury: an expedient diagnostic approach Paraplegia 1990 28(7):460 5 2250989
Gadsby JG, Flowerdew, MW. Transcutaneous electrical nerve stimulation and acupuncture-like transcutaneous electrical nerve stimulation for chronic low back pain. Cochrane Database Syst Rev. 2000;2.
Gallien P, Nicolas B, Robineau S, Lebot MP, Brissot R The reflex sympathetic dystrophy syndrome in patients who have had a spinal cord injury Paraplegia 1995 33(12):715 20 8927411
Gellman H, Eckert RR, Botte MJ, Sakimura I, Waters RL Reflex sympathetic dystrophy in cervical spinal cord injury patients Clin Orthop 1988(233):126 31
Gibson JC, White LE, Jr. Denervation hyperpathia: a convulsive syndrome of the spinal cord responsive to carbamazepine therapy. J Neurosurg. 1971;35:287-90.
Glynn CJ, Jamous MA, Teddy PJ Cerebrospinal fluid kinetics of epidural clonidine in man Pain 1992 49(3):361 7 1408302
Glynn CJ, Jamous MA, Teddy PJ, Moore RA, Lloyd JW Role of spinal noradrenergic system in transmission of pain in patients with spinal cord injury Lancet 1986 2(8518):1249 50 2878134
Gronning M, Ertzgaard P, Myrseth E Central nervous pain in patients with spinal cord injury. Medical and surgical treatment Tidsskr Nor Laegeforen 1997 117(13):1904 7 9214011
Grzesiak RC Relaxation techniques in treatment of chronic pain Arch Phys Med Rehabil 1977 58(6):270 2 67831
Hansebout RR, Blight AR, Fawcett S, Reddy K 4-Aminopyridine in chronic spinal cord injury: a controlled, double-blind, crossover study in eight patients J Neurotrauma 1993 10(1):1 18 8320728
Heilporn A Two therapeutic experiments on stubborn pain in spinal cord lesions: coupling melitracen-flupenthixol and the transcutaneous nerve stimulation Paraplegia 1978 15(4):368 72 305021
Henderson M, Mowry RL A pilot study of the impact of laughter on the experience of chronic pain by people with spinal cord injuries SCI Psychosocial Process 1995 6(4):154 6
Herman RM, D'Luzansky SC, Ippolito R Intrathecal baclofen suppresses central pain in patients with spinal lesions. A pilot study Clin J Pain 1992 8(4):338 45 1493344
Hosobuchi Y, Adams JE, Rutkin B Chronic thalamic and internal capsule stimulation for the control of central pain Surg Neurol 1975 4(1):91 2 1080907
Hyndman OR. Lissauer's tract section. A contribution to chordotomy for the relief of pain (preliminary report). J Int Coll Surg. 1942;5:294-400.
http://www.halcyon.com/iasp/sigs.html#SYSTEMATIC REVIEWS IN PAIN RELIEF (In Formation). Accessed on July 16, 2000.
Ioannidis JP, Cappelleri JC, Lau J Issues in comparisons between meta-analyses and large trials JAMA 1998 279(14):1089 93 9546568
Jadad AR, Carroll D, Glynn CJ, McQuay HJ Intravenous regional sympathetic blockade for pain relief in reflex sympathetic dystrophy: a systematic review and a randomized, double-blind crossover study J Pain Symptom Manage 1995 10(1):13 20 7536227
Jadad AR, Carroll D, Moore A, McQuay H Developing a database of published reports of randomised clinical trials in pain research Pain 1996 66(2-3):239 46 8880846
Jadad AR, Cook DJ, Jones A, Klassen TP, Tugwell P, Moher M, Moher D Methodology and reports of systematic reviews and meta-analyses: a comparison of Cochrane reviews with articles published in paper-based journals JAMA 1998 280(3):278 80 9676681
Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, McQuay HJ Assessing the quality of reports of randomized clinical trials: is blinding necessary? Control Clin Trials 1996 17(1):1 12 8721797
Jadad A. Neuropathic pain. Refresher Course Syllabus. Seattle: IASP Publications. 1993.
Jadad A. Bruera EPR, editors. Topics in Palliative Care. New York: Oxford University Press. Opioids in the treatment of neuropathic pain: a systematic review of controlled clinical trials. 1998:p. 31-40.
Jaeschke R, Guyatt G, and Sackett DL Users' guides to the medical literature. III. How to use an article about a diagnostic test. A. Are the results of the study valid? Evidence-Based Medicine Working Group JAMA 1994 271(5):389 91 Department of Medicine, McMaster University, Hamilton, Ontario, Canada. Journal Article; 2 8283589
Jefferson A. Lipton S, Miles J, editors. Persistent pain, modern methods of treatment. London: Grune & Stratton. 7, Cordectomy for intractable pain in paraplegia. 1983:p. 115-32.
Jung BF Effect of coping skills and time on pain in spinal cord injury Dissertation Abstracts International 1990(3-B):
Kalso E, Tramer MR, McQuay HJ, Moore RA. Systemic local-anaesthetic-type drugs in chronic pain: a systematic review. European Journal of Pain. 1998;2:3-14. [pmid: 10700296].
Kaplan LI, Grynbaum BB, Lloyd KE, Rusk HA. Pain and spasticity in patients with spinal cord dysfunction. JAMA. 1962;182:918-25.
Kennedy P, Frankel H, Gardner B, Nuseibeh I Factors associated with acute and chronic pain following traumatic spinal cord injuries Spinal Cord 1997 35(12):814 7 9429260
Kennedy R. A new viewpoint toward spinal cord injuries. Ann Surg. 1946;124:1057-65.
Kerr, FWL. 1966. Lecture given to the American College of Surgeons. [pmcid: 292881].
Kumar K, Nath R, Wyant GM Treatment of chronic pain by epidural spinal cord stimulation: a 10-year experience J Neurosurg 1991 75(3):402 7 1869942
Kumar K, Toth C, Nath RK Deep brain stimulation for intractable pain: a 15-year experience Neurosurgery 1997 40(4):736 46 9092847
Laupacis A, Wells G, Richardson WS, Tugwell P Users' guides to the medical literature. V. How to use an article about prognosis. Evidence-Based Medicine Working Group JAMA 1994 272(3):234 7 8022043
Lazorthes Y, Verdie JC, Arbus L Anterior and posterior medullary analgesic stimulation, using a percutaneous implantation technic Acta Neurochir 1978 40(3-4):277 83
Lenz FA, Kwan HC, Dostrovsky JO, Tasker RR Characteristics of the bursting pattern of action potentials that occurs in the thalamus of patients with central pain Brain Res 1989 496(1-2):357 60 2804648
Levi R, Hultling C, Nash MS, Seiger A The Stockholm spinal cord injury study: 1. Medical problems in a regional SCI population Paraplegia 1995 33(6):308 15 7644255
Levi R, Hultling C, Seiger A The Stockholm Spinal Cord Injury Study: 2. Associations between clinical patient characteristics and post-acute medical problems Paraplegia 1995 33(10):585 94 8848313
Levy RM, Lamb S, Adams JE Treatment of chronic pain by deep brain stimulation: long term follow-up and review of the literature Neurosurgery 1987 21(6):885 93 3325851
Levy WJ, Nutkiewicz A, Ditmore M, et al Laser-induced dorsal root entry zone lesions for pain control. Report of three cases J Neurosurg 1983 59(5):884 6 6194280
Livshits AV, Sokolova AA, Demina NA Characteristics of the late components in somatosensory evoked potentials of patients with a pain syndrome in spinal cord involvement Zhurnal Nevropatologii i Psikhiatrii Imeni S - S - Korsakova 1988 88(5):30 4
Livshits LI, Kereselidze SG Surgery of the pain-conducting tract of the spinal cord in the combined treatment of pain syndromes of the trunk and limbs Zhurnal Voprosy Neirokhirurgii Imeni N - N - Burdenko 1990(1):24 6
Loeser JD, Ward AAJ, White LE, Jr Chronic deafferentation of human spinal cord neurons J Neurosurg 1968 29(1):48 50 5244625
Long DM. Bonica JJ, Albe-Fessard D, editors. Advances in pain research and therapy. New York: Raven Press. 1, Use of peripheral and spinal cord stimulation in the relief of chronic pain. 1976:p. 395-403.
Long DM, Erickson DE Stimulation of the posterior columns of the spinal cord for relief of intractable pain Surg Neurol 1975 4(1):134 41 126498
Loubser PG Adverse effects of epidural spinal cord stimulation on bladder function in a patient with chronic spinal cord injury pain [letter] J Pain Symptom Manage 1997 13(5):251 2 9185428
Loubser PG, Akman NM Effects of intrathecal baclofen on chronic spinal cord injury pain J Pain Symptom Manage 1996 12(4):241 7 8898508
Loubser PG, Clearman RR Evaluation of central spinal cord injury pain with diagnostic spinal anesthesia Anesthesiology 1993 79(2):376 8 8342845
Loubser PG, Donovan WH Diagnostic spinal anaesthesia in chronic spinal cord injury pain Paraplegia 1991 29(1):25 36 1708859
Max MB Towards physiologically based treatment of patients with neuropathic pain Pain 1990 42(2):131 7 1701044
McQuay H, Carroll D, Jadad AR, Wiffen P, Moore A Anticonvulsant drugs for management of pain: a systematic review BMJ 1995 311(7012):1047 52 7580659
McQuay HJ, Tramer M, Nye BA, Carroll D, Wiffen PJ, Moore RA A systematic review of antidepressants in neuropathic pain Pain 1996 68(2-3):217 27 9121808
McQuay H; Moore R. An evidence-based resource for pain relief. Oxford: Oxford University Press; 1998.
Meglio M, Cioni B, Prezioso A, Talamonti G Spinal cord stimulation (SCS) in deafferentation pain Pacing Clin Electrophysiol 1989 12(2):709 12 2470055
Meglio M, Cioni B, Rossi GF Spinal cord stimulation in management of chronic pain. A 9-year experience J Neurosurg 1989 70(4):519 24 2538588
Melzack R, Loeser JD Phantom body pain in paraplegics: evidence for a central "pattern generating mechanism" for pain Pain 1978 4(3):195 210 273200
Mercadante S Gabapentin in spinal cord injury pain Pain Clinic 1998 10(3):203 6
Merskey H and Bogduk N, editors. Classification of Chronic Pain. 2nd ed. Seattle: IASP Press. 1994. [pmcid: 43273].
Michaelis LS The problem of pain in paraplegia and tetraplegia Bull N Y Acad Med 1970 46(2):88 96 5262937
Moossy JJ, Nashold Jr. BS, Osborne D, Friedman AH Conus medullaris nerve root avulsions J Neurosurg 1987 66(6):835 41 3572514
Moraci A, Ambrosio D, Mignini R Spinal cord stimulation in the treatment of post-traumatic intractable pain Rass Int Clin Ter 1982 62(10):649 53
Morley S, Eccleston C, Williams A Systematic review and meta-analysis of randomized controlled trials of cognitive behaviour therapy and behaviour therapy for chronic pain in adults, excluding headache Pain 1999 80(1-2):1 13 10204712
Nagaro T, Shimizu C, Inoue H, Fujitani T, Adachi N, Amakawa K, Kimura S, Arai T, Watanabe T, Oka S The efficacy of intravenous lidocaine on various types of neuropathic pain Masui 1995 44(6):862 7 7637167
Nagaro T, Takaishi K, Kimura S, Arai T Inhibition of pain following spinal cord injury by the stimulation of the region just above deafferentation Pain Clinic 1995 9(2):201 4
Nashold Jr. BS, Bullitt E Dorsal root entry zone lesions to control central pain in paraplegics J Neurosurg 1981 55(3):414 9 6167696
Nashold Jr. BS, Ostdahl RH Dorsal root entry zone lesions for pain relief J Neurosurg 1979 51(1):59 69 448420
Nashold Jr. BS, Vieira J, el-Naggar AO Pain and spinal cysts in paraplegia: treatment by drainage and DREZ operation Br J Neurosurg 1990 4(4):327 35 2222879
Nashold BS. Nashold B, Ovelmen-Levitt J, editors. Deafferentation Pain Syndrome: Pathophysiology and Treatment. New York: Raven Press. Paraplegia and pain. 1991:p. 301-19.
Nepomuceno C, Fine PR, Richards JS, Gowens H, Stover SL, Rantanuabol U, Houston R Pain in patients with spinal cord injury Arch Phys Med Rehabil 1979 60(12):605 9 518270
Ness TJ, San Pedro E, Richards JS, Kezar L, Liu HG, Mountz JM A case of spinal cord injury-related pain with baseline rCBF brain SPECT imaging and beneficial response to gabapentin Pain 1998 78(2):139 43 9839825
New PW, Lim TC, Hill ST, Brown DJ A survey of pain during rehabilitation after acute spinal cord injury Spinal Cord 1997 35(10):658 63 9347594
Nguyen JP, Keravel Y, Feve A, Uchiyama T, Cesaro P, Le Guerinel C, Pollin B. Treatment of deafferentation pain by chronic stimulation of the motor cortex: report of a series of 20 cases. Acta Neurochir Suppl. 1997;68:54-60. [pmid: 9233414].
Nguyen JP, Lefaucheur JP, Decq P, Uchiyama T, Carpentier A, Fontaine, Brugieres P, Pollin B, Feve A, Rostaing S Chronic motor cortex stimulation in the treatment of central and neuropathic pain. Correlations between clinical, electrophysiological and anatomical data Pain 1999 82(3):245 51 10488675
Nielson KD, Adams JE, Hosobuchi Y Experience with dorsal column stimulation for relief of chronic intractable pain: 1968-1973 Surg Neurol 1975 4(1):148 52 1080899
North RB, Ewend MG, Lawton MT, Piantadosi S Spinal cord stimulation for chronic, intractable pain: superiority of "multi-channel" devices Pain 1991 44(2):119 30 2052378
Ozerbil OM, Duman A, Yosunkaya A, Bayram A, Ustun ME Epidural administration of midasolam for chronic central pain and spasticity in spinal cord injured patients Journal of Rheumatology & Medical Rehabilitation 1997 8(4):328 30
Pagni CA, Canavero S Cordomyelotomy in the treatment of paraplegia pain. Experience in two cases with long-term results Acta Neurol Belg 1995 95(1):33 6 7725895
Pollock LJ. Pain below the level of injury of the spinal cord. Archives of Neurological Psychiatry. 1951;65:319-22.
Portenoy R. Bruera E, Portenoy R, editors. Topics in Palliative Care. New York: Oxford University Press. Introduction: Neuropathic pain: from unresolved questions to clinical practice. 1998:p. 3-5.
Potter PJ, Hayes KC, Hsieh JC, Delaney GA, Segal JL Sustained improvements in neurological function in spinal cord injured patients treated with oral 4-aminopyridine: Three cases Spinal Cord 1998 36(3):147 55 9554012
Powers SK, Barbaro NM, Levy RM Pain control with laser-produced dorsal root entry zone lesions Appl Neurophysiol 1988 51(2-5):243 54 3389802
Quigley P, Veit N Interdisciplinary pain assessment of spinal cord injury patients SCI Nurs 1996 13(3):62 8 8900667
Rath SA, Braun V, Soliman N, Antoniadis G, Richter HP Results of DREZ coagulations for pain related to plexus lesions, spinal cord injuries and postherpetic neuralgia Acta Neurochir 1996 138(4):364 9
Rath SA, Seitz K, Soliman N, Kahamba JF, Antoniadis G, Richter HP DREZ coagulations for deafferentation pain related to spinal and peripheral nerve lesions: indication and results of 79 consecutive procedures Stereotact Funct Neurosurg 1997 68(1-4 Pt 1):161 7 9711710
Ravenscroft A, Ahmed YS, Burnside IG Chronic pain after spinal cord injury: a survey of practice in UK spinal injury units Spinal Cord 1999 37(1):25 8 10025691
Rawlings CE, el-Naggar AO, Nashold Jr. BS The DREZ procedure: an update on technique Br J Neurosurg 1989 3(6):633 42 2697214
Richards JS, Stover SL, Jaworski T Effect of bullet removal on subsequent pain in persons with spinal cord injury secondary to gunshot wound J Neurosurg 1990 73(3):401 4 2384778
Richardson RR Posterior spinal cord stimulation for treatment of sequela spinal injury Journal of Orthopaedic Surgical Techniques 1987 3(3-4):165 73
Richardson RR, Meyer PR, Cerullo LJ Neurostimulation in the modulation of intractable paraplegic and traumatic neuroma pains Pain 1980 8(1):75 84 6966047
Richter HP, Seitz K Dorsal root entry zone lesions for the control of deafferentation pain: experiences in ten patients Neurosurgery 1984 15(6):956 9 6514172
Riddoch G. The clinical features of central pain. Lancet. 1938;234:1093-209.
Rintala DH, Loubser PG, Castro J, Hart KA, Fuhrer MJ Chronic pain in a community-based sample of men with spinal cord injury: prevalence, severity, and relationship with impairment, disability, handicap, and subjective well-being Arch Phys Med Rehabil 1998 79(6):604 14 9630137
Roelcke U, Curt A, Otte A, Missimer J, Maguire RP, Dietz V, Leenders KL Influence of spinal cord injury on cerebral sensorimotor systems: a PET study J Neurol Neurosurg Psychiatry 1997 62(1):61 5 9010401
Rose M, Robinson JE, Ells P, Cole JD Pain following spinal cord injury: results from a postal survey Pain 1988 34(1):101 2 3405616
Roth EJ. Yarkony G, editors. Spinal Cord Injury: Medical and Rehabilitation Management. Gaithersburg, MD. Pain in spinal cord injury. 1994:p. 141-58.
Samii M, Moringlane JR Thermocoagulation of the dorsal root entry zone for the treatment of intractable pain Neurosurgery 1984 15(6):953 5 6514171
Sampson JH, Cashman RE, Nashold Jr. BS, Friedman AH Dorsal root entry zone lesions for intractable pain after trauma to the conus medullaris and cauda equina J Neurosurg 1995 82(1):28 34 7815130
Sandford PR, Lindblom LB, Haddox JD Amitriptyline and carbamazepine in the treatment of dysesthetic pain in spinal cord injury Arch Phys Med Rehabil 1992 73(3):300 1 1543437
Schaller B, Mindermann T, Gratzl O Treatment of syringomyelia after posttraumatic paraparesis or tetraparesis J Spinal Disord 1999 12(6):485 8 10598990
Segatore M Understanding chronic pain after spinal cord injury J Neurosci Nurs 1994 26(4):230 6 7814915
Sherman RA, Barja RH, Bruno GM. Thermographic correlates of chronic pain: analysis of 125 patients incorporating evaluations by a blind panel. Arch Phys Med Rehabil. 1987;68:273-9. [pmid: 3579531].
Sherman RA, Ernst JL, Markowski J Relationships between near surface blood flow and altered sensations among spinal cord injured veterans Am J Phys Med 1986 65(6):281 97 3789129
Shimoji K, Hokari T, Kano T, Tomita M, Kimura R, Watanabe S, Endoh, Fukuda S, Fujiwara N, Aida S Management of intractable pain with percutaneous epidural spinal cord stimulation: differences in pain-relieving effects among diseases and sites of pain Anesth Analg 1993 77(1):110 6 8317715
Siddall PJ, Gray M, Rutkowski S, Cousins MJ Intrathecal morphine and clonidine in the management of spinal cord injury pain: a case report Pain 1994 59(1):147 8 7854795
Siddall PJ, Taylor DA, Cousins MJ Classification of pain following spinal cord injury Spinal Cord 1997 35(2):69 75 9044512
Siddall PJ, Taylor DA, McClelland JM, Rutkowski SB, Cousins MJ Pain report and the relationship of pain to physical factors in the first 6 months following spinal cord injury Pain 1999 81(1-2):187 97 10353507
Simpson BA Spinal cord stimulation in 60 cases of intractable pain J Neurol Neurosurg Psychiatry 1991 54(3):196 9 1827648
Song ZK, Cohen MJ, Ament PA, Ho WH, Vulpe M, Schandler SL Two-point discrimination thresholds in spinal cord injured patients with dysesthetic pain Paraplegia 1993 31(8):485 93
Spaic M, Petkovic S, Tadic R, Minic L DREZ surgery on conus medullaris (after failed implantation of vascular omental graft) for treating chronic pain due to spine (gunshot) injuries Acta Neurochir. (Wien.) 1999 141(12):1309 12 300905 10672302
Stensman R Adjustment to traumatic spinal cord injury. A longitudinal study of self-reported quality of life Paraplegia 1994 32(6):416 22 8090550
Stormer S, Gerner HJ, Gruninger W, Metzmacher K, Follinger S, Wienke, Aldinger W, Walker N, Zimmermann M, Paeslack V Chronic pain/dysaesthesiae in spinal cord injury patients: results of a multicentre study Spinal Cord 1997 35(7):446 55 9232750
Stranjalis G, Torrens M Dorsal root entry zone lesion performed with Nd:YAG laser Br J Neurosurg 1997 11(3):238 40 9231013
Summers JD, Rapoff MA, Varghese G, Porter K, Palmer RE Psychosocial factors in chronic spinal cord injury pain Pain 1991 47(2):183 9 1762813
Sved P, Siddall PJ, McClelland J, Cousins MJ Relationship between surgery and pain following spinal cord injury Spinal Cord 1997 35(8):526 30 9267918
Svendsen L, Drewes AM, Biering-Sorensen F, et al Chronic pain after spinal cord injury: a descriptive study Ugeskr Laeger 1993 155(39):3118 22 8212402
Taira T, Kawamura H, Tanikawa T, Kawabatake H, Iseki H, Ueda A, Takakura K. A new approach to the control of central deafferentation pain: spinal intrathecal baclofen. Acta Neurochir Suppl. 1995;64:136-8. [pmid: 8748602].
Tharion G, Bhattacharji S Aspirin in chloroform as an effective adjuvant in the management of chronic neurogenic pain Arch Phys Med Rehabil 1997 78(4):437 9 9111466
Tsuda T, Tasker RR Percutaneous epidural electrical stimulation of the spinal cord for intractable pain -- with special reference to deafferentation pain No Shinkei Geka 1985 13(4):409 15 3875050
Tunks E. Bloch R, Basbaum M, editors. Management of Spinal Cord Injuries. Baltimore. Pain in spinal cord injured patients. 1986:p. 180-211.
Turner JA, Cardenas DD Chronic pain problems in individuals with spinal cord injuries Semin Clin Neuropsychiatry 1999 4(3):186 94 10498786
Urban BJ, Nashold Jr. BS Percutaneous epidural stimulation of the spinal cord for relief of pain. Long-term results J Neurosurg 1978 48(3):323 8 305469
Virozub ID, Bublik LA, Chernovskii VI Treatment of pain in vertebral-spinal cord injury by functional operations on the spinal cord Zh Vopr Neirokhir Im N N Burdenko 1990(1):11 3
Waisbrod H, Hansen D, Gerbershagen HU Chronic pain in paraplegics Neurosurgery 1984 15(6):933 4 6514167
Wang D, Bodley R, Sett P, Gardner B, Frankel H A clinical magnetic resonance imaging study of the traumatised spinal cord more than 20 years following injury Paraplegia 1996 34(2):65 81 8835030
Westgren N, Levi R Quality of life and traumatic spinal cord injury Arch Phys Med Rehabil 1998 79(11):1433 9 9821906
Wiegand H, Winkelmuller W Treatment of deafferentation pain by high-frequency intervention on the dorsal root entry zone Dtsch Med Wochensch 1985 110(6):216 20
Woodward KG, Vulpe M The proximal tap or "central Tinel" sign in central dysesthetic syndrome after spinal cord injury J Am Paraplegia Soc 1991 14(3):136 8 1885951
Woolsey RM Chronic pain following spinal cord injury J Am Paraplegia Soc 1986 9(3-4):39 41 3783152
Yaksh TL. Frederick W.L. Kerr comments on his life with notes on his contributions to the understanding of facial neuralgias Appl Neurophysiol 1988 51(2-5):65 75
Yezierski RP Pain following spinal cord injury: the clinical problem and experimental studies Pain 1996 68(2-3):185 94 9121805
Young RF Clinical experience with radiofrequency and laser DREZ lesions J Neurosurg 1990 72(5):715 20 1691282
Young RF, Rinaldi PC, Wall P, Melzack R, editors. Textbook of Pain. 3rd ed. Edinburgh: Churchill Livingstone. 66, Brain stimulation for relief of chronic pain. 1994:p. 1225-33.
Young RF, Tronnier V, Rinaldi PC Chronic stimulation of the Kolliker-Fuse nucleus region for relief of intractable pain in humans J Neurosurg 1992 76(6):979 85 1588433