# Conclusions and Implications for Future Research

Central neuropathic pain is a significant problem experienced by many people after a TSCI. Most estimates of the prevalence of chronic pain after TSCI range from 40 percent to 75 percent of patients. Pain is moderate to severe in 25 percent to 60 percent of these individuals, is often associated with psychological and psychiatric conditions, and is severe enough to impair or prevent optimal physical function and daily living. Given the extent and burden of the problem, it was disappointing to find relatively little research on important areas such as the assessment or treatment of CNP after TSCI. Perhaps the state of research is understandable given the complexity of the condition; the variety of plausible but poorly understood underlying mechanisms of CNP; and major difficulties (ethical, logistical, and methodological) in conducting research in this area resulting in tentative and incomplete data.

This Evidence Report has summarized the available research studies, thereby setting the stage for the development of a research agenda. This agenda needs to include methods to improve the quality of research designs; since nearly all of the research published to date is of poor methodological quality, with most intervention studies lacking a control group, blind assessment of the primary outcomes, and adequate followup of subjects. There are also problems related to generalizability that may reflect poor reporting or, more likely, indicate weak study execution. These problems include lack of explicit inclusion criteria; missing or incomplete demographic descriptions of the study sample; and missing or incomplete information related to the severity, location, quality, and nature of the pain.

Given the state of the body of existing evidence and the mandate of AHRQ, this final chapter focuses on the implications for further research to assist in the development of a research agenda rather than on general implications for clinical practice. Specific implications for clinical practice are found in each chapter. It is imperative to develop effective strategies to improve the number, validity, precision, and relevance of future studies.

## General Implications for Research

Future research efforts should consider:

- Multicenter collaboration to set a research agenda. The CSCM may be well positioned to facilitate this level of collaboration, or alternative strategies may be needed to foster pragmatic working relationships, even among groups that do not have a tradition of cooperation. Such collaborative groups could study the research problems and provide training in clinical research to young investigators.
- Developing of standardized definitions of CNP and a core set of outcome measures. Outcomes should be important to patients, clinicians, and purchasers (e.g., proportion of patients achieving adequate analgesia, impact of treatment on quality of life, unacceptable adverse effects, resource utilization).
- Larger studies involving multiple centers (including international collaboration) with more rigorous design, more comprehensive reports, and longer term followup are needed to establish the effectiveness and adverse effects of most of the interventions available. Special emphasis should be placed on gathering evidence on the effects of different interventions in women and adolescents.
- Focus on studies of people with TSCI and CNP rather than including individuals poststroke or with peripheral nerve injuries.
- Priority should be given to interventions with established roles for the management of other types of neuropathic pain, such as tricyclic antidepressants, anticonvulsants, local anesthetics, and opioids. Studies designed to judge the added value of these interventions given in combination (including treatment algorithms), through invasive routes (e.g., epidural and intrathecal infusions of opioids and local anesthetics), or using different formulations (e.g., sustained release preparations) should also be a priority.
- Since CNP is associated with psychosocial difficulties, other noninvasive approaches such as multidisciplinary or self-management approaches should be developed and evaluated for those with TSCI.
- Based on the evidence available, SCS and DREZ lesions may be useful in selected individuals. These interventions, however, are also invasive and potentially harmful. The studies that are needed will require complex, controlled designs with close attention to safety issues, substantial amounts of resources, and efficient collaboration among research groups.
- Studies are also needed to determine whether the response to treatment is influenced by the level and cause of the SCI as well as by the duration, distribution, and characteristics of the pain, and by comorbid factors (e.g., anxiety and depressive disorders).
- There is a great opportunity for consumer groups to call for and support more research activities, given the number of important questions that remain unanswered.
- Funding and conducting the research that is required will not be easy, given the complexity of the disorder, the frequent presence of comorbidity, and the variety of interventions and outcomes available.

Most of the current problems we encountered could be easily corrected if journal editors adopted evidence-based reporting recommendations such as the Consolidation of the Standards of Reporting Trials (CONSORT) statement (Begg, Cho, Eastwood et al., 1996) and kept track of new methodological developments that could increase the validity and applicability of research. The CONSORT statement was produced and published by an international group of clinical epidemiologists, biostatisticians, and journal editors in 1996 and is now available on the Internet (www.icmje.org). The aim of this statement is to improve the standards of written reports of RCTs and to ensure that readers find all the information they require in the reports to interpret the trial results with confidence. This statement includes a checklist of 21 items and a flow diagram that authors can use to provide necessary information on the progress of patients through a study. The statement has already been adopted by over 70 major biomedical journals (Jadad and Rennie, 1998). Similar efforts are evolving in relation to observational studies.

## Limitations of This Task Order Report

The findings and conclusions of this Task Order are based on the information that was available in the published reports of the studies included. Additional information obtained directly from the authors could have overcome many of the reporting limitations described above. Contact with authors could have also led to reduction in the likelihood of publication bias through the identification of unpublished studies. The budget and timelines available, however, were insufficient to allow this.

The interpretability of the data included in most of the tables of this evidence report is limited because so many different outcome instruments were used, often with limited descriptions.

## Closing Remarks

In summary, this report includes the first set of systematic reviews on the management of CNP following TSCI. They incorporate state-of-the-art methodology and are ready for incorporation into evidence-based clinical practice guidelines or performance measures. The report also provides a detailed description of the many limitations of the evidence available and provides recommendations to fill existing knowledge gaps through rigorous research. Filling such gaps will not be easy and will require highly innovative efforts and collaboration among different groups of decisionmakers. If this field continues to produce few, small, incompletely reported studies with heterogeneous designs instead of the rigorous and ambitious high-quality collaborative efforts required, research in this area will continue to be of little value to guide important clinical and policy decisions.