# Spinal Cord and Deep Brain Stimulation Techniques

## Introduction

Several invasive approaches have been used to treat refractory chronic pain conditions such as CNP following TSCI. Initially, these included destructive neurosurgical techniques such as posterior and anterior rhizotomies, neurectomies, radiofrequency thermocoagulation, or cryosurgical destruction of spinal nerves (Richardson, 1987). With increasing understanding of the complexity and plasticity of the spinal cord physiology, it was realized that it might be possible to obtain clinically useful analgesia with techniques that did not require destruction of neural tissue. These techniques involve stimulation of the spinal cord (spinal cord stimulation [SCS]) or specific sites within the brain (deep brain stimulation [DBS]). Both therapies are usually reserved for selected patients with chronic intractable pain shown to be resistant to conventional noninvasive therapies. Both involve the placement of electrodes over nervous tissue and electrical stimulation of underlying structures to produce pain relief. Both techniques also have the advantage of allowing assessment of responsiveness to therapy prior to permanent implantation (Nguyen, Keravel, Feve, et al., 1997; Richardson, Meyer, and Cerullo, 1980). DBS is generally used as a last resort for selected patients with severe pain after failure of SCS or in cases where SCS is contraindicated (Young and Rinaldi, 1994).

The precise mechanisms by which pain relief may be achieved using SCS or DBS are unclear. The theory underlying SCS involves the selective stimulation of large Aα and Aβ fibers to inhibit the nociceptive input from smaller Aδ and C fibers closing the spinal "gate." Stimulation of dorsal nerve roots and the dorsal columns is thought to activate inhibitory networks within the spinal cord that prevent transmission of pain (Meglio, Cioni, and Rossi, 1989). SCS may also result in the activation of descending inhibitory pathways as well as the release of neurochemical mediators that suppress pain (Richardson, 1987). In turn, stimulation of specific deep brain structures is thought to produce inhibition of nociceptive pathways within the brain as well as modulation of descending inhibitory pathways (Levy, Lamb, and Adams, 1987; Young and Rinaldi, 1994).

This chapter also includes a brief discussion of two studies of transcutaneous nerve stimulation (TNS) (Davis and Lentini, 1974; Doctor, 1996).

## Types of Stimulation

### Spinal Cord Stimulation

Spinal cord stimulation may be achieved via percutaneous insertion of electrodes into the epidural space near new roots corresponding to painful dermatomes. Potential responsiveness to therapy is generally associated with superimposition of stimulation-related paresthesias or pain relief over pain segments on testing. If responsiveness is shown, a receiver is implanted that allows the patient to regulate pain relief. Surgical placement of electrodes by laminectomy is generally reserved for patients in whom percutaneous placement is not possible.

### Deep Brain Stimulation

Deep brain stimulation involves surgical placement of electrodes over selected sites within the brain. Deafferentation pain has been treated by stimulation of several sites within the thalamus, the internal capsule, and the motor cortex (Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987; Nguyen, Lefaucheur, Decq, et al., 1999). The electrodes may be placed using several techniques, including positioning them into the intracranial epidural space via a burr hole or by craniotomy (Nguyen, Lefaucheur, Decq, et al., 1999). Pain relief after electrode placement is regulated by the patient in a manner similar to SCS.

### Transcutaneous Electrical Nerve Stimulation

Transcutaneous nerve stimulation involves the placement of electrodes placed over the skin to deliver electrical bursts to cutaneous and deep mechanoreceptors and is thought to affect the perception of pain. Treatment parameters can be altered by varying the frequency, amplitude, and voltage. The effectiveness of TNS for the treatment of chronic pain has been debated, and its effect on CNP following TSCI is unknown (Gadsby and Flowerdew, 2000).

## Methods

The specific search strategies and methods used for data extraction are summarized in Chapter 2.

## Results

A total of 33 eligible reports were identified and retrieved. Seventeen unique studies reported on the effectiveness of SCS (Broggi, Servello, Dones, et al., 1994; Buchhaas, Koulousakis, and Nittner, 1989; Cole, Illis, and Sedgwick, 1991; Devulder, Vermeulen, De Colvenaer, et al., 1991; Kumar, Nath, and Wyant, 1991; Lazorthes, Verdie, and Arbus, 1978; Long and Erickson, 1975; Meglio, Cioni, Prezioso, et al., 1989; Moraci, Ambrosio, and Mignini, 1982; Nielson, Adams, and Hosobuchi, 1975; North, Ewend, Lawton, et al., 1991; Richardson, 1987; Richardson, Meyer, and Cerullo, 1980; Shimoji, Hokari, Kano, et al., 1993; Simpson, 1991; Tsuda and Tasker, 1985; Urban and Nashold Jr., 1978), six evaluated DBS (Hosobuchi, Adams, and Rutkin, 1975; Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987; Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999; Young, Tronnier, and Rinaldi, 1992), and two evaluated TNS (Davis and Lentini, 1974; Doctor, 1996).

The general quality of studies was poor. The reports consisted of noncomparative observational studies or case reports and contained information specific to patients with TSCI that was often inextricably intermeshed with that of other patients treated for chronic pain of different etiologies so that data extraction was impossible (Broggi, Servello, Dones, et al., 1994; Nielson, Adams, and Hosobuchi, 1975; Richardson, 1987; Shimoji, Hokari, Kano, et al., 1993). A lack of standardization was found in some of the outcome measures (definitions of the quality of pain relief and VAS reductions) (Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999).

No studies were found that compared the efficacy of SCS to DBS for the treatment of pain.

### Spinal Cord Stimulation

Twenty-two citations yielded 17 original reports on SCS. This was represented by five unique studies of more than 12 subjects (Evidence Table 6.1) (Broggi, Servello, Dones, et al., 1994; Meglio, Cioni, Prezioso, et al., 1989; Nielson, Adams, and Hosobuchi, 1975; Richardson, 1987; Shimoji, Hokari, Kano, et al., 1993), and 12 case reports of seven subjects or fewer (Supplemental Evidence Table S6.1) (Buchhaas, Koulousakis, and Nittner, 1989; Cole, Illis, and Sedgwick, 1991; Devulder, Vermeulen, De Colvenaer, et al., 1991; Kumar, Nath, and Wyant, 1991; Lazorthes, Verdie, and Arbus, 1978; Long and Erickson, 1975; Moraci, Ambrosio, and Mignini, 1982; North, Ewend, Lawton, et al., 1991; Richardson, Meyer, and Cerullo, 1980; Simpson, 1991; Tsuda and Tasker, 1985; Urban and Nashold Jr., 1978).

The five studies on SCS were all case series and involved a total of 84 patients. No controlled trials were found. The sample sizes of the studies varied from 12 cases to 23 patients with TSCI. Two studies were prospective (Richardson, 1987; Shimoji, Hokari, Kano, et al., 1993) and three were retrospective (Broggi, Servello, Dones, et al., 1994; Meglio, Cioni, Prezioso, et al., 1989; Nielson, Adams, and Hosobuchi, 1975). The general inclusion criteria for these studies included chronic pain unresponsive to medical therapy, acupuncture, TENS, and physiotherapy. Only one study mentioned any exclusion criteria (major psychiatric illness) (Meglio, Cioni, Prezioso, et al., 1989).

One study permitted extraction of data on the number of patients with SCI at various levels of the spine. The number of patients in this study was 16 (Meglio, Cioni, Prezioso, et al., 1989). Eleven of them had thoracic, four had lumbar, and one patient had a cervical level SCI. Completeness of the injury was not reported or not extractable in any of the five studies.

Descriptive information regarding the gender and age of patients was found in two studies (Meglio, Cioni, Prezioso, et al., 1989; Shimoji, Hokari, Kano, et al., 1993) representing 28 patients. Seventy-four percent were male. Mean ages of this sample were 51 and 54.9 years. No studies provided a definition of neuropathic pain.

Outcome measures included categorical measures of pain relief (Broggi, Servello, Dones, et al., 1994; Nielson, Adams, and Hosobuchi, 1975); percent pain relief (Meglio, Cioni, Prezioso, et al., 1989; Richardson, 1987); binary pain relief: > 50% pain relief (Meglio, Cioni, Prezioso, et al., 1989; Shimoji, Hokari, Kano, et al., 1993), and satisfactory/unsatisfactory (Nielson, Adams, and Hosobuchi, 1975). Reductions in medication usage were used as an outcome in two studies (Meglio, Cioni, Prezioso, et al., 1989; Shimoji, Hokari, Kano, et al., 1993) but were reported only in one of the studies (Shimoji, Hokari, Kano, et al., 1993).

SCS can be achieved through percutaneous insertion of electrodes into the epidural space (PSCS) or via surgical placement of electrodes on the dura above or below the lesion (Buchhaas, Koulousakis, and Nittner, 1989) for dorsal column stimulation (DCS). One study reported on the relatively long-term use of percutaneously-placed electrodes (Shimoji, Hokari, Kano, et al., 1993). The remaining four studies involved patients whose potential responsiveness to SCS was assessed using PSCS prior to surgical implantation or patients receiving DCS (Broggi, Servello, Dones, et al., 1994; Meglio, Cioni, Prezioso, et al., 1989; Nielson, Adams, and Hosobuchi, 1975; Richardson, 1987). One study examined the use of continuous low frequency percutaneous epidural SCS (Shimoji, Hokari, Kano, et al., 1993).

One study reported statistical analysis of the results (Shimoji, Hokari, Kano, et al., 1993). The five studies involving SCS used similar outcome measures. In general, the studies showed initial improvement with stimulation in 50 to 70 percent of selected patients but a decline in effectiveness of stimulation on followup to 19 to 41 percent (Meglio, Cioni, Prezioso, et al., 1989; Richardson, 1987).

Adverse effects of SCS were reported for entire study samples. Information on adverse effects in the TSCI population was not usually extractable. It included lead displacement or breakage and failure of pain relief, cerebrospinal fluid leak, infection of the subcutaneous pocket or infection of the surgical wound, muscle spasms, and radicular muscle twitches. No major complications were noted in any of the studies.

The 12 case reports or small case series showed similar results, with at least one or two patients receiving partial pain relief and some patients having complications resulting from the procedure.

### Deep Brain Stimulation

Reports examining the use of DBS in this patient population were limited to one case series (Levy, Lamb, and Adams, 1987) (Evidence Table 6.2) and five case reports (Hosobuchi, Adams, and Rutkin, 1975; Kumar, Toth, and Nath, 1997; Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999; Young, Tronnier, and Rinaldi, 1992) (Supplemental Evidence Table S6.2).

The case series of DBS reported on 11 patients as a subset of a larger study of 141 subjects (Levy, Lamb, and Adams, 1987) (Evidence Table 6.2). The case reports (Hosobuchi, Adams, and Rutkin, 1975; Kumar, Toth, and Nath, 1997; Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999; Young, Tronnier, and Rinaldi, 1992) described 10 patients in total (Supplemental Evidence Table S6.2). General inclusion criteria in the case series included chronic pain refractory to available medical and/or surgical therapies in all studies. Explicit inclusion criteria were noted in one of the case reports (Kumar, Toth, and Nath, 1997). Specific exclusion criteria were noted in that same study. The cause of the injury was reported in two studies (Kumar, Toth, and Nath, 1997; Young, Tronnier, and Rinaldi, 1992) and included gunshot wounds to the spine (two patients), a complication of spinal cord surgery for removal of a neurofibroma (one patient) (Kumar, Toth, and Nath, 1997), and a motor vehicle accident in one subject (Young, Tronnier, and Rinaldi, 1992). The level of injury was reported in two reports (Adams, Hosobuchi, and Fields, 1974; Young, Tronnier, and Rinaldi, 1992).

Cumulatively, the six studies examined 21 patients after TSCI (Hosobuchi, Adams, and Rutkin, 1975; Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987; Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999; Young, Tronnier, and Rinaldi, 1992). Twenty out of the 21 patients studied had incomplete SCI.

Descriptive information regarding the age and gender of patients with CNP after TSCI was variably reported. Most of the studies included the data in summary form and included patients with chronic pain of differing etiologies, making this information unextractable for patients with TSCI (Hosobuchi, Adams, and Rutkin, 1975; Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987; Nguyen, Lefaucheur, Decq, et al., 1999). Ages of patients with TSCI were reported for 14 patients in three studies, with a mean age of 47 years (Levy, Lamb, and Adams, 1987; Nguyen, Keravel, Feve, et al., 1997; Young, Tronnier, and Rinaldi, 1992). Gender was reported for three patients in two studies (all were male) (Levy, Lamb, and Adams, 1987; Nguyen, Keravel, Feve, et al., 1997). Age and gender-related data were completely absent in one article (Hosobuchi, Adams, and Rutkin, 1975).

An explicit description of the pain reported by patients was given in three of the eight studies (Levy, Lamb, and Adams, 1987; Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999) and consisted of severe (2/3 studies), constant (2/3 studies), superficial (1/3 studies) or deep (2/3 studies), diffuse (2/3 studies), burning (3/3 studies), or aching (2/3 studies) pain.

The time of pain onset after injury was reported in one report (Levy, Lamb, and Adams, 1987). The length of time that CNP was experienced by patients with TSCI prior to DBS was reported in two studies (Levy, Lamb, and Adams, 1987; Nguyen, Keravel, Feve, et al., 1997) and was 14 years. The mean followup after DBS was reported nonspecifically for the study samples and varied from 27 to 80 months.

Patients with deafferentation pain following TSCI were treated by stimulation of the sensory thalamus (Hosobuchi, Adams, and Rutkin, 1975; Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987), the internal capsule (Hosobuchi, Adams, and Rutkin, 1975; Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987), or the motor cortex (Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999). Exact electrode implantation sites were not extractable in one study (Kumar, Toth, and Nath, 1997). The stimulation parameters, when reported, were noted in general terms for the entire study sample, and the data for patients with TSCI were not extractable (Kumar, Toth, and Nath, 1997; Nguyen, Lefaucheur, Decq, et al., 1999).

The studies cited examined several types of outcome measures. These included binary outcomes for short-term pain relief (Hosobuchi, Adams, and Rutkin, 1975; Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987; Nguyen, Keravel, Feve, et al., 1997); long-term pain relief (Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987; Nguyen, Keravel, Feve, et al., 1997); percentage reduction in pain (Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999); a modified MPQ (Kumar, Toth, and Nath, 1997), VAS measures of pain pre- and postoperatively (Kumar, Toth, and Nath, 1997; Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999); ordinal measures of improvement in the activities of daily living (Kumar, Toth, and Nath, 1997; Nguyen, Lefaucheur, Decq, et al., 1999); and reduction in medication usage (Levy, Lamb, and Adams, 1987; Nguyen, Lefaucheur, Decq, et al., 1999).

One study reported statistical analysis of the results. The analysis appeared appropriate (Nguyen, Lefaucheur, Decq, et al., 1999). Another reported no statistical difference in outcomes between patients receiving different types of electrodes but did not give further details of the analysis (Kumar, Toth, and Nath, 1997).

The four studies involving DBS used similar outcome measures. One study reported early pain relief in one of three patients with TSCI receiving sensory thalamic or internal capsule stimulation. None of the patients in the study achieved long-term pain relief. The authors believed that failure of the device in the patient with early pain relief was due to the development of tolerance (Kumar, Toth, and Nath, 1997). The followup period was a mean of 78 months for patients in this study.

Stimulation of the periaqueductal gray/periventricular gray matter or the sensory thalamus in patients with SCI led to early pain relief in 4 of 11 patients. None of the patients experienced long-term pain relief (Levy, Lamb, and Adams, 1987). The mean followup for the patients was 3.8 years.

Chronic motor cortex stimulation was found to reduce pain by over 80 percent in one of three patients with paraplegia (Nguyen, Lefaucheur, Decq, et al., 1999). The remaining two patients had 60 percent and 40 percent reductions in pain. Medication use was reduced in the two patients with more optimal responses. In a similar study, chronic stimulation of the motor cortex was reported to produce excellent pain relief (80-100% reduction) in one quadriplegic patient but did not produce pain relief (< 40% reduction) in a paraplegic patient (Nguyen, Keravel, Feve, et al., 1997). Data pertaining to adverse effects of DBS specific to patients with SCI were not extractable. In general, the most common complication of DBS in the studies was headache (Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987). Other complications included wound infections (Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987); meningitis (Levy, Lamb, and Adams, 1987); fractured electrodes (Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987); skin erosions (Levy, Lamb, and Adams, 1987; Nguyen, Lefaucheur, Decq, et al., 1999); blurred vision with stimulation (Kumar, Toth, and Nath, 1997); psychosis (Levy, Lamb, and Adams, 1987); hardware malfunction or migration (Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987); temporary hemi- or monoparesis, confusion, lethargy, dysphagia and local pain with stimulation, foreign body reaction (Levy, Lamb, and Adams, 1987); electrical leaks (Kumar, Toth, and Nath, 1997)' postoperative seizures (Kumar, Toth, and Nath, 1997); intracerebral hematoma (Kumar, Toth, and Nath, 1997; Levy, Lamb, and Adams, 1987); extradural hematoma (Nguyen, Keravel, Feve, et al., 1997; Nguyen, Lefaucheur, Decq, et al., 1999); periventricular hemorrhage (Levy, Lamb, and Adams, 1987); and death (Levy, Lamb, and Adams, 1987).

### Transcutaneous Nerve Stimulation

Two studies evaluated the effectiveness of TNS (Davis and Lentini, 1974; Doctor, 1996) (Evidence Table 6.3). Doctor (1996) conducted a randomized double-blind placebo controlled trial with 40 subjects. Of these, 20 patients had neurogenic pain described as centrally mediated pain resulting in sensations of pain below the level of the injury, while the remaining patients had musculoskeletal pain. He reported that TNS did not have a significant effect in reducing pain intensity in patients post-SCI with either neurogenic or musculoskeletal pain. He also reported that TNS may be effective in reducing the sensation of pain unpleasantness when patients are given a positive expectation about treatment effectiveness. Davis (1974) evaluated TNS in a series of 31 patients (11 with central pain). He reported that 13 of 31 had at least partial relief, and 18 patients had no relief at all.

## Discussion

Spinal stimulation has been used in an attempt to help patients with medically intractable pain find relief. Some patients in the case series identified in this evidence report have experienced at least partial relief of pain. However, it is difficult to place much confidence in these findings since the strength of evidence is poor for studies of SCI and DBS in patients with CNP following TSCI. Existing studies are observational in nature, of small sample size, without control or comparison groups, and have incomplete reports. Detailed descriptions of the patients involved in these studies are lacking. In addition, many of the outcomes specific to patients with CNP were not extractable and were not uniformly defined, such as short-term and long-term success of therapy.

The two studies of TNS report conflicting results. This is not surprising given the differences in rigor of study design. Given the paucity of evidence, it does not appear that TNS is effective in reducing the intensity of CNP, but the experience of "unpleasantness" may be reduced if patients have a positive expectation of treatment effectiveness.

### Implications for Practice

The data on SCS suggest that the technique has a variable rate of early success and a lower rate of long-term efficacy. The DBS data reveal a low rate of early success and an even lower long-term success, coupled with significant adverse risks of the procedure. These findings make it difficult to justify the use of either procedure as a method of treating CNP after TSCI. TNS may reduce the sensation of "pain unpleasantness" if patients have positive expectations of treatment effectiveness.

### Implications for Research

A discussion of the implications for future research is found in Chapter 8.