# Pharmacological Interventions

## Background

Pharmacological interventions are usually the first line during the treatment of patients with CNP of any origin. The number of pharmacological interventions with proven effectiveness, however, is so small that clinicians and patients are usually forced to adopt a "trial and error" policy, running through the same categories of treatments regardless of the origin of the pain (Max, 1990). These categories often include NSAIDs, opioids, antidepressants, anticonvulsants, alpha-2-agonists, steroids, and local anesthetics. Clinicians and patients not only have a wide variety of choices within each of these categories, but also can expand the number of options through the use of drug combinations, different routes of administration, novel formulations, and sometimes very sophisticated delivery systems. Progress in our understanding of the mechanisms responsible for neuropathic pain has led to the development of new compounds, most of which remain under development and evaluation.

To our understanding, there are no systematic reviews designed specifically to evaluate the effectiveness and safety of established or emerging interventions used for the treatment of CNP following TSCI.

The objective of this chapter is to describe the results of a systematic review of studies addressing the following questions, all of which were listed under Group III in the questions proposed by the CSCM:

- What is the evidence for the effectiveness and safety of each of the following classes of medications: simple analgesics (including NSAIDs and acetaminophen); antidepressants (including tricyclics and SSRIs); antiseizure medication; narcotics; muscle relaxants; NMDA antagonists; and local anesthetics?
- How do these classes of medications compare with each other?
- What is the strength of evidence for the effectiveness and safety of treatment algorithms including these classes of medication?

No studies were found that addressed the last questions. A complete description of the general methods of the review is found in Chapter 2.

## Results

A total of 31 potentially eligible studies were identified. Three studies were excluded during the data extraction phase (Attal, Gaudé, Brasseur, et al., 2000) because the study was not about the management of neuropathic pain (Hansebout, Blight, Fawcett, et al., 1993) or because data pertaining to patients with TSCI could not be extracted (Attal, Gaudé, Brasseur, et al., 2000; Bravo, Labarta, and Garcia, 1988). One study (Taira, Kawamura, Tanikawa, et al., 1995) was published twice in two different journals.

Fifteen unique studies are described in Supplemental Evidence Table 5.1.1 through 5.1.17 because they described case reports or observational studies with fewer than eight patients or provided insufficient descriptions of pain or TSCI (Gallien, Nicolas, Robineau, et al., 1995; Gibson and White, Jr., 1971; Herman, D'Luzansky, and Ippolito, 1992; Loubser and Clearman, 1993; Mercadante, 1998; Nagaro, Shimizu, Inoue, et al., 1995; Nagaro, Takaishi, Kimura, et al., 1995; Ness, San Pedro, Richards, et al., 1998; Ozerbil, Duman, Yosunkaya, et al., 1997; Potter, Hayes, Hsieh, et al., 1998; Sandford, Lindblom, and Haddox, 1992; Segatore, 1994; Siddall, Gray, Rutkowski, et al., 1994; Taira, Kawamura, Tanikawa, et al., 1995; Tharion and Bhattacharji, 1997).

A total of 12 independent studies were included in the review (Chiou-Tan, Tuel, Johnson, et al., 1996; Davidoff, Guarracini, Roth, et al., 1987; Drewes, Andreasen, and Poulsen, 1994; Eide, Stubhaug, and Stenehjem, 1995; Epstein and Childers, 1998; Erzurumlu, Dursun, Gunduz, et al., 1996; Fenollosa, Pallares, Cervera, et al., 1993; Glynn, Jamous, and Teddy, 1992; Glynn, Jamous, Teddy, et al., 1986; Heilporn, 1978; Loubser and Akman, 1996; Loubser and Donovan, 1991). Of these, five were RCTs (Chiou-Tan, Tuel, Johnson, et al., 1996; Davidoff, Roth, Guarracini, et al., 1987; Drewes, Andreasen, and Poulsen, 1994; Eide, Stubhaug, and Stenehjem, 1995; Loubser and Donovan, 1991), two were non-RCTs with contemporaneous controls (Erzurumlu, Dursun, Gunduz, et al., 1996; Glynn, Jamous, Teddy, et al., 1986), and seven were case series with more than eight patients (Davidoff, Guarracini, Roth, et al., 1987; Epstein and Childers, 1998; Fenollosa, Pallares, Cervera, et al., 1993; Glynn, Jamous, and Teddy, 1992; Heilporn, 1978; Loubser, 1997; Loubser and Akman, 1996).

All five RCTs included a placebo group. All but one of the RCTs included only one active group. This RCT compared ketamine, alfentanyl, and placebo (Eide, Stubhaug, and Stenehjem, 1995).

For the 12 studies included in the review, 9 included groups of single drugs (Chiou-Tan, Tuel, Johnson, et al., 1996; Davidoff, Guarracini, Roth, et al., 1987; Drewes, Andreasen, and Poulsen, 1994; Eide, Stubhaug, and Stenehjem, 1995; Epstein and Childers, 1998; Glynn, Jamous, and Teddy, 1992; Glynn, Jamous, Teddy, et al., 1986; Loubser and Akman, 1996; Loubser and Donovan, 1991), 2 studies included drug combinations (Erzurumlu, Dursun, Gunduz, et al., 1996; Heilporn, 1978), and 1 study included one group with a single drug and three groups with combinations (Fenollosa, Pallares, Cervera, et al., 1993) (Evidence Table 5.1.1 to Evidence Table 5.1.12).

Of the studies with single agents, three included opioids (2 morphine and 1 alfentanil); two studies each evaluated anticonvulsants (1 valproate and 1 gabapentin); and four studied local anesthetics (lidocaine) or alpha-2-adrenergic agonists (both evaluated clonidine). One study each evaluated an antispasticity drug (baclofen), an antidepressant (trazodone), or an NMDA receptor antagonist (ketamine). Two studies reported on combination treatments. The total number does not add up to 12 because three studies had more than one group with active interventions (Eide, Stubhaug, and Stenehjem, 1995; Fenollosa, Pallares, Cervera, et al., 1993; Glynn, Jamous, Teddy, et al., 1986). All included studies will be described in detail below and in Evidence Table 5.1.1 to Evidence Table 5.1.12 with a summary in Evidence Table 5.2.

### Studies Evaluating Single Drugs

#### Opioids

There were three studies evaluating opioids. One of them was an RCT (Eide, Stubhaug, and Stenehjem, 1995), one a nonrandomized comparative single-blind crossover study (Glynn, Jamous, Teddy, et al., 1986), and one was a case series (Fenollosa, Pallares, Cervera, et al., 1993).

The RCT had a double-blind crossover design (Eide, Stubhaug, and Stenehjem, 1995). It included nine patients, mostly men, with central dysesthesia pain after TSCI. The severity of continuous and evoked pain was examined before and after intravenous infusion of alfentanil (bolus of 7 μg/Kg followed by 0.6 μg/Kg/min), ketamine (bolus of 60 μg/Kg followed by 6 μg/Kg/min), and placebo. The study duration was 1 day. The results indicate that alfentanil and ketamine markedly reduce continuous and evoked pain compared with placebo (allodynia and wind-up like pain). No significant difference in pain reduction was observed between alfentanil and kentamine (Evidence Table 5.1.1).

The nonrandomized comparative single-blind crossover study included 15 patients, mostly men, with deafferentation pain due to TSCI (Glynn, Jamous, Teddy, et al., 1986). These patients received epidural administration of morphine (5 mg) or clonidine (150 μg). If pain was not relieved, epidural buprenorphine was provided to patients in both groups. Epidural morphine had "an effect on pain relief" in five patients, three of whom had also pain relief with epidural clonidine. Epidural clonidine had "an effect on pain" in seven patients who did not respond to morphine. Of the five patients who did not respond to morphine or clonidine, two responded to buprenorphine 0.3 mg. One patient did not obtain relief with any of the drugs. The study duration was 1 day, and no statistical analysis was conducted (Evidence Table 5.1.2).

The case series included 33 individuals with pain following TSCI (Fenollosa, Pallares, Cervera, et al., 1993). The report also included data from a survey of 145 patients, and it was not clear whether there was overlap between the two groups. In the case series, the authors evaluated four different interventions. Three of the groups included combinations of amitriptyline and clonazepam with other analgesic interventions (NSAIDs, Tryptophan, TENS, spinal cord stimulation). The other group included 12 patients with pain after TSCI who received an intrathecal morphine (0.6 mg initially followed by 0.3 mg to 1.0 mg according to response, and a permanent infusion of 0.6 mg/day). Eight of the 12 patients in this group obtained satisfactory pain relief and none developed tolerance to morphine after 3 years of treatment. It was necessary to replace the intrathecal catheter due to displacement in two subjects. The report did not include information on other adverse effects (Evidence Table 5.1.3).

#### Anticonvulsants

Two studies evaluated anticonvulsants. One of them was an RCT (Drewes, Andreasen, and Poulsen, 1994) and the other a case series (Epstein and Childers, 1998).

The RCT had a double-blind crossover design and included 20 patients, mostly men, who were tetraplegic and had neuropathic pain below level (Drewes, Andreasen, and Poulsen, 1994). These patients received valproate in titrated doses up to 2,400 mg twice a day. The authors report results on 10 patients who improved, four in the placebo and six in the treatment group. Two patients reported worsening of pain while on valproate, compared with one patient in the placebo group. It is unclear from the study whether seven of the patients had no change in their pain or if they were lost to followup (Evidence Table 5.1.4).

The case series (Epstein and Childers, 1998) included 29 patients with pain, 10 of whom had had a TSCI. These patients received gabapentin at a dose of 600 mg/day to 2,700 mg/day orally. Patients were kept in the study until they reported pain relief. The authors reported the SCI patients achieved at least 50 percent pain reduction (Evidence Table 5.1.5).

#### Local Anesthetics

Two studies evaluated local anesthetics. Both of these studies were RCTs with crossover designs (Chiou-Tan, Tuel, Johnson, et al., 1996; Loubser and Donovan, 1991).

One of the studies evaluated the effects of mexiletine (lidocaine) vs. placebo in 15 patients with severe pain after TSCI (Chiou-Tan, Tuel, Johnson, et al., 1996). Mexiletine was given in a dose of 150 mg orally, three times a day for 4 weeks. Only 11 of the patients completed the study. Patients were followed weekly with MPQ, Visual Analog Scale (VAS) and Barthel index of functional ability for 10 weeks. This study showed no significant effect of mexiletine on pain or disability (Evidence Table 5.1.6).

The other study was reported as double-blinded and included 21 patients with TSCI and neuropathic below level (Loubser and Donovan, 1991). These patients received lidocaine (5% in dextrose) or placebo intrathecally, through a lumbar subarachnoid catheter. The dose of lidocaine was titrated, using 25 mg aliquots, to a mean dose of 80 mg. The authors reported a statistically significant difference in the number of patients who reported reduction in pain intensity and duration after administration of lidocaine (13/21) compared with placebo (4/21) (Evidence Table 5.1.7).

#### Alpha-2-Adrenergic Agonists

Two studies performed by the same research group evaluated the effect of clonidine in patients with pain after TSCI. One of the studies was a nonrandomized comparative single-blind crossover study (Glynn, Jamous, Teddy, et al., 1986), and the other was a case series (Glynn, Jamous, and Teddy, 1992).

Some aspects of the nonrandomized comparative single-blind crossover study were described above under "Opioids." In this study, 15 patients with deafferentation pain due to TSCI received epidural morphine (5 mg) or clonidine (150 μg). Epidural morphine had "an effect on pain relief" in five patients, three of whom also had pain relief with epidural clonidine. Epidural clonidine had "an effect on pain" in seven patients who did not respond to morphine. Of the five patients who did not respond to morphine or clonidine, two responded to buprenorphine 0.3 mg. One patient did not obtain relief with any of the drugs. The study duration was 1 day, and no statistical analysis was conducted. None of the patients suffered from adverse effects (Evidence Table 5.1.2).

The case series included 10 patients with "deafferentation pain" after TSCI who received clonidine 150 μg. Seven patients reported analgesia. Of these, two had good pain relief, four had "average" relief, and one had minimal relief. Most of the patients reported drowsiness (Evidence Table 5.1.8).

#### Baclofen, Trazodone, and Ketamine

One study each evaluated the effect of baclofen, trazodone, and ketamine for pain after TSCI.

The study on baclofen was a case series (Loubser and Akman, 1996). It included nine patients who received a dose of baclofen that controlled spasticity intrathecally with the assistance of an intrathecal pump and a lumbar subarachnoid catheter. Seven of the patients with "neurogenic pain" had no significant change in pain severity, while two had an increase in pain both at 6 and 12 months (Evidence Table 5.1.9).

The study on trazodone was an RCT with a double-blind and parallel design (Davidoff, Guarracini, Roth, et al., 1987). This study included a total of 19 patients who received trazodone in a dose of 150 mg/day orally. Followup was 80-100 percent of patients in the placebo group and less than 60 percent of patients in the treatment group. Four patients in the trazodone group withdrew because of adverse effects. There was a comprehensive description of withdrawals and dropouts in each group. The study did not show statistically significant differences between or within the groups in terms of pain relief (Evidence Table 5.1.10)

The study on ketamine was described briefly above (Eide, Stubhaug, and Stenehjem, 1995). In this RCT with crossover design, nine patients with continuous and evoked pain received intravenous infusions of alfentanil (bolus of 7 μg/Kg followed by 0.6 μg/Kg/min), ketamine (bolus of 60 μg/Kg followed by 6 μg/Kg/min), and placebo. The study duration was 1 day. The results indicate that alfentanil and ketamine markedly reduce continuous and evoked pain (allodynia and wind-up like pain) (Evidence Table 5.1.1).

### Studies Evaluating Drug Combinations

There were three studies that included drug combinations. One of these studies was a non-RCT comparative study with contemporaneous controls (Erzurumlu, Dursun, Gunduz, et al., 1996). The other two were case series (Fenollosa, Pallares, Cervera, et al., 1993; Heilporn, 1978).

The comparative study included 28 patients who received either electroacupuncture or a combination of carbamazepine 600 mg/day and amitriptyline 50 mg/day (Erzurumlu, Dursun, Gunduz, et al., 1996). The characteristics of the patients and the completeness of followup were not described clearly. Pain intensity scores (10-point numerical analog scale) were recorded before and after the interventions. The authors concluded that both therapeutic modalities are safe and effective in the management of chronic pain in SCI patients (Evidence Table 5.1.11).

One of the case series was described above under "Opioids" (Fenollosa, Pallares, Cervera, et al., 1993). It included 33 individuals with pain following TSCI. The report also provided data from a survey of 145 patients, but did not include sufficient information to determine whether there was overlap between the patients of the two studies. In the case series, the authors evaluated three different drug combinations. All of the combinations included amitriptyline and clonazepam plus one or two additional interventions. The dose of amitriptyline in all of the groups with drug combinations started at 30 mg per day and was increased to 75 mg per day by the 10^th^ day. The dose of clonazepam was 0.6 to 1.7 mg per day. In the group that received an NSAID in addition to amitriptyline and clonazepam, 6 of the 33 reported satisfactory pain relief. This figure was 16/27 when tryptophane and TENS were added instead of the NSAID. Seven patients received spinal cord stimulation in addition to amitriptyline and clonazepam, and three of them reported satisfactory pain relief. Catheter displacement occurred in 3/12 patients, and there were two cases of respiratory depression (Evidence Table 5.1.3).

The other case series included 12 patients, 11 of whom had TSCI (Heilporn, 1978). These patients received a combination of melitracen 150 mg/day and flumpenthinol 3 mg/day with or without TENS. The treatment period varied from 2 weeks to 3 months. The outcomes were measured by the treating physicians and were based on judgement of global improvement. The results were not clearly described and it was not possible to establish the number of patients who benefited from the treatments. Three patients had ocular problems or micturition difficulties (Evidence Table 5.1.12).

## Implications for Practice

It was disappointing to find so few studies evaluating the effect of pharmacological interventions for CNP after TSCI. The small sample sizes, the poor methodological quality, and the incomplete reporting of the studies available compounded this dearth of research efforts.

The main conclusion from the limited data identified in this review is that it is difficult to determine whether pharmacological interventions have a role in the management of CNP after TSCI. There was only one small study on antidepressants, which are regarded as one of the cornerstones of the management of other types of neuropathic pain. This study evaluated the effect of trazodone and did not show a statistically significant difference with placebo. The lack of more studies on antidepressants as a single therapy, particularly some evaluating tricyclic compounds, limits any attempt to judge the value of this group of interventions in patients with CNP after TSCI.

A similar situation was found in relation to anticonvulsants. Two studies, one of which was a case series, had small sample sizes and such incomplete reports that it was impossible to determine the value of this group of interventions, which is also regarded as very important for the treatment of other types of neuropathic pain.

There was some evidence of effectiveness for local anesthetics given intrathecally. The only study available showed that lidocaine led to a statistically significant difference in the number of patients who reported reduction in pain intensity compared with placebo. The sample size of this study was small and the double-blinding questionable. Mexiletine, a local anesthetic-like drug, showed no benefit compared with placebo when given orally to 11 patients.

The situation was similarly disappointing in relation to alpha-2-adrenergic agonists. We found two studies, with 25 patients in total, showing some promise for clonidine. No firm conclusion, however, can be derived from these small studies.

Opioids were evaluated in three studies with a total of 36 patients. The drugs and routes of administration used in the studies were variable. The only RCT showed reduction in pain with alfentanyl in nine patients. The other studies also showed response of pain after the administration of morphine epidurally and intrathecally.

Studies of drug combinations were either poorly reported or designed to answer questions of very limited clinical relevance.

In sum, research on pharmacological interventions for the management of CNP after TSCI is in its infancy. The evidence available is so limited that it is impossible to draw any conclusions regarding their role in clinical practice. Although it appears that local anesthetics, opioids, and clonidine given spinally may play a role in the management of CNP after TSCI, the evidence available comes from few, small, poorly reported, and largely uncontrolled studies.

While the needed evidence is gathered directly from patients with CNP after TSCI, clinicians interested in using pharmacological interventions will have to rely on research on these interventions in other patient populations.