# Diagnosis, Assessment and Natural History of Pain After Traumatic Spinal Cord Injury

## Background

Three of the most complex and overlooked aspects of pain after TSCI are the diagnosis, assessment, and study of the natural history of CNP. To a large extent, the complexity associated with these aspects of CNP stems from the nature of the pain itself and from the inherent difficulty in defining and classifying it.

As with other types of pain, CNP remains a construct or concept, derived from clinical observations and patients' reports, that cannot be independently and objectively verified or measured by laboratory tests. Even if clinicians agree that the presentation of a pain is "neuropathic," there can be no independent verification of a neuropathic pathophysiology in the clinical setting. To date, there has been no confirmation that a constellation of "neuropathic mechanisms" exists (Portenoy, 1998). If such mechanisms exist, they are likely to be complex and highly variable, both within and across pain syndromes (Bennett, 1993; Portenoy, 1998). On the other hand, multiple mechanisms can be present within any given diagnostic category and even within individual patients (Fields and Rowbotham, 1994).

The corollary is that, although useful from the clinical perspective, the current construct of CNP is overly simplistic (Portenoy, 1998) and has limited value during the development of valid and accurate diagnostic criteria. As a result, most of the systems available to classify CNP typically rely on clinical interpretation of pain location (e.g., pain at or below the level of the neurological lesion), the anatomic basis of pain (e.g., visceral or root pain), or its putative pathophysiology (e.g., mechanical or psychological) (Burke, 1973; Donovan, Dimitrijevic, Dahm, et al., 1982; Siddall, Taylor, and Cousins, 1997). These systems retain the advantage of clinical simplicity and have been used to guide therapy. These pain classifications, however, require the simultaneous consideration of several different pain constructs of which there is little understanding. Another limitation of the classification schemes used to diagnose CNP (discriminative tools) is that they are not useful for measurement of pain severity or functional impact, which require evaluative instruments. There are numerous pain measurement instruments that have been developed for the quantification of pain, usually for the purposes of performing therapeutic studies (Jadad, Moore, Carroll, et al., 1996). Several of these instruments are generic tools that have been employed in the specific setting of TSCI. Others are likely to be developed exclusively for use in studies including people with pain following TSCI. Regardless of the initial purpose behind their development, the use of these instruments for discriminative or evaluative purposes ideally requires the establishment of acceptable psychometric properties (validity, reliability, and responsiveness) in the specific context of interest. For example, an instrument that is valid and reliable for measurement of neuropathic pain secondary to diabetic peripheral neuropathy may not be valid and reliable for individuals with CNP after TSCI.

For these reasons, the CSCM included questions pertaining to discriminative and evaluative approaches and the natural history of CNP as part of the review of the management of CNP after TSCI. To our knowledge, there have been no systematic efforts to identify, collect, synthesize, and distill the research evidence on the assessment, diagnosis, and natural history of CNP after TSCI. In this chapter, we describe the results of such an effort.

## Methods

A complete description of the general methods of the review is described in Chapter 2. In the next section, we describe our approach to addressing the questions related to assessment or natural history of CNP in TSCI.

### Review Questions

This chapter includes the evaluation of the literature to address the first two groups of questions proposed by the CSCM regarding the assessment and natural history of CNP in TSCI. These questions were:

#### Group I: Issues related to assessment

1. What are the measurement properties of:
  a. assessment approaches for chronic CNP per se (including criteria and tools such as inventories, questionnaires, and scales);
  b. other outcome measures or assessments (related to the experience of pain); and
  c. assessment approaches (including criteria and tools such as inventories, questionnaires, and scales) to identify new onset musculoskeletal pain against a background of chronic CNP?
2. What is the strength of evidence for strategies for the differential diagnosis of chronic CNP from other types of pain?

#### Group II: Issues related to natural history

3 What is the strength of evidence for identifying the prevalence of acute and chronic neuropathic pain and factors that could predict the development of chronic CNP?

### Assessment of Study Quality and Data Extraction

In addition to the generic methods described in Chapter 2, two reviewers (DW, MAO) assessed each study (using the form found in Appendix E) and categorized the studies into each of the following groups.

#### Classification of Publications

After reviewing all studies, we judged that none of the studies adequately addressed Question 1a and b. Instead, we report the results of any study that assessed or diagnosed CNP (Question 1a) (Evidence Table 4.1) and any study that addressed an outcome measure (Question 1b) (Evidence Table 4.2). For Questions 1c and 2, there was only one study that addressed the questions directly (Evidence Table 4.1). The publications that addressed the prevalence of CNP (acute or chronic) (Question 3) are found in Evidence Table 4.3 and 4.4. Lastly, the studies that primarily investigated the generation or testing of a hypothesis related to CNP are found in Evidence Table 4.5.

#### Diagnosis or Assessment of CNP

For articles related to the assessment and measurement of CNP, we extracted and evaluated information on the spectrum of pain severity and types of pain disorders included in the study sample, a description of the setting, sampling frame, referral filter, sampling methods, and use of a reference standard (Evidence Table 4.1).

#### Validation of an Outcome Tool/Measure Related to the Experience of Pain

We evaluated the quality of outcome measure assessment by determining if the validity, reproducibility, inter- and intrarater variation, and responsiveness were measured or referenced by the authors. We assessed descriptions of test procedures and reporting of adverse effects associated with their use. We summarized the results, including statistical analyses when available, for each study (Evidence Table 4.2).

#### Study of the Development or Prevalence of Acute or Chronic CNP

Publications that addressed factors associated with or predictive of CNP and studies that addressed prevalence of CNP were assessed for sampling methods, sampling frame, and response rate (Evidence Table 4.3 and Supplemental Evidence Table 4.3).

#### Generation or Testing of a Hypothesis Related to CNP

The studies that initially appeared to address question 1b but subsequently were categorized as generating or testing hypotheses about CNP in TSCI were described qualitatively, and the results were summarized separately (Evidence Table 4.5).

## Results

The literature search yielded 158 publications that addressed chronic CNP in TSCI. There were 65 citations that provided 58 unique reports addressing assessment and natural history questions. Of these, 7/58 (14%) addressed diagnosis or assessment; 2/58 (3%) addressed validation of an outcome tool or measure for CNP; 35/58 (60%) addressed factors that are associated with, predict, or addressed the prevalence of CNP; and 17/58 (29%) generated or tested hypotheses related to CNP. Some reports addressed more than one question.

### Diagnosis and Assessment of CNP

Five of 58 publications addressed the assessment or diagnosis of CNP in patients with TSCI (Evidence Table 4.1) (Beric, Dimitrijevic, and Light, 1992; Cohen, McArthur, Vulpe, et al., 1988; Davidoff, Roth, Guarracini, et al., 1987; Frisbie and Aguilera, 1990; Quigley and Veit, 1996). Two case series of less than eight subjects are included in Supplemental Evidence Table 4.1 but will not be discussed in detail here (Aisen, Stallman, and Aisen, 1995; Gellman, Eckert, Botte, et al., 1988).

There were methodological limitations present in all five of the studies. Neuropathic pain was partially or fully defined in three of the publications (Cohen, McArthur, Vulpe, et al., 1988; Davidoff, Roth, Guarracini, et al., 1987; Frisbie and Aguilera, 1990). The sampling method was either not reported or a convenience sample was used in each study, limiting the ability to assess the representativeness of each sample. Although three of the assessment studies used more than one instrument to measure pain severity (Beric, Dimitrijevic, and Light, 1992; Davidoff, Roth, Guarracini, et al., 1987; Quigley and Veit, 1996), none designated one instrument to be a reference standard in an attempt to determine construct validity.

One study was designed to determine how reliably the clinical history could discriminate CNP from other pain syndromes (Frisbie and Aguilera, 1990); and the others were designed to prospectively assess the quality or intensity of CNP in individuals with TSCI (Beric, Dimitrijevic, and Light, 1992; Cohen, McArthur, Vulpe, et al., 1988; Davidoff, Roth, Guarracini, et al., 1987; Quigley and Veit, 1996).

In 1990, Frisbie et al. (Frisbie and Aguilera, 1990) determined that two clinical history points -- pain quality and pain location relative to the level of paralysis -- were 100 percent reliable (sensitive) for CNP diagnosis (rather than musculoskeletal or syringomyelia pain) when judged by the standard of the absence of structural pathology found by clinical examination or radiography. Neuropathic pain was defined in this study as "neurogenic," based on adjectival description and being located at or distal to the level of paralysis. This study was not blinded and all assessments were done by the same clinicians, potentially increasing the possibility of bias.

Three publications (Cohen, McArthur, Vulpe, et al., 1988; Davidoff, Roth, Guarracini, et al., 1987; Quigley and Veit, 1996) used all or part of the McGill Pain Questionnaire (MPQ) to assess the presence and severity of CNP. Other instruments used included visual analog scales, the Sternbach Pain Index, the Zung Pain and Distress Scale (PAD), and pain drawings. All of the studies but one (Davidoff, Roth, Guarracini, et al., 1987) were prospective. In this study, patients with the symptoms of chronic CNP were compared to patients in a database. Cohen et al., 1988 compared patients with chronic CNP following a TSCI to those without a spinal cord injury. In some studies, pain was judged as being more severe in quadriplegic individuals but more common in those with paraplegia (Davidoff, Roth, Guarracini, et al., 1987; Quigley and Veit, 1996). Pain syndromes resulting from both complete and incomplete TSCI were generally more severe than chronic pain syndromes from other causes (Davidoff, Roth, Guarracini, et al., 1987). One study provided data on the correlations between different outcome measures: the Number of Words Chosen subscale of the MPQ correlated positively with the results of the PAD (Davidoff, Roth, Guarracini, et al., 1987).

### Validation of Outcome Tool/Measure

Two publications (Sherman, Barja, and Bruno, 1987; Sherman, Ernst, and Markowski, 1986) attempted to validate an instrument for use in assessment of patients with CNP (Evidence Table 4.2). Assessment by a blind panel showed that thermography was 87 percent efficient in differentiating complete from incomplete SCI in patients with CNP (Sherman, Barja, and Bruno, 1987). Video thermography showed that temperature changes correlated highly with the level at which sensation changed from normal to abnormal and pain locations (Sherman, Ernst, and Markowski, 1986).

### Factors Associated With or Predictive of CNP

Several publications that addressed other questions, especially CNP prevalence, also investigated factors that were associated with or predictive of CNP. There are 25 studies from 32 publications. These studies can be found in Evidence Table 4.3. An additional 11 case reports or case series of less than eight patients are included in Supplemental Evidence Table 4.3 but are not included in the discussion that follows.

Patients who were older at injury or at the time of study had a higher prevalence of CNP (Anke, Stenehjem, and Stanghelle, 1995; Demirel, Yllmaz, Gencosmanoglu, et al., 1998; Jung, 1990; Levi, Hultling, Nash, et al., 1995; Nepomuceno, Fine, Richards, et al., 1979). The presence of CNP was associated with incomplete spinal cord injuries in three publications (Demirel, Yllmaz, Gencosmanoglu, et al., 1998; Jung, 1990; Siddall, Taylor, McClelland, et al., 1999) but not in three others (Anke, Stenehjem, and Stanghelle, 1995; Levi, Hultling, Nash, et al., 1995; Summers, Rapoff, Varghese, et al., 1991). The level of spinal cord injury (thoracic level or paraplegia rather than quadriplegia) was associated with higher pain prevalence in some studies (Davidoff, Roth, Guarracini, et al., 1987; Demirel, Yllmaz, Gencosmanoglu, et al., 1998; Fenollosa, Pallares, Cervera, et al., 1993; Kennedy, Frankel, Gardner, et al., 1997; Rintala, Loubser, Castro, et al., 1998; Siddall, Taylor, McClelland, et al., 1999) but not others (Anke, Stenehjem, and Stanghelle, 1995; Levi, Hultling, Nash, et al., 1995). The presence of chronic pain was not associated with gender (Anke, Stenehjem, and Stanghelle, 1995; Fenollosa, Pallares, Cervera, et al., 1993; Levi, Hultling, Nash, et al., 1995), time since injury (Jung, 1990; Levi, Hultling, Nash, et al., 1995), or pain at 6 weeks postinjury (Demirel, Yllmaz, Gencosmanoglu, et al., 1998). Gunshot wounds were associated with a higher prevalence of CNP (Richards, Stover, and Jaworski, 1990; Rintala, Loubser, Castro, et al., 1998). Surgical intervention was not associated with CNP in two studies (Siddall, Taylor, McClelland, et al., 1999; Summers, Rapoff, Varghese, et al., 1991) but in another, patients with CNP were less likely to have received surgery (Davidoff, Roth, Guarracini, et al., 1987).

The presence of CNP may be associated with certain pathological changes in the spinal cord, such as extended atrophy, malacia, and syrinx formation, that are detectable by magnetic resonance imaging (Wang, Bodley, Sett, et al., 1996).

Higher pain severity was associated with incomplete lesions in one study (Rintala, Loubser, Castro, et al., 1998) but not in another (Summers, Rapoff, Varghese, et al., 1991). Pain severity was not related to the level of injury or surgical intervention, except in one study where quadriplegics had more intense pain than paraplegics (Summers, Rapoff, Varghese, et al., 1991). Gunshot wounds and other violent etiologies were associated with increased pain levels (Richards, Stover, and Jaworski, 1990; Rintala, Loubser, Castro, et al., 1998), but etiology was not an important factor in other studies (Cairns, Adkins, and Scott, 1996; Fenollosa, Pallares, Cervera, et al., 1993). There was no relationship between pain severity scores and the time from injury (Jung, 1990) or the duration of pain symptoms (Davidoff, Roth, Guarracini, et al., 1987).

Several studies assessed the relationship of psychological and social factors with chronic pain. The presence of pain was associated with worse quality of life (Anke, Stenehjem, and Stanghelle, 1995; Stensman, 1994; Svendsen, Drewes, Biering-Sorensen, et al., 1993), increased depression and stress (Kennedy, Frankel, Gardner, et al., 1997), and worse self-assessed health (Cairns, Adkins, and Scott, 1996; Rintala, Loubser, Castro, et al., 1998). Increased pain severity was associated with higher levels of anxiety, stress, depression, and anger (Demirel, Yllmaz, Gencosmanoglu, et al., 1998; Nepomuceno, Fine, Richards, et al., 1979; Rintala, Loubser, Castro, et al., 1998; Stormer, Gerner, Gruninger, et al., 1997; Summers, Rapoff, Varghese, et al., 1991). Coping strategies were found to be important predictors of pain after SCI (Jung, 1990; Stensman, 1994; Stormer, Gerner, Gruninger, et al., 1997).

The failure to use a clear definition of CNP, use of unvalidated outcome instruments, and inadequate sampling techniques threaten the validity of most of these association studies and largely prevents between-study comparisons of study results.

Seventeen studies contained a complete or partial definition of neuropathic pain or referenced another source. Seventeen studies were prospective. The cross-sectional methods employed included surveys done either in the clinic or at home (Cairns, Adkins, and Scott, 1996; Fenollosa, Pallares, Cervera, et al., 1993; Jung, 1990; Nepomuceno, Fine, Richards, et al., 1979; Rintala, Loubser, Castro, et al., 1998; Rose, Robinson, Ells, et al., 1988; Svendsen, Drewes, Biering-Sorensen, et al., 1993; Turner and Cardenas, 1999; Waisbrod, Hansen, and Gerbershagen, 1984) or personal or telephone interview (Anke, Stenehjem, and Stanghelle, 1995; Beric, 1990; Davidoff, Guarracini, Roth, et al., 1987; Kennedy, Frankel, Gardner, et al., 1997; Levi, Hultling, Nash, et al., 1995; New, Lim, Hill, et al., 1997; Richards, Stover, and Jaworski, 1990; Siddall, Taylor, McClelland, et al., 1999; Stensman, 1994; Stormer, Gerner, Gruninger, et al., 1997; Summers, Rapoff, Varghese, et al., 1991; Wang, Bodley, Sett, et al., 1996; Woolsey, 1986).

Five studies evaluated at least some patients in the sample on more than one occasion (Burke, 1973; Cairns, Adkins, and Scott, 1996; New, Lim, Hill, et al., 1997; Siddall, Taylor, McClelland, et al., 1999; Stensman, 1994). The response rates ranged from 37 to 93 percent for surveys and from 39 to 100 percent for interviews. The sampling frame was defined clearly in seven studies (Fenollosa, Pallares, Cervera, et al., 1993; Jung, 1990; Levi, Hultling, and Seiger, 1995; Rintala, Loubser, Castro, et al., 1998; Rose, Robinson, Ells, et al., 1988; Turner and Cardenas, 1999; Wang, Bodley, Sett, et al., 1996); most other studies used samples of convenience from rehabilitation hospitals or surveyed from populations in which the denominator was not estimable.

Acute pain (within the first 8 weeks postinjury) was specifically measured in all individuals in two studies (Kennedy, Frankel, Gardner, et al., 1997; Sved, Siddall, McClelland, et al., 1997); the individuals in these studies were also evaluated later to determine the prevalence of CNP. Five other studies included some individuals with acute pain due to the range of postinjury assessments included (Anke, Stenehjem, and Stanghelle, 1995; Cairns, Adkins, and Scott, 1996; Demirel, Yllmaz, Gencosmanoglu, et al., 1998; Long, 1976; New, Lim, Hill, et al., 1997). The remaining studies included only patients evaluated more than 8 weeks after TSCI.

#### Prevalence of Acute or Early Neuropathic Pain

The prevalence of acute or early neuropathic pain (within the first 8 weeks) depended on the time of assessment and definition of CNP. At 2 weeks in one study, 38 percent of individuals had pain at the level of the lesion and 14 percent had pain below the lesion (Sved, Siddall, McClelland, et al., 1997). In another study, 80 percent experienced pain at 6 weeks post-injury, but CNP was not defined (Kennedy, Frankel, Gardner, et al., 1997). The remaining studies that included some individuals during the acute postinjury stage estimated the prevalence of pain at admission to a rehabilitation facility to be 8 to 76 percent.

#### Prevalence of CNP

Twenty-five studies addressed the prevalence and factors associated with CNP (Evidence Table 4.3). The mean time from TSCI until study evaluation was not extractable or not reported in six studies (Beric, 1990; Fenollosa, Pallares, Cervera, et al., 1993; Richards, Stover, and Jaworski, 1990; Stensman, 1994; Svendsen, Drewes, Biering-Sorensen, et al., 1993; Waisbrod, Hansen, and Gerbershagen, 1984) and was at least 1 year (without specific figures given) in six other studies (Cobeljic, Kovacevic, Vulovic, et al., 1998; Jung, 1990; Nepomuceno, Fine, Richards, et al., 1979; Rose, Robinson, Ells, et al., 1988; Summers, Rapoff, Varghese, et al., 1991; Woolsey, 1986). The remaining four studies that exclusively evaluated CNP included individuals from 11 to 29 years after TSCI (Levi, Hultling, and Seiger, 1995; Rintala, Loubser, Castro, et al., 1998; Turner and Cardenas, 1999; Wang, Bodley, Sett, et al., 1996). Neuropathic pain that eventually became chronic was found to begin in the first week after injury in 41 percent, between 1 and 4 weeks in 19 percent, and between 1 and 3 months in 23 percent of patients (Turner and Cardenas, 1999). The estimates of CNP prevalence ranged from 10 to 82 percent, although most studies found the prevalence to be between 40 and 70 percent.

Four studies in three countries (Sweden, United Kingdom, United States) used a community-based sample (Levi, Hultling, Seiger 1995; Rintala, Loubser, Castro et al., 1998; Rose, Robinson, Ells, et al., 1988; Turner and Cardenas, 1999) to determine prevalence (Evidence Table 4.4). In these studies, the sample varied from 77 to 615 individuals post-TSCI. Prevalence estimates for CNP were 42, 47, 64, and 69 percent, depending on the definition of CNP.

Two studies evaluated neuropathic pain prevalence longitudinally and extended to at least 1 year postinjury (Kennedy, Frankel, Gardner, et al., 1997; Siddall, Taylor, McClelland, et al., 1999). The prevalence of neuropathic pain at the level of the neurological lesion was relatively stable during the first postinjury year (38% at 2 weeks, 38% at 26 weeks, and 28% at 52 weeks), but below-lesion pain increased sharply between 26 weeks (19%) and 52 weeks (50%) (Siddall, Taylor, McClelland, et al., 1999). Another study, however, showed that "pain" prevalence was 80 percent at 6 weeks and fell to 63 percent at 1 year; neuropathic pain was not defined in this study (Kennedy, Frankel, Gardner, et al., 1997).

In sum, these publications demonstrate that neuropathic pain begins shortly after TSCI and is a common problem even many years after the injury. There are several methodological problems with this group of articles that resulted in the wide range of prevalence estimates. In many cases, the description of the sampling frame was unclear and selection bias was likely. In other studies, it was uncertain what the appropriate denominator was for prevalence calculation. The lack of uniform neuropathic pain definition, low response rates, inadequate sampling techniques, and variable time from injury until pain assessment all contributed to heterogeneous prevalence assessments.

### Testing or Generation of Hypotheses

Nineteen of 45 publications were judged to primarily generate or test one or more hypotheses related to the diagnosis, measurement, or pathophysiology of CNP in TSCI (Evidence Table 4.5) (Beric, Dimitrijevic, and Lindblom, 1988; Bowsher, 1996; Cheng, Hong, and Liaw, 1997; Cohen, Song, Schandler, et al., 1996; Defrin, Ohry, Blumen, et al., 1999; Donovan, Dimitrijevic, Dahm, et al., 1982; Eide, Jorum, and Stenehjem, 1996; Lenz, Kwan, Dostrovsky, et al., 1989; Melzack and Loeser, 1978; Ness, San Pedro, Richards, et al., 1998; Roelcke, Curt, Otte, et al., 1997; Sherman, Barja, and Bruno, 1987; Sherman, Ernst, and Markowski, 1986; Song, Cohen, Ament, et al., 1993) (Aisen, Stallman, and Aisen, 1995; Dressler, Thompson, Gledhill, et al., 1994; Livshits, Sokolova, and Demina, 1988; Loeser, Ward, and White, Jr., 1968; Woodward and Vulpe, 1991). Six studies employed electrophysiological testing and correlated the results with clinical examination findings (Beric, Dimitrijevic, and Light, 1992; Beric, Dimitrijevic, and Lindblom, 1988; Bowsher, 1996; Cheng, Hong, and Liaw, 1997; Cohen, Song, Schandler, et al., 1996; Donovan, Dimitrijevic, Dahm, et al., 1982) and two studies used brain imaging techniques (Ness, San Pedro, Richards, et al., 1998; Roelcke, Curt, Otte, et al., 1997).

## Discussion

The findings of this systematic review demonstrate that many investigators have addressed important assessment and natural history issues regarding CNP in TSCI. Neuropathic pain is common in individuals who suffer TSCI, both in the acute (first 8 weeks postinjury) and chronic phases, with most prevalence estimates ranging from 40 percent to 75 percent for chronic pain. This pain is moderate to severe in 25 percent to 60 percent of these individuals and may interfere with activities of daily living. An increased likelihood of developing CNP may be associated with certain factors such as older age and having a gunshot wound as the cause of SCI. The presence and severity of CNP appears to be associated with anxiety, depression, and lower perceived health status. The description and location of pain may allow accurate diagnosis of CNP. There are no discriminative or evaluative measurement instruments that have been adequately investigated with respect to psychometric measurement properties in this setting.

We noted a wide range of definitions of CNP in samples of patients with TSCI. Some authors explicitly defined CNP using their own definition, others referred to previously described classification systems, and some simply used the labels "spinal cord injury pain" or "spinal cord pain." This disparity results in uncertainty regarding what type of pain syndrome a given sample has, complicates interpretation of results, and impairs the ability to replicate the study.

There were very few studies that systematically evaluated the psychometric properties (validity, reliability, responsiveness) of a discriminative or evaluative instrument for the measurement of CNP in individuals with TSCI. Several authors utilized pain measurement instruments that have been validated in other settings but provided predominantly descriptive information concerning the subjects they studied. These instruments, however, may have different properties when used to assess CNP after TSCI. There were no studies that defined a CNP construct, identified a reference standard instrument, or attempted to assess the validity of the construct.

The studies of prevalence of CNP in TSCI patients varied strikingly in methodology. Most studies did not adequately define CNP, describe the sampling frame in sufficient detail, or provide an estimate of an appropriate denominator. Many of the studies used a sample of convenience or consecutive patients admitted to one rehabilitation center, possibly resulting in selection bias. These reasons, as well as the use of different outcome measures and evaluations at different stages of rehabilitation, led to the wide range of prevalence estimates.

### Implications for Clinical Practice

The results of this systematic review support the notion that CNP is very prevalent in individuals after TSCI and warrants specific inquiry by health care professionals caring for such individuals. It is associated with several psychological and psychiatric comorbidities and is often severe enough to impair or prevent optimal physical function and daily activities.

### Implications for Research

The results of this systematic review demonstrate that improvements are needed in defining the construct of chronic neuropathic pain in the setting of SCI. The most commonly used classifications of CNP (Donovan, Dimitrijevic, Dahm, et al., 1982; Siddall, Taylor, and Cousins, 1997) and the ad hoc definitions used in many other studies emphasize interpretation of the source of the pain (neurogenic versus visceral, root, musculoskeletal, or otherwise) and its location (at or below the level of neurological injury). The construct of neuropathic pain used in these classification systems is therefore multidimensional and subject to individual interpretation. The strength of current concepts of CNP definitions is their widespread acceptance as constructs. The number of different classification systems and their heterogeneity represents a weakness of currently available research.

The measurement properties of instruments used to evaluate neuropathic pain have not been defined. Well-designed experimental and observational studies are needed to establish construct validity for neuropathic pain definitions and for instruments that assess pain severity. This improvement would allow for better prevalence and association studies. Without this advancement, studies that generate or test new hypotheses concerning the pathophysiology of neuropathic pain will not be replicable. Test-retest reliability and responsiveness must also be established in order for future research to advance beyond the descriptive stage towards valid evaluative and therapeutic studies.

Future studies of assessment and diagnostic tools may benefit from improvements in study design. Definition of the sampling frame and methods of sampling that reduce selection bias would strengthen prevalence and association studies. Blinded outcome assessment, which was utilized by a small number of studies we identified, would also strengthen validity studies.