# Methodology

## Introduction

In this chapter, we report our overall approach in conducting the systematic reviews included in this Task Order. The chapter starts with a brief description of the TEP, TOO, and partners at the CSCM and the process followed to interact with them throughout the development of the Task Order. The chapter concludes with details of the methodological approach that was followed to answer each of the questions formulated by the CSCM.

In subsequent chapters, we report the findings of systematic reviews of the available evidence relevant to each of such questions. When appropriate, we will provide additional information on specific methodological issues relevant to the question (s) addressed by each chapter.

## Technical Expert Panel

The TEP for this Task Order included individuals who represented professional organizations, providers of health care, purchasers of health services, researchers, and consumers. The membership list is appended (Appendix B). These individuals are recognized as national and international leaders in the management of pain or in issues related to SCI. Given the number of questions, the wide variety of issues that they address, and the diversity of backgrounds among the large number of members of our TEP, we consulted with each of the panelists regarding their interest in focusing their attention on particular questions. We asked about their preferences, collated their responses, and ensured coverage of each question from at least two panelists, allocating them to areas of interest that matched their background. This communication strategy facilitated the topic refinement process and enabled us to approach all of the questions simultaneously and efficiently. We anticipated that this strategy also would assist in determining authorship of individual publications derived from this work. Members of our TEP were asked to nominate two or three peer reviewers.

## Consultations With the Task Order Officer and Partners

We consulted our TOO, Dr. Harry Handelsman, and representatives of the CSCM at each step in the process. Mr. Paul Thomas and Ms. Dawn Sexton were the main contact people at the CSCM. Initially, the team of the MU-EPC communicated with the TOO and the representatives from the CSCM by telephone to discuss the goals and objectives of this Task Order. We also had a face-to-face meeting to complement the telephone discussions. The Chair of the Steering Committee of the CSCM, Dr. Kenneth Parsons, was consulted and agreed to become a member of the TEP. This facilitated collaboration with the CSCM and helped to ensure that we fully addressed the questions that formed the basis for this Evidence Report. Members of the CSCM were asked to identify potential peer reviewers for the draft Evidence Report.

## Peer Reviewers

A preliminary list of potential peer reviewers was drafted in October of 1999 and sent to the TOO. The final list of peer reviewers appears in Appendix C. In April of 2000, each proposed reviewer was contacted to request their assistance with the review of this draft Evidence Report and to provide a timeline and directions for their involvement. We delivered the report for their review in early July 2000. Their comments were returned to our criticisms editor, Dr. Pat Huston. The comments were then synthesized and returned to us for incorporation and editing of this final report.

### Refinement of the Population

Initially, we considered other groups of individuals with central neuropathic pain such as those with stroke or multiple sclerosis. However, in discussion with the TOO and the representatives from our partners, we established that the task order would focus upon adults and adolescents with CNP following TSCI.

### Refinement of Research Questions

The wording of some of the original questions asked for clinical recommendations, which are more appropriate for clinical practice guidelines than for an Evidence Report. For example, one question was originally stated as: "What are the best outcome measures and/or assessments that detect clinical changes in pain management for chronic central neuropathic pain?" Following discussions with our TOO and the representatives from our partners, the questions were reworded and reordered to ensure that they were clinically important and potentially answerable by research evidence. In answering the questions, the strength of evidence was summarized, but clinical recommendations were not made. The complete list of questions, which were grouped into those related to assessment, natural history, and interventions for treatment, is found in Chapter 1.

The last question formulated by the CSCM dealt with cost issues. Ideally, this question should have been answered in terms of the added value of quality of life relative to the costs of different management strategies. We searched our core electronic databases for studies that incorporated economic analyses or cost information. We also searched two economic databases, the National Health Services Economic Evaluations Database as well as the Health Economic Evaluations Database. We were unable to locate any studies specific to the management of CNP following SCI, therefore, this evidence report does not deal with cost issues. The TOO advised that performing an economic analysis was beyond the scope of the Task Order and, therefore, would not be conducted by us.

### Inclusion/Exclusion Criteria

In consultation with the TEP and our partners, we developed a set of inclusion and exclusion criteria. Initially, we used very liberal selection criteria. We regarded as potentially eligible any article that described a study: (1) in humans; and (2) about the cause, management, or measurement of CNP. We excluded reports that were not primary studies; studies where the sample consisted of people without a TSCI, those without chronic neuropathic pain, or children younger than 13 years. We also excluded primary studies that did not contain data in the published report and studies in which the sample included individuals with TSCI as well as other types of CNP but where the results were not presented separately for individuals with TSCI.

Since there are nearly as many definitions of CNP as there are published reports, we did not attempt to provide a definition ourselves. We accepted any definition provided by the primary study authors. We also developed a tentative list of descriptions of CNP based on our preliminary searches. This list was used to guide the research team during the two-step screening process. We excluded studies that only used the term "chronic pain" without any other description of the pain experienced by the individuals in the study sample that could have helped us judge it as central and neuropathic.

Many studies included individuals with CNP and pathologies other than TSCI (e.g., multiple sclerosis, stroke). For the purposes of this Evidence Report and the evidence tables, we included only the results pertaining to those with TSCI. The only exception to this decision concerned adverse effects. If adverse effects were reported only for the entire sample, we indicated this in the evidence tables.

Studies of individuals with TSCI and CNP as well as reflex sympathetic dystrophy or post-traumatic syringomyelia were considered separately and are reported in the supplementary rather than in the primary evidence tables. We considered injuries to the cauda equina as peripheral nerve lesions rather than a central problem. It was uncertain if reflex sympathetic dystrophy, now referred to as complex regional pain syndrome, type 1 (CRPS-1) or complex regional pain syndrome, type 2 (CRPS-2), could be considered to be a form of CNP. Further, it is unclear if studies of individuals with pain associated with post-traumatic syringomyelia are sufficiently similar to those with CNP post TSCI who do not have a syrinx.

Treatment options were confined to conventional medicine. We did not seek out reports of nontraditional therapies. We anticipated that we would identify many studies of single or multiple case reports. While these studies can be important in determining adverse effects or generating hypotheses related to CNP, they are not useful to evaluate the effectiveness of interventions. For this reason, single or multiple case reports (usually with fewer than eight individuals with TSCI) are described in supplemental evidence tables within each chapter. Early in the screening process, we discovered that some larger studies of neuropathic pain included fewer than 10 people with TSCI. While results were reported separately for these individuals, the characteristics of the sample were provided for the entire group. Such studies also are reported in the supplemental evidence tables.

### Literature Search Strategies

Citations of potentially eligible studies were identified through a systematic search of:

- MEDLINE, EMBASE, PsycINFO were searched from the date of their release to end of May 2000.
- CINAHL, HEALTHStar, Sociological Abstracts. These databases were searched from the date of their release to November 1999.
- The Cochrane Library (issue 4, 1999).
- The reference lists of any eligible article identified in any of the above sources.
- Personal files of all members of the local team and the TEP.

The development of the search strategy followed an iterative process. Initially, we chose search terms based on the MEDLINE indexing terms of several key publications. We then tested our initial search using the "See Related" function of PubMed to ensure that the search would retrieve the key publications previously identified. The search terms were then refined using the same process. The final MEDLINE search strategy appears in Appendix D. The MEDLINE strategy was modified to meet the specific features of CINAHL, EMBASE, and PsycINFO. We searched for unpublished studies by contacting members of the TEP. After discussion with the TOO, we decided not to attempt to contact study authors for additional information.

## Screening Process

To identify relevant articles, we conducted a two-step screening process with six raters working in pairs. The first step was based upon the information available in titles and abstracts (where available) and was conducted by the same two raters working independently. Each citation was rated as "include," "exclude," or "unclear." A citation marked by either rater as "include" or "unclear" was retrieved. The terms sought during the first screening step were human, neuropathic pain, and spinal cord injuries. The second step of the screening process was based upon full text reports and involved all six raters randomly paired. Discrepancies were resolved by discussion. The form for the second screening is found in Appendix E.

Since we used different pairs of raters, we determined our agreement in applying the criteria for the second screening. The statistician on the McMaster Team, Dr. Charlie Goldsmith, designed a randomization schedule. Initially, all six raters screened the same set of 10 articles. The project assistant (who did not rate any articles), then assigned the articles sequentially following the unblinded randomization schedule to six raters for the first 90 articles. For the remaining articles, five raters were used.

### Quality Criteria

In assessing the methodologic quality of the RCTs, we used a three-item validated scale, complemented with assessments of individual components supported by empirical methodological evidence (Jadad, Cook, Jones, et al., 1998). For observational studies evaluating effectiveness or safety of interventions, we used an instrument adapted from Downs and Black (Downs and Black, 1998). For studies on diagnosis or assessment of pain, we used the corresponding User's Guides to the Medical Literature (Jaeschke, Guyatt, and Sackett, 1994). We adapted the User's Guides on prognosis to evaluate studies on natural history (Laupacis, Wells, Richardson, et al., 1994). For studies that assessed predictors of outcome, we noted the comprehensiveness with which possible predictors were examined, the representativeness of the population studied, the extent to which assessments of predictor status and outcome were independent, and the completeness of followup. For the assessment of the quality of qualitative studies, we planned to use a tool adapted from Boulton et al. (Boulton, Fitzpatrick, and Swinburn, 1996).

## Data Extraction Process

All data extraction forms were developed, pilot-tested, and revised by members of the local research team including the team statisticians. After consultations with the TEP, our TOO, and our partners, the forms were approved for content. A general data extraction form was used with all studies, while individual forms were used for RCTs, observational studies, and case reports (Appendix E). Items related to study quality were embedded within the data extraction forms. Two reviewers completed data extraction independently for all studies except the case reports. For these studies, data were extracted by one reviewer and checked by another. Any disagreements were resolved by consensus. Following consensus on each item, the data forms were scanned into a Microsoft Access database using Teleform software.^1^

1 TELEform Standard Version 6.0, Cardiff Software Incorporated, San Marcos CA, USA.

## Data Synthesis

Descriptive statistics were calculated for all fields of the database. Evidence tables were constructed to describe the most salient features of the included studies according to the review question. These tables are found at the end of each chapter along with the relevant supplementary tables. The tables have the following general structure:

- a summary of the key characteristics of the studies reviewed, including the name of the first author, the year of publication of the study, the country where the study was centered, the type of study design, and items related to quality;
- items related to the characteristics of the sample, including the number of patients allocated, level and completeness of the injury, time since injury, onset of pain, duration of pain, and description of pain;
- the interventions studied and the duration of exposure to each of the interventions;
- the outcomes of interest measured (following the list provided above);
- the key results for the outcomes of interest; and
- adverse effects.

To make the data extracted easier to understand, the information on the studies was organized in the tables following alphabetical order. The studies are also presented in alphabetical order within the text. In addition, every effort was made to describe the studies according to their methodological quality, taking into account both the evidence-based criteria and the elements that were not supported by empirical evidence.

The local research team at the MU-EPC, in consultation with members of the partner organization and the TOO, evaluated the overall quantity and quality of the data available. This evaluation led to the conclusion that meta-analysis would be inappropriate to summarize the evidence on each of the research questions or for each of the main categories of interest. The main reasons for this decision were substantial clinical heterogeneity across the studies (e.g., interventions evaluated, patient samples, duration); inconsistency in outcome measurements; low methodological quality; and incomplete data reporting (see detailed descriptions within each category). The use of meta-analysis to synthesize this type of data has been associated with a greater chance of obtaining imprecise and potentially misleading results (Ioannidis, Cappelleri, and Lau, 1998). Therefore, this report represents a systematic qualitative review of the existing evidence, emphasizing the implications for clinical practice and the directions that future researchers could take to fill existing knowledge gaps.

Every effort was made to present the information obtained in each of the categories following a uniform format. Overall, each section begins with a general description of the most salient characteristics of the studies and ends with a summary of the main findings of the studies. The way in which the results from the individual studies are presented varies substantially across chapters. This reflects the different perspectives that the questions provide on the management of CNP following TSCI.