# Appendix F. Acronyms and Abbreviations

Abbreviation/Acronym | Definition
2PDTs | 2-Point Discrimination Thresholds
ADS | Acceptance of Disability Scale (ADS)
AE | Adverse Effects
AHRQ | Agency for Healthcare Research and Quality
ASIA | American Spinal Injury Association Impairment Scale
BDI | Beck Depression Inventory
CA DREZ | Computer Assisted, Radiofrequency Dorsal Root Entry Zone
CES-D | Center for Epidemiological Study-Depression Scale
CHART | Craig Handicap Assessment and Reporting Technique
CNP | Central Neuropathic Pain
CNS | Central Nervous System
CO_2_ | Carbon Dioxide
CONSORT | Consolidation of the Standards of Reporting Trials
COPE | Coping Strategy Scales - Carver et al., 1989
CSCM | Consortium for Spinal Cord Medicine
d | days
DBS | Deep Brain Stimulation
DCS | Dorsal Column Stimulation
DPS | Dysesthetic Pain Syndrome
Dx | diagnosis
DREZ | Dorsal Root Entry Zone
EMG | Electromyographic
EPC | Evidence-based Practice Center
FIM | Functional Independence Measure
GSW | gunshot wound
HPT | Heat Pain Threshold
LSIA | Life Satisfaction Index - A
m | months
MMPI | Minnesota Multiphasic Personality Inventory
MPI | Multidimensional pain inventory
MPQ | McGill Pain Questionnaire
MU-EPC | McMaster University Evidence-based Practice Center
MQS | Medication Quantification Scale
MVA | Motor Vehicle Accident
Nd: YAG | Neodymium: yttrium aluminum garnet
NMDA | N-methyl-D-aspartate
NS | Not Statistically Significant
NSAIDs | Non-Steroidal Anti Inflammatory Drugs
NR | Not Reported
NRS | Numerical Rating Scale
NWC | McGill subscale: Number of Words Chosen
PAD | Zung Pain and Distress Scale
PAG | periaqueducted gray stimulation
PES | Pain Experience Scale
PET | Positron Emission Tomography
PIS | Pain Inventory Scale
PPI | McGill subscale: Present Pain Intensity
POMS | Profile of Mood States
PRI | McGill subscale: Pain Rating Index
PSCS | Percutaneous insertion of electrodes into epidural space
PVA | Paralyzed Veterans Association
PVG | periventricular grey stimulation
pts | patients
QOL | Quality of Life
Rx | treatment
rCBF | Regional Cerebral Blood Flow
RCT | Randomized Controlled Trial
RSDS | Reflex Sympathetic Dystrophy Syndrome
SAPB | Subarachnoid phenol block
SCI | Spinal Cord Injury
SCIIS | Spinal Cord Injury Interference Scale
SCS | Spinal Cord Stimulation
SD | Standard Deviation
SE | Standard Error
SHS | Shoulder Hand Syndrome
SPECT | Single Emission Computed Tomography
SPI | Sternbach Pain Intensity
SSR | Sympathetic Skin Response
SSRIs | Selective Seratonin Reuptake Inhibitors
STAI | State-Trait Anxiety Inventory
TENS | Transcutaneous Electrical Nerve Stimulation
TOO | Task Order Officer
TSCI | Traumatic Spinal Cord Injury
UTI | Urinary Tract Infection
VAS | Visual Analogue Scale
w | weeks
y | years