# Appendix E. Assessment and Natural History Study Form

## Section I: Describe the purpose of the study

Is the purpose of the study to (check all that apply):
1. Assess or diagnose central neuropathic pain? | Yes | No | Not clear | Not reported
1. Assess or diagnose central neuropathic pain? | If yes, go to Section II
2. Validate an outcome tool/measure related to the experience of pain? | Yes | No | Not clear | Not reported
2. Validate an outcome tool/measure related to the experience of pain? | If yes, go to Section II
3. Determine the factors that are associated with or could predict the development of chronic central neuropathic pain? | Yes | No | Not clear | Not reported
3. Determine the factors that are associated with or could predict the development of chronic central neuropathic pain? | If yes, go to Section III
4. Estimate the prevalence of acute or chronic central neuropathic pain? | Yes | No | Not clear | Not reported
4. Estimate the prevalence of acute or chronic central neuropathic pain? | If yes, go to Section IV
5. Generate/test a hypothesis related to central neuropathic pain | Yes | No | Not clear | Not reported
5. Generate/test a hypothesis related to central neuropathic pain | If yes, stop
If no to all questions, describe the purpose of the study: | ________________________________________
If yes to question 5 only, stop.
If yes to any of questions 1-4, also complete the General Data Extraction Form.

Ref ID#_________
Reviewers Initials_________

## Section II: For studies about the assessment/diagnosis of central neuropathic pain or about the validation of an outcome tool/measure related to the experience of pain, complete the next section

Assessment/Outcome Tool/Measure Code___________________________________________________________
6. Does the study describe the use of the tool in patients with traumatic spinal cord injury (TSCI)? | Yes | No | Not clear | Not reported
7. Does the sample include an appropriate spectrum of individuals with mild and severe pain plus individuals with different but commonly confused disorders, e.g., cauda equina? | Yes | No | Not clear | Not reported
8. Was the setting for this evaluation, as well as the filter through which study patients passed, adequately described? | Yes | No | Not clear | Not reported
9. Was validity of the tool assessed in the study? If yes, how was validity assessed? content construct predictive concurrent other _________________________ Describe the results of the validity assessment: | Yes | No | Not clear | Not reported
If no, was validity referenced? | Yes | No
10. Was the reproducibility of the test determined in the study? If yes, describe the results. | Yes | No | Not clear | Not reported
If no, was reproducibility referenced? | Yes | No
11. Was inter-rater variation of the test result determined? If yes, describe the results. | Yes | No | Not clear | Not reported
If no, was inter-rater variation referenced? | Yes | No
12. Was intra-rater variation of the test result determined (if appropriate)? If yes, describe the results. | Yes | No | Not clear | Not reported
If no, was intra-rater variation referenced? | Yes | No

Ref ID#_________
Reviewers Initials_________

The next question pertains to studies about the validation of an outcome measure/tool only.
13. Was responsiveness to change measured in the study? If yes, describe the results. | Yes | No | Not clear | Not reported
If no, was responsiveness to change reported elsewhere? | Yes | No
14. If the test is advocated as part of a cluster or sequence of tests, has its individual contribution to the overall validity of the cluster or sequence been determined? | Yes | No | Not clear | Not reported
15. Have the tactics for carrying out the test been described in sufficient detail to permit their exact replication? | Yes | No | Not clear | Not reported
16. Were any adverse effects reported as a result of using the tool? If yes, describe the adverse effect. | Yes | No
17. Briefly, describe any other results of the study

## Section III: For studies about factors that could predict the development of chronic central neuropathic pain, complete the next section

Complete Questions 18 to 23 for studies where outcomes were measured at more than one point in time. Complete Questions 21 to 24 if the outcomes were measured at one point in time.

18. Was an inception cohort assembled? | Yes | No | Not clear | Not reported
19. Was the referral pattern described? | Yes | No | Not clear | Not reported
20. Was complete follow-up achieved? If no, indicate the follow-up ___________________________ | Yes | No | Not clear | Not reported
21. Were objective outcome criteria developed and used? | Yes | No | Not clear | Not reported
22. Was the outcome assessment blind? | Yes | No | Not clear | Not reported
23. Was adjustment for extraneous prognostic factors carried out? | Yes | No | Not clear | Not reported
List the factors that were considered.
24. Briefly describe the results.

Ref ID#_________
Reviewers Initials_________

For studies where the outcomes were measured at one point in time, e.g., a cross sectional survey, also complete questions 25 to 30.
25. How was the sample selected? random consecutive patients other not reported
26. What was the sampling frame? institution community other not reported
27. Was the survey instrument pre-tested? yes no not reported
28. If the survey instrument was pre-tested, was the instrument:
  | Yes | No | Not Clear | Not Reported | Not Applicable
  internally valid
  externally valid (content, concurrent, predictive, construct)
  reliable within a subject
  responsive (if appropriate)
29. What was the response rate to the survey? 80-100% 60-79% less than 50% not reported
30. Did the authors address specific hypotheses to be tested?

Ref ID#_________
Reviewers Initials_________

## Section IV: For studies about estimating the prevalence of acute or chronic pain, complete the next section

31. How was the sample selected? random consecutive patients other not reported
32. What was the sampling frame? institution community other not reported
33. If a survey, what was the response rate? 80-100% 60-79% less than 50% not reported
34. Indicate the prevalence