# Appendix D. Final Search Strategy for Primary Studies

Database: Medline <1966 - May 2000> Set Search | | Results
001 | exp spinal cord injuries/ | 16264
002 | spinal cord injur:.tw. | 7297
003 | spinal cord trauma:.tw. | 442
004 | spinal cord compression.tw. | 1674
005 | parapleg:.tw. | 5819
006 | quadripleg:.tw. | 1867
007 | tetrapleg:.tw. | 1392
008 | exp paraplegia/ | 6776
009 | quadriplegia/ | 4159
010 | neurologic: deterioration.tw. | 1207
011 | exp spinal cord/ | 46431
012 | exp wounds/ | 331681
013 | 11 and 12 | 3004
014 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 13 | 28974
015 | nociception.tw. | 1891
016 | (anaesthesia dolorosa or anesthesia dolorosa).tw. | 60
017 | hyperalgesia.tw. | 1854
018 | causalgia.tw. | 262
019 | exp hyperesthesia/ | 1399
020 | (hyperaesthesia or hyperesthesia).tw. | 274
021 | hypersensitivit:.tw. | 23726
022 | allodynia.tw. | 626
023 | causalgia/ | 318
024 | (post traumatic pain or posttraumatic pain).tw. | 78
025 | (dysesthe: pain or dysaesthe: pain).tw. | 41
026 | neuropath: pain.tw. | 903
027 | neurogen: pain.tw. | 114
028 | (phantom adj4 pain).tw. | 390
029 | paraplegic pain.tw. | 8
030 | central pain.tw. | 264
031 | chronic pain.tw. | 4576
032 | sci pain.tw. | 10
033 | deafferent:.tw. | 3069
034 | (central dysesthe: or central dysaesthe:).tw. | 5
035 | (pain adj4 spinal cord).tw. | 555
036 | (pain adj4 parapleg:).tw. | 114
037 | (spinal cord adj4 pain).tw. | 555
038 | or/15-34 | 36947
039 | 38 and 14 | 337
040 | 35 or 36 or 37 or 39 | 881
041 | limit 40 to human | 648
042 | 41 | 648