# Appendix C. Peer Reviewers for the Management of Chronic Central Neuropathic Pain Following Traumatic Spinal Cord Injury

## Criticism Editor

- Patricia Huston, MD, MPH. Scientific Communications International, Inc., Ottawa, Ontario

## Reviewers

- Willem JJ Assendelft MD, PhD. Department of General Practice, Division Public Health and Dutch Cochrane Centre, Academic Medical Centre -- University of Amsterdam, The Netherlands
- Michael Cousins, MD. Head, Department of Anaesthesia and Pain Management, University of Sydney, Australia
- Fred Cowell. Staff Director, Paralyzed Veterans of America (PVA), Policy Department, Washington, DC
- Matthew Elrod, PT, MEd. National Rehabilitation Hospital, American Physical Therapy Association (APTA), VA
- Allan Gordon, MD. Associate Professor, University of Toronto, Neurologist Director, Wasser Pain Centre, Mount Sinai Hospital, Toronto, Canada
- Neil A. Hagen M.D. Associate Professor, Departments of Oncology, Clinical Neurosciences and Medicine, University of Calgary; and Head, Cancer Pain Clinic, Tom Baker Cancer Centre, Calgary
- Claire E. Hulsebosch, Ph.D. Professor, Anatomy and Neurosciences, University of Texas Medical Branch, Galveston, TX
- Douglas Justins, M.D. Consultant in Pain Management and Anaesthesia, St. Thomas Hospital, London, United Kingdom
- Paul G. Loubser, M.D. Assistant Professor, Department of Anesthesiology, Baylor College of Medicine, Houston, TX
- Anthony J. Mariano, Ph.D. Codirector, Pain Clinic, Clinical Psychologist, Spinal Cord Injury Service, Puget Sound Veterans Adminstration Health System, Seattle, WA
- Harold Merskey, M.D. Professor Emeritus, Department of Psychiatry, University of Western Ontario, London, Ontario, Canada
- Louis Papastrat, MBA. Vice President, Medical Management for American Re-Insurance Company, Princeton, NJ
- Daniel Rohe, Ph.D. Associate Professor of Psychology, Mayo Medical School, MN
- Audrey J. Schmerzler, RN, MSN, CRRN. Mount Sinai Spinal Cord Injury Model System, Mount Sinai School of Medicine, New York, NY
- Paul Shekelle, M.D., Ph.D. RAND Health Program and the Veterans Affairs Health Services Research and Development Service, CA
- Richard A. Sherman, PhD. Consultant for Orthopedic Research, Madigan Army Medical Center, Tacoma, WA
- Ronald Tasker, MD. Toronto Western Hospital, Toronto, Canada
- Frances M. Weaver, PhD. Deputy Director, Midwest Center for Health Services & Policy Research, Hines VA Hospital and Research Associate Professor, Northwestern University, Hines, IL

## Partners

- Dawn M. Sexton, Project Administrator for CPGs, Consortium for Spinal Cord Medicine, Paralyzed Veterans of America, Washington, DC
- J. Paul Thomas, Consortium Coordinator, Consortium for Spinal Cord Medicine, Paralyzed Veterans of America, Washington, DC