# Appendix B. Personnel

## McMaster Research Team

Alejandro (Alex) Jadad, MD, DPhil (Task Order Leader): Dr. Jadad is a Professor in the Department of Clinical Epidemiology and Biostatistics, Director of the McMaster University Evidence-based Practice Centre, Chief of the Health Information Research Unit, Co-Director of the Canadian Cochrane Centre at McMaster University in Hamilton, Ontario, Canada. His clinical training is in anesthesiology, pain relief, and palliative care. Dr. Jadad has a Doctor of Philosophy degree in systematic reviews and meta-analyses in pain relief from the University of Oxford (Balliol College).

Dr. Jadad has extensive experience in the study and management of neuropathic pain. He has participated in RCTs on the role of opioids, NMDA receptor antagonists, and alpha-2-agonists during the management of neuropathic pain. He has also conducted systematic reviews on the effect of opioids, antidepressants, sympathetic blockades and anticonvulsants for the relief of neuropathic pain and reviewed the evidence on the prevalence and management of pain in long-term care facilities. In 1993, he was invited to present the best available knowledge on the management of neuropathic pain at the 7^th^ World Congress on Pain in Paris. He discussed the role of systematic reviews in pain relief and presented the database on the measurement of pain at the 8^th^ World Congress on Pain in Vancouver in 1996. He will lead the first refresher course on evidence-based decisionmaking at a World Congress on Pain in Vienna this year.

Dr. Jadad has also developed innovative methods to include consumers as members of the research team. His methods have enabled the development of the first validated tool to assess the quality of RCTs, the largest databases of RCTs and measurement tools in pain relief, the guide "A Team Approach to Pain Relief," tools for the development of consumer versions of clinical practice guidelines, questionnaires for the Internet surveys, and projects to improve the treatment of pain in nursing homes and the measurement of pain in general.

Mary Ann O'Brien, MSc (Task Order Coordinator): Ms. O'Brien is an Assistant Clinical Professor in the School of Rehabilitation Sciences at McMaster University. She has graduate training in the science of conducting systematic reviews and is a licensed physical therapist with extensive clinical experience in rehabilitation. She is a member of the Board of Examiners for the Canadian Physical Therapy Examination. She is also a member of the Cochrane Collaboration Effective Professional Practice and Organization of Care Review Group. Ms. O'Brien has extensive experience in coordinating the production of systematic reviews. Recently, she coordinated the production of 13 systematic reviews of public health interventions for the Ontario government. In addition, she is the author or coauthor of 10 systematic reviews in the areas of health professional behavior change, public health, and temporomandibular joint disorders.

Charles Goldsmith, PhD (Biostatistics): Dr. Goldsmith is a Professor and statistician in the Department of Clinical Epidemiology and Biostatistics and Associate Member of the Department of Mathematics and Statistics, McMaster University; and Head of Biostatistics, Father Sean O'Sullivan Research Centre, St. Joseph's Health Care System Research Network. He will lead and supervise the statistical aspects of the project. He is interested in the measurement of the attitudes of the public and in the study of the validity of diagnostic tests and has provided statistical input to the validation of measurement tools to assess the methodological quality of review articles and the functional status of patients with juvenile arthritis. He received the 1995 Founders Award of the American Statistical Association. In 1992 and 1998, he received the Silver Quill Award for Basic and Applied Research for his work on observer variation in an audit of charts of patients with rheumatoid arthritis and on the measurement of lumbar flexion, respectively.

Ann McKibbon, MLS (Library Sciences): Mrs. McKibbon is an Associate Professor in the Department of Clinical Epidemiology and Biostatistics. She is well known internationally for her expertise in searching and reviewing the medical literature and supervises the production of several evidence-based journals produced at McMaster, including Evidence-based Medicine, Evidence-based Mental Health, Evidence-based Nursing, Best Evidence, and ACP Journal Club. She implemented the first Canadian demonstration site of an online searching system for the Canadian Institute of Scientific and Technical Institute in 1973. Since then, she has collaborated on and led many research projects related to information retrieval. She has taught more than 2,000 physicians MEDLINE-searching skills and more than 1,000 health science librarians the basic principles of clinical epidemiology and how they apply to information retrieval. Her research on clinical informatics is published widely and used extensively by clinicians, teachers, researchers, and systematic reviewers. She is the author of the book, "PDQ Evidence-based Principles and Practice," published in 1999.

Gordon Guyatt, MD, FRCPC, MSc (Measurement Methodology): Dr. Guyatt is a Professor in the Departments of Medicine, and Clinical Epidemiology and Biostatistics, McMaster University. He is the person who coined the term "Evidence-based Medicine." He has written many systematic reviews and meta-analyses of different clinical topics in medicine and nursing on diagnosis, measurement, prognosis, and treatment. He has authored several landmark methods papers addressing key issues in measurement, RCTs, systematic reviews, and levels of evidence. He is Chair of the Evidence-based Medicine Working Group. From this role, he has written and/or edited the series of articles in JAMA called the Users' Guides to the Medical Literature, translated now into 11 languages.

Bernie O'Brien, PhD (Health Economics): Dr. O'Brien is an Associate Professor in the Department of Clinical Epidemiology and Biostatistics, Associate member of the Centre for Health Economics and Policy Analysis at McMaster University, and Associate Director of the Centre for Evaluation of Medicines at St. Joseph's Hospital. His work focuses on methods of economic evaluation as applied to new therapeutic interventions, particularly in the context of clinical trials. Other interests include decision analysis, measurement of health-related quality of life, pharmaceutical utilization, and risk assessment. He is a recipient of a PMAC Health Research Foundation -- Medical Research Council of Canada Career Award in Health Sciences (1995-2000).

Dean Wingerchuk, MD: Dr. Wingerchuk received his MD from the University of Saskatchewan. He performed his internship, neurology residency, and clinical neuroimmunology fellowship at the Mayo Clinic in Rochester, MN. Subsequently he has completed a multiple sclerosis fellowship at the University of Western Ontario and the MSc program in Health Research Methodology at McMaster University. As of July 2000, Dr. Wingerchuk will be the senior associate consultant (Mayo Clinic, Scottsdale, AZ) and Assistant Professor of Neurology (Mayo Medical School, Rochester, MN). His clinical and research interests are multiple sclerosis (MS), natural history of MS, and the use of databases for observational and experimental studies in MS.

Pamela Angle, MD, DABA, FRCP (C): Dr. Angle is an Assistant Professor at the Department of Anesthesia at Sunnybrook and Women's College Health Sciences Centre in Toronto. She is completing her Masters in Health Research Methodology at McMaster Univesity. Her special interests include obstetrical anesthesia.

Julian Mulcaster, MD, FRCP (C): Dr. Mulcaster is a Clinical Scholar, Pain Management, Department of Anaesthesia, McMaster University and Hamilton Health Sciences Corporation.

Carmen Tamayo, MD: Dr. Tamayo has an MD Degree from the Central University of Venezuela and a degree in Public Health from the University of Toronto. She has acted as a research advisor for the University of Texas Center for Alternative Medicine Research in Cancer (UT-CAM), a National Institute of Health (NIH)-funded exploratory research center associated with the National Cancer Institute and the National Center for Complementary and Alternative Medicine in the United States. She is currently director of the Complementary and Alternative Medicine Division of Foresight Links Corporation, a private consultanting firm engaged in data analysis and evidence-based medicine. She is involved in research development, clinical protocol design, and review of CAM proposals and related literature, developing and coordinating scientific protocols to assess the effectiveness of CAM therapies in clinical trials. She is presently involved with the Health Information Research Unit and the Canadian Center for Evidence-based Medicine at McMaster University in Hamilton, Ontario. Dr. Tamayo is a member of the College of Physicians in Venezuela, the Drug Information Association, the National Breast Cancer Coalition, and the Canadian Cochrane Collaboration.

Matthew Denkers: Mr. Denkers graduated in 1998 from McMaster University with a Bachelor's degree in Kinesiology with a Minor in Biology. He graduated from McMaster in September 2000 with a Bachelor of Health Sciences Degree (Physiotherapy). He has entered Medical School at McMaster.

Heather Biagi: Ms. Biagi completed a Bachelor of Physical Education (BPE) degree at the University of British Columbia and a Masters of Science (MSc) degree at the University of British Columbia where her area of research was on the effectiveness of bracing on knee osteoarthritis. She graduated in September 2000 as a Physiotherapist BHSc (PT). Her area of interest is Orthopedics/Sports Medicine.

Mary Gauld: Ms. Gauld is a Research Coordinator in the Department of Clinical Epidemiology and Biostatistics, McMaster University. She has participated in numerous systematic reviews, including the AHRQ Task Order on the Treatment of Attention-Deficit/Hyperactivity Disorder.

## Technical Expert Panel

Alexia Antzack-Bouckoms, DMD ScD MPH: Dr. Antzack-Bouckoms is the Co-Director of the New England Cochrane Centre and one of the Editors of the Cochrane Oral Health Group. She is a dentist with vast experience in systematic review methodology. She suffered spinal cord injury, has neuropathic pain, and has become a very active consumer representative, raising awareness about the importance of rigorous research on spinal cord injury.

Gary Bennett, PhD: Dr. Bennett is Professor, Department of Neurology, Director of Pain Research, and Director of the Quantitative Sensory Testing and Autonomic Nervous System Testing Laboratories, MCP Hahnemann University, Philadelphia, PA. He acted as Head, Neuropathic Pain and Pain Assessment Group, Neurobiology and Anesthesiology Branch, National Institute of Dental Research, NIH, Bethesda, MD, from 1990 to 1991, and as Chief, Neuropathic Pain and Pain Measurement Section, Neurobiology and Anesthesiology Branch, National Institute of Dental Research, NIH, Bethesda, MD, from 1991 to 1996. Dr. Bennett is one of the most productive basic researchers in the field of neuropathic pain in the world.

Daniel Carr, MD: Dr. Carr is Saltonstall Professor of Pain Research; Vice Chair for Research, Department of Anesthesiology, Tufts-New England Medical Center, Boston, MA. He has background and expertise in internal medicine, anesthesiology, pain relief, and basic research. He has an extensive research record in pain relief. From 1990 to 1992, Dr. Carr acted as Co-Chair of the USDHHS/AHCPR, Acute and Cancer Pain Management Guideline Panels. He is currently the lead editor within the Cochrane Pain, Palliative and Supportive Care (PaPas) Collaborative Review Group.

John Farrar, MD: Dr. Farrar is Adjunct Assistant Professor of Epidemiology and Anesthesia; and Senior Scholar, Center for Clinical Epidemiology & Biostatistics, University of Pennsylvania, Philadelphia, PA. He is a neurologist with strong methodological expertise, specifically on clinical and methodological issues related to the definition, diagnosis, and management of neuropathic pain.

Angela Mailis, MD, MSc, FRCPC: Dr. Mailis is Director, Comprehensive Pain Program and Pain Investigation Unit, The Toronto Hospital; Associate Professor, Department of Medicine, and Associate member of the Playfair Neuroscience Unit, University of Toronto, Canada. She is also Co-chair of the College of Physicians and Surgeons of Ontario Chronic Pain Task Force. Dr. Mailis is a physiatrist with a Master of Science degree in human spinal plasticity. She has spent most of her research career studying human neuropathic pain, human pain syndromes, the effect of demographics on pain, and adverse effects of invasive procedures for pain management. She is currently working on several systematic reviews as a member of the Cochrane PaPas Group.

Dwight Moulin, MD: Dr. Moulin is an Associate Professor, Clinical Neurological Sciences and Oncology, at the University of Western Ontario, London, Ontario. He is a member of the College of Physicians and Surgeons of Ontario Task Force on Management of Chronic Nonmalignant Pain. His main clinical and research interests are in pharmacological and nonpharmacological treatment of neuropathic pain.

Kenneth Parsons, MD: Dr. Parsons has served as the chairperson of the Consortium for Spinal Cord Medicine since its inception. He is the Director of the Spinal Cord Injury Program at the Institute for Rehabilitation and Research in Houston, TX, Vice-Chair of the Department of Physical Medicine and Rehabilitation at the University of Texas Medical School, as well as director of the residency program there. He is currently the President of the American Spinal Injury Association. Dr. Parsons' clinical activities frequently include the diagnosis and management of pain states in patients with SCI.

Russell K. Portenoy, MD: Chairman, Department of Pain Medicine and Palliative Care, Beth Israel Medical Center; Professor, Department of Neurology, Albert Einstein College of Medicine. Dr. Portenoy is the current President of the American Pain Society and Editor-in-Chief of the Journal of Pain and Symptom Management. He is a neurologist, has received multiple awards, and is the author of hundreds of articles on pain and its management.

Diana Rintala, PhD: Dr. Rintala is a Research Health Science Specialist at the Center of Excellence on Healthy Aging with a Disability at the Veterans Affairs Medical Center in Houston, TX. She has an appointment as an Associate Professor in the Department of Physical Medicine and Rehabilitation at the Baylor College of Medicine. She has a PhD with a minor in data analytic techniques, with a specific interest in the instruments used to measure pain and the evaluation of the cost implications of different therapies for neuropathic pain.

Christine N. Sang, MD, MPH: Dr. Sang is currently Director, Clinical Trials Program, and Assistant Professor of Anesthesia and Critical Care, Massachusetts General Hospital, Harvard Medical School. Her background is in anesthesiology, epidemiology, and biostatistics. The primary aim of her ongoing research is to study mechanisms of central and peripheral neuropathic pain, particularly after spinal cord injury, and the development and evaluation of dysesthetic pain following spinal cord injury. She currently holds a 5-year grant from the Paralyzed Veterans of America/Spinal Cord Research Foundation for clinical trials evaluating several pharmacological interventions and testing methods for pain after spinal cord injury.

Peter Tugwell, MD: Dr. Tugwell is Physician-in-Chief, Professor and Chairman, Department of Medicine, University of Ottawa; and Chair, Editorial Group of the Cochrane Collaborative Review Group for Musculoskeletal Disease. Dr. Tugwell has received many awards for his work on rheumatology and clinical epidemiology and has hundreds of publications in these areas.

Eldon Tunks, MD FRCP (C): Dr. Tunks is Professor, Department of Psychiatry, McMaster University; Director, Pain Program of the Hamilton Health Sciences Corporation; Co-Chair, College of Physicians and Surgeons of Ontario Task Force on the Management of Chronic Non-malignant Pain. Dr. Tunks was one of the founding members of the International Association for the Study of Pain and is the Associate Editor for Psychiatry for Pain Research and Management, the journal of the Canadian Pain Society. Dr. Tunks is actively involved in the development of evidence-based clinical practice guidelines on the management of chronic nonmalignant pain and has led the critical appraisal of all existing guidelines on this subject produced in North America.