# Appendix A. Consortium for Spinal Cord Medicine Member Organizations

The Consortium of Spinal Cord Medicine (CSCM), a group of 18 health professional organizations representing physicians, therapists, nurses, psychologists, and social workers, organized and supported by PVA, develops and disseminates clinical practice guidelines to professionals and consumers.

- American Academy of Orthopedic Surgeons
- American Academy of Physical Medicine and Rehabilitation
- American Association of Neurological Surgeons
- American Association of Spinal Cord Injury Nurses
- American Association of Spinal Cord Injury Psychologists and Social Workers
- American Congress of Rehabilitation Medicine
- American Occupational Therapy Association
- American Paraplegia Society
- American Physical Therapy Association
- American Psychological Association
- American Spinal Injury Association
- Association of Academic Physiatrists
- Association of Rehabilitation Nurses
- Congress of Neurological Surgeons
- Eastern Paralyzed Veterans Association
- Insurance Rehabilitation Study Group
- Paralyzed Veterans of America
- U.S. Department of Veterans Affairs