# Appendixes

Appendix A. Consortium for Spinal Cord Medicine Member Organizations

Appendix B. Personnel

Appendix C. Peer Reviewers for the Management of Chronic Central Neuropathic Pain Following Traumatic Spinal Cord Injury

Appendix D. Final Search Strategy for Primary Studies

Appendix E. Assessment and Natural History Study Form

Appendix F. Acronyms and Abbreviations