# Evidence Tables

Evidence Table 1-1. Study characteristics

A. ICS vs placebo (or no ICS)
Citation | Study Design | Study Setting | Asthma Severity | Eligibility
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Parallel, controlled; double-blinded; placebo; randomized | Country: Multicountry; Funding: Govt. grant and pharm. co. supplied meds; Tx Setting: Unknown/Other Multicenter | Stated: Mild-moderate Estimated: Mild-moderate | Patient eligibility based on lung function and symptoms; Methacholine PC20 maximum 12.5; elig: presence of symptoms, or use of inhaled bronchodilator at least twice weekly, or use of daily meds for asthma
Jonasson, Carlsen and Blomquist, 1998 | Randomized, parallel arm, double-blinded, placebo- controlled trial | Country: Scandinavia; Funding: Not specified; Tx Setting: Specialty care, university | Stated: Mild; Estimated: Mild | Eligibility based on symptoms only: At least three previous obstructive episodes or one obstructive episode with atopy. At least one obstructive episode within the last year Exclusions: ICS use within 2 mths; Cromolyn use within 4 wks; respiratory infection or asthma exacerbation requiring ER visit or hospitalization within 4 wks
Simons, Dolovich, Moote, et al., 1997 | Randomized, parallel arm, double-blinded, placebo- controlled trial | Country: Canada; Funding: Pharm. Ind., grant; Tx Setting: Unknown/Other; Multicenter | Stated: persistent; Estimated: Mild-moderate | Eligibility based on lung function, symptoms, utilization: FEV1 (prebronchodilator) minimum 70% predicted; at least 10% increase FEV1 postbronchodilator; Methacholine PC20 maximum 8 mg; Exclusions: ICS or oral steroids within 3 mths; more than 1 mth steroid use at any time; ER visits or hospitalizations for asthma within the last 3 mths; history of life-threatening asthma; adverse reactions to medications in study
Hoekstra, Grol, Hovenga, et al., 1998 | Randomized, parallel arm, double-blinded, placebo- controlled trial | Country: Netherlands; Funding: Pharm + government grant; Tx Setting: Primary/specialty combination, univ/non-univ | Stated: Moderate; Estimated: Mild-moderate | Eligibility based on lung function and symptoms; FEV1 (type not specified) minimum 75% of predicted; Histamine PC20 maximum 8 mg/mL; increase in FEV1 at least 10% postbronchodilator; perennial symptoms requiring maintenance treatment Exclusions: ICS use within 4 wks; oral steroids on more than three occasions within 6 mths.
Agertoft and Pedersen, 1994 | Parallel arm, controlled trial | Country: Scandinavia; Funding: Not specified; Tx Setting: Unknown/Other | Stated: Mild-moderate; Estimated: Mild-Severe | Eligibility based on utilization only: Attended clinic for at least three visits during previous year. Exclusions: ICS or oral steroid use for more than 2wks per year
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Randomized, parallel arm, double-blinded, placebo- controlled trial | Country: Netherlands; Funding: Other: government; Tx Setting: Unknown/Other: university/non-university; Multicenter | Stated: Not specified; Estimated: Mild-Severe | Eligibility based on lung function only: FEV1 (prebronchodilator) minimum 55% of predicted, maximum 90% of predicted; Increase in FEV1 at least 15% postbronchodilator; Histamine PC20 maximum 150mcg Exclusions: none stated
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Randomized, parallel arm, double-blinded, placebo- controlled trial | Country: United Kingdom; Funding: Academic grant; Tx Setting: Unknown/Other | Stated: Severe; Estimated: Unable to estimate | Eligibility based on symptoms and utilization: Unsatisfactory control of asthma, including hospital admissions within the past 6 months. Exclusions: none stated
Connett, Warde, Wooler, et al., 1993 | Randomized, parallel arm, double-blinded, placebo- controlled trial | Country: United Kingdom; Funding: Not specified; Tx Setting: Hospital inpatient | Stated: Severe; Estimated: Unable to estimate | Patient eligibility based on Symptoms only; Minimum 3 days/wk with symptoms during 2 wk run-in. History of troublesome asthma, responsive to bronchodilators Exclusions: tx with ICS or oral steroids in 2 weeks prior to 2 wk run-in
Verbene, Frost, Roorda, et al., 1997 | Randomized, parallel arm, double-blinded controlled trial | Country: Netherlands; Funding: Pharm. Ind., grant; Tx Setting: Unknown/Other: university/non-university; Multicenter | Stated: Mild-moderate; Estimated: Mild-moderate | Eligibility based on lung function and symptoms: FEV1 (prebronchodilator) minimum 55% predicted, maximum 90% predicted; Increase in FEV1 at least 10% postbronchodilator; Methacholine PC20 maximum 150 mcg; Exclusions: respiratory infection or exacerbation of asthma within 1 mth; ICS use within 6 mths; cromolyn use within 2 wk.
Simons, Dolovich, Moote, et al., 1997 | Randomized, parallel arm, double-blinded, placebo- controlled trial | Country: Canada; Funding: Pharm. Ind., grant; Tx Setting: Unknown/Other; Multicenter | Stated: persistent; Estimated: Mild-moderate | Eligibility based on lung function, symptoms, utilization: FEV1 (prebronchodilator) minimum 70% predicted; at least 10% increase FEV1 postbronchodilator; Methacholine PC20 maximum 8 mg; Exclusions: ICS or oral steroids within 3 mths; more than 1 mth steroid use at any time; ER visits or hospitalizations for asthma within the last 3 mths; history of life-threatening asthma; adverse reactions to medications in study
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Randomized, parallel arm, double-blinded, placebo-controlled trial | Country: USA; Funding: Pharm + Other (AAAI); Tx Setting: Unknown/Other; Multicenter | Stated: Mild-moderate; Estimated: Mild-Severe | Eligibility based on lung function and symptoms; FEV1 (prebronchodilator) minimum 50% of predicted; increase in FEV1 at least 15% postbronchodilator; episodes of dyspnea, cough and wheezing requiring bronchodilator treatment Exclusions: cigarette, cigar, pipe, marijuana smoking; respiratory infection within 3 wks; oral steroids within 1mth or more than 30 days in past 2 yrs; use of ICS and theophylline together for more than 1 mth in past year; regular cromolyn use within 60 days; nasal steroids within 30 days; receiving immunotherapy and not at maintenance dose; adverse reactions to ICS or theophylline in past; psychological, emotional disorder requiring treatment; substance abuse; females pregnant, lactating or sexually active not using reliable birth control
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Parallel, controlled; double-blinded; placebo; randomized | Country: Multicountry; Funding: Govt grant and pharm. co. supplied meds; Tx Setting: Unknown/Other Multicenter | Stated: Mild-moderate; Estimated: Unable to estimate | Patient eligibility based on Lung function and symptoms; Methacholine PC20 maximum 12.5; elig: presence of symptoms, or use of inhaled bronchodilator at least twice weekly, or use of daily meds for asthma

Evidence Table 1-2. Study parameters

A. ICS vs placebo (or no ICS)
Citation | Pretreatment | Study Arm | N enrolled | Treatment | Duration (weeks) | Comments
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | | Control | 418 | Placebo | 224 | to account for remission, doses could be tapered to a dose of zero according to specified guidelines.
Childhood Asthma Management Program Research Group, 2000a | | Exp 1 | 311 | 200 mcg budesonide 2x daily | 224 | to account for remission, doses could be tapered to a dose of zero according to specified guidelines.
Jonasson, Carlsen and Blomquist, 1998 | Run-in 2 weeks, to standardize treatment meds | Control | 40 | placebo | 12 | Not stated how patients with moderate/severe asthma were excluded
Jonasson, Carlsen and Blomquist, 1998 | Run-in 2 weeks, to standardize treatment meds | Exp 1 | 40 | 100 mcg budesonide 2x daily | 12 | Not stated how patients with moderate/severe asthma were excluded
Jonasson, Carlsen and Blomquist, 1998 | Run-in 2 weeks, to standardize treatment meds | Exp 2 | 42 | 200 mcg budesonide 1x daily | 12 | Not stated how patients with moderate/severe asthma were excluded
Jonasson, Carlsen and Blomquist, 1998 | Run-in 2 weeks, to standardize treatment meds | Exp 3 | 41 | 100 mcg budesonide 1x daily | 12 | Not stated how patients with moderate/severe asthma were excluded
Simons, Dolovich, Moote, et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Control | 55 | placebo | 52
Simons, Dolovich, Moote, et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 67 | 200 mcg beclomethasone dipropionate 2x daily | 52
Hoekstra, Grol, Hovenga, et al., 1998 | Run-in 2 weeks, to establish patient eligibility; Pre-treatment washout, 4 weeks | Control | 19 | placebo; all patients received 200 mcg albuterol (salbutamol) 2x daily | 12
Hoekstra, Grol, Hovenga, et al., 1998 | Run-in 2 weeks, to establish patient eligibility; Pre-treatment washout, 4 weeks | Exp 1 | 15 | 100 mcg fluticasone 2x daily; all patients received 200 mcg albuterol (salbutamol) 2x daily | 12
Agertoft and Pedersen, 1994 | Run-in 52 weeks, to establish patient eligibility | Control | 62 | not specified | 270.4 (mean) | Control patients were those patients who declined recommendation to take ICS. ICS-free period after diagnosis is referred to as the run-in period, equal to at least 1 year
Agertoft and Pedersen, 1994 | Run-in 52 weeks, to establish patient eligibility | Exp 1 | 216 | 800 mcg budesonide daily | 192.4 (mean) | Control patients were those patients who declined recommendation to take ICS. ICS-free period after diagnosis is referred to as the run-in period, equal to at least 1 year
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Run-in 2 weeks, to standardize treatment meds; Pretreatment washout, 4 weeks | Control | 58 | placebo; all patients received 200 mcg albuterol (salbutamol) 3x daily | 95.3 (median) | Pharmaceutical company supplied study medication
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Run-in 2 weeks, to standardize treatment meds; Pretreatment washout, 4 weeks | Exp 1 | 58 | 200 mcg budesonide 3x daily; all patients received 200 mcg albuterol (salbutamol) 3x daily | 95.3 (median) | Pharmaceutical company supplied study medication
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Run-in 2 weeks, to establish patient eligibility | Control | 14 | placebo | 26 | Study took place over an 18mth period in an attempt to eliminate seasonal bias.
Storr, Lenney and Lenney, 1986 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 15 | 100 mcg beclomethasone dipropionate 3x daily | 26 | Study took place over an 18mth period in an attempt to eliminate seasonal bias.
Connett, Warde, Wooler, et al., 1993 | Run-in 2 weeks, to establish patient eligibility; Pre-treatment washout, 4 weeks | Control | 20 | placebo | 26 | Patients treated for up to 6 months, included in analysis if treated at least 5 wks Study medication adjusted to between 200-400 mcg 2x/day budesonide or 1-2 puffs 2x/day placebo depending on clinical need
Connett, Warde, Wooler, et al., 1993 | Run-in 2 weeks, to establish patient eligibility; Pre-treatment washout, 4 weeks | Exp 1 | 20 | 100% received 200 mcg budesonide 2x daily | 26
B. ICS vs long-acting Beta-2 agonists
Verbene, Frost, Roorda, et al., 1997 | Run-in 6 weeks, to establish patient eligibility; Pretreatment washout, 6 weeks | Control | 32 | 50 mcg salmeterol 2x daily | 48
Verbene, Frost, Roorda, et al., 1997 | Run-in 6 weeks, to establish patient eligibility; Pretreatment washout, 6 weeks | Exp 1 | 35 | 200 mcg beclomethasone dipropionate 2x daily | 48
Simons, Dolovich, Moote, et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 67 | 200 mcg beclomethasone dipropionate 2x daily | 52
Simons, Dolovich, Moote, et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Exp 2 | 58 | 50 mcg salmeterol 2x daily | 52
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Run-in 4 weeks, to establish patient eligibility | Control | 93 | theophylline 2x daily, dose titrated to blood levels | 36
Tinkelman, Reed, Nelson, et al., 1993 | Run-in 4 weeks, to establish patient eligibility | Exp 1 | 102 | 84mcg beclomethasone dipropionate 4x daily | 36
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | | Control | 418 | placebo | 224 | to account for remission, doses could be tapered to a dose of zero according to specified guidelines
Childhood Asthma Management Program Research Group, 2000a | | Exp 2 | 312 | 8 mg nedocromil 2x daily | 224 | to account for remission, doses could be tapered to a dose of zero according to specified guidelines

Evidence Table 1-3. Population characteristics

A. ICS vs placebo (or no ICS)
Citation | Study Arm | Population Age (mean +/− SD) | % Male/Female | Avg Duration (Months) | % Atopic Patients | Baseline Lung Function Values | | Baseline Symptom Values
Citation | Study Arm | Population Age (mean +/− SD) | % Male/Female | Avg Duration (Months) | % Atopic Patients | FEV1 | PEF | Baseline Symptom Values
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Control | 9 (Mean) +/− 2.2 | 56.0 / 44.0 | 58.8 | | | | Episode-free days/month, 9.6 Nights/month with symptoms, 0.8
  94.2 +/− 14% pred (prebronchodilator)
  103 +/− 12% pred (postbronchodilator)
Childhood Asthma Management Program Research Group, 2000a | Bud | 9 (Mean) +/− 2.1 | 58.2 / 41.8 | 62.4 | | | | Episode-free days/month, 9.7 Nights/month with symptoms, 0.9
  93.6 +/− 14.4% pred (prebronchodilator)
  103 +/− 13% pred (postbronchodilator)
Jonasson, Carlsen and Blomquist, 1998 | Placebo | 9.6 | 67.5 / 32.5 | NR | 70.0 | | | NR
  102 +/− 14% pred (type not specified) | 237 +/− 63 L/min (am., home)
Jonasson, Carlsen and Blomquist, 1998 | Bud 1 | 10.2 | 65.0 / 35.0 | NR | 65.0 | | | NR
  105 +/− 14% pred (type not specified) | 260 +/− 86 L/min (a.m., home)
Jonasson, Carlsen and Blomquist, 1998 | Bud 2 | 10.0 | 54.8 / 45.2 | NR | 59.5 | | | NR
  101 +/− 11% pred (type not specified) | 272 +/− 81 L/min (a.m., home)
Jonasson, Carlsen and Blomquist, 1998 | Bud 3 | 9.8 | 75.6 / 24.4 | NR | 75.6 | | | NR
  103 +/− 12% pred (type not specified) | 245 +/− 71 L/min (a.m., home)
Simons, Dolovich, Moote, et al., 1997 | Placebo | 9.5 +/− 2.4 | 55.0 / 45.0 | NR | 35.0 | | | NR
  96 +/− 16% pred (type not specified) | 258 +/− 77 L/min (a.m., home)
Simons, Dolovich, Moote, et al., 1997 | Beclo | 9.6 +/− 2.6 | 59.0 / 41.0 | NR | 38.0 | | | NR
  92 +/− 13% pred (type not specified) | 268 +/− 86 L/min (a.m., home)
Hoekstra, Grol, Bouman, et al., 1996 | Placebo | 11 +/− 1.8 | 78.9 / 21.1 | NR | 100.0 | | | Daytime symptom score, 3.2 +/− 2.4 (scale, 0-32)
  88 +/− 11.7% pred (type not specified) | 310 +/− 91 L/min (a.m., home)
Hoekstra, Grol, Bouman, et al., 1996 | Flutic | 10.6 +/− 1.8 | 73.3 / 26.7 | NR | 100.0 | | | Daytime symptom score, 3.2 +/− 2.4 (scale, 0-32)
  92 +/− 12.4% pred (type not specified) | 322 +/− 54.7 L/min (a.m., home)
Agertoft and Pedersen, 1994 | Control | 6.1 | 74.2 / 25.8 | 42 | NR | | | NR
  79.2% pred (type not specified), | NR
Agertoft and Pedersen, 1994 | Bud | 6.2 | 68.5 / 31.5 | 44 | NR | | | NR
  81.3% pred (type not specified), | NR
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Placebo | 10.9 +/− 1.9 | 76.0 / 24.0 | NR | NR | | | Days/wk with symptoms, 2
  78.7 +/− 12.0% pred (prebronchodilator) | 278 +/− 63 L/min (a.m., home)
  95.5 +/− 11.3% pred (postbronchodilator)
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Bud | 11 +/− 1.9 | 72.0 / 28.0 | NR | NR | | | Days/wk with symptoms, 2
  75.7 +/− 10.8% pred (prebronchodilator) | 287 +/− 73 L/min (a.m., home)
  93.6 +/− 11.4% pred (postbronchodilator)
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Placebo | 3.4 +/− 1.5 | 71.4 / 28.6 | NR | NR | | | NR
  NR | NR
Storr, Lenney and Lenney, 1986 | Beclo | 3.6 +/− 1.2 | 53.3 / 46.7 | NR | NR | | | NR
  NR | NR
Connett, Warde, Wooler, et al., 1993 | Placebo | 1.9 +/− 0.5 | 75.0 / 25.0 | 15.6 | NR | | | Nighttime cough score, 0.8 +/− 0.4 (scale, 0-2)
  NR | NR
Connett, Warde, Wooler, et al., 1993 | Bud | 1.7 +/− 0.6 | 55.0 / 45.0 | 13.2 | NR | | | Nighttime cough score, 0.9 +/− 0.5 (scale, 0-2)
  NR | NR
B. ICS vs long-acting Beta-2 agonists
Verbene, Frost, Roorda, et al., 1997 | Salmet | 10.6 +/− 2.9 | 71.9 / 28.1 | 79.2 | 100.0 | | | Days/wk with symptoms, 3; Nights/wk with symptoms, 3.5
  82.0 +/− 13.9% pred (prebronchodilator) | 297 +/− 96 L/min (a.m., home)
  99.2 +/− 13.8% pred | (postbronchodilator)
Verbene, Frost, Roorda, et al., 1997 | Beclo | 10.5 +/− 2.3 | 62.9 / 37.1 | 75.6 | 82.9 | | | Days/wk with symptoms, 3; Nights/wk with symptoms, 3
  84.4 +/− 16.7% pred (prebronchodilator) | 284 +/− 69 L/min (a.m., home)
  99.2 +/− 15.3% pred (postbronchodilator)
Simons, Dolovich, Moote, et al., 1997 | Beclo | 9.6 +/− 2.6 | 59.0 / 41.0 | NR | 38.0 | | | NR
  92 +/− 13% pred (type not specified) | 268 +/− 86 L/min (a.m., home)
Simons, Dolovich, Moote, et al., 1997 | Salmet | 8.8 +/− 2.1 | 60.0 / 40.0 | NR | 45.0 | | | NR
  95 +/− 13% pred (type not specified) | 246 +/− 63 L/min (a.m., home)
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Theo | 11.9 +/− 2.8 | 69.9 / 30.1 | NR | NR | | | Daytime symptom score, 1.1 +/− 0.9 (scale, 0-6); % patients with sx score >4, 55.4
  74.2 +/− 13% pred (prebronchodilator) | 86 +/− 19% pred (a.m., home)
  93 +/− 12% pred (postbronchodilator)
Tinkelman, Reed, Nelson, et al., 1993 | Beclo | 11.9 +/− 2.7 | 55.9 / 44.1 | NR | NR | | | Daytime symptom score, 1.1 +/− 0.8 (scale, 0-6); % patients with sx score >4, 54.9
  74.1 +/− 13% pred (prebronchodilator) | 87 +/− 20% pred (a.m., home)
  94 +/− 14% pred (postbronchodilator)
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Control | 9 (Mean) +/− 2.2 | 56.0 / 44.0 | 58.8 | | | | Episode-free days/month, 9.6; Nights/month with symptoms, 0.8
  103 +/− 12% predicted (Type Postdose)
Childhood Asthma Management Program Research Group, 2000a | Exp 2 | 8.8 (Mean) +/− 2.1 | 66.0 / 34.0 | 60 | | | | Episode-free days/month, 9.9; Nights/month with symptoms, 1
  102 +/− 12% pred (Type Postdose),

Evidence Table 1-4. Lung function outcomes: FEV1

A. ICS vs placebo (or no ICS)
Citation | Study Arm | # Enrolled | # Evaluable | Duration (weeks) | FEV1 Baseline (mean +/− SD) | FEV1 Final (mean +/− SD) | p Value | Comments
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | 94.2 +/− 14% pred (prebronchodilator) 103 +/− 12% pred (postbronchodilator) | 0.9 (Mean change) % pred −0.1 (Mean change) % pred | | SD for change in FEV1 estimated for entire population from regression model: 9.6% predicted for postbronchodilator FEV1; 11.2% predicted for prebronchodilator FEV1
Childhood Asthma Management Program Research Group, 2000a | Exp 1 | 311 | 306 | 224 | 93.6 +/− 14.4% pred (prebronchodilator) 103 +/− 13% pred (postbronchodilator) | 2.9 (Mean change) % pred 0.6 (Mean change) % pred | =0.02 NS ^a^ | SD for change in FEV1 estimated for entire population from regression model: 9.6% predicted for postbronchodilator FEV1; 11.2% predicted for prebronchodilator FEV1
Jonasson, Carlsen and Blomquist, 1998 | Placebo | 40 | 40 | 12 | 102 +/− 14% pred (type not specified) | NR | | Difference in FEV1 Bud 1 vs Bud 2 4.1%, p=0.035 in favor of Bud 1
Jonasson, Carlsen and Blomquist, 1998 | Bud 1 | 40 | 40 | 12 | 105 +/− 14% pred (type not specified) | NR (5.2% pred greater than control group) | =0.0080 ^a^ | Difference in FEV1 Bud 1 vs Bud 2 4.1%, p=0.035 in favor of Bud 1
Jonasson, Carlsen and Blomquist, 1998 | Bud 2 | 42 | 42 | 12 | 101 +/− 11% pred (type not specified) | NR | NS ^a^ | Difference in FEV1 Bud 1 vs Bud 2 4.1%, p=0.035 in favor of Bud 1
Jonasson, Carlsen and Blomquist, 1998 | Bud 3 | 41 | 41 | 12 | 103 +/− 12% pred (type not specified) | NR | NS ^a^ | Difference in FEV1 Bud 1 vs Bud 2 4.1%, p=0.035 in favor of Bud 1
Simons, Dolovich, Moote, et al., 1997 | Placebo | 80 | 55 | 52 | 96 +/− 16% pred (type not specified) | 101% pred ^d^ (reported as 5% pred mean improvement)
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | 92 +/− 13% pred (type not specified) | 102 % pred ^d^ (reported as 10% pred mean improvement) | =0.0010 ^a^
Hoekstra, Grol, Bouman, et al., 1996 | Placebo | 19 | 15 | 12 | 88 +/− 11.7% pred (type not specified) | 90 +/− 10.2% pred
Hoekstra, Grol, Bouman, et al., 1996 | Flutic | 15 | 15 | 12 | 92 +/− 12.4% pred (type not specified) | 101 +/− 13.3% pred | <0.0500 ^c^
Agertoft and Pedersen, 1994 | Control | 62 | NR | 270.4 | 79.2% pred (type not specified) | 84.7% pred ^d^ (Reported as 7% increase from baseline (95%CI, (−3), 17)
Agertoft and Pedersen, 1994 | Bud | 216 | NR | 192.4 | 81.3 (mean) % pred (type not specified) | 101.6 % pred ^d^ (Reported as 25% increase from baseline (95%CI, 20, 30) | <0.0010 ^b^
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Placebo | 58 | 17 | 95.3 | 78.7 +/− 12% pred (prebronchodilator) 95.5 +/− 11.3% pred (postbronchodilator) | 80 +/− 16.5% pred (prebronchodilator) 95 +/− 15.2% pred (postbronchodilator) | | Statistically significant differences in favor of ICS group reported at intermediate time points.
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Bud | 58 | 29 | 95.3 | 75.7 +/− 10.8% pred (prebronchodilator) 93.6 +/− 11.4% pred (postbronchodilator) | 87 +/− 10.8% pred (prebronchodilator) 99 +/− 15.2% pred (postbronchodilator) | NR for final time point values | Statistically significant differences in favor of ICS group reported at intermediate time points.
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Placebo | 14 | | 26 | NR | NR
Storr, Lenney and Lenney, 1986 | Beclo | 15 | | 26 | NR | NR
Connett, Warde, Wooler, et al., 1993 | Placebo | 20 | 19 | 26 | NR | NR
Connett, Warde, Wooler, et al., 1993 | Bud | 20 | 17 | 26 | NR | NR
B. ICS vs long-acting Beta-2 agonist
Verbene, Frost, Roorda, et al., 1997 | Salmet | 32 | 25 | 48 | 85.6 +/− 15% pred (prebronchodilator) 100.8 +/− 10.9% pred (postbronchodilator) | 83.0 +/− 15.0% pred 97.5 +/− 12.5% pred
Verbene, Frost, Roorda, et al., 1997 | Beclo | 35 | 32 | 48 | 86.3 +/− 13.6% pred (prebronchodilator) 99.2 +/− 15.3% pred (postbronchodilator) | 95 +/− 15.0% pred (prebronchodilator) 102.5 +/− 12.5% pred (postbronchodilator) | <0.0001 ^a^ =0.0070 ^a^
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | 92 +/− 13% pred (type not specified) | 102% ^d^ (reported as 10% pred mean improvement)
Simons, Dolovich, Moote, et al., 1997 | Salmet | 80 | 58 | 52 | 95 +/− 13% pred | 105% ^d^ (reported as 10% pred mean improvement) | NR
Tinkelman, Reed, Nelson, et al., 1993 | Theo | 93 | 69 | 36 | 74.2 +/− 13% pred (prebronchodilator) 93 +/− 12% pred (postbronchodilator) | 87 +/− 20% pred (prebronchodilator) 91 +/− 16% pred (postbronchodilator)
Tinkelman, Reed, Nelson, et al., 1993 | Beclo | 102 | 76 | 36 | 74.1 +/− 13% pred (prebronchodilator) 94 +/− 14% pred (postbronchodilator) | 85 +/− 19% pred (prebronchodilator) 93 +/− 17% pred (postbronchodilator) | NS ^a^ NS ^a^
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | 103 +/− 12% pred (Type Postdose) | −0.1 (Mean change) % pred
Childhood Asthma Management Program Research Group, 2000a | Exp 2 | 312 | 307 | 224 | 102 +/− 12% pred (Type Postdose) | −0.5 (Mean change) % pred | NS ^a^

a Statistical significance determined by comparing the absolute change in outcomes from baseline to final time point between groups.

b Statistical significance determined by comparing the percent change in outcomes from baseline to final time point between groups.

c Statistical significance determined by comparing the absolute value in outcomes at the final time point between groups.

d Calculated value.

Evidence Table 1-5. Lung function outcomes: PEF

A. ICS vs placebo (or no ICS)
Citation | Study Arm | # Enrolled | # Evaluable | Treatment Duration (weeks) | PEF Baseline (type) | PEF Final | p Value | Comments
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | | 132 (Mean change) L/min (a.m. home)
Childhood Asthma Management Program Research Group, 2000a | Exp 1 | 311 | 306 | 224 | | 131 (Mean change) L/min (a.m., home) | NS ^a^
Jonasson, Carlsen and Blomquist, 1998 | Placebo | 40 | 40 | 12 | 237 +/− 63 L/min (a.m., home) | NR | | NS differences in pre- and post- PEF results between experimental groups
Jonasson, Carlsen and Blomquist, 1998 | Bud 1 | 40 | 40 | 12 | 260 +/− 86 L/min (a.m., home) | NR (Reported as 5.8 L/min greater than control) (95% CI, (−8.1)-19.7) | NS ^a^ | NS differences in pre- and post- PEF results between experimental groups
Jonasson, Carlsen and Blomquist, 1998 | Bud 2 | 42 | 42 | 12 | 272 +/− 81 L/min (a.m., home) | NR (Reported as 2.9 L/min greater than control) (95% CI, (−11.0)−16.7) | NS ^a^ | NS differences in pre- and post- PEF results between experimental groups
Jonasson, Carlsen and Blomquist, 1998 | Bud 3 | 41 | 41 | 12 | 245 +/− 71 L/min (a.m., home) | NR (Reported as 3 L/min greater than control) (95% CI, (−10.8)−16.8) | NS ^a^ | NS differences in pre- and post- PEF results between experimental groups
Simons, Dolovich, Moote, et al., 1997 | Placebo | 80 | 55 | 52 | 258 +/− 77 L/min (a.m., home) | 283 ^d^ (Reported as 25 L/min change from baseline)
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | 268 +/− 86 L/min (a.m., home) | 303 ^d^ (Reported as 35 L/min change from baseline) | =0.0200 ^a^
Hoekstra, Grol, Bouman, et al., 1996 | Placebo | 19 | 15 | 12 | 310 +/− 91 L/min (a.m., home) | 328 +/− 80 L/min
Hoekstra, Grol, Bouman, et al., 1996 | Flutic | 15 | 15 | 12 | 322 +/− 54.7 L/min (a.m., home) | 365 +/− 47.2 L/min | =0.0003 ^a^
Agertoft and Pedersen, 1994 | Control | 62 | | 270.4 | NR | NR
Agertoft and Pedersen, 1994 | Bud | 216 | | 192.4 | NR | NR
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Placebo | 58 | 17 | 95.3 | 278 +/− 63 L/min (a.m., home) | 345 +/− 114.2 L/min
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Bud | 58 | 29 | 95.3 | 287 +/− 73 L/min (a.m., home) | 380 +/− 228.5 L/min | NR at final time point
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Placebo | 14 | | 26 | NR | NR
Storr, Lenney and Lenney, 1986 | Beclo | 15 | | 26 | NR | NR
Connett, Warde, Wooler, et al., 1993 | Placebo | 20 | 19 | 26 | NR | NR
Connett, Warde, Wooler, et al., 1993 | Bud | 20 | 17 | 26 | NR | NR
B. ICS vs long-acting Beta-2 agonist
Verbene, Frost, Roorda, et al., 1997 | Salmet | 32 | 25 | 48 | 297 +/− 96 L/min (a.m., home) | 345.8 ^d^ (Reported as 48.8 L/min mean increase in PEF) (95% CI, 29.8, 67.8)
Verbene, Frost, Roorda, et al., 1997 | Beclo | 35 | 32 | 48 | 284 +/− 69 L/min (a.m., home) | 344.9 ^d^ (Reported as 60.9 L/min mean increase in PEF) (95% CI, 49.9, 71.9) | NS ^c^
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | 268 +/− 86 L/min (a.m., home) | 303 ^d^ (Reported as 35 L/min change from baseline) | NR
Simons, Dolovich, Moote, et al., 1997 | Salmet | 80 | 58 | 52 | 246 +/− 63 L/min (a.m., home) | 287 ^d^ (Reported as 41 L/min change from baseline) | NR
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Theo | 93 | 69 | 36 | 86 +/− 19% pred (a.m., home) | 88 +/− 16% pred
Tinkelman, Reed, Nelson, et al., 1993 | Beclo | 102 | 76 | 36 | 87 +/− 20% pred (a.m., home) | 93 +/− 20% pred | NS ^c^
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | | 132 (Mean change) L/min (a.m. home)
Childhood Asthma Management Program Research Group, 2000a | Exp 2 | 312 | 307 | 224 | | 131 (Mean change) L/min (a.m. home) | NS ^a^

a Statistical significance determined by comparing the absolute change in outcomes from baseline to final time point between groups.

b Statistical significance determined by comparing the percent change in outcomes from baseline to final time point between groups.

c Statistical significance determined by comparing the absolute value in outcomes at the final time point between groups.

d Calculated value

Evidence Table 1-6. Lung function outcomes: PC20

A. ICS vs placebo (or no ICS)
Citation | Study Arm | # Enrolled | # Evaluable | Duration (weeks) | PC20 Baseline | PC20 Final | p value | Comments
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | 1.1 +/− 3.3 | 1.9 Methacholine
Childhood Asthma Management Program Research Group, 2000a | Exp 1 | 311 | 306 | 224 | 1.1 +/− 3.3 | 3.0 Methacholine | <0.0010 ^a^
Jonasson, Carlsen and Blomquist, 1998 | Placebo | 40 | 40 | 12 | 3.02 mcmol (Mean) methacholine
Jonasson, Carlsen and Blomquist, 1998 | Bud 1 | 40 | 40 | 12 | 3.67 mcmol (Mean) methacholine | 156% methacholine (95% CI, 101.5-239.5) | =0.0400 ^d^
Jonasson, Carlsen and Blomquist, 1998 | Bud 2 | 42 | 42 | 12 | 4.14 mcmol (Mean) methacholine | 107% methacholine (95% CI, 70-163.5) | NS ^d^
Jonasson, Carlsen and Blomquist, 1998 | Bud 3 | 41 | 41 | 12 | 3.74 mcmol (Mean) methacholine | 121% methacholine (95% CI, 78.3-186.7) | NS ^d^
Simons, Dolovich, Moote, et al., 1997 | Placebo | 80 | 55 | 52 | 0.83 mg/mL (Mean) Methacholine | 1.4 mg/mL Methacholine
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | 0.83 mg/mL (Mean) Methacholine | 2.2 mg/mL Methacholine | =0.0040 ^a^
Hoekstra, Grol, Bouman, et al., 1996 | Placebo | 19 | 15 | 12 | 0.89 DD Histamine +/− 1.62 | 1.92 DD Histamine +/− 1.52
Hoekstra, Grol, Bouman, et al., 1996 | Flutic | 15 | 15 | 12 | 1.17 DD Histamine +/− 1.085 | 3.15 DD Histamine +/− 1.24 | =0.0150 ^c^
Agertoft and Pedersen, 1994 | Control | 62 | | 270.4
Agertoft and Pedersen, 1994 | Bud | 216 | | 192.4
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Placebo | 58 | 17 | 95.3 | 21.5 mcg (Mean) Histamine | 25 mcg Histamine +/− 53.3
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Bud | 58 | 29 | 95.3 | 21.5 mcg (Mean) Histamine | 80 mcg Histamine +/− 114.2 | <0.0001 ^c^
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Placebo | 14 | | 26
Storr, Lenney and Lenney, 1986 | Beclo | 15 | | 26
Connett, Warde, Wooler, et al., 1993 | Placebo | 20 | 19 | 26 | NR | NR
Connett, Warde, Wooler, et al., 1993 | Bud | 20 | 17 | 26 | NR | NR
B. ICS vs long-acting Beta-2 agonist
Verbene, Frost, Roorda, et al., 1997 | Salmet | 32 | 25 | 48 | 18 mcg (median) Methacholine | +2.02 DD Methacholine (95% CI, 1.26, 2.78)
Verbene, Frost, Roorda, et al., 1997 | Beclo | 35 | 32 | 48 | 20.5 mcg (median) Methacholine | −0.73 DD Methacholine (95% CI, −1.46, 0) | <0.0001 ^a^
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | 0.83 mg/mL (Mean) Methacholine | 2.2 mg/mL Methacholine | =0.02
Simons, Dolovich, Moote, et al., 1997 | Salmet | 80 | 58 | 52 | 0.76 mg/mL (Mean) Methacholine | 1.6 mg/mL Methacholine
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Theo | 93 | 69 | 36 | 5.01 mcg/mL (Mean) Methacholine | 8.71 mcg/mL Methacholine
Tinkelman, Reed, Nelson, et al., 1993 | Beclo | 102 | 76 | 36 | 5.75 mcg/mL (Mean) Methacholine | 14.79 mcg/mL Methacholine | NS ^c^
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | 1.1 +/− 3.3 | 1.9 Methacholine
Childhood Asthma Management Program Research Group, 2000a | Exp 2 | 312 | 307 | 224 | 1.2 +/− 3.3 | 1.8 Methacholine | NS ^a^

a Statistical significance determined by comparing the absolute change in outcomes from baseline to final time point between groups.

b Statistical significance determined by comparing the percent change in outcomes from baseline to final time point between groups.

c Statistical significance determined by comparing the absolute value in outcomes at the final time point between groups.

d Statistical significance determined by comparing the 'treatment effect ratio' between groups.

Evidence Table 1-7. Symptom score outcomes

A. ICS vs placebo (or no ICS)
Citation | Study Arm | # Enrolled | # Evaluable | Treatment Duration (weeks) | Baseline Daytime Symptom Score | Final Daytime Symptom Score | p Value | Final Nighttime Symptom Score | p Value | Comments
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | | −0.37 (Mean change; scale, 0-3)
Childhood Asthma Management Program Research Group, 2000a | Exp 1 | 311 | 306 | 224 | | −0.44 (Mean change; scale, 0-3) | =0.0050 ^a^
Jonasson, Carlsen and Blomquist, 1998 | Placebo | 40 | | | | | | | | Difference in SxScoreNight and SxFreqNight Exp2 vs Exp 3 −0.11, p=0.040. Other comparisons of symptom scores not reported
Jonasson, Carlsen and Blomquist, 1998 | Bud 1 | 40 | 40 | 12 | | | NS ^a^ | −0.11 (Mean; scale, 0-3) | =0.0470 ^a^ | Difference in SxScoreNight and SxFreqNight Exp2 vs Exp 3 −0.11, p=0.040. Other comparisons of symptom scores not reported
Jonasson, Carlsen and Blomquist, 1998 | Bud 2 | 42 | 42 | 12 | | | NS ^a^ | | NS ^a^ | Difference in SxScoreNight and SxFreqNight Exp2 vs Exp 3 −0.11, p=0.040. Other comparisons of symptom scores not reported
Jonasson, Carlsen and Blomquist, 1998 | Bud 3 | 41 | 41 | 12 | | | NS ^a^ | | NS ^a^ | Difference in SxScoreNight and SxFreqNight Exp2 vs Exp 3 −0.11, p=0.040. Other comparisons of symptom scores not reported
Simons, Dolovich, Moote, et al., 1997 | Placebo | 80 | 55 | 52 | | | | | | 66% pts in control with no school missed due to asthma vs 81% in ICS group, statistical tests not given.
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | | | | | | 66% pts in control with no school missed due to asthma vs 81% in ICS group, statistical tests not given.
Hoekstra, Grol, Bouman, et al., 1996 | Placebo | 19 | 15 | 12 | 3.2 +/− 2.4 (scale, 0-32) | 1.84 +/− 1.86, (scale, 0-32) | | | | The number of school absence days was small in both groups and not significantly different.
Hoekstra, Grol, Bouman, et al., 1996 | Flutic | 15 | 15 | 12 | 3.2 +/− 2.4 (scale, 0-32) | 1.92 +/− 2.45, (scale, 0-32) | NS ^c^ | | | The number of school absence days was small in both groups and not significantly different.
Agertoft and Pedersen, 1994 | Control | 62
Agertoft and Pedersen, 1994 | Bud | 216
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Placebo | 58 | 17 | 95.3 | | | | | | 47% of control pts, 61% of ICS pts with no symptoms in 2 wks, statistical tests not reported.
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Bud | 58 | 29 | 95.3 | | | | | | 47% of control pts, 61% of ICS pts with no symptoms in 2 wks, statistical tests not reported.
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Placebo | 14 | 13 | 26 | | 0.33 (Mean; scale, 0-3) | | 0.35 (Mean; scale, 0-3) | | Symptoms reported for wheeze subscores. For cough, % symptom-free days, % symptom-free nights, NS differences between groups
Storr, Lenney and Lenney, 1986 | Beclo | 15 | 15 | 26 | | 0.26 (Mean; scale, 0-3) | <0.0500 ^c^ | 0.26 (Mean; scale, 0-3) | <0.0500 ^c^ | Symptoms reported for wheeze subscores. For cough, % symptom-free days, % symptom-free nights, NS differences between groups
Connett, Warde, Wooler, et al., 1993 | Placebo | 20 | 19 | 26 | 0.8 +/− 0.4 (scale, 0-2) | 0.05 +/− 0.15, mean change (scale, 0-2) | | 0.07 +/− 0.18, (scale, 0-2) | | Symptom scores refer to cough; Other sx change score (pl vs bud): daytime wheezing, 0.1+/−0.15 vs −0.15+/−0.15, p NS; nighttime wheezing, 0.1+/−0.2 vs −0.2+/−0.15, p NS; limited activity d/wk, 0.26+/−2.26 vs −0.71+/−1.76, p NS
Connett, Warde, Wooler, et al., 1993 | Bud | 20 | 17 | 26 | 0.9 +/− 0.5 (scale, 0-2) | −0.5 +/− 0.2, mean change (scale, 0-2) | <0.03 ^a^ | −0.4 +/− 0.2, (scale, 0-2) | <0.05 ^a^
B. ICS vs long-acting Beta-2 agonists
Verbene, Frost, Roorda, et al., 1997 | Salmet | 32 | 25 | 54 | | | | | | Symptoms reported as % of pts with no symptoms during 2 week period. Difference in symptoms was "only significant at some time points" in favor of ICS
Verbene, Frost, Roorda, et al., 1997 | Beclo | 35 | 32 | 54 | | | | | | Symptoms reported as % of pts with no symptoms during 2 week period. Difference in symptoms was "only significant at some time points" in favor of ICS
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | | | | | | 81% pts in ICS group with no school missed due to asthma vs 88% in salmeterol group, statistical tests not given.
Simons, Dolovich, Moote, et al., 1997 | Salmet | 80 | 58 | 52 | | | | | | 81% pts in ICS group with no school missed due to asthma vs 88% in salmeterol group, statistical tests not given.
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Theo | 93 | 69 | 52 | 1.1 +/− 0.9 (scale, 0-6) | 0.7 +/− 0.8, (scale, 0-6) | | | | Assessed change in mean daily symptom scores during first and last 6 mths - difference in slopes in favor of BDP p<0.001
Tinkelman, Reed, Nelson, et al., 1993 | Beclo | 102 | 76 | 52 | 1.1 +/− 0.8 (scale, 0-6) | 0.8 +/− 0.9, (scale, 0-6) | NS ^c^ | | | Assessed change in mean daily symptom scores during first and last 6 mths - difference in slopes in favor of BDP p<0.001
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | | −0.37 (Mean; scale, 0-3)
Childhood Asthma Management Program Research Group, 2000a | Exp 2 | 312 | 307 | 224 | | −0.38 (Mean; scale, 0-3) | NS ^a^

a statistical significance determined by comparing the absolute change in outcomes from baseline to final time point between groups

b statistical significance determined by comparing the percent change in outcomes from baseline to final time point between groups

c statistical significance determined by comparing the absolute value in outcomes at the final time point between groups

d statistical significance determined by comparing the 'treatment effect ratio' between groups

Evidence Table 1-8. Symptom frequency and exacerbation outcomes

A. ICS vs placebo (or no ICS)
Citation | Study Arm | # Enrolled | # Evaluable | Treatment Duration (weeks) | Baseline Daytime Symptom Frequency | Final Daytime Symptom Frequency | p Value | Baseline Nighttime Symptom Frequency | Final Nighttime Symptom Frequency | p Value
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | Episode-free days/month, 9.6 | Episode-free days/month, 18.9 | | Nights/month with symptoms, 0.8 | Nights/month with symptoms, 0.2
Childhood Asthma Management Program Research Group, 2000a | Exp 1 | 311 | 306 | 224 | Episode-free days/month, 9.7 | Episode-free days/month, 21.0 | =0.0100 ^a^ | Nights/month with symptoms, 0.9 | Nights/month with symptoms, 0.2 | NS ^a^
Jonasson, Carlsen and Blomquist, 1998 | Placebo | 40
Jonasson, Carlsen and Blomquist, 1998 | Bud 1 | 40 | 40 | 12
Jonasson, Carlsen and Blomquist, 1998 | Bud 2 | 42 | 42 | 12 | | | | | Nights/week without symptoms, −0.11 | =0.0470 ^c^
Jonasson, Carlsen and Blomquist, 1998 | Bud 3 | 41 | 41 | 12
Simons, Dolovich, Moote, et al., 1997 | Placebo | 80 | 55 | 52 | | % rescue-free days, 83 | | | % symptom-free nights, 99%
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | | % rescue-free days, 92 | <0.0010 ^c^ | | % symptom-free nights, 99% | NS
Hoekstra, Grol, Bouman, et al., 1996 | Placebo | 19 | 15 | 12
Hoekstra, Grol, Bouman, et al., 1996 | Flutic | 15 | 15 | 12
Agertoft and Pedersen, 1994 | Control | 62
Agertoft and Pedersen, 1994 | Bud | 216
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Placebo | 58 | 17 | 95.3 | Days/wk with symptoms, 2 | Days/wk with symptoms, 2
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Bud | 58 | 29 | 95.3 | Days/wk with symptoms, 2 | Days/wk with symptoms, 0 | NS ^c^
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Placebo | 14 | 13 | 26 | | % symptom-free days, 75 | | | % symptom-free nights, 74
Storr, Lenney and Lenney, 1986 | Beclo | 15 | 15 | 26 | | % symptom-free days, 79 | NS ^c^ | | % symptom-free nights, 80 | NS ^c^
Connett, Warde, Wooler, et al., 1993 | Placebo | 20 | 19 | 26 | | % symptom-free days, 31
Connett, Warde, Wooler, et al., 1993 | Bud | 20 | 17 | 26 | | % symptom-free days, 54 | <0.0001
B. ICS vs long-acting Beta-2 agonists
Verbene, Frost, Roorda, et al., 1997 | Salmet | 32 | 25 | 54 | Days/wk with symptoms, 3 | % pts with no symptoms, 36 | | Nights/week with symptoms, 3.5
Verbene, Frost, Roorda, et al., 1997 | Beclo | 35 | 32 | 54 | Days/wk with symptoms, 3 | % pts with no symptoms, 55 | | Nights/week with symptoms, 3
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | 52 | | % rescue-free days, 92 | | | % symptom-free nights, 99 | NS, outcomes compared by
Simons, Dolovich, Moote, et al., 1997 | Salmet | 80 | 58 | 52 | | % rescue-free days, 88 | NR | | % symptom-free nights, 99 | NS, outcomes compared by
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Theo | 93 | 69 | 52 | % patients with sx score > 4, 55.4 | % pts with score > 4, 25.8
Tinkelman, Reed, Nelson, et al., 1993 | Beclo | 102 | 76 | 52 | % patients with sx score >4, 54.9 | % pts with score > 4, 37.3 | NS ^c^
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 224 | Episode Free days/month, 9.6 | Episode Free days/month, 9.3 | | Nights/month with symptoms, 0.8 | Nights/month with symptoms, −0.6
Childhood Asthma Management Program Research Group, 2000a | Exp 2 | 312 | 307 | 224 | Episode Free days/month, 9.9 | Episode Free days/month, 9.3 | NS ^a^ | Nights/month with symptoms, 1 | Nights/month with symptoms, −0.6 | NS ^a^

a Statistical significance determined by comparing the absolute change in outcomes from baseline to final time point between groups.

b Statistical significance determined by comparing the percent change in outcomes from baseline to final time point between groups.

c Statistical significance determined by comparing the absolute value in outcomes at the final time point between groups.

d Statistical significance determined by comparing the 'treatment effect ratio' between groups.

Evidence Table 1-9. Medication use outcomes

A. ICS vs placebo (or no ICS)
Citation | Study Arm | # Enrolled | # Evaluable | Baseline Meds | Baseline Puffs/Day | Final Puffs/Day | p Value | Oral Steroid Use | p Value | Comments
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 38.3% on cromolyn/nedocromil | 10.2 +/− 9.6 | −5.3 (Mean) | | 122 | | Beta-2 agonist use reported as puffs/week Oral steroid use reported as # courses/100 pt-years
Childhood Asthma Management Program Research Group, 2000a | Exp 1 | 311 | 306 | 42.8% on cromolyn/nedocromil | 10.4 +/− 9.8 | −7.4 (Mean) | <0.0010 ^a^ | 70 | <0.0010 ^a^ | Beta-2 agonist use reported as puffs/week Oral steroid use reported as # courses/100 pt-years
Jonasson, Carlsen and Blomquist, 1998 | Placebo | 40 | 40
Jonasson, Carlsen and Blomquist, 1998 | Bud 1 | 40 | 40 | | | | NS ^c^
Jonasson, Carlsen and Blomquist, 1998 | Bud 2 | 42 | 42 | | | | NS ^c^
Jonasson, Carlsen and Blomquist, 1998 | Bud 3 | 41 | 41 | | | | NS ^c^
Simons, Dolovich, Moote, et al., 1997 | Placebo | 80 | 55 | | | | | 17 courses | | Albuterol not required for median 83% of days in controls vs 92% in ICS (p<0.001) 84% of control group did not require albuterol in vs 95% of ICS group (p=0.03).
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | | | | | 10 courses | | Albuterol not required for median 83% of days in controls vs 92% in ICS (p<0.001) 84% of control group did not require albuterol in vs 95% of ICS group (p=0.03).
Hoekstra, Grol, Bouman, et al., 1996 | Placebo | 19
Hoekstra, Grol, Bouman, et al., 1996 | Flutic | 15
Agertoft and Pedersen, 1994 | Control | 62 | | | | | | | | At end of study, 58% vs 0% on cromolyn, 64% vs 12 % on theophylline, 42% vs 8% on oral beta-2 agonists, all significantly higher in control group compared with budesonide (p<0.001)
Agertoft and Pedersen, 1994 | Bud | 216 | | | | | | | | At end of study, 58% vs 0% on cromolyn, 64% vs 12 % on theophylline, 42% vs 8% on oral beta-2 agonists, all significantly higher in control group compared with budesonide (p<0.001)
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Placebo | 58 | | | 52% used no beta-2 agonist | 67% used no beta-2 agonist | | 48% of patients | | Beta-2 agonist use reported as percent of patients using no beta-2 agonists in 2 wks. Oral steroid use reported as percent of patients with an exacerbation requiring prednisolone. Number of pts evaluated for these outcomes uncertain.
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Bud | 58 | | 48.0% on cromolyn nedocromil | 49% used no beta-2 agonist | 71% used no beta-2 agonist | NS ^c^ | 14% of patients | <0.0010 ^c^
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Control | 14 | 13 | | | 0.98 (Mean) | | | | Beta-2 agonist use reported as mean number of nebules used per day. Percentage of days salbutamol required 38% control vs 18% ICS
Storr, Lenney and Lenney, 1986 | Beclo | 15 | 15 | | | 0.52 (Mean) | <0.0500 ^c^ | | | Beta-2 agonist use reported as mean number of nebules used per day. Percentage of days salbutamol required 38% control vs 18% ICS
Connett, Warde, Wooler, et al., 1993 | Placebo | 20 | 19 | | | 1.8 +/− 1 | | 125+/−40 mg/pt | | Beta-2 agonist use reported as change in doses/day; change in nighttime puff/day (pl vs bud), 1.3+/−0.7 vs 0.4+/−0.8, p<0.05; change in total doses of study medication, 1.5+/−0.3 vs 0.7+/−0.3, p NS
Connett, Warde, Wooler, et al., 1993 | Bud | 20 | 17 | | | −0.1 +/− 0.9 | NS ^a^ | 60+/−33 mg/pt | NS ^a^ | Beta-2 agonist use reported as change in doses/day; change in nighttime puff/day (pl vs bud), 1.3+/−0.7 vs 0.4+/−0.8, p<0.05; change in total doses of study medication, 1.5+/−0.3 vs 0.7+/−0.3, p NS
B. ICS vs long-acting Beta-2 agonists
Verbene, Frost, Roorda, et al., 1997 | Salmet | 32 | 25 | 46.9% on cromolyn/nedocromil | | 0.44 (Median) | | 17 courses
Verbene, Frost, Roorda, et al., 1997 | Beclo | 35 | 32 | 42.9% on cromolyn/nedocromil | | 0.07 (Median) | =0.0001 ^c^ | 2 courses
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | 67 | | | | | 10 courses
Simons, Dolovich, Moote, et al., 1997 | Salmet | 80 | 58 | | | | | 15 courses
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Beclo | 102 | 76 | 42.0% on theophylline | | | | 81.4% of pts with no oral steroid use | | Beta-2 agonist use analyzed by percent of pts with low, medium, and high use. NS difference between groups. Oral steroid use reported as % of pts requiring no courses of steroids.
Tinkelman, Reed, Nelson, et al., 1993 | Theo | 93 | 69 | 39.0% on theophylline | | | | 63.4% of pts with no oral steroid use | | Beta-2 agonist use analyzed by percent of pts with low, medium, and high use. NS difference between groups. Oral steroid use reported as % of pts requiring no courses of steroids.
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 38.3% on cromolyn/nedocromil | 10.2 +/− 9.6 | −5.3 (Mean) | | 122
Childhood Asthma Management Program Research Group, 2000a | Exp 2 | 312 | 307 | 47.4% on cromolyn/nedocromil | 10.5 +/− 9.8 | −5.7 (Mean) | NS ^a^ | 102 | =0.0100 ^a^

a Statistical significance determined by comparing the absolute change in outcomes from baseline to final time point between groups.

b Statistical significance determined by comparing the percent change in outcomes from baseline to final time point between groups.

c Statistical significance determined by comparing the absolute value in outcomes at the final time point between groups.

d Statistical significance determined by comparing the 'treatment effect ratio' between groups.

Evidence Table 1-10. Utilization outcomes

A. ICS vs placebo (or no ICS)
Citation | Study Arm | # Enrolled | # Evaluable | Hospital Visits | p Value | Missed Days at Work/School | p Value | Comments
Children older than 5 years
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | 4.4 hospitalizations/100 pt-years 22 urgent care visits/100 pt-years
Childhood Asthma Management Program Research Group, 2000a | Exp 1 | 311 | 306 | 2.5 hospitalizations/100 pt-years 12 urgent care visits/100 pt-years | 0.04 <0.001
Jonasson, Carlsen and Blomquist, 1998 | Placebo | 40
Jonasson, Carlsen and Blomquist, 1998 | Bud 1 | 40
Jonasson, Carlsen and Blomquist, 1998 | Bud 2 | 42
Jonasson, Carlsen and Blomquist, 1998 | Bud 3 | 41
Simons, Dolovich, Moote, et al., 1997 | Placebo | 80 | | | | % of patients not missing school, 66 | | Activities affected by asthma 2% of days in control group vs 1% of days in ICS group, NS difference
Simons, Dolovich, Moote, et al., 1997 | Beclo | 81 | | | | % of patients not missing school, 81 | NS | Activities affected by asthma 2% of days in control group vs 1% of days in ICS group, NS difference
Hoekstra, Grol, Bouman, et al., 1996 | Placebo | 19 | 15 | | | | | Number of school absence days was small in both groups and not significantly different.
Hoekstra, Grol, Bouman, et al., 1996 | Flutic | 15 | 15 | | | | | Number of school absence days was small in both groups and not significantly different.
Agertoft and Pedersen, 1994 | Control | 62 | | Total/pt/yr, 0.03 | | 47%
Agertoft and Pedersen, 1994 | Bud | 216 | 216 | Total/pt/yr, 0.0041 | <0.0010 | 62%
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Placebo | 58 | | Total, 3 | | Total, 23 | | Missed school reported as total number of patients with no missed school days due to asthma, statistical tests not reported.
van Essen-Zandvliet, Hughes, Waalkens, et al., 1992 | Bud | 58 | | Total, 0 | NS | Total, 32 | NS | Missed school reported as total number of patients with no missed school days due to asthma, statistical tests not reported.
Children younger than 5 years
Storr, Lenney and Lenney, 1986 | Placebo | 14
Storr, Lenney and Lenney, 1986 | Beclo | 15
Connett, Warde, Wooler, et al., 1993 | Placebo | 20 | 19 | Total, 8 | | | | Total # exacerbations 10 in placebo group, 5 in antibiotic group, statistical test NR
Connett, Warde, Wooler, et al., 1993 | Bud | 20 | 17 | Total, 3 | | | | Total # exacerbations 10 in placebo group, 5 in antibiotic group, statistical test NR
B. ICS vs long-acting Beta-2 agonists
Verbene, Frost, Roorda, et al., 1997 | Salmet | 32
Verbene, Frost, Roorda, et al., 1997 | Beclo | 35
Simons, Dolovich, Moote, et al., 1997 | Salmet | 81 | | | | % of patients not missing school, 88
Simons, Dolovich, Moote, et al., 1997 | Beclo | 80 | | | | % of patients not missing school, 81 | NR
C. ICS vs theophylline
Tinkelman, Reed, Nelson, et al., 1993 | Theo | 93 | 69 | % pts with ER visits/hospitalizations, 11.8 | | | | Percentage of missed school days not significantly different between groups, further data not given.
Tinkelman, Reed, Nelson, et al., 1993 | Beclo | 102 | 76 | % pts with ER visits/hospitalizations, 4.9 | NS | | | Percentage of missed school days not significantly different between groups, further data not given.
D. ICS vs nedocromil
Childhood Asthma Management Program Research Group, 2000a | Control | 418 | 411 | no./100 person-yr., 22
Childhood Asthma Management Program Research Group, 2000a | Exp 2 | 312 | 307 | no./100 pt yr., 16 | =0.0200

a Statistical significance determined by comparing the absolute change in outcomes from baseline to final time point between groups.

b Statistical significance determined by comparing the percent change in outcomes from baseline to final time point between groups.

c Statistical significance determined by comparing the absolute value in outcomes at the final time point between groups.

d Statistical significance determined by comparing the 'treatment effect ratio' between groups.

Evidence Table 2-1. Study characteristics

Citation | Study Design | Study Setting | Asthma Severity | Eligibility
Overbeek, Huib, Kerstjens, et al., 1996 | Open label extension of randomized parallel arm, double-blinded, placebo controlled trial; | Country: Netherlands; Funding: Pharm + gov't grant; Tx Setting: Unknown/Other; Multicenter | Stated: Not specified; Estimated: Unable to estimate | Patient eligibility based on lung function only; 1) FEV1 (type not specified) minimum 1.2 L and 1.64 to 4.5 residual SDs below predicted, or FEV1/inspiratory vital capacity ratio >1.64 residual SDs below predicted; 2) Histamine PC20 maximum 8 mg/ml Exclusions: Patients with medication use or conditions likely to interfere with the purpose of the study
Haahtela, Jarvinen, Kava, et al., 1994 | Open label extension of randomized parallel arm, double-blinded, controlled trial; | Country: Scandinavia; Funding: Not specified; Tx Setting: Unknown/Other; Multicenter | Stated: Mild; Estimated: Mild | Patient eligibility based on lung function and symptoms; FEV1 (postdose) minimum 80% of predicted; increase of more than 15% after inhalation of beta-2 agonist or decrease of more than 15% after exercise tolerance test. Maximum duration of symptoms 12 months. Exclusions: history of smoking within 6 months, regular asthma treatment, prior treatment with corticosteroids or cromolyn
Agertoft and Pedersen, 1994 | Prospective cohort analysis within parallel, controlled trial; Patients stratified by prior duration of asthma. | Country: Scandinavia; Funding: Not specified; Tx Setting: Unknown/Other | Stated: Mild-moderate; Estimated: Mild-Severe | Patient eligibility based on utilization and stated severity; Minimum of three prior visits to clinic within past year, with mild to moderate asthma. Exclusions: prior use of inhaled corticosteroids for more than 2 weeks per year; other chronic diseases
Selroos, Pietinalho, Lofroos, et al., 1995 | Prospective cohort study; Patients stratified by prior duration of asthma. | Country: Scandinavia; Funding: Not specified; Tx Setting: Unknown/Other | Stated: Mild-moderate; Estimated: Mild-Severe | Patient eligibility based on lung function and symptoms; FEV1 (type not specified) maximum 75% of predicted or PEF (a.m. clinic) maximum 75% of predicted; and/or use of inhaled bronchodilators >3x/week, and/or regular asthma symptoms during day or night, and/or reduced exercise tolerance, Exclusions: prior use of inhaled corticosteroids; irreversible airway obstruction

Evidence Table 2-2. Study parameters

Citation | Pretreatment | Study Arm | N enrolled | Corticosteroid Delay | Treatment
N | None | ICS-immediate | | Corticosteroids delayed 0 months, then administered for 36 months | All patients received 200 mcg beclomethasone dipropionate 4x daily; All patients received 500 mcg Terbutaline 4x daily
N | None | ICS-delayed | | 6 | All patients received 500 mcg terbutaline 4x daily for entire study; Some patients received 40 mcg ipratropium bromide 4x daily for first 30 mths; All patients received 200 mcg beclomethasone dipropionate 4x daily for final 6 months of study.
Haahtela, Jarvinen, Kava, et al., 1994 | Run-in 2 weeks, to establish patient eligibility; | ICS-immediate | | Corticosteroids delayed 0 months, then administered for 36 months | All patients received 600 mcg budesonide 2x daily for first 24mths, then reduced to 200 mcg 2x daily for final 12mths.
Haahtela, Jarvinen, Kava, et al., 1994 | Run-in 2 weeks, to establish patient eligibility; | ICS-delayed | | Corticosteroids delayed 24 months, then administered for 12 months | All patients received 600 mcg budesonide 2x daily for final 12mths of study
Agertoft and Pedersen, 1994 | Run-in 52 weeks, to establish patient eligibility | ICS-immediate | | Prior duration of asthma 0-12 months; inhaled corticosteroids administered for at least 24 months | All patients received 800 mcg budesonide daily (frequency of dosing not specified)
Agertoft and Pedersen, 1994 | Run-in 52 weeks, to establish patient eligibility | ICS-delayed 1 | | Prior duration of asthma 12-24 months; inhaled corticosteroids administered for at least 24 months | All patients received 800 mcg budesonide daily (frequency of dosing not specified)
Agertoft and Pedersen, 1994 | Run-in 52 weeks, to establish patient eligibility | ICS-delayed 2 | | Prior duration of asthma 24-36 months; inhaled corticosteroids administered for at least 24 months | All patients received 800 mcg budesonide daily (frequency of dosing not specified)
Agertoft and Pedersen, 1994 | Run-in 52 weeks, to establish patient eligibility | ICS-delayed 3 | | Prior duration of asthma 12-24 months; inhaled corticosteroids administered for at least 24 months | All patients received 800 mcg budesonide daily (frequency of dosing not specified)
Selroos, Pietinalho, Lofroos, et al., 1995 | None | ICS-immediate | | Prior duration of asthma 0-6 months; inhaled corticosteroids administered for 24 months | Average daily dose for entire population 454 mcg budesonide 2x daily at start of study; 374 mcg 2x daily after 2 years' treatment.
Selroos, Pietinalho, Lofroos, et al., 1995 | None | ICS-delayed 1 | | Prior duration of asthma 6-12 months; inhaled corticosteroids administered for 24 months | Average daily dose for entire population 454 mcg budesonide 2x daily at start of study; 374 mcg 2x daily after 2 years' treatment.
Selroos, Pietinalho, Lofroos, et al., 1995 | None | ICS-delayed 2 | | Prior duration of asthma 12-24 months; inhaled corticosteroids administered for 24 months | Average daily dose for entire population 454 mcg budesonide 2x daily at start of study; 374 mcg 2x daily after 2 years' treatment.
Selroos, Pietinalho, Lofroos, et al., 1995 | None | ICS-delayed 3 | | Prior duration of asthma 24-60 months; inhaled corticosteroids administered for 24 months | Average daily dose for entire population 454 mcg budesonide 2x daily at start of study; 374 mcg 2x daily after 2 years' treatment.
Selroos, Pietinalho, Lofroos, et al., 1995 | None | ICS-delayed 4 | | Prior duration of asthma 60-120 months; inhaled corticosteroids administered for 24 months | Average daily dose for entire population 454 mcg budesonide 2x daily at start of study; 374 mcg 2x daily after 2 years' treatment.
Selroos, Pietinalho, Lofroos, et al., 1995 | None | ICS-delayed 5 | | Prior duration of asthma >120 months; inhaled corticosteroids administered for 24 months | Average daily dose for entire population 454 mcg budesonide 2x daily at start of study; 374 mcg 2x daily after 2 years' treatment.

Evidence Table 2-3. Population characteristics

Citation | Study Arm | Pop Age (mean +/− SD) | % Male/Female | Avg Duration of Asthma (Months) | % Atopic Patients | Baseline Lung Function Values | | Baseline Symptom Values
Citation | Study Arm | Pop Age (mean +/− SD) | % Male/Female | Avg Duration of Asthma (Months) | % Atopic Patients | FEV1 | PEF | Baseline Symptom Values
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-immediate | 36.8 +/− 11.9 | 53.1/46.9 | NR | 67.3 | 64.6 +/− 14.1% pred | | NR
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-delayed | 37.7 +/− 12.6 | 64.2/35.8 | NR | 66.0 | 61.2 +/− 15.6% pred | | NR
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-immediate | 37.3 +/− 11.3 | 30.0/70.0 | 7.3 | 68.0 | | | Daytime symptom score, 2.2 (mean)
  3.17 +/− 0.8 L (postdose) | 436 +/− 84.9 L/min (home)
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-delayed | 38.1 +/− 13.1 | 26.4/73.6 | 6.7 | 75.5 | | | Daytime symptom score, 2.2 (mean)
  3.05 +/− 0.7 L (postdose) | 438 +/− 72.8 L/min (home)
Agertoft and Pedersen, 1994 | ICS-immediate | 6.2 (entire study population) | 68.5/31.5 | 0-24 mths (range) | NR | 81.3% pred (entire study population) | | NR
Agertoft and Pedersen, 1994 | ICS-delayed1 | NR | NR | 24-36 mths (range) | NR | NR | | NR
Agertoft and Pedersen, 1994 | ICS-delayed2 | NR | NR | 36-60 mths (range) | NR | NR | | NR
Agertoft and Pedersen, 1994 | ICS-delayed3 | NR | NR | >60 mths (range) | NR | NR | | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-immediate | 42 +/− 10 | 7.1 / 92.9 | 0-6 mths (range) | 64.2 | | | NR
  70 +/− 21% pred | 72 +/− 24% pred (clinic)
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 1 | 52 +/− 12 | 42.9 / 57.1 | 6-12 mths (range) | 57.1 | | | NR
  70 +/− 21% pred | 67 +/− 24% pred (clinic)
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 2 | 39 +/− 16 | 46.2 / 53.8 | 12-24 mths (range) | 61.5 | | | NR
  78 +/− 18% pred | 79 +/− 16% pred (clinic)
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 3 | 49 +/− 16 | 52.6 / 47.4 | 24-60 mths (range) | 63.2 | | | NR
  60 +/− 16% pred | 66 +/− 20% pred (clinic)
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 4 | 54 +/− 14 | 46.7 / 53.3 | 60-120 mths (range) | 60.0 | | | NR
  62 +/− 18% pred | 62 +/− 24% pred (clinic)
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 5 | 62 +/− 9 | 33.3 / 66.7 | >120 mths (range) | 77.8 | | | NR
  67 +/− 21% pred | 65 +/− 28% pred (clinic)

Evidence Table 2-4. Lung function outcomes: FEV1

Citation | Study Arm | # Enrolled | # Evaluable | Study Duration (years) | FEV1 Baseline | FEV1 Final | FEV1 p value | Comments
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-immediate | (91) | 49 | 3.0 | 64.6 +/− 14.1% predicted | 13.8% pred (change, 95% CI, 7.7-18.7) | | Number of patients enrolled includes both COPD and asthma patients, number evaluable includes only asthma patients.
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-delayed | (183) | 53 | 3.0 | 61.2 +/− 15.6% predicted | 8.5% pred (change, 95% CI, 3.3-15.9) | NS | Comparison only made of rise in FEV1 during initial 3 mths treatment with ICS in both groups.
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-immediate | 50 | 16 | 3.0 | 3.17 +/− 0.8 L | 3.32 L | | Values represent FEV1 at start of initial study and final FEV1 after 3 years.
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-delayed | 53 | 36 | 3.0 | 3.05 +/− 0.7 L | 3.07 L | | No statistical comparison performed on change in FEV1 from start of study until final endpoint.
Agertoft and Pedersen, 1994 | ICS-immediate | | | 3.7 | NR | 8.2% pred/yr (change, 95% CI, 6.1, 10.3) | | Final FEV1 % predicted 101 +/− 13.6% Calculation of % increase/yr in FEV1 by linear regression probably not appropriate.
Agertoft and Pedersen, 1994 | ICS-delayed 1 | | | 3.7 | NR | 6.7% pred/yr (change, 95% CI, 5.0, 8.4)
Agertoft and Pedersen, 1994 | ICS-delayed 2 | | | 3.7 | NR | 3% pred/yr (change, 95% CI, 1.8, 4.2)
Agertoft and Pedersen, 1994 | ICS-delayed 3 | | | 3.7 | NR | 2.4% pred/yr (95% CI, 1.1, 3.7) | | Final FEV1 % predicted 96.2 +/− 9.5%, p<0.05 as compared to ICS-immediate group.
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-immediate | 14 | | 2.0 | 70 +/− 21 % predicted | 87 +/− 18.7 % predicted
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 1 | 35 | | 2.0 | 70 +/− 21 % predicted | 75 +/− 17.7 % predicted | .0100, | Comparison of change in FEV1 vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 2 | 13 | | 2.0 | 78 +/− 18 % predicted | 85 +/− 18.0 % predicted | <.0500, | Comparison of change in FEV1 vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 3 | 19 | | 2.0 | 60 +/− 16 % predicted | 68 +/− 21.8 % predicted | NS | Comparison of change in FEV1 vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 4 | 15 | | 2.0 | 62 +/− 18 % predicted | 66 +/− 19.4 % predicted | <.0500, | Comparison of change in FEV1 vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 5 | 9 | | 2.0 | 67 +/− 21 % predicted | 67 +/− 30.0 % predicted | <.0100, | Comparison of change in FEV1 vs. Ctl

Evidence Table 2-5. Lung function outcomes: PEF

Citation | Study Arm | # Enrolled | # Evaluable | Study Duration (years) | PEF Baseline | PEF Final | PEF p Value | Comments
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-immediate | (91) | 49 | 3.0 | NR | NR
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-delayed | (183) | 53 | 3.0 | NR | NR
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-immediate | 50 | 16 | 3.0 | 436 +/− 84.9 L/min | 482 L/min | | No statistical tests of initial and final PEF values performed.
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-delayed | 53 | 36 | 3.0 | 438 +/− 72.8 L/min | 453 L/min
Agertoft and Pedersen, 1994 | ICS-immediate | | | 3.7 | NR | NR
Agertoft and Pedersen, 1994 | ICS-delayed 1 | | | 3.7 | NR | NR
Agertoft and Pedersen, 1994 | ICS-delayed 2 | | | 3.7 | NR | NR
Agertoft and Pedersen, 1994 | ICS-delayed 3 | | | 3.7 | NR | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-immediate | 14 | | 2.0 | 72 +/− 24% predicted | 93 +/− 26.2% predicted | | Outcomes compared by change, Tx vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 1 | 35 | | 2.0 | 67 +/− 24% predicted | 79 +/− 23.7% predicted | NS | Outcomes compared by change, Tx vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 2 | 13 | | 2.0 | 79 +/− 16% predicted | 91 +/− 21.6% predicted | NS | Outcomes compared by change, Tx vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 3 | 19 | | 2.0 | 66 +/− 20% predicted | 72 +/− 17.4% predicted | <.050 | Outcomes compared by change, Tx vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 4 | 15 | | 2.0 | 62 +/− 24% predicted | 64 +/− 15.5% predicted | <.010 | Outcomes compared by change, Tx vs. Ctl
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 5 | 9 | | 2.0 | 65 +/− 28% predicted | 67 +/− 33.0% predicted | <.050 | Outcomes compared by change, Tx vs. Ctl

Evidence Table 2-6. Lung function outcomes: Bronchial hyperreactivity

Citation | Study Arm | # Enrolled | # Evaluable | Study Duration (years) | PC20 Baseline | PC20 Final | PC20 p Value | Comments
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-immediate | (91) | 49 | 3.0 | | 1.77 DD Histamine (95% CI, 1.07-2.56)
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-delayed | (183) | 53 | 3.0 | | 0.79 DD Histamine (95% CI, 0.00-1.44) | =.030 | Outcomes compared by change, Tx vs. Ctl
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-immediate | 50 | 16 | 3.0 | 2.80 DD Histamine +/− 2.2 | 5.0 DD Histamine | | Results reported as PC15.
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-delayed | 53 | 36 | 3.0 | 2.80 DD Histamine +/− 2.1 | 4.2 DD Histamine | | Results reported as PC15.
Agertoft and Pedersen, 1994 | ICS-immediate | | | 3.7 | NR | NR
Agertoft and Pedersen, 1994 | ICS-delayed 1 | | | 3.7 | NR | NR
Agertoft and Pedersen, 1994 | ICS-delayed 2 | | | 3.7 | NR | NR
Agertoft and Pedersen, 1994 | ICS-delayed 3 | | | 3.7 | NR | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-immediate | 14 | | 2.0 | NR | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 1 | 35 | | 2.0 | NR | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 2 | 13 | | 2.0 | NR | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 3 | 19 | | 2.0 | NR | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 4 | 15 | | 2.0 | NR | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 5 | 9 | | 2.0 | NR | NR

Evidence Table 2-7. Symptoms/medications outcomes

Citation | Study Arm | Enrolled | Pts Eval | Treatment Duration (weeks) | Baseline Daytime Symptom Score | Final Daytime Symptom Score | p Value | Oral Steroid Use | p Value
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-immediate | 49
Overbeek, Huib, Kerstjens, et al., 1996 | ICS-delayed | 53
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-immediate | 50 | 16 | 156 | 2.2 (scale, 0-10) | 1.4 (scale, 0-10) | NR | 9 courses in 4 pts | NR
Haahtela, Jarvinen, Kava, et al., 1994 | ICS-delayed | 53 | 36 | 156 | 2.2 (scale, 0-10) | 1.8 (scale, 0-10) | NR | 12 courses in 8 pts | NR
Agertoft and Pedersen, 1994 | ICS-immediate | NR
Agertoft and Pedersen, 1994 | ICS-delayed3 | NR
Agertoft and Pedersen, 1994 | ICS-delayed2 | NR
Agertoft and Pedersen, 1994 | ICS-delayed1 | NR
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-immediate | 14
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 5 | 9
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 4 | 15
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 3 | 19
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 2 | 13
Selroos, Pietinalho, Lofroos, et al., 1995 | ICS-delayed 1 | 35

Evidence Table 3-1. Study characteristics

Citation | Treatment Comparison | Study Design | Study Setting | Eligibility ^a^ | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | FP + placebo vs. FP + salmeterol | randomized; parallel, controlled (placebo); double-blinded | Country: Multicountry; Funding: Pharm. Ind., grant; Tx Setting: Hospital clinics; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 50% pred; FEV1 maximum 100% pred; PEF (a.m. (home)) minimum 51% of normal; Symptom score >2 on at least 4 of 7 consecutive days
Boulet, Cartier, Milot, et al., 1998 | ICS + placebo vs. ICS + salmeterol | randomized; crossover, randomized sequence (placebo); double-blinded | Country: Canada; Funding: Pharm. Ind., grant; Tx Setting: Unknown | Patient eligibility based on lung function, symptoms, utilization; FEV1 (Predose) minimum 61% pred; FEV1 (Predose) maximum 100% pred; Methacholine PC20 maximum 7.9
Boyd, 1995 | ICS + placebo vs. ICS + salmeterol | randomized; parallel, controlled (placebo); double-blinded | Country: United Kingdom; Funding: Pharm. Ind., grant; Tx Setting: Outpatient departments; Multicenter | Patient eligibility based on lung function, symptoms, utilization; FEV1 minimum 40% pred; Use of >1,500 mcg/day ICS and under consideration for oral steroids; At least 2 of: nighttime symptom score >1, daytime symptom score >2, >8 puffs/day, PEF variability >15% on at least 3 of 7 days
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS + placebo vs. ICS + formoterol | randomized; parallel, controlled (placebo); double-blinded | Country: Canada; Funding: Pharm. Ind., grant; Tx Setting: 15 Canadian centers; Multicenter | Patient eligibility based on lung function, symptoms, utilization; methacholine PC20 maximum 8; patients on ICS, 400-1,200 mcg/day and short-acting beta-agonists for at least one month | Not 100% sure that control group got placebo, paper states that "all pts. inhaled the content of 1 dry powder capsule 4 times daily to achieve the desired regimen while maintaining blinding (double-dummy technique)
Grutters, Brinkman, Aslander, et al., 1999 | BDP vs. BDP + salmeterol | randomized; parallel, controlled; double-blinded | Country: Netherlands; Funding: Pharm. Ind., grant; Tx Setting: Specialty care, university; Multicenter | Patient eligibility based on lung function, symptoms, utilization; FEV1 (Predose) minimum 61% pred; FEV1 (Predose) maximum 100% pred; Histamine PC20 maximum 3.9
Kavuru, Melamed, Gross, et al., 2000 | FP vs FP + salmeterol | randomized; parallel, controlled; double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: Unknown/Other (specify); Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (Type a.m. Predose) minimum 40% of predicted; FEV1 (Type a.m. Predose) maximum 85% of predicted; mAwakenings/night maximum 3 | Patients using ICS for >=3 mos prior to screening not eligible if used >=12 puffs/day albuterol for >3 days; patients using salmeterol prior to screening not eligible if used >=6 puffs/day albuterol for >3 days
Kemp, Cook, Incaudo, et al., 1998 | ICS + placebo vs. ICS + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: Unknown; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 40% pred; FEV1 maximum 80% pred; Average symptom score of 1 during run-in period; Using a fixed dose of ICS
Langley, Masterson, Batty, et al., 1998 | ICS + placebo vs. ICS + salmeterol | Randomized; parallel, controlled; double-blinded | Country: United Kingdom; Funding: Not specified; Tx Setting: Specialty care, non-university | Patient eligibility based on lung function, symptoms, utilization; FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 90% pred; ipratropium (<240 mcg/day) use on >4 of 7 days prior to randomization OK
Li, Ward, Thien, et al., 1999 | BDP or BUD + placebo vs. BDP or BUD + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: Australia; Funding: Pharm + Other: hospital foundation/private(?); Tx Setting: Unknown | Patient eligibility based on lung function, symptoms, utilization; FEV1 (a.m. predose) minimum 60% pred; FEV1 (a.m. predose) maximum 100% pred; PEF variability minimum 16%; Symptom score of >2 on 7 of 14 days | Run-in period was actually 2-6 weeks; 71 pts were enrolled for study but only 50 were eligible to be randomized after run-in; also says FEV done by ATS criteria; elig also rescue med use in run-in;
Pauwels, Lofdahl, Postma, et al, 1997 (QOL data from Juniper et al., 1999) | BUD + placebo vs. BUD + formoterol | Randomized; parallel, controlled (placebo); double-blinded | Country: Multi-country; Funding: Pharm. Ind., grant; Tx Setting: Unknown/Other; Multicenter | Patient eligibility based on lung function, symptoms, utilization; FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 100% pred | Juniper et al 1999 reports QOL data on subset of study patients. QOL data reported from Juniper, other outcomes reported from Pauwels et al.
Pearlman, Stricker, Weinstein, et al., 1999 | Placebo vs. FP vs. FP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: Specialty care, non-university; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (a.m. predose) minimum 50% pred; FEV1 (a.m. predose) maximum 80% pred
Russell, Williams, Weller, et al., 1995 | BDP + placebo vs. BDP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: United Kingdom; Funding: Pharm. Ind., "sponsored"; Tx Setting: Unknown; Multicenter | Patient eligibility based on lung function and symptoms; PEF (a.m. (home)) maximum 90% pred; PEF variability minimum 15%; Days/wk with symptoms minimum 3.5
Shapiro, Lumry, Wolfe, et al., 2000 | FP vs FP + salmeterol | Randomized; parallel, controlled; double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: Unknown/Other (specify); Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (Type Not specified) minimum 40% of predicted; FEV1 (Type Not specified) maximum 85% of predicted; Nights/week with symptoms minimum 0: Puffs/day minimum 0
van der Molen, Postma, Turner, et al., 1997 | ICS + placebo vs. ICS + formoterol | Randomized; parallel, controlled (placebo); double-blinded | Country: Netherlands and Canada; Funding: Pharm. Ind., grant; Tx Setting: Primary care, nonuniversity; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (a.m.) minimum 40% pred: Puffs/day minimum 1; Regular use of ICS | FEV1 measured according to standardized guidelines, ref. Quanjer, Bull Eur Physiopathol Respir 1983;19(Suppl 5):1-95; Nighttime comcgh and chest discomfort subscales also recorded by patient; total sxsc 21
Verberne, Frost, Duiverman, et al., 1998 | BDP + placebo vs. BDP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: Netherlands; Funding: Pharm. Ind., grant; Tx Setting: Primary/specialty combination, univ/nonuniv; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 55% pred; FEV1 maximum 90% pred; PC20 of <150 mcg methacholine; No exacerbations or URI for at least 1 month prior to study
Weersink, Douma, Postma, et al., 1997 | FP + placebo vs. FP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: Netherlands; Funding: Pharm. Ind., grant; Tx Setting: Specialty care, university | Patient eligibility based on lung function and symptoms; PEF variability minimum 15%; Methacholine PC20 maximum 9.6; Patients had a history of episodic dyspnea or wheezing consistent with asthma | No formal pre-tx period but ICS stopped 4 wks and nedocromil/long-acting beta-2 agonists stopped 2 wks prior to study
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS + placebo vs. ICS + salmeterol | Randomized; crossover, randomized sequence (placebo); double-blinded | Country: Canada; Funding: Pharm. Ind., grant; Tx Setting: Specialty care, university | Patient eligibility based on lung function and symptoms; Methacholine PC20 maximum 8; Puffs/day maximum 4; <4 puff/day rescue beta-agonist
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP + placebo vs. BDP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: Netherlands; Funding: Pharm. Ind., grant; Tx Setting: Unknown; Multicenter | Patient eligibility based on lung function, symptoms, utilization; FEV1 (Predose) minimum 61% pred; FEV1 (Predose) maximum 100% pred; PEF (a.m. (home)) minimum 61% pred; PEF variability minimum 0%; Total symptom score >2 | 5 period trial, baseline, sensitivity, high dose, treatment, follow-up; comparison is between sensitivity and treatment period; total symptom score based on daytime (0-5 scale) and nighttime (0-4 scale);
Wilding, Clark, Coon, et al., 1997 | ICS + placebo vs. ICS + salmeterol | Randomized; crossover, randomized sequence (placebo); double-blinded | Country: British Isles; Funding: Pharm + Other: private grant; Tx Setting: Outpatient clinics; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (Predose) minimum 50% pred; Patients receiving >400 mcg/day of BDP or BUD, titered during run-In to >200 mcg/day
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | FP + placebo vs. FP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: Specialty care, university; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (a.m. Predose) minimum 40% pred; FEV1 (a.m. Predose) maximum 85% pred | Pt eligibility for run-in was FEV of 40-85 and rev. of airway, but for randomization, it dif. 65.1-85
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP vs. BDP + formoterol | Randomized; parallel, controlled | Country: Greece; Funding: Pharm. Ind., grant; Tx Setting: Mixed univ/non-univ; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (Predose) minimum 40% pred; FEV1 (Predose) maximum 85% pred; Daytime and nighttime symptom score of 2 or greater on at least 4 of 7 days prior to randomization
Condemi, Goldstein, Kalberg, et al., 1999 | FP + placebo vs. FP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: 36 centers; Multicenter | Patient eligibility based on lung function, symptoms, utilization; FEV1 (a.m. Predose) minimum 40% pred; FEV1 (a.m. Predose) maximum 85% pred; PEF variability minimum 20%; Days/wk with symptoms minimum 3; If FEV1 65-85%, then required >4 puffs/day or >2 days when a.m. PEF variation >20% or >2 nights with awakenings or symptom score >2 on >3 days, during 7 days prior to randomization | Run-in=2-4wks
Greening, Ind, Northfield, et al., 1994 (Hyland and Crocker, 1995 for QOL data) | BDP + placebo vs. BDP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: United Kingdom; Funding: Pharm. Ind., grant; Tx Setting: Primary care, non-university; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 50% pred; PEF variability minimum 15%; Days/wk with symptoms minimum 4; Use of 400 mcg BDP
Kelsen, Church, Gillman, et al., 1999 | BDP vs. BDP + salmeterol | Randomized; parallel, controlled; double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: 34 outpatient clinical sites; Multicenter | Patient eligibility based on lung function, symptoms, utilization; FEV1 (a.m. Predose) minimum 45% pred; FEV1 (a.m. Predose) maximum 80% pred | 156 patients were not randomized to either group afire run-in period. Diary card values were obtained by averaging individual measurements over the 7 days prior to treatment day 1
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Murray, Church, Anderson, et al., 1999 | BDP vs. BDP + salmeterol | Randomized; parallel, controlled; double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: 35 investigative sites; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (a.m. Predose) minimum 45% pred; FEV1 (a.m. Predose) maximum 80% pred; >3 nights with awakenings, >3 days with symptoms or with albuterol use during 7 days prior to randomization | Run-in was 2-4 wks
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD + placebo vs. BUD + formoterol | Randomized; parallel, controlled (placebo); double-blinded | Country: Multicountry; Funding: Pharm. Ind., grant; Tx Setting: Unknown/Other; Multicenter | Patient eligibility based on Lung function, symptoms, utilization; FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 100% pred
Pearlman, Stricker, Weinstein, et al., 1999 | placebo vs. FP vs. FP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: USA; Funding: Pharm. Ind., grant; Tx Setting: Specialty care, non-university; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (a.m. Predose) minimum 50% pred; FEV1 (a.m. Predose) maximum 80% pred
van Noord, Schreurs, Mol, et al., 1999 | FP vs. FP + salmeterol | Randomized; parallel, controlled; double-blinded | Country: Netherlands; Funding: Pharm. Ind., grant; Tx Setting: Unknown; Multicenter | Patient eligibility based on lung function, symptoms, utilization; FEV1 (a.m. predose) minimum 50% pred; FEV1 (a.m. predose) maximum 100% pred; PEF variability minimum 15%; Total daytime plus nighttime symptoms score of >1 or use of beta-agonist on >2 occasions in 4 days
Verberne, Frost, Duiverman, et al., 1998 | BDP vs. BDP + salmeterol | Randomized; parallel, controlled (placebo); double-blinded | Country: Netherlands; Funding: Pharm. Ind., grant; Tx Setting: Primary/specialty combination, univ/nonuniv; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 55% pred; FEV1 maximum 90% pred
Vermetten, Boermans, Luiten, et al., 1999 | BDP vs. BDP + salmeterol | Randomized; parallel, controlled; double-blinded | Country: Netherlands; Funding: Not specified; Tx Setting: Primary care, univ/nonuniv; Multicenter | Patient eligibility based on lung function and symptoms; PEF (Not specified (clinic)) minimum 60% pred; patients on ICS at least 6 weeks and needed beta-agonist rescue medication
Woolcock, Lundback, Ringdal, et al., 1996 | BDP vs. BDP + salmeterol | Randomized; parallel, controlled; double-blinded | Country: Multicountry; Funding: Pharm. Ind., grant; Tx Setting: Unknown; Multicenter | Patient eligibility based on lung function, symptoms, utilization; FEV1 minimum 50% pred; PEF (Mean a.m., p.m.) minimum 50% pred; Either daytime plus nighttime symptom score >2, PEF variability >15%, or >4 puffs/day on 4 of 7 days prior to randomization | Run-in 1 wk for patients already on 500 mcg BDP, 4 wks if on 400 mcg; 2nd 1 wk run-in
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 | BDP + placebo vs. BDP + theophylline | Parallel, controlled (placebo) | Country: Iran; Funding: Not specified; Tx Setting: Dept. of Internal Med, Shiraz Univ. | Patient eligibility based on lung function and symptoms; Objective evidence of airways obstruction during episodes of wheezing or dyspnea, and objective evidence of improved airflow when symptom-free | Elig type is really "objective evidence of airways obstruction during episodes of wheezing or dyspnea; sufficient hx avail. To categorize asthma severity, objective evidence of improved airflow when symptom free"; no FEV specified for elig.
Meltzer, Orgel, Ellis, et al., 1992 | BDP + placebo vs. BDP + theophylline | Randomized; parallel, controlled (placebo); double-blinded | Country: USA; Funding: Pharm Ind. grant + Other (unknown); Tx Setting: Primary/specialty combination, univ/nonuniv; Multicenter | Patient eligibility based on lung function only; FEV1 (a.m. Predose) maximum 75% pred
Minoguchi, Kohno, Oda, et al., 1998 | BDP + theophylline withdrawal vs. BDP + theophylline | Randomized; parallel, controlled | Country: Japan; Funding: Not specified; Tx Setting: Specialty care, univ/nonuniversity; Multicenter | Patient eligibility based on lung function and symptoms; PEF minimum 80% pred; PEF variability maximum 20%; All patients already treated with ICS and theophylline | Cough evaluated on a scale of 0.5 (infrequent) to 1 (frequent); Nighttime symptoms evaluated on a scale of 1 (slept well) to 12 (kept awake most of night by asthma)
Nassif, Weinberger, Thompson, et al., 1981 | BDP + placebo vs. BDP + theophylline | Randomized; crossover, randomized sequence (placebo); double-blinded | Country: USA; Funding: Pharm + Other (NIH, Univ IA); Tx Setting: Specialty care, university | Patient eligibility based on symptoms and utilization; Steroid-dependent children with asthma, with a history of frequent hospitalizations and emergency room visits
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | BUD + placebo vs. BUD + theophylline | Randomized; parallel, controlled (placebo); double-blinded | Country: Multicountry Funding: Pharm Ind. grant; Tx Setting: Specialty care, university; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 50% pred; Continued symptoms despite 800-1,000 ug or equivalent dose of BDP or FP; no exacerbations or theophylline tx within prior 3 wks; at end of screening, combined symptom score of >4 (combined scale, 0-9) or >10% PEF variation
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP + placebo vs. BDP + theophylline | Randomized; parallel, controlled (placebo); double-blinded | Country: Multicountry; Funding: Pharm. Ind., grant; Tx Setting: Unknown; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 50% pred; FEV1 maximum 85% pred; Nights/week with symptoms minimum 3: Puffs/day minimum 4; Symptom score >2 on >3 days during week prior to randomization | Run-in lasted 1-6 weeks
Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | BDP + placebo vs. BDP + montelukast | Randomized; parallel, controlled (placebo); double-blinded | Country: Multicountry; Funding: Pharm. Ind., grant; Tx Setting: 70 study centers; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 85% pred; minimum 64: Puffs/day minimum 1
Tamaoki, Kondo, Sakai, et al., 1997 | BDP + theophylline + placebo vs. BDP + theophylline + pranlukast | Randomized; parallel, controlled (placebo); double-blinded | Country: Japan; Funding: Pharm supplies + gov't grant; Tx Setting: Int/Pul Med Univ/nonuniv; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 70% pred; PEF (a.m. (home)) minimum 70% pred; Days/wk with symptoms maximum 0.71; Patients already on > 1,500 mcg ICS and well-controlled >6 weeks
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP vs BDP + pranlukast | Randomized; parallel, controlled | Country: Japan; Funding: Not specified; Tx Setting: Specialty care, nonuniversity; Multicenter | Patient eligibility based on lung function and symptoms
Virchow, Prasse, Naya, et al., 2000 | ICS + placebo vs. ICS + zafirlukast | Randomized; parallel, controlled (placebo); double-blinded | Country: Multicountry; Funding: Pharm. Ind., grant; Tx Setting: Unknown; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 minimum 50% pred; FEV1 maximum 75% pred; symptom score > 10/wk (scale, 0-3/d) at end of 2 week baseline period
Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | ICS + placebo vs. ICS + montelukast | Randomized; parallel, controlled (placebo); double-blinded | Country: Multicountry; Funding: Pharm. Ind., grant; Tx Setting: Univ med ctr/large group practice; Multicenter | Patient eligibility based on lung function and utilization; FEV1 minimum 70% pred

a FEV1 pre- or post-bronchodilator status unknown unless otherwise indicated.

Evidence Table 3-2. Study treatment arms

Citation | Pretreatment | Study Arm | N Enrolled | Treatment Arm | | Treatment Duration (weeks) | Comments
Citation | Pretreatment | Study Arm | N Enrolled | Inhaled Corticosteroid and Other Standard Treatment | Additional Medication | Treatment Duration (weeks) | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 165 | 500 mcg FP 2x daily | placebo | 28
Aubier, Pieters, Schlosser, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 167 | 500 mcg FP 2x daily | 50 mcg salmeterol 2x daily | 28
Boulet, Cartier, Milot, et al., 1998 | | Xover Ctl | 16 | ICS: BDP or equivalent at a dose of at least 400 mcg but not greater than 1,000 mcg; mean ± SEM dose at baseline was 640 ± 60. | placebo | 4
Boulet, Cartier, Milot, et al., 1998 | | Xover Exp 1 | 16 | ICS: BDP or equivalent at a dose of at least 400 mcg but not greater than 1,000 mcg; mean ± SEM dose at baseline was 640 ± 60. | 50 mcg salmeterol 2x daily | 4
Boyd, 1995 | Run-in 2 weeks, to establish patient eligibility | Control | 64 | 1,500 mcg BDP or equivalent daily | placebo | 12
Boyd, 1995 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 55 | 1,500 mcg BDP or equivalent daily | 100 mcg salmeterol 2x daily | 12
FitzGerald, Chapman, Della Cioppa, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 91 | ICS: All patients used 400-1,200 mcg/day of BDP or BUD; avg. dose 734 mcg | placebo | 24 | Assume ctl group and exp 1 rec'd placebo b/c article states that "all pts. inhaled the content of 1 dry powder capsule 4 times daily containing the appropriate active and inert ingredients to achieve the desired regimen while maintaining blinding"
FitzGerald, Chapman, Della Cioppa, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 89 | ICS: All patients used 400-1,200 mcg/day of BDP or BUD; avg. dose 730 mcg | 12 mcg formoterol 2x daily | 24
Grutters, Brinkman, Aslander, et al., 1999 | | Control | 15 | 400 mcg BDP 2x daily | | 8
Grutters, Brinkman, Aslander, et al., 1999 | | Exp 1 | 12 | 400 mcg BDP 2x daily | 50 mcg salmeterol 2x daily | 8
Kavuru, Melamed, Gross, et al., 2000 | Run-in 2 weeks, to establish patient eligibility | Control | 90 | FP 100 mcg 2x daily | | 12 | Compliance ranged from 93-100% across all treatment arms
Kavuru, Melamed, Gross, et al., 2000 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 92 | FP 100 mcg 2x daily | salmeterol 50 mcg 2x daily | 12 | Compliance ranged from 93-100% across all treatment arms
Kemp, Cook, Incaudo, et al., 1998 | Run-in 2 weeks, to establish patient eligibility | Control | 254 | ICS: dose within package insert guidelines i.e. BDP, 252-840 mcg/day, flunisolide 1,000-2,000 mcg/day, or TAA 600-1,600 mcg/day | Placebo | 12
Kemp, Cook, Incaudo, et al., 1998 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 252 | ICS: dose within package insert guidelines i.e. BDP, 252-840 mcg/day, flunisolide 1,000-2,000 mcg/day, or TAA 600-1,600 mcg/day | 42 mcg salmeterol 2x daily | 12
Langley, Masterson, Batty, et al., 1998 | Run-in 2 weeks, to establish patient eligibility; Pre-treatment washout, 2 weeks | Control | 25 | ICS: 400-1,000 mcg/day BDP or BUD, or 200-500 mcg FP; 100% received Ipratropium bromide as needed | Placebo | 4
Langley, Masterson, Batty, et al., 1998 | Run-in 2 weeks, to establish patient eligibility; Pre-treatment washout, 2 weeks | Exp 1 | 24 | ICS: 400-1,000 mcg/day BDP or BUD, or 200-500 mcg FP; 100% received Ipratropium bromide as needed | 50 mcg salmeterol 2x daily | 4
Li, Ward, Thien, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 16 | 400 mcg BDP or BUD 1x daily | placebo | 12 | ICS dose = median; range for all groups=200-500;
Li, Ward, Thien, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 13 | 400 mcg BDP or BUD 1x daily | 50 mcg salmeterol 2x daily | 12
Pauwels, Lofdahl, Postma, et al, 1997 | Run-in 4 weeks, to establish patient eligibility | Control | 213 | 100 mcg BUD 2x daily | Placebo | 52
Pauwels, Lofdahl, Postma, et al, 1997 | Run-in 4 weeks, to establish patient eligibility | Exp 1 | 210 | 100 mcg BUD 2x daily | 12 mcg formoterol 2x daily | 52
Pauwels, Lofdahl, Postma, et al, 1997 | Run-in 4 weeks, to establish patient eligibility | Exp 2 | 214 | 400 mcg BUD 2x daily | Placebo | 52
Pauwels, Lofdahl, Postma, et al, 1997 | Run-in 4 weeks, to establish patient eligibility | Exp 3 | 215 | 400 mcg BUD 2x daily | 12 mcg formoterol 2x daily | 52
Pearlman, Stricker, Weinstein, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 23 | | Placebo | 4
Pearlman, Stricker, Weinstein, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 2 | 23 | 88 mcg FP 2x daily | | 4
Pearlman, Stricker, Weinstein, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 3 | 23 | 220 mcg FP 2x daily | | 4
Pearlman, Stricker, Weinstein, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 4 | 25 | 88 mcg FP 2x daily | 42 mcg salmeterol 2x daily | 4
Pearlman, Stricker, Weinstein, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 5 | 21 | 220 mcg FP 2x daily | 42 mcg salmeterol 2x daily | 4
Russell, Williams, Weller, et al., 1995 | Run-in 2 weeks, to establish patient eligibility | Control | 99 | BDP or BUD in doses ranging from 400-2,400 mcg/day, average dose 750 mcg/day | Placebo | 12
Russell, Williams, Weller, et al., 1995 | Run-in 2 weeks, to establish patient eligibility | Exp1 | 107 | BDP or BUD in doses ranging from 400-2,400 mcg/day, average dose 750 mcg/day | 50 mcg salmeterol 2x daily | 12
Shapiro, Lumry, Wolfe, et al., 2000 | Run-in 2 weeks, to establish patient eligibility | Control | | 250 mcg FP 2x daily | | 12
Shapiro, Lumry, Wolfe, et al., 2000 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | | 250 mcg FP 2x daily | 50 mcg salmeterol 2x daily | 12
van der Molen, Postma, Turner, et al., 1997 | Run-in 4 weeks, to establish patient eligibility | Control | 114 | Many kinds of ICS used, equipotent doses as follows: 92 patients used <800 mcg/day, 99 800-1,600 mcg/day, 44 >1,600 mcg/day | placebo | 24
van der Molen, Postma, Turner, et al., 1997 | Run-in 4 weeks, to establish patient eligibility | Exp 1 | 125 | Many kinds of ICS used, equipotent doses as follows: 92 patients used <800 mcg/day, 99 800-16,00 mcg/day, 44 >1,600 mcg/day | 24 mcg formoterol 2x daily | 24
Verberne, Frost, Duiverman, et al., 1998 | Run-in 6 weeks, to establish patient eligibility | Control | 57 | 200 mcg BDP 2x daily | Placebo | 54
Verberne, Frost, Duiverman, et al., 1998 | Run-in 6 weeks, to establish patient eligibility | Exp 1 | 60 | 200 mcg BDP 2x daily | 50 mcg Salmeterol 2x daily | 54
Weersink, Douma, Postma, et al., 1997 | Run-in 1 weeks, to establish patient eligibility | Control | 17 | 250 mcg FP 2x daily | Placebo | 6
Weersink, Douma, Postma, et al., 1997 | Run-in 1 weeks, to establish patient eligibility | Exp 1 | 16 | 250 mcg FP 2x daily | 50 mcg salmeterol 2x daily | 6
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | Run-in 1 weeks, to establish patient eligibility | Xover Ctl | 17 | 1,500 mcg ICS 1x daily, dose progressively reduced during tx until exacerbation or total withdrawal | Placebo | Until mild exacerbation or total ICS withdrawal
McIvor, Pizzichini, Turner, et al., 1998 | Run-in 1 weeks, to establish patient eligibility | Xover Exp 1 | 17 | 1,500 mcg ICS 1x daily, dose progressively reduced during tx until exacerbation or total withdrawal | 50 mcg salmeterol 2x daily | Until mild exacerbation or total ICS withdrawal
Nielsen, Pedersen, Faurschou, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 19 | BDP, 800-1,600 mcg daily, avg. dose 1,179 mcg; dose reduced by 200 mcg per week until patients became unstable | Placebo | Until minimal acceptable ICS dose achieved | Actual length of treatment period is unknown but 12 wks is estimated from Fig
Nielsen, Pedersen, Faurschou, et al., 1999 | 'Sensitivity' period during which ICS reduced by 200 mcg each week until asthma became unstable | Exp 1 | 15 | BDP, 800-1,600 mcg daily, avg. dose 1,280 mcg; dose reduced by 200 mcg per week until patients became unstable | 50 mcg salmeterol 2x daily | Until minimal acceptable ICS dose achieved
Wilding, Clark, Coon, et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Xover Ctl | 100 | Minimum 100 mcg/day BDP or BUD 2x daily | Placebo | 24
Wilding, Clark, Coon, et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Xover Exp 1 | 100 | Minimum 100 mcg/day BDP or BUD 2x daily | 50 mcg salmeterol 2x daily | 24
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 223 | 220 mcg FP 2x daily | Placebo | 12
Baraniuk, Murray, Nathan, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 231 | 88 mcg FP 2x daily; | 42 mcg salmeterol 2x daily | 12
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 65 | 500 mcg BDP 2x daily | | 12
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 69 | 250 mcg BDP 2x daily | 12 mcg formoterol 2x daily | 12
Condemi, Goldstein, Kalberg, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 216 | 220 mcg FP 2x daily | Placebo | 24 | During screening period, all pts. used 88 mcg of FP
Condemi, Goldstein, Kalberg, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 221 | 88 mcg FP 2x daily | 42 mcg salmeterol 2x daily | 24
Greening, Ind, Northfield, et al., 1994 | Run-in 2 weeks, to establish patient eligibility | Control | 206 | 500 mcg BDP 2x daily | Placebo | 21
Greening, Ind, Northfield, et al., 1994 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 220 | 200 mcg BDP 2x daily | 50 mcg salmeterol 2x daily | 21
Kelsen, Church, Gillman, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 244 | 336 mcg BDP 2x daily | | 24
Kelsen, Church, Gillman, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 239 | 168 mcg BDP 2x daily | 42 mcg salmeterol 2x daily | 24
Murray, Church, Anderson, et al., 1999 | Run-in weeks, to establish patient eligibility | Control | 254 | 336 mcg BDP 2x daily; maintenance theophylline allowed, no doses stated | | 24
Murray, Church, Anderson, et al., 1999 | Run-in weeks, to establish patient eligibility | Exp 1 | 260 | 168 mcg BDP 2x daily; maintenance theophylline allowed, no doses stated | 42 mcg salmeterol 2x daily | 24
Pauwels, Lofdahl, Postma, et. al., 1997 | Run-in 4 weeks, to establish patient eligibility | Control | 214 | 400 mcg BUD 2x daily | Placebo | 52
Pauwels, Lofdahl, Postma, et. al., 1997 | Run-in 4 weeks, to establish patient eligibility | Exp 1 | 210 | 100 mcg BUD 2x daily | 12 mcg formoterol 2x daily | 52
Pearlman, Stricker, Weinstein, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 23 | 220 mcg FP 2x daily | | 4
Pearlman, Stricker, Weinstein, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 2 | 25 | 88 mcg FP 2x daily | 42 mcg salmeterol 2x daily | 4
van Noord, Schreurs, Mol, et al., 1999 | Run-in 4 weeks, to establish patient eligibility | Control | 135 | FP either 100 (if prestudy ICS dose 400-600 mcg/day) or 250 mcg (if pre-study ICS dose 800-1,200 mcg/day) 2x daily | | 12
van Noord, Schreurs, Mol, et al., 1999 | Run-in 4 weeks, to establish patient eligibility | Exp 1 | 139 | FP either 100 (if prestudy ICS dose 400-600 mcg/day) or 250 mcg (if prestudy ICS dose 800-1,200 mcg/day) 2x daily | 50 mcg salmeterol 2x daily | 12
Verberne, Frost, Duiverman, et al., 1998 | | Control | 60 | 200 mcg BDP 2x daily | 200 mcg BDP 2x daily | 54
Verberne, Frost, Duiverman, et al., 1998 | | Exp 1 | 60 | 200 mcg BDP 2x daily | 50 mcg salmeterol 2x daily | 54
Vermetten, Boermans, Luiten, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Control | 120 | 400 mcg BDP 2x daily | | 12
Vermetten, Boermans, Luiten, et al., 1999 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 113 | 200 mcg BDP 2x daily | 50 mcg salmeterol 2x daily
Woolcock, Lundback, Ringdal, et al., 1996 | Run-in 1 week for patients on 500 mcg BDP, 4 weeks if on 400 mcg; additional 1 week run-in for all; to standardize treatment meds | Control | 251 | 1,000 mcg BDP 2x daily; 18% received Methylxanthines; 4% received Cromolyn; 5% received inhaled anticholinergics | | 26
Woolcock, Lundback, Ringdal, et al., 1996 | Run-in 1 week for patients on 500 mcg BDP, 4 weeks if on 400 mcg; additional 1 week run-in for all; to standardize treatment meds | Exp 1 | 243 | 500 mcg BDP 2x daily; 21% received Methylxanthines; 3% received Cromolyn; 2% received inhaled anticholinergics at prestudy doses | 50 mcg salmeterol 2x daily | 26
Woolcock, Lundback, Ringdal, et al., 1996 | Run-in 1 week for patients on 500 mcg BDP, 4 weeks if on 400 mcg; additional 1 week run-in for all; to standardize treatment meds | Exp 2 | 244 | 500 mcg BDP 2x daily; 21% received Methylxanthines; 2% received Cromolyn; 2% received inhaled anticholinergics at prestudy doses | 100 mcg salmeterol 2x daily | 26
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 | | Control | 40 | 500 mcg BDP x daily | Placebo | 24
Emad, 1996 | | Exp 1 | 40 | 500 mcg BDP x daily | 250 mg theophylline 1x daily | 24
Meltzer, Orgel, Ellis, et al., 1992 | Run-in 2 weeks, to standardize treatment meds | Control | 37 | 84 mcg BDP 4x daily; 180 mcg Albuterol (salbutamol) 4x daily | Placebo | 12
Meltzer, Orgel, Ellis, et al., 1992 | Run-in 2 weeks, to standardize treatment meds | Exp 1 | 35 | 84 mcg BDP 4x daily; 180 mcg Albuterol (salbutamol) 4x daily | Theophylline | 12
Minoguchi, Kohno, Oda, et al., 1998 | Run-in 12 weeks, to standardize treatment meds | Control | 19 | 400 mcg BDP 1x daily | 400 mg theophylline 1x daily | 6
Minoguchi, Kohno, Oda, et al., 1998 | Run-in 12 weeks, to standardize treatment meds | Exp 1 | 19 | 400 mcg BDP 1x daily | 400 mg theophylline 1x daily | 6
Nassif, Weinberger, Thompson, et al., 1981 | | Xover Ctl | 22 | 200 mcg BDP 1x daily | Placebo | 4
Nassif, Weinberger, Thompson, et al., 1981 | | Xover Exp 1 | 22 | 200 mcg BDP 1x daily | Theophylline | 4 | Patients had been previously receiving theophylline; all titered to serum concentration of 10-20 mcg/mL
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Control | 31 | 800 mcg BUD 2x daily | Placebo | 12 | 66 patients randomized (distribution not reported), 4 dropped before 1^st^ clinic visit, no baseline data available; All patients received 800 mcg BUD daily during run-in
Evans, Taylor, Zetterstrom et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 31 | 400 mcg BUD 2x daily | 375 mg theophylline 2x daily | 12 | 66 patients randomized (distribution not reported), 4 dropped before 1^st^ clinic visit, no baseline data available; All patients received 800 mcg BUD daily during run-in
Ukena, Harnest, Sakalauskas, et al., 1997 | Run-in 6 weeks, to establish patient eligibility | Control | 90 | 400 mcg BDP 2x daily | Placebo | 6
Ukena, Harnest, Sakalauskas, et al., 1997 | Run-in 6 weeks, to establish patient eligibility | Exp 1 | 100 | 200 mcg BDP 2x daily | 375 mg theophylline 2x daily | 6
Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | Run-in 4 weeks, to establish patient eligibility | Control | 200 | 200 mcg BDP 2x daily | Placebo | 16
Laviolette, Malmstrom, Lu, et al., 1999 | Run-in 4 weeks, to establish patient eligibility | Exp 1 | 193 | 200 mcg BDP 2x daily | 10 mg montelukast sodium 1x daily | 16
Tamaoki, Kondo, Sakai, et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Control | 40 | 750 mcg BDP 1x daily; 91.9% received Theophylline daily; 51.4% received Anticholinergic daily | Placebo | 6
Tamaoki, Kondo, Sakai, et al., 1997 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 43 | 750 mcg BDP 1x daily; 92.9% received Theophylline daily; 50.0% received Anticholinergic daily | 450 mg pranlukast 2x daily | 6
Tomita, Hashimoto, Matsumoto, et al., 1999 | None | Control | 17 | 200 mcg Beclomethasone dipropionate 2x daily; | | 8
Tomita, Hashimoto, Matsumoto, et al., 1999 | None | Exp 1 | 24 | 200 mcg Beclomethasone dipropionate 2x daily; | 225 mg pranlukast 2x daily | 8
Virchow, Prasse, Naya, et al., 2000 | Run-in 2 weeks, to establish patient eligibility | Control | 188 | BDP, BUD, or FP, equivalent mean dose 1,598 mcg 1x daily, range 1,200-4,000 | Placebo | 6
Virchow, Prasse, Naya, et al., 2000 | Run-in 2 weeks, to establish patient eligibility | Exp 1 | 180 | BDP, BUD, or FP, equivalent mean dose 1,650 mcg 1x daily, range 1,000-4,000 | 80 mg zafirlukast 2x daily | 6
Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | Run-in 7 weeks, to standardize treatment meds | Control | 113 | Variety of ICS medications, titered to minimum prestudy, avg. dose 1,079 mcg | placebo | 12
Lofdahl, Reiss, Leff, et al., 1999 | Run-in 7 weeks, to standardize treatment meds | Exp 1 | 113 | Variety of ICS medications, titered to minimum prestudy, avg. dose 976 mcg | 10 mg montelukast sodium 1x daily | 12

Evidence Table 3-3. Population Characteristics

Citation | Asthma Severity | Treatment Arm | Population Age | % Male/Female | Avg Duration of Asthma (Months) | % Atopic Patients | Baseline Lung Function | | Baseline Symptoms
Citation | Asthma Severity | Treatment Arm | Population Age | % Male/Female | Avg Duration of Asthma (Months) | % Atopic Patients | Baseline FEV1 ^a^ , Mean ± SD | Baseline PEF, Mean ± SD | Baseline Symptoms
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | Stated: Not specified; Estimated: Mild-Severe | FP 1,000 mcg; placebo | 50 (Mean); Range: 12-76 | 52.7 / 47.3 | 19% >60-120, 54% >120 | 49.0 | 2.33 +/− 0.8 L | 351 +/− 104.0 L/min (a.m., home)
Aubier, Pieters, Schlosser, et al., 1999 | Stated: Not specified; Estimated: Mild-Severe | FP 1,000 mcg; salmeterol 100 mcg; placebo | 46 (Mean); Range: 12-78 | 57.5 / 42.5 | 22% >60-120, 53% >120 | 52.0 | 2.44 +/− 0.8 L | 359 +/− 95.6 L/min (a.m., home)
Boulet, Cartier, Milot, et al., 1998 | Stated: Mild-moderate Estimated: Mild-moderate | ICS ^b^ ; placebo | 45.3 (Mean) +/− 17.2 | 46.7 / 53.3 | 186 | 46.7 | 77.3 +/− 11.2% pred (prebronchodilator)
Boulet, Cartier, Milot, et al., 1998 | Stated: Mild-moderate Estimated: Mild-moderate | ICS ^b^ ; salmeterol 100 mcg | 45.3 (Mean) +/− 17.2 | 46.7 / 53.3 | 186 | 46.7 | 76.7 +/− 10.0% pred (prebronchodilator)
Boyd, 1995 | Stated: Severe; Estimated: Severe | ICS 1,500 mcg; placebo | 47 (Mean); Range: 18-73 | 45.3 / 54.7 | | | 1.87 +/− 0.74L | 289 +/− 111 L/min (a.m., home) | Daytime symptom score, 0.94 +/− 0.22 (scale, 0-4); % symptom-free days, 7; % symptom-free nights, 29
Boyd, 1995 | Stated: Severe; Estimated: Severe | ICS 1,500 mcg; salmeterol 200 mcg | 47 (Mean); Range: 18-79 | 40.0 / 60.0 | | | 1.78 +/− 0.71L | 267 +/− 94 L/min (a.m., home) | Daytime symptom score, 0.94 +/− 0.23 (scale, 0-4); % symptom-free days, 8; % symptom-free nights, 20
FitzGerald, Chapman, Della Cioppa, et al., 1999 | Stated: Not specified; Estimated: Unable to estimate | ICS ^c^ 734 mcg; placebo | 36 (Mean) +/− 12 | 36.3 / 63.7 | | | 2.67 +/− 0.74 L (a.m. pre-bronchodilator) | 438 +/− 86 L/min (a.m., home) | Daytime symptom score, 0.93 (Mean; scale, 0-4)
FitzGerald, Chapman, Della Cioppa, et al., 1999 | Stated: Not specified; Estimated: Unable to estimate | ICS ^c^ 730 mcg; formoterol 24 mcg; Placebo | 36 (Mean) +/− 13 | 52.8 / 47.2 | | | 2.79 +/− 0.79 L (a.m. pre-bronchodilator) | 442 +/− 90 L/min (a.m., home) | Daytime symptom score, 1.01 (Mean; scale, 0-4)
Grutters, Brinkman, Aslander, et al., 1999 | Stated: Moderate; Estimated: Moderate | BDP 800 mcg | 26 (Mean) +/− 19.4 | 53.0 / 47.0 | | 100.0 | 86 +/− 15.5% pred (prebronchodilator)
Grutters, Brinkman, Aslander, et al., 1999 | Stated: Moderate; Estimated: Moderate | BDP 800 mcg; salmeterol 100 mcg; | 27 (Mean) +/− 20.8 | 50.0 / 50.0 | | 100.0 | 79 +/− 17.3% pred (prebronchodilator)
Kavuru, Melamed, Gross, et al., 2000 | Stated: Estimated: | FP 200 mcg | 39 (Mean); Range: 12-67 | 52.0/48.0 | | | 2.11 +/− 0.7 L (prebronchodilator) | 374 +/− 107.2 L/min (a.m., home) | Daytime symptom score, 1.6 +/− 1.0 (scale, 0-5; % symptom-free days, 19.4+/−34.5; % symptom-free nights, 91.3+/−16.5
Kavuru, Melamed, Gross, et al., 2000 | Stated: Estimated: | FP 200 mcg; salmeterol 100 mcg | 38 (Mean); Range: 12-70 | 59.0/41.0 | | | 2.17 +/− 0.6 L (prebronchodilator) | 393 +/− 101.7 L/min(a.m., home) | Daytime symptom score, 1.5 +/− 1.1 (scale, 0-5; % symptom-free days, 25.2+/−37.3; % symptom-free nights, 91.7+/−14.7
Kemp, Cook, Incaudo, et al., 1998 | Stated: Not specified; Estimated: Moderate-severe | ICS ^d^ ; placebo | 41.6 (Mean) +/− 15.9 | 48.0 / 52.0 | | | 2.17 +/− 0.6 L | 369 +/− 95.6 L/min (a.m., home) | % symptom-free days, 4
Kemp, Cook, Incaudo, et al., 1998 | Stated: Not specified; Estimated: Moderate-severe | ICS ^d^ ; salmeterol 84 mcg | 42 (Mean) +/− 15.9 | 45.0 / 55.0 | | | 2.16 +/− 0.6 L | 372 +/− 111.1 L/min (a.m., home) | % symptom-free days, 5
Langley, Masterson, Batty, et al., 1998 | Stated: Mild-moderate; Estimated: Mild-Severe | ICS ^e^ ; ipratropium bromide; placebo | 37.5 (Median); Range: 20-69 | 50.0 / 50.0 | | | 2.4 +/− 0.64 L (prebronchodilator) | 370 +/− 440.9 L/min (a.m., home) | Daytime symptom score, 1 (scale not reported); % symptom-free days, 19.8
Langley, Masterson, Batty, et al., 1998 | Stated: Mild-moderate; Estimated: Mild-Severe | ICS ^e^ ; ipratropium bromide; salmeterol 100 mcg | 49 (Median); Range: 19-68 | 52.0 / 48.0 | | | 2.29 +/− 0.54 L (prebronchodilator) | 368 +/− 350.0 L/min (a.m., home) | Daytime symptom score, 1 (scale not reported); % symptom-free days, 30.3
Li, Ward, Thien, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | BDP or BUD 400 mcg; placebo | 33 (Median); Range: 22-68 | 43.7 / 56.3 | | 75.0 | 82 +/− 12.0% pred (a.m. prebronchodilator) | 405 +/− 80.0 L/min (a.m., home) | Daytime symptom score, 1.45 +/− 1.0 (scale, 0-4)
Li, Ward, Thien, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | BDP or BUD 400 mcg; salmeterol 100 mcg | 38 (Median); Range: 20-70 | 61.5 / 38.5 | | 100.0 | 85 +/− 14.4% pred (a.m. Prebronchodilator) | 460 +/− 108.2 L/min (a.m., home) | Daytime symptom score, 1.5 +/− 0.9 (scale, 0-4)
Pauwels, Lofdahl, Postma, et al, 1997 | Stated: Not specified; Estimated: Moderate-severe | BUD 200 mcg; placebo | 42 18-70 | 50.1 / 49.9 | | | 75.8 +/− 17.5% pred (prebronchodilator) | 397 L/min (a.m., home) | Daytime symptom score, 0.50 (Mean; scale, 0-3)
Pauwels, Lofdahl, Postma, et al, 1997 | Stated: Not specified; Estimated: Moderate-severe | BUD 200 mcg; Formoterol 24 mcg | 41 18-68 | 49.5 / 50.5 | | | 75.7 +/− 17.4% pred (prebronchodilator) | 399 L/min (a.m., home) | Daytime symptom score, 0.52 (Mean; scale, 0-3)
Pauwels, Lofdahl, Postma, et al, 1997 | Stated: Not specified; Estimated: Moderate-severe | BUD 800 mcg; placebo | 44 18-70 | 47.7 / 52.3 | | | 75.4 +/− 16.1% pred (prebronchodilator) | 381 L/min (a.m., home) | Daytime symptom score, 0.49 (Mean; scale, 0-3)
Pauwels, Lofdahl, Postma, et al, 1997 | Stated: Not specified; Estimated: Moderate-severe | BUD 800 mcg; formoterol 24 mcg | 42 17-70 | 47.4 / 52.6 | | | 76.3 +/− 16.1% pred (prebronchodilator) | 394 L/min (a.m., home) | Daytime symptom score, 0.52 (Mean; scale, 0-3)
Pearlman, Stricker, Weinstein, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | FP 176 mcg | 27 (Mean); Range: 13-50 | 74.0 / 26.0 | | | 2.91 +/− 0.6 L (a.m. Pre-bronchodilator) | 438 +/− 76.7 L/min (a.m., home) | Daytime symptom score, 1.2 +/− 0.5 (scale, 0-3); % symptom-free days, 11; % symptom-free nights, 88
| | salmeterol 84 mcg; FP 176 mcg | 33 (Mean); Range: 14-60 | 40.0 / 60.0 | | | 2.31 +/− 0.6 L (a.m. pre-bronchodilator) | 399 +/− 90.0 L/min (a.m., home) | Daytime symptom score, 1.2 +/− 1.0 (scale, 0-3); % symptom-free days, 29; % symptom-free nights, 90
| | FP 440 mcg | 32 (Mean); Range: 14-61 | 57.0 / 43.0 | | | 2.52 +/− 0.7 L (a.m. pre-bronchodilator) | 411 +/− 100.7 L/min (a.m., home) | Daytime symptom score, 1.3 +/− 1.0 (scale, 0-3); % symptom-free days, 22; % symptom-free nights, 90
| | salmeterol 84 mcg; FP 440 mcg | 26 (Mean); Range: 13-52 | 67.0 / 33.0 | | | 2.62 +/− 0.5 L (a.m. pre-bronchodilator) | 458 +/− 110.0 L/min (a.m., home) | Daytime symptom score, 1.1 +/− 0.9 (scale, 0-3); % symptom-free days, 27; % symptom-free nights, 92
Shapiro, Lumry, Wolfe, et al., 2000 | Stated: Not specified Estimated: Mild-severe | FP 500 mcg | 40 (Mean); Range: 12-67 | 54.0 / 46.0 | | | 2.12 +/− 0.54 L (a.m. prebronchodilator) | 83 +/− 15.6% of predicted (a.m., home) | Daytime symptom score, 1.6 +/− 1.1 (scale, 0-5); % symptom-free days, 23.5; % symptom-free nights, 90.5
Shapiro, Lumry, Wolfe, et al., 2000 | Stated: Not specified Estimated: Mild-severe | FP 500 mcg; salmeterol 100 mcg | 38 (Mean); Range: 12-69 | 48.0 / 52.0 | | | 2.23 +/− 0.63 L (a.m. prebronchodilator) | 79 +/− 16.5% of predicted (a.m., home) | Daytime symptom score, 1.4 +/− 1.0 (scale, 0-5); % rescue-free days, 26.5; % symptom-free nights, 90.7
Russell, Williams, Weller, et al., 1995 | Stated: Moderate-severe; Estimated: Moderate-severe | BDP ^g^ Or equiv, avg. 750 mcg; placebo | 10.3 (Mean) +/− 2.7 | 61.0 / 39.0 | 77% >60, 22% 12-60, 1% <12 | | | 79.7% pred (a.m., home) | % symptom-free days, 8; % symptom-free nights, 38
Russell, Williams, Weller, et al., 1995 | Stated: Moderate-severe; Estimated: Moderate-severe | BDP ^g^ or equiv, avg. 750 mcg; salmeterol 100 mcg | 10.2 (Mean) +/− 2.7 | 60.0 / 40.0 | 74% >60, 20% 12-60, 6% <12 | | | 79.2% pred (a.m., home) | % symptom-free days, 15; % symptom-free nights, 57
van der Molen, Postma, Turner, et al., 1997 | Stated: Mild-moderate; Estimated: Moderate-severe | ICS ^h^ ; placebo | 45.4 (Mean) +/− 14 | 49.2 / 50.8 | 247.2, overall | 66.6 | 2.16 +/− 0.8 L (a.m. prebronchodilator) | 382 +/− 101.4 L/min (a.m., home) | Daytime symptom score, 3.6 +/− 3 (scale, 0-3)
van der Molen, Postma, Turner, et al., 1997 | Stated: Mild-moderate; Estimated: Moderate-severe | ICS ^h^ ; formoterol 48 mcg | 40.5 (Mean) +/− 13.7 | 48.8 / 51.2 | 247.2, overall | 68.8 | 2.29 +/− 0.7 L (a.m. prebronchodilator) | 392 +/− 99.3 L/min (a.m., home) | Daytime symptom score, 3.7 +/− 2.8 (scale, 0-3)
Verberne, Frost, Duiverman, et al., 1998 | Stated: Mild-moderate; Estimated: Mild-moderate | BDP 400 mcg | 11.1 (Mean) +/− 2.7 | 63.2 / 36.8 | 102 | 87.7 | 102.2 +/− 12% pred (postbronchodilator) | 317 +/− 79 L/min (a.m., home + ?clinic) | % patients without symptoms, 11
Verberne, Frost, Duiverman, et al., 1998 | Stated: Mild-moderate; Estimated: Mild-moderate | BDP 400 mcg; salmeterol 100 mcg | 10.8 (Mean) +/− 2.5 | 66.7 / 33.3 | 93.6 | 88.3 | 103.5 +/− 13.1% pred (postbronchodilator) | 299 +/− 79 L/min (a.m., home + ?clinic)
Weersink, Douma, Postma, et al., 1997 | Stated: Not specified; Estimated: Mild-moderate | FP 500 mcg | 28 (Mean) +/− 6.2 | 43.8 / 56.2 | | 100.0 | 88.4 +/− 19.5% pred (a.m.)
Weersink, Douma, Postma, et al., 1997 | Stated: Not specified; Estimated: Mild-moderate | FP 500 mcg; salmeterol 100 mcg | 26 (Mean) +/− 7 | 50.0 / 50.0 | | 100.0 | 83.1 +/− 14.4% pred (a.m.)
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | Stated: Not specified; Estimated: Mild-Severe | ICS 1,500 mcg; placebo | 43.6 (Mean) +/− 10.7 | 38.5 / 61.5 | | 76.9 | 77.4 +/− 17.2% pred (prebronchodilator) | 414 +/− 112 L/min (a.m., home) | Daytime symptom score, 31.4 +/− 2.9 (scale, 9-1)
McIvor, Pizzichini, Turner, et al., 1998 | Stated: Not specified; Estimated: Mild-Severe | ICS 1,500 mcg; salmeterol 100 mcg | 43.6 (Mean) +/− 10.7 | 38.5 / 61.5 | | 76.9 | 75.2 +/− 16.3% pred (prebronchodilator) | 419 +/− 108 L/min (a.m., home) | Daytime symptom score, 30.9 +/− 4.7 (scale, 9-1)
Nielsen, Pedersen, Faurschou, et al., 1999 | Stated: Not specified; Estimated: Moderate | BDP ^f^ avg. 1,179 mcg; placebo | 43 (Mean) | 52.6 / 47.4 | 154.8 | | 86.7% pred (prebronchodilator)
Nielsen, Pedersen, Faurschou, et al., 1999 | Stated: Not specified; Estimated: Moderate | BDP ^f^ avg. 1,280 mcg; salmeterol 100 mcg | 45 (Mean) | 33.3 / 66.7 | 184.8 | | 86.1% pred (prebronchodilator)
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
Wilding, Clark, Coon, et al., 1997 | Stated: Mild-moderate; Estimated: Moderate-severe | ICS ^j^ ; placebo | 39 (Mean) +/− 10 | 50.5 / 49.5 | | 79.0 | 2.71 +/− 0.79 L (prebronchodilator) | 415 +/− 101 L/min (a.m., home) | Daytime symptom score, 0 (Median; scale, 0-5); % symptom-free days, 56; % symptom-free nights, 93
Wilding, Clark, Coon, et al., 1997 | Stated: Mild-moderate; Estimated: Moderate-severe | ICS ^j^ ; salmeterol 100 mcg | 39 (Mean) +/− 10 | 50.5 / 49.5 | | 79.0 | 2.71 +/− 0.79 L (prebronchodilator) | 415 +/− 101 L/min (a.m., clinic) | Daytime symptom score, 0 (Median; scale, 0-5); % symptom-free days, 56; % symptom-free nights, 93
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | Stated: Not specified; Estimated: Mild-Severe | FP 440 mcg; placebo | 40 (Mean); Range: 12-74 | 39.0 / 61.0 | | | 63.1 +/− 12.2% pred (a.m. prebronchodilator) | 65 +/− 14.9% pred (home) | Daytime symptom score, 1.09 +/− 0.7 (scale, 0-4); % symptom-free days, 11.6; nights/week with symptoms, 0.47
Baraniuk, Murray, Nathan, et al., 1999 | Stated: Not specified; Estimated: Mild-Severe | FP 176 mcg; salmeterol 84 mcg | 41 (Mean); Range: 12-79 | 41.0 / 59.0 | | | 63.1 +/− 11.9% pred (a.m. prebronchodilator) | 68 +/− 15.2 L/min (home) | Daytime symptom score, 0.98 +/− 0.6 (scale, 0-4); % symptom-free days, 11.7; nights/week with symptoms, 0.47
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | BDP 1,000 mcg | 43 (Mean) +/− 14.9 | 34.8 / 65.2 | | | 2.15 +/− 0.75 L (prebronchodilator) | 356.4 +/− 96.2 L/min (a.m., home) | Daytime symptom score, 1.1 (Mean; scale, 0-4)
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | BDP 500 mcg; formoterol 24 mcg | 43 (Mean) +/− 14.9 | 34.8 / 65.2 | | | 2.27 +/− 0.79 L (prebronchodilator), | 380.4 +/− 108.8 L/min (a.m., home) | Daytime symptom score, 1.2 (Mean; scale, 0-4)
Condemi, Goldstein, Kalberg, et al., 1999 | Stated: Not specified; Estimated: Mild-Severe | FP 440 mcg; placebo | 36.8 (Mean) +/− 13.2 | 40.0 / 60.0 | | | 2.14 +/− 0.6 L (a.m. prebronchodilator) | 363.7 +/− 111.7 L/min (a.m., home) | Daytime symptom score, 1.04 (Mean; scale, 0-4); % symptom-free days, 15.3; % symptom-free nights, 76.6
Condemi, Goldstein, Kalberg, et al., 1999 | Stated: Not specified; Estimated: Mild-Severe | FP 176 mcg; salmeterol 84 mcg | 36.9 (Mean) +/− 13.4 | 38.0 / 62.0 | | | 2.12 +/− 0.6 L (a.m. prebronchodilator) | 363.6 +/− 116.0 L/min (a.m., home) | Daytime symptom score, 1.07 (Mean; scale, 0-4); % symptom-free days, 10; % symptom-free nights, 71.7
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Greening, Ind, Northfield, et al., 1994 | Stated: Not specified; Estimated: Moderate-severe | BDP 1,000 mcg; placebo | 47 (Mean) +/− 15 | 41.0 / 59.0 | 132 | | | 339 +/− 99 L/min (a.m., home) | % days with symptoms, 87; % nights with symptoms, 35; daytime symptom score, 1.43 (Median; scale range, 6)
Greening, Ind, Northfield, et al., 1994 | Stated: Not specified; Estimated: Moderate-severe | BDP 400 mcg; salmeterol 100 mcg | 48 (Mean) +/− 15 | 46.0 / 54.0 | 133.2 | | | 349 +/− 109 L/min (a.m., home) | % days with symptoms, 87; % nights with symptoms, 41; daytime symptom score, 1.5 (Median; scale range, 6)
Kelsen, Church, Gillman, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | BDP 672 mcg | 42 (Mean) +/− 12.5 | 35.0 / 65.0 | | | 64.14 +/− 10.2% pred (a.m. prebronchodilator) | 387.6 L/min (a.m., home) | % symptom-free days, 10; % symptom-free nights, 68
Kelsen, Church, Gillman, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | BDP 336 mcg; salmeterol 84 mcg | 42.4 (Mean) +/− 13.9 | 43.0 / 57.0 | | | 64.93 +/− 10.2% pred (a.m. prebronchodilator) | 389.7 L/min (a.m., home) | % symptom-free days, 9.5; % symptom-free nights, 67
Murray, Church, Anderson, et al., 1999 | Stated: Not specified; Estimated: Mild-Severe | BDP 672 mcg | 41.9 (Mean) +/− 14.3 | 45.0 / 55.0 | | | 2.31 L (a.m. prebronchodilator) | 381.6 L/min (a.m., home) | Daytime symptom score, 1.1 (Mean; scale, 0-4); % symptom-free days, 12; % symptom-free nights, 61.5
Murray, Church, Anderson, et al., 1999 | Stated: Not specified; Estimated: Mild-Severe | BDP 336 mcg; salmeterol 84 mcg | 42.8 (Mean) +/− 12.9 | 41.0 / 59.0 | | | 2.3 L (a.m. prebronchodilator) | 390.2 L/min (a.m., home) | Daytime symptom score, 1.15 (Mean; scale, 0-4); % symptom-free days, 10; % symptom-free nights, 61.5
Pauwels, Lofdahl, Postma, et. al., 1997 | Stated: Not specified; Estimated: Moderate-severe | BUD 800 mcg; placebo | 44 18-70 | 47.7 / 52.3 | | | 75.4 +/− 16.1% pred (prebronchodilator) | 381 L/min (a.m., home) | Daytime symptom score, 0.49 (Mean; scale, 0-3)
Pauwels, Lofdahl, Postma, et. al., 1997 | Stated: Not specified; Estimated: Moderate-severe | BUD 200 mcg; formoterol 24 mcg | 41 18-68 | 49.5 / 50.5 | | | 75.7 +/− 17.4% pred (prebronchodilator) | 399 L/min (a.m., home) | Daytime symptom score, 0.52 (Mean; scale, 0-3)
Pearlman, Stricker, Weinstein, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | FP 440 mcg | 32 (Mean); Range: 14-61 | 57.0 / 43.0 | | | 2.52 +/− 0.7 L (a.m. prebronchodilator) | 411 +/− 100.7 L/min (a.m., home) | Daytime symptom score, 1.3 +/− 1.0 (scale, 0-3); % symptom-free days, 22; % symptom-free nights, 90
Pearlman, Stricker, Weinstein, et al., 1999 | Stated: Not specified; Estimated: Moderate-severe | salmeterol 84 mcg; FP 176 mcg | 33 (Mean); Range: 14-60 | 40.0 / 60.0 | | | 2.31 +/− 0.6 L (a.m. prebronchodilator) | 399 +/− 90.0 L/min (a.m., home) | Daytime symptom score, 1.2 +/− 1.0 (scale, 0-3); % symptom-free days, 29; % symptom-free nights, 90
van Noord, Schreurs, Mol, et al., 1999 | Stated: Mild-moderate; Estimated: Mild-Severe | FP 400 or 1,000 mcg/day | 47 (Mean) +/− 14 | 49.6 / 50.4 | | | 2.39 +/− 8.7 L (a.m. Prebronchodilator) | 365 +/− 1,359.4 L/min (home) | Days/wk with symptoms, 9; nights/week with symptoms, 5.9
van Noord, Schreurs, Mol, et al., 1999 | Stated: Mild-moderate; Estimated: Mild-Severe | FP 200 or 500 mcg/day salmeterol 100 mcg | 46 (Mean) +/− 15 | 47.5 / 52.5 | | | 2.38 +/− 8.8 L (a.m. prebronchodilator) | 367 +/− 1,344.0 L/min (home) | Days/wk with symptoms, 9; nights/week with symptoms, 6.8
Verberne, Frost, Duiverman, et al., 1998 | Stated: Mild-moderate; Estimated: Mild-moderate | BDP 400 mcg | 11.4 (Mean) +/− 2.9 | 60.0 / 40.0 | 108 | 91.7 | 100.9 +/− 12.3% pred (postbronchodilator) | 315 +/− 90 L/min (a.m., home + ? clinic) | % patients without symptoms, 13
Verberne, Frost, Duiverman, et al., 1998 | Stated: Mild-moderate; Estimated: Mild-moderate | BDP 200 mcg; salmeterol 100 mcg | 10.8 (Mean) +/− 2.5 | 66.7 / 33.3 | 93.6 | 88.3 | 103.5 +/− 13.1% pred (postbronchodilator) | 299 +/− 79 L/min (a.m., home + ? clinic)
Vermetten, Boermans, Luiten, et al., 1999 | Stated: Mild-persistent; Estimated: Mild-moderate | BDP 800 mcg | 42 (Mean) +/− 14 | 38.0 / 62.0 | | | | 84 +/− 17% pred (a.m., home) | Daytime symptom score, 0.5 +/− 0.5 (scale, 0-3); % days/wk with symptoms, 0.54; % nights/week with symptoms, 41
Vermetten, Boermans, Luiten, et al., 1999 | Stated: Mild-persistent; Estimated: Mild-moderate | BDP 400 mcg; salmeterol 100 mcg | 42 (Mean) +/− 14 | 53.0 / 47.0 | | | | 83 +/− 17% pred (a.m., home) | Daytime symptom score, 0.5 +/− 0.5 (scale, 0-3); % days/wk with symptoms, 0.56; % nights/week with symptoms, 43
Woolcock, Lundback, Ringdal, et al., 1996 | Stated: Not specified; Estimated: Moderate-severe | BDP 2,000 mcg | 42; Range: 17-72 | 54.0 / 46.0 | | | 75% pred | 82% pred (a.m., home) | % symptom-free days, 0; % symptom-free nights, 29
Woolcock, Lundback, Ringdal, et al., 1996 | Stated: Not specified; Estimated: Moderate-severe | BDP 1,000 mcg; salmeterol 100 mcg | 44; Range: 18-79 | 51.0 / 49.0 | | | 72% pred | 82% pred (a.m., home) | % symptom-free days, 0; % symptom-free nights, 43
Woolcock, Lundback, Ringdal, et al., 1996 | Stated: Not specified; Estimated: Moderate-severe | BDP 1,000 mcg; salmeterol 200 mcg | 46; Range: 19-75 | 51.0 / 49.0 | | | 71% pred | 82% pred (a.m., home) | % symptom-free days, 0; % symptom-free nights, 43
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 | Stated: Moderate-severe; Estimated: Unable to estimate | BDP 500 mcg; placebo | 34.47 (Mean) +/− 5.26 | 42.5 / 57.5 | | 20.0 | 1.32 +/− 0.19 L | 174.6 +/− 30.6 L/min (clinic)
Emad, 1996 | Stated: Moderate-severe; Estimated: Unable to estimate | BDP 500 mcg; theophylline 250 mg | 34.52 (Mean) +/− 5.52 | 27.5 / 72.5 | | 12.5 | 1.31 +/− 0.19 L | 172.2 +/− 30.6 L/min (clinic)
Meltzer, Orgel, Ellis, et al., 1992 | Stated: Moderate-severe; Estimated: Moderate-severe | albuterol (salbutamol) 180 mcg; BDP 336 mcg; placebo | 10 (Mean); Range: 6-16 | 24.0 / 76.0 | | | 71 +/− 18.2% pred (a.m. prebronchodilator) | | % patients with score 0/1, 80
Meltzer, Orgel, Ellis, et al., 1992 | Stated: Moderate-severe; Estimated: Moderate-severe | albuterol (salbutamol) 180 mcg; BDP 336 mcg; theophylline 250 mg | 10.1 (Mean); Range: 6-16 | 46.0 / 54.0 | | | 70 +/− 20.1% pred (a.m. prebronchodilator) | | % patients with score 0/1, 72
Minoguchi, Kohno, Oda, et al., 1998 | Stated: Not specified; Estimated: Moderate | BDP 400 mcg; theophylline 400 mg | 45.9 (Mean); Range: 28-65 | 50.0 / 50.0 | 122.4, overall | 56.0 | 2.36 +/− 0.6 L | 485.5 +/− 130.8 L/min (a.m., home) | Daytime symptom score, 1.3 +/− 3.1 (scale, 0-9)
Minoguchi, Kohno, Oda, et al., 1998 | Stated: Not specified; Estimated: Moderate | BDP 400 mcg; theophylline 400 mg | 44.7 (Mean); Range: 19-65 | 53.0 / 47.0 | 122.4, overall | 53.0 | 2.3 +/− 0.6 L | 469.6 +/− 196.2 L/min (a.m., home) | Daytime symptom score, 1.2 +/− 3.1 (scale, 0-9)
Nassif, Weinberger, Thompson, et al., 1981 | Stated: Not specified; Estimated: Unable to estimate | BDP 200 mcg; placebo | 13.6 (Mean); Range: 7-19 | | 126
Nassif, Weinberger, Thompson, et al., 1981 | Stated: Not specified; Estimated: Unable to estimate | BDP 200 mcg; theophylline | 13.6 (Mean); Range: 7-19 | | 126
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | Stated: Moderate Estimated: Mild-severe | BUD 1,600 mcg; placebo | 39.5 (Mean) +/− 14.5; Range: 18-66 | 32/68 | | | 2.50 +/− 0.78 L | 383 +/− 89 L/min (a.m., home)
Evans, Taylor, Zetterstrom et al., 1997 | Stated: Moderate Estimated: Mild-severe | BUD 800 mcg; theophylline 750 mg | 38.1 +/− 13.9; Range, 18-67 | 48/52 | | | 2.48 +/− 1.0 L | 397 +/− 106 L/min (a.m., home)
Ukena, Harnest, Sakalauskas, et al., 1997 | Stated: Mild-moderate; Estimated: Mild-moderate | BDP 800 mcg; placebo | 49 (Mean); Range: 18-70 | 59.4 / 40.6 | | | 2.4 +/− 0.75 L | 344 +/− 105 L/min (a.m., home) | Daytime symptom score, 1.5 (Median; scale, 0-4)
Ukena, Harnest, Sakalauskas, et al., 1997 | Stated: Mild-moderate; Estimated: Mild-moderate | BDP 400 mcg; theophylline 750 mg | 48 (Mean); Range: 20-70 | 53.6 / 46.4 | | | 2.3 +/− 0.62 L | 345 +/− 95 L/min (a.m., home) | Daytime symptom score, 1.5 (Median; scale, 0-4)
Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | Stated: Mild-Severe; Estimated: Moderate | BDP 400 mcg; placebo | 39 (Median); Range: 15-78 | 52.0 / 48.0 | 216 (median) | | 71 +/− 12% pred (a.m.) | 403 +/− 86 L/min (a.m., home) | Daytime symptom score, 2.2 +/− 0.8 (scale, 0-6)
Laviolette, Malmstrom, Lu, et al., 1999 | Stated: Mild-Severe; Estimated: Moderate | BDP 400 mcg; montelukast sodium 10 mg | 40 (Median); Range: 15-76 | 56.0 / 44.0 | 228 (median) | | 72 +/− 12% pred (a.m.) | 412 +/− 91 L/min (a.m., home) | Daytime symptom score, 2.2 +/− 0.8 (scale, 0-6)
Tamaoki, Kondo, Sakai, et al., 1997 | Stated: Not specified; Estimated: Moderate-severe | BDP 750 mcg; theophylline placebo | 47 (Mean) +/− 19.0 | 43.2 / 56.8 | 127.2 | | 81.6 +/− 14.5% pred | 448 +/− 113.8 L/min (a.m., home) | Daytime symptom frequency/wk, 3.5; nighttime symptom frequency/week, 1.4
Tamaoki, Kondo, Sakai, et al., 1997 | Stated: Not specified; Estimated: Moderate-severe | BDP 750 mcg; theophylline; pranlukast 900 mg | 49 (Mean) +/− 19.7 | 42.9 / 57.1 | 135.6 | | 79.1 +/− 17.0% pred | 437 +/− 98.4 L/min (a.m., home) | Daytime symptom frequency/wk, 2.7; nighttime symptom frequency/week, 1.5
Tomita, Hashimoto, Matsumoto, et al., 1999 | Stated: Mild-moderate Estimated: Mild-Moderate | BDP 400 mcg; | 42.2 (Mean) +/− 16.9 | 58.8 / 41.2 | | 64.7 | | 86.3 +/− 19% of predicted (am) | Daytime symptom score, 2.3 +/− 4.0 (scale, ?)
Tomita, Hashimoto, Matsumoto, et al., 1999 | Stated: Mild-moderate Estimated: Mild-Moderate | BDP 400 mcg pranlukast 450 mg | 56.7 (Mean) +/− 18 | 62.5 / 37.5 | | 66.7 | | 90.3 +/− 13.4% of predicted (am) | Daytime symptom score, 2.7 +/− 4.5 (scale, ?)
Virchow, Prasse, Naya, et al., 2000 | Stated: Not specified Estimated: Mild-severe | ICS ^e^ ; placebo | 49.2 (Mean) +/− 12.9; Range: 17-70 | 48/52 | | | 2.01 +/− 0.59 L | 288 +/− 107 L/min (a.m., home) | Daytime symptom score 1.8 +/− 0.03 (scale, 0-3); nighttime awakenings/week, 3.7 +/− 0.4
Virchow, Prasse, Naya, et al., 2000 | Stated: Not specified Estimated: Mild-severe | ICS ^e^ ; zafirlukast 80 mg | 47.4 (Mean) +/− 12.6; Range: 19-71 | 53/47 | | | 2.08 +/− 0.61 L | 308 +/− 103 L/min (a.m., home) | Daytime symptom score 1.8 +/− 0.03 (scale, 0-3); nighttime awakenings/week, 3.6 +/− 0.4
Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | Stated: Not specified; Estimated: Mild-moderate | ICS ^k^ 1,079 mcg; placebo | 41 (Mean); Range: 16-68 | 54.0 / 46.0 | 228 | | 82.3 +/− 12.9% pred | | Daytime symptom score, 1.38 +/− 0.8 (scale, 0-6)
Lofdahl, Reiss, Leff, et al., 1999 | Stated: Not specified; Estimated: Mild-moderate | ICS ^k^ 976 mcg; montelukast sodium 10 mg | 40 (Mean); Range: 17-70 | 41.6 / 58.4 | 216 | | 84.8 +/− 11.1% pred | | Daytime symptom score, 1.29 +/− 0.7 (scale, 0-6)

a Pre- or postbronchodilator status unknown unless otherwise indicated.

b All patients were on BDP or equivalent at a dose of at least 400 mcg but not greater than 1,000 mcg; mean ± SEM dose at baseline was 640 ± 60.

c All patients used 400-1,200 mcg/day of BDP or BUD.

d Patients used ICS dose within package insert guidelines; i.e., BDP, 252-840 mcg/day, flunisolide 1,000-2,000 mcg/day, or triamcinolone 600-1,600 mcg/day.

e Patients were required to be taking 400-1,000 mcg/day ICS such as BDP or BUD, or 200-500 mcg FP for study eligibility. Authors stated only that during the study, "all patients were receiving ICS."

f All patients were on BDP, 800-1,600 mcg daily. The dose was reduced by 200 mcg per week until patients became unstable.

g All patients on either BDP or BUD in doses ranging from 400-2,400 mcg/day, average dose 750 mcg/day. "Additional asthma medications did not preclude patients from continuing in the study."

h Many kinds of ICS used, doses (kept constant at entry and expressed in equipotent doses) as follows: 92 patients used <800 mcg/day, 99 800-1,600 mcg/day, 44 >1,600 mcg/day.

i For patients receiving Salmeterol, FP dose was either 100 mcg or 250 mcg twice a day, depending on prestudy ICS use; those using a dose of 400-600 mcg/day received 200 mcg/day, and those using 800-1,200 mcg/day ICS, received 500 mcg/day. For those receiving FP alone, the dose was doubled.

j All patients continued taking at least 200 mcg/day total BDP or BUD, broken into twice daily doses.

k Patients took a variety of ICS medications and doses, which were tapered to a minimum during the pre-tx period.

l Patients taking placebo also took an average equivalent dose of 1,598 +/− 381 ug/d of BDP, BUD, or FP; for those taking zafirlukast, the average equivalent dose was 1,650 +/− 456.

Evidence Table 3-4. Lung function outcomes. FEV1

Citation | Treatment Arm | N Enrolled | N Evaluable | Treatment Duration (weeks) | Baseline FEV1, Mean ± SD | Final FEV1 ^a^ , Mean ± SD | p-Value | p-Value Comparison | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; placebo | 165 | | 12 | 2.33 +/− 0.8 L | 0.17 +/− 0.3 L (change)
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; salmeterol 100 mcg; placebo | 167 | | 12 | 2.44 +/− 0.8 L | 0.25 +/− 0.6 L (change) | NS | Change, Tx vs. Ctl
Boulet, Cartier, Milot, et al., 1998 | ICS; placebo | 16 | 15 | 4 | 77.3 +/− 11.2% pred (prebronchodilator) | 75 +/− 7.8% pred (prebronchodilator)
Boulet, Cartier, Milot, et al., 1998 | ICS; salmeterol 100 mcg | 16 | 15 | 4 | 76.7 +/− 10.0% pred (prebronchodilator) | 77 +/− 15.5% pred (prebronchodilator)
Boyd, 1995 | ICS 1,500 mcg; placebo | 64 | 52 | 12 | 1.87 +/− 0.74 L | 2.01 +/− 0.68 L
Boyd, 1995 | ICS 1,500 mcg; salmeterol 200 mcg | 55 | 48 | 12 | 1.78 +/− 0.71 L | 1.99 +/− 0.78 L | NS | Change, Tx vs. Ctl
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 734 mcg; placebo | 91 | 72 | 24 | 2.67 +/− 0.74 L (a.m. prebronchodilator) | 2.68 +/− 0.78 L (a.m. prebronchodilator)
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 730 mcg; formoterol 24 mcg; placebo | 89 | 72 | 24 | 2.79 +/− 0.79 L (a.m. prebronchodilator) | 2.92 +/− 0.8 L (a.m. prebronchodilator) | NS | Absolute value, Tx vs. Ctl
Grutters, Brinkman, Aslander, et al., 1999 | BDP 800 mcg | 15 | 15 | 8 | 86 +/− 15.5% pred (prebronchodilator) | 95 +/− 15.5% pred (prebronchodilator)
Grutters, Brinkman, Aslander, et al., 1999 | BDP 800 mcg; salmeterol 100 mcg; | 12 | 12 | 8 | 79 +/− 17.3% pred (prebronchodilator) | 94 +/− 13.8% pred (prebronchodilator) | NS | Absolute value, Tx vs. Ctl
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg | 90 | 85 | 12 | 2.11 +/− 0.7 L (prebronchodilator) | 0.28 +/− 0.5 L (change) (prebronchodilator) | | | Analyzed intent-to-treat population minus 21 patients excluded due to significant deviations from good clinical practice standards; FEV1, PEF values = change
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg; salmeterol 100 mcg | 92 | 87 | 12 | 2.17 +/− 0.6 L (prebronchodilator) | 0.51 +/− 0.5 L (change) (prebronchodilator) | <0.0010 | Change, Tx vs, Ctl | Analyzed intent-to-treat population minus 21 patients excluded due to significant deviations from good clinical practice standards; FEV1, PEF values = change
Kemp, Cook, Incaudo, et al., 1998 | ICS; placebo | 254 | | 12 | 2.17 +/− 0.6 L | 0.15 L (change)
Kemp, Cook, Incaudo, et al., 1998 | ICS; salmeterol 84 mcg | 252 | | 12 | 2.16 +/− 0.6 L | 0.42 L (change) | <0.0010 | Change, Tx vs. Ctl
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; placebo | 24 | 23 | 4 | 2.4 +/− 0.64 L (prebronchodilator) | 3.05 +/− 0.24 L (prebronchodilator)
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; salmeterol 100 mcg | 25 | 24 | 4 | 2.29 +/−0.54 L (prebronchodilator) | 3.01 +/− 0.24 L (prebronchodilator) | NS | Change, Tx vs. Ctl
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; placebo | 16 | 16 | 12 | 82 +/− 12.0% pred (a.m. prebronchodilator) | 83 +/− 8.0% pred (a.m. prebronchodilator)
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; salmeterol 100 mcg | 13 | 13 | 12 | 85 +/− 14.4% pred (a.m. prebronchodilator) | 87 +/− 18.0% pred (a.m. prebronchodilator)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; Placebo | 213 | 694/851 for total study | 52 | 75.8 +/− 17.5% pred (prebronchodilator) | 78 +/− 16.1% pred (prebronchodilator)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | 694/851 for total study | 52 | 75.7 +/− 17.4% pred (prebronchodilator) | 84 +/− 15.9% pred (prebronchodilator)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; placebo | 214 | 694/851 for total study | 52 | 75.4 +/− 16.1% pred (prebronchodilator) | 81 +/− 17.6% pred (prebronchodilator)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; formoterol 24 mcg | 215 | 694/851 for total study | 52 | 76.3 +/− 16.1% pred (prebronchodilator) | 87 +/− 14.5% pred (prebronchodilator) | NR
Pearlman, Stricker, Weinstein, et al., 1999 | FP 176 mcg | 23 | 23 | 4 | 2.91 +/− 0.6 L (a.m. prebronchodilator) | 0.27 +/− 0.3 L (a.m. prebronchodilator, change)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 4 | 2.31 +/− 0.6 L (a.m. prebronchodilator) | 0.59 +/− 0.5 L (a.m. prebronchodilator, change) | <0.0500 | Change, Tx vs. Ctl
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 4 | 2.52 +/− 0.7 L (a.m. prebronchodilator) | 0.3 +/− 0.4 L (a.m. prebronchodilator, change)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 440 mcg | 21 | 21 | 4 | 2.62 +/− 0.5 L (a.m. prebronchodilator) | 0.73 +/− 0.7 L (a.m. prebronchodilator, change) | <0.0500 | Change, Tx vs. Ctl
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg | 84 | 81 | 12 | 2.12 +/− 0.54 L (a.m. prebronchodilator) | 0.25 +/− 0.45 L (a.m. prebronchodilator, change)
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg; salmeterol 100 mcg | 84 | 81 | 12 | 2.23 +/− 0.63 L (a.m. prebronchodilator) | 0.48 +/− 0.45 L (a.m. prebronchodilator, change) | <0.0010 | Change, Tx vs. Ctl
van der Molen, Postma, Turner, et al., 1997 | ICS; placebo | 114 | 113 | 24 | 2.16 +/− 0.8 L (a.m. prebronchodilator) | 2.25 +/− 0.84 L (a.m.)
van der Molen, Postma, Turner, et al., 1997 | ICS; formoterol 48 mcg | 125 | 125 | 24 | 2.29 +/− 0.7 L (a.m. prebronchodilator) | 2.51 +/− 0.85 L (a.m.) | NS | Absolute value, Tx vs. Ctl
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 57 | | 54 | 102.2 +/− 12% pred (postbronchodilator) | 2 +/− 2.5% pred (postbronchodilator, change)
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg; salmeterol 100 mcg | 60 | 55 | 54 | 103.5 +/− 13.1% pred (postbronchodilator) | −0.1 +/− 2% pred (postbronchodilator, change) | NS | Absolute value, Tx vs. Ctl
Weersink, Douma, Postma, et al., 1997 | FP 500 mcg | 17 | 16 | 6 | 88.4 +/− 19.5% pred (a.m.) | 102 +/− 12.0% pred (a.m.)
Weersink, Douma, Postma, et al., 1997 | FP 500 mcg; salmeterol 100 mcg | 16 | 14 | 6 | 83.1 +/− 14.4% pred (a.m.) | 93 +/− 13.1% pred (a.m.) | NS | Absolute value, Tx vs. Ctl
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; placebo | 17 | 13 | | 77.4 +/− 17.2% pred (prebronchodilator) | 69.1 +/− 16.1% pred (postbronchodilator) | | | No defined treatment period; lung function values at exacerbation or full withdrawal of ICS
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; salmeterol 100 mcg | 17 | 13 | | 75.2 +/− 16.3% pred (prebronchodilator) | 75.6 +/− 15.6% pred (postbronchodilator) | NS | Absolute value, Tx vs. Ctl | No defined treatment period; lung function values at exacerbation or full withdrawal of ICS
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,179 mcg; placebo | 19 | 19 | | 2.98 (Mean) L (prebronchodilator) | −0.04 +/− 0.7 L (prebronchodilator, change)
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,280 mcg; salmeterol 100 mcg | 15 | 15 | | 2.80 (Mean) L (prebronchodilator) | 0.16 +/− 0.8 L (prebronchodilator, change) | NS | Absolute value, Tx vs. Ctl
Wilding, Clark, Coon, et al., 1997 | ICS; placebo | 100 | 87 | 24 | 2.71 +/− 0.79 L (prebronchodilator) | 2.71 (Mean) L (prebronchodilator)
Wilding, Clark, Coon, et al., 1997 | ICS; salmeterol 100 mcg | 100 | 87 | 24 | 2.71 +/− 0.79 L (prebronchodilator) | 2.84 (Mean) L (prebronchodilator) | <0.0010 | Absolute value, Tx vs. Ctl | Difference between groups, 0.13 L (95% CI, 0.085-0.174)
Addition of Long-Acting Beta-2 Agonists
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | FP 440 mcg; placebo | 223 | 223 | 12 | 63.1 +/− 12.2% pred (a.m. prebronchodilator) | 14 +/− 13.4% pred (a.m. prebronchodilator, change)
Baraniuk, Murray, Nathan, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 231 | 231 | 12 | 63.1 +/− 11.9% pred (a.m. prebronchodilator) | 16.7 +/− 15.2% pred (a.m. prebronchodilator, change) | =0.0180 | Change, Tx vs. Ctl
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 1,000 mcg | 65 | 58 | 12 | 2.15 +/− 0.75 L (prebronchodilator) | 2.35 +/− 0.89 L (prebronchodilator)
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 500 mcg; formoterol 24 mcg | 69 | 64 | 12 | 2.27 +/− 0.79 L (prebronchodilator) | 2.55 +/− 0.82 L (prebronchodilator) | NS | Absolute value, Tx vs. Ctl
Condemi, Goldstein, Kalberg, et al., 1999 | FP 440 mcg; placebo | 216 | | 24 | 2.14 +/− 0.6 L (a.m. prebronchodilator) | 0.33 +/− 0.44 L, (a.m. prebronchodilator, change)
Condemi, Goldstein, Kalberg, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 221 | | 24 | 2.12 +/− 0.6 L (a.m. prebronchodilator) | 0.43 +/− 0.59 L, (a.m. prebronchodilator, change) | =0.0130 | Change, Tx vs. Ctl
Kelsen, Church, Gillman, et al., 1999 | BDP 672 mcg | 244 | | 24 | 64.14 +/− 10.2% pred (a.m. prebronchodilator) | 0.25 +/− 0.31 L, (a.m. prebronchodilator, change)
Kelsen, Church, Gillman, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 239 | | 24 | 64.93 +/− 10.2% pred (a.m. prebronchodilator) | 0.34+/− 0.31 L, (a.m. prebronchodilator, change) | NS | Change, Tx vs. Ctl
Murray, Church, Anderson, et al., 1999 | BDP 672 mcg | 254 | 253 | 24 | 2.31 L (a.m. prebronchodilator) | 0.22 +/− 0.48 L (a.m. prebronchodilator, change)
Murray, Church, Anderson, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 260 | 259 | 24 | 2.3 L (a.m. prebronchodilator) | 0.36 +/− 0.64 L (a.m. prebronchodilator, change) | <0.0500 | Absolute value or change (?)
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg; placebo | 214 | | 52 | 75.4 +/− 16.1% pred (prebronchodilator) | 81 +/− 17.6% pred (pre-bronchodilator) | | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | | 52 | 75.7 +/− 17.4% pred (prebronchodilator) | 84 +/− 15.9% pred (prebronchodilator) | NR | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 4 | 2.52 +/− 0.7 L (a.m. prebronchodilator) | 0.3 +/− 0.4 L (a.m. prebronchodilator, change)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 4 | 2.31 +/− 0.6 L (a.m. prebronchodilator) | 0.59 +/− 0.5 L (a.m. prebronchodilator, change) | <0.0500 | Change, Tx vs. Ctl
van Noord, Schreurs, Mol, et al., 1999 | FP 400 or 1,000 mcg/day | 135 | 135 | 12 | 2.39 +/− 0.75 L (a.m. prebronchodilator) | 2.48 +/− 0.89 L (a.m. prebronchodilator)
van Noord, Schreurs, Mol, et al., 1999 | FP 200 or 500 mcg/day salmeterol 100 mcg | 139 | | 12 | 2.38 +/− 0.75 L (a.m. prebronchodilator) | 2.47 +/− 0.76 L (a.m. prebronchodilator) | NS | Absolute value, Tx vs. Ctl | Difference between groups significant at week 4, p=0.04
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 60 | 54 | 54 | 102.3 +/− 11.4% pred (postbronchodilator) | 3.5 +/− 1.8% pred (postbronchodilator, change)
Verberne, Frost, Duiverman, et al., 1998 | BDP 200 mcg; salmeterol 100 mcg | 60 | 55 | 54 | 103.5 +/− 13.1% pred (postbronchodilator) | −0.1 +/− 2% pred (postbronchodilator, change) | NS | Absolute value, Tx vs. Ctl
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 2,000 mcg | 251 | | 26 | 75% pred | 3.2 +/04.0% pred (change)
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 100 mcg | 243 | | 26 | 72% pred | 7.2 +/− 3.9% pred (change) | <0.0500 | Change, Tx vs. Ctl
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 200 mcg | 244 | | 26 | 71% pred | 7.2 +/− 3.9% pred (change) | <0.0500 | Change, Tx vs. Ctl
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 | BDP 500 mcg; placebo | 40 | 40 | 24 | 1.32 +/− 0.19 L | 1.49 +/− 0.19 L
Emad, 1996 | BDP 500 mcg; theophylline 250 mg | 40 | 40 | 24 | 1.31 +/− 0.19 L | 1.82 +/− 0.13 L | =0.0010 | Absolute value, Tx vs. Ctl
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; Placebo | 37 | 33 | 12 | 71 +/− 18.2% pred (a.m. prebronchodilator) | 93 +/− 28.7% pred (a.m. prebronchodilator)
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; theophylline 250 mg | 35 | 29 | 12 | 70 +/− 20.1% pred (a.m. prebronchodilator) | 98 +/− 21.5% pred (a.m. prebronchodilator) | NS | Absolute value, Tx vs. Ctl
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 18 | 6 | 2.36 +/− 0.6 L | 2.36 +/− 0.5 L
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 17 | 6 | 2.3 +/− 0.6 L | 2.25 +/− 0.6 L
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 cg; placebo | 22 | 18 | 4 | | 91 +/− 12.7% pred (prebronchodilator)
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; theophylline | 22 | 18 | 4 | | 94 +/− 17.0% pred (prebronchodilator)
Addition of Theophylline
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | BUD 1,600 mcg; placebo | 31 | 31 | 12 | 2.50 +/− 0.78 L | 2.61 +/− 0.78 L
Evans, Taylor, Zetterstrom et al., 1997 | BUD 800 mcg; theophylline 750 mg | 31 | 31 | 12 | 2.48 +/− 1.0 L | 2.69 +/− 0.89 | 0.03 | Change, Tx vs. Ctl
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 800 mcg; placebo | 90 | 64 | 6 | 2.4 +/− 0.75 L | 2.59 +/− 6.2 L
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 400 mcg; theophylline 750 mg | 100 | 69 | 6 | 2.3 +/− 0.62 L | 2.56 +/− 6.2 L | NS | Other ^b^
Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | BDP 400 mcg; placebo | 200 | 200 | 16 | 71 +/− 12% pred (a.m.) | 0.72%, 95% CI, (−0.89)−2.33 (a.m., change)
Laviolette, Malmstrom, Lu, et al., 1999 | BDP 400 mcg; montelukast sodium 10 mg | 193 | 193 | 16 | 72 +/− 12% pred (a.m.) | 5.08%, 95% CI, 3.43-6.74 (a.m., change) | <0.0010 | Change, Tx vs. Ctl
Tamaoki, Kondo, Sakai, et al., 1997 | BDP 750 mcg; theophylline Placebo | 40 | 37 | 6 | 81.6 +/− 14.5% pred | −0.33 +/− 1.22% pred (change)
Tamaoki, Kondo, Sakai, et al., 1997 | BDP 750 mcg; theophylline; pranlukast 900 mg | 43 | 42 | 6 | 79.1 +/− 17.0% pred | 0.08 +/− 3.24% pred (change) | =0.0070 | Change, Tx vs. Ctl
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg; | 17 | 17 | 8
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400mcg pranlukast 450 mg | 24 | 24 | 8
Virchow, Prasse, Naya, et al., 2000 | ICS; placebo | 188 | 188 | 6 | 2.01 +/− 0.59 L | 0.09 +/− 0.41 L (change)
Virchow, Prasse, Naya, et al., 2000 | ICS; zafirlukast 80 mg | 180 | 180 | 6 | 2.08 +/− 0.61 L | 0.19 +/− 0.54 L (change) | =0.014 | Change, Tx vs. Ctl
Addition of Leukotriene Receptor Antagonists
Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | ICS1,079 mcg; placebo | 113 | 113 | 12 | 82.3 +/− 12.9% pred | 5.4 (Mean) % pred (change)
Lofdahl, Reiss, Leff, et al., 1999 | ICS 976 mcg; montelukast sodium 10 mg | 113 | 112 | 12 | 84.8 +/− 11.1% pred | 2.7 (Mean) % pred (change) | NS | Change, Tx vs. Ctl

a "Pre- or postbronchodilator status unknown unless otherwise indicated."

b Geometric mean and 95% CI calculated for test/reference ration of baseline-adjusted medians, and equivalence concluded if the lower limit of the CI was above 0.90.

Evidence Table 3-5. Lung function outcomes. PEF

Citation | Treatment Arm | N Enrolled | N Evaluable | Treatment Duration (weeks) | Baseline PEF, Mean ± SD | Final PEF, Mean ± SD | p-Value | p-Value Comparison | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; placebo | 165 | | 12 | 351 +/− 104.0 L/min (a.m., home) | 15 +/− 39.8 L/min (a.m., home, change)
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; salmeterol 100 mcg; placebo | 167 | | 12 | 359 +/− 95.6 L/min (a.m., home) | 35 +/− 40.1 L/min (a.m., home, change) | <0.0010 | Change, Tx vs. Ctl
Boyd, 1995 | ICS 1,500 mcg; placebo | 64 | 52 | 12 | 289 +/− 111 L/min (a.m., home) | 321 +/− 121 L/min (a.m., home)
Boyd, 1995 | ICS 1,500 mcg; salmeterol 200 mcg | 55 | 48 | 12 | 267 +/− 94 L/min (a.m., home) | 319 +/− 98 L/min (a.m., home) | =0.0060 | Change, Tx vs. Ctl
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 734 mcg; placebo | 91 | 72 | 24 | 438 +/− 86 L/min (a.m., home) | 446 (Mean) L/min (a.m., home)
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 730 mcg; formoterol 24 mcg; placebo | 89 | 72 | 24 | 442 +/− 90 L/min (a.m., home) | 473 (Mean) L/min (a.m., home) | <0.0500 | Absolute value, Tx vs. Ctl
Kavuru, Melamed, Gross, et al., 2000 | FP 200mcg | 90 | 85 | 12 | 374 +/− 107.2 L/min (a.m., home) | 17.3 +/− 41.7 L/min (change) (a.m., home) | | | Analyzed intent-to-treat population minus 21 patients excluded due to significant deviations from good clinical practice standards; FEV1, PEF values = change
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg; salmeterol 100 mcg | 92 | 87 | 12 | 393 +/− 101.7 L/min (a.m., home) | 52.5 +/− 50.8 L/min (change) (a.m., home) | <0.0250 | Change, Tx vs. Ctl | Analyzed intent-to-treat population minus 21 patients excluded due to significant deviations from good clinical practice standards; FEV1, PEF values = change
Kemp, Cook, Incaudo, et al., 1998 | ICS; placebo | 254 | | 12 | 369 +/− 95.6 L/min (a.m., home) | 14 (Mean) L/min (a.m., home, change)
Kemp, Cook, Incaudo, et al., 1998 | ICS; salmeterol 84 mcg | 252 | | 12 | 372 +/− 111.1 L/min (a.m., home) | 47 (Mean) L/min (a.m., home, change) | <0.0010 | Change, Tx vs. Ctl
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; placebo | 24 | 23 | 4 | 370 +/− 440.9 L/min (a.m., home) | 361 +/− 403 L/min (a.m., home)
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; salmeterol 100 mcg | 25 | 24 | 4 | 368 +/− 350.0 L/min (a.m., home) | 395 +/− 343 L/min (a.m., home) | =0.0001 | Change, Tx vs. Ctl
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; placebo | 16 | 16 | 12 | 405 +/− 80.0 L/min (a.m., home) | 410 +/− 100.0 L/min (a.m., home)
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; salmeterol 100 mcg | 13 | 13 | 12 | 460 +/− 108.2 L/min (a.m., home) | 495 +/− 90.1 L/min (a.m., home)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; placebo | 213 | 694/851 for entire study | 52 | 397 L/min (a.m., home) | −11 (change) L/min (a.m., home)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | 694/851 for entire study | 52 | 399 L/min (a.m., home) | 17 (change) L/min (a.m., home)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; placebo | 214 | 694/851 for entire study | 52 | 381 L/min (a.m., home) | 2 change) L/min (a.m., home)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; formoterol 24 mcg | 215 | 694/851 for entire study | 52 | 394 L/min (a.m., home) | 26 (change) L/min (a.m., home) | NR
Pearlman, Stricker, Weinstein, et al., 1999 | FP 176 mcg | 23 | 23 | 4 | 438 +/− 76.7 L/min (a.m., home) | 10 +/− 38.4 L/min (a.m., home, change)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 4 | 399 +/− 90.0 L/min (a.m., home) | 57 +/− 50.0 L/min (a.m., home, change) 5 | <0.0500 | Change, Tx vs. Ctl
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 4 | 411 +/− 100.7 L/mi (a.m., home) | 25 +/− 43.2 L/min (a.m., home, change)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 440 mcg | 21 | 21 | 4 | 458 +/− 110.0 L/min (a.m., home) | 32 +/− 59.6 L/min (a.m., home, change) | NS | Change, Tx vs. Ctl
Russell, Williams, Weller, et al., 1995 | BDP or equiv, avg. 750 mcg; placebo | 107 | 89 | 12 | 79.7% pre (a.m., home) | 4.9% pred (a.m., home, change)
Russell, Williams, Weller, et al., 1995 | BDP or equiv, avg. 750 mcg; salmeterol 100 mcg | 99 | 78 | 12 | 79.2% pred (a.m., home) | 8.2% pred (a.m., home, change) | =0.0170 | Change, Tx vs. Ctl
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg | 84 | 81 | 12 | 83 +/− 15.6% of predicted (a.m.home) | 3.3 +/− 9.2% of predicted (a.m.home)
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg; salmeterol 100 mcg | 84 | 81 | 12 | 79 +/− 16.5% of predicted (a.m.home) | 11.8 +/− 11.0% of predicted (a.m.home)
van der Molen, Postma, Turner, et al., 1997 | ICS; placebo | 114 | 113 | 24 | 382 +/− 101.4 L/min (a.m., home) | −2.1 L/min (a.m., home, change)
van der Molen, Postma, Turner, et al., 1997 | ICS; formoterol 48 mcg | 125 | 125 | 24 | 392 +/− 99.3 L/min (a.m., home) | 25.9 L/min (a.m., home) | <0.0010 | Absolute value, Tx vs. Ctl
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 57 | 53 | 54 | 317 +/− 79 L/min (a.m., home) | 27.3 +/− 37.4 L/min (a.m., home, change)
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg; salmeterol 100 mcg | 60 | 55 | 54 | 299 +/− 79 L/min (a.m., home) | 41.8 +/− 42.4L/min (a.m., home, change) | NS | Absolute value, Tx vs. Ctl
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; Placebo | 17 | 13 | | 414 +/− 112 L/min (a.m., home) | 424 +/− 81 L/min (a.m., home) | | | No defined treatment period; lung function values at exacerbation or full withdrawal of ICS
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; salmeterol 100 mcg | 17 | 13 | | 419 +/− 108 L/min (a.m., home) | 451 +/− 96 L/min (a.m., home) | NS | Absolute value, Tx vs. Ctl | No defined treatment period; lung function values at exacerbation or full withdrawal of ICS
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,179 mcg; placebo | 19 | 19 | | | 3.7 +/− 37.1 L/min (a.m., home, change)
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,280 mcg; salmeterol 100 mcg | 15 | 15 | | | 17.4 +/− 37.2 L/min (a.m., home, change) | NS | Other: diff btwn trt & sensiti
Wilding, Clark, Coon, et al., 1997 | ICS; placebo | 100 | 87 | 24 | 415 +/− 101 L/min (a.m., home) | 431 L/min (a.m., home)
Wilding, Clark, Coon, et al., 1997 | ICS; salmeterol 100 mcg | 100 | 87 | 24 | 415 +/− 101 L/min (a.m., home) | 451 L/min (a.m., home) | <0.0010 | Absolute value, Tx vs. Ctl | Difference between groups 19 L/min (95% CI, 14-24)
Addition of Long-Acting Beta-2 Agonists
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | FP 440 mcg; placebo | 223 | 223 | 12 | 65 +/− 14.9% pred (home) | 9 +/− 14.9% pred (home, change)
Baraniuk, Murray, Nathan, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 231 | 231 | 12 | 68 +/− 15.2 L/min (home) | 11 +/− 15.2% pred (home, change) | <0.0330 | Change, Tx vs. Ctl
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 1,000 mcg | 65 | 58 | 12 | 356.4 +/− 96.2 L/min (a.m., home) | 375 +/− 114 L/min (a.m., home)
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 500 mcg; formoterol 24 mcg | 69 | 64 | 12 | 380.4 +/− 108.8 L/min (a.m., home) | 415 +/− 120 L/min, (a.m., home) | =0.0020 | Absolute value, Tx vs. Ctl
Condemi, Goldstein, Kalberg, et al., 1999 | FP 440 mcg; placebo | 216 | | 24 | 363.7 +/− 111.7 L/min (a.m., home) | 31.3 L/min, 95% CI, 26.6-36.0 (a.m., home, change)
Condemi, Goldstein, Kalberg, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 221 | | 24 | 363.6 +/− 116.0 L/min (a.m., home) | 52.3 L/min, 95% CI, 48.0-56.6 (a.m., home, change) | <0.0220 | Change, Tx vs. Ctl
Greening, Ind, Northfield, et al., 1994 | BDP 1,000 mcg; placebo | 206 | 126 | 21 | 339 +/− 99 L/min (a.m., home) | 7 +/− 64.6 L/min (a.m., home, change)
Greening, Ind, Northfield, et al., 1994 | BDP 400 mcg; salmeterol 100 mcg | 220 | 137 | 21 | 349 +/− 109 L/min (a.m., home) | 27.5 +/− 66.7 L/min (a.m., home, change) | <0.0100 | Change, Tx vs. Ctl
Kelsen, Church, Gillman, et al., 1999 | BDP 672 mcg | 244 | | 24 | 387.6 L/min (a.m., home) | 20 +/− 31.2 L/min, (a.m., home, change)
Kelsen, Church, Gillman, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 239 | | 24 | 389.7 L/min (a.m., home) | 46+/− 46.4 L/min, (a.m., home, change) | <0.0010 | Change, Tx vs. Ctl
Murray, Church, Anderson, et al., 1999 | BDP 672 mcg | 254 | 253 | 24 | 381.6 L/min (a.m., home) | 412.6 L/min (a.m., home)
Murray, Church, Anderson, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 260 | 259 | 24 | 390.2 L/min (a.m., home) | 439.6 L/min (a.m., home) | <0.0500 | Abs value or change ?
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg; placebo | 214 | | 52 | 381 L/min (a.m., home) | 2 change) L/min (a.m., home) | | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | | 52 | 399 L/min (a.m., home) | 17 (change) L/min (a.m., home) | NR | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 4 | 411 +/− 100.7 L/min (a.m., home) | 25 +/− 43.2 L/min (a.m., home, change)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 4 | 399 +/− 90.0 L/min (a.m., home) | 57 +/− 50.0 L/min (a.m., home, change) | <0.0500 | Change, Tx vs. Ctl
van Noord, Schreurs, Mol, et al., 1999 | FP 400 or 1,000 mcg/day | 135 | | 12 | 365 +/− 117 L/min (home) | 384 +/− 120 L/min (home) | | | Difference between groups significant at week 4, p=0.02
van Noord, Schreurs, Mol, et al., 1999 | FP 200 or 500 mcg/day salmeterol 100 mcg | 139 | | 12 | 367 +/− 114 L/min (home) | 386 +/− 122 L/min (home) | NS | Absolute value, Tx vs. Ctl
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 60 | 54 | 54 | 315 +/− 90 L/min (a.m., home) | 41.1 +/− 33.3L/min (a.m., home, change)
Verberne, Frost, Duiverman, et al., 1998 | BDP 200 mcg; salmeterol 100 mcg | 60 | 55 | 54 | 299 +/− 79 L/min (a.m., home) | 41.8 +/− 42.4 L/min (a.m., home, change) | NS | Absolute value, Tx vs. Ctl
Vermetten, Boermans, Luiten, et al., 1999 | BDP 800 mcg | 120 | | 12 | 84 +/− 17% pred (clinic) | 6.3% pred (a.m., home, change)
Vermetten, Boermans, Luiten, et al., 1999 | BDP 400 mcg; salmeterol 100 mcg | 113 | | 12 | 83 +/− 17% pred (clinic) | 7% pred (a.m., home, change) | NS | Absolute value, Tx vs. Ctl
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 2,000 mcg | 251 | | 26 | 82% pred (a.m., home) | 85% pred (a.m., home)
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 100 mcg | 243 | | 26 | 82% pred (a.m., home) | 92% pred (a.m., home) | <0.0010 | Change, Tx vs. Ctl
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 200 mcg | 244 | | 26 | 82% pred (a.m., home) | 92% pred (a.m., home) | <0.0010 | Change, Tx vs. Ctl
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 | BDP 500 mcg; placebo | 40 | 40 | 24 | 174.6 +/− 30.6 L/min (clinic) | 187.2 +/− 22.8 L/min (clinic)
Emad, 1996 | BDP 500 mcg; Theophylline 250 mg | 40 | 40 | 24 | 172.2 +/− 30.6 L/min (clinic) | 243.6 +/− 34.2 L/min (clinic) | =0.0010 | Absolute value, Tx vs. Ctl
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; Placebo | 37 | 33 | 12 | | 25% pred (a.m., home, change)
Meltzer, Orgel, Ellis, et al., 1992 | Albuterol (salbutamol) 180 mcg; BDP 336 mcg; theophylline 250 mg | 35 | 29 | 12 | | 38% pred (a.m., home, change) | NS | Change, Tx vs. Ctl
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 18 | 6 | 485.5 +/− 130.8 L/min (a.m., home) | 450 +/− 123 L/min (a.m., home)
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 17 | 6 | 469.6 +/− 196.2 L/mi (a.m., home) | 474 +/− 177 L/min (a.m., home)
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; placebo | 22 | 18 | 4 | | 104 +/− 29.7% pred (a.m., home)
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; theophylline | 22 | 18 | 4 | | 109 +/− 25.5% pre (a.m., home)
Addition of Theophylline
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | BUD 1,600 mcg; placebo | 31 | 31 | 12 | 411 +/− 89 L/min (a.m., home) | 436 +/− 100 L/min (a.m., home)
Evans, Taylor, Zetterstrom et al., 1997 | BUD 800 mcg; theophylline 750 mg | 31 | 31 | 12 | 430 +/− 117 L/min (a.m., home) | 453 +/− 106 L/min (a.m., home) | 0.16 | Change, Tx vs. Ctl
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 800 mcg; placebo | 90 | 64 | 6 | 344 +/− 105 L/min (a.m., home) | 22 +/− 40 L/min (a.m., home, change)
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 400 mcg; theophylline 750 mg | 100 | 69 | 6 | 345 +/− 95 L/min (a.m., home) | 33 +/− 58 L/min (a.m., home, change) | NS | Other ^a^
Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | BDP 400 mcg; placebo | 200 | 200 | 16 | 403 +/− 86 L/min (a.m., home) | 2.65 L/min, 95% CI, (−1.31)−6.60 (a.m., home, change)
Laviolette, Malmstrom, Lu, et al., 1999 | BDP 400 mcg; montelukast sodium 10 mg | 193 | 193 | 16 | 412 +/− 91 L/min (a.m., home) | 10.41 L/min, 95% CI, 6.36-14.47 (a.m., home, change) | =0.0041 | Change, Tx vs. Ctl
Tamaoki, Kondo, Sakai, et al., 1997 | BDP 750 mcg; theophylline placebo | 40 | 37 | 6 | 448 +/− 113.8 L/min (a.m., home) | −46 +/− 42.6 L/min (a.m., home, change)
Tamaoki, Kondo, Sakai, et al., 1997 | BDP 750 mcg; theophylline; pranlukast 900 mg | 43 | 42 | 6 | 437 +/− 98.4 L/min (a.m., home) | 5 +/− 25.9 L/min (a.m., home, change) | <0.0010 | Change, Tx vs. Ctl
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg; | 17 | 17 | 8 | 86.3 +/− 19% of predicted (am) | 94 +/− 13% of predicted (a.m.)
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg pranlukast 450 mg | 24 | 24 | 8 | 90.3 +/− 13.4% of predicted (am) | 100 +/− 6% of predicted (a.m.) | <0.0500 | Absolute value, Tx vs. Ctl
Virchow, Prasse, Naya, et al., 2000 | ICS; placebo | 188 | 188 | 6 | 288 +/− 107 L/min (a.m., home) | 1.5 +/− 52.1 L/min (a.m., home, change)
Virchow, Prasse, Naya, et al., 2000 | ICS; zafirlukast 80 mg | 180 | 180 | 6 | 308 +/− 103 L/min (a.m., home) | 18.7 +/− 48.3 L/min (a.m., home, change) | <0.001 | Change, Tx vs. Ctl

a Geometric mean and 95% CI calculated for test/reference ration of baseline-adjusted medians, and equivalence concluded if the lower limit of the CI was above 0.90.

Evidence Table 3-6. Lung function outcomes. PC20

Citation | Treatment Arm | N Enrolled | N Evaluable | Treatment Duration (weeks) | PC20 Baseline, Mean ± SD | PC20 Final, Mean ± SD | PC20 p-Value | PC20 Comparison | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; placebo | 165 | | 12
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; salmeterol 100 mcg; placebo | 167 | | 12
Boulet, Cartier, Milot, et al., 1998 | ICS; placebo | 16 | 15 | 4 | 1.9 +/− 2.0 mg/mL Methacholine (geom. mean) | 2.0 +/− 1.9 mg/mL Methacholine (geom. mean)
Boulet, Cartier, Milot, et al., 1998 | ICS; salmeterol 100 mcg | 16 | 15 | 4 | 2.4 +/− 2.0 mg/mL Methacholine | 2.80 +/− 3.9 mg/mL Methacholine
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 734 mcg; placebo | 91 | 72 | 24 | 0.68 mg/mL (geom. mean) Methacholine | 1.6 mg/mL (geom. mean) Methacholine
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 730 mcg; formoterol 24 mcg; placebo | 89 | 72 | 24 | 0.72 mg/mL (geom. mean) Methacholine | 4.9 mg/mL (geom. mean) Methacholine | <0.0010 | Absolute value, Tx vs. Ctl
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; placebo | 16 | 16 | 12 | 0.011 mg (geom mean) Methacholine
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; salmeterol 100 mcg | 13 | 13 | 12 | 0.022 mg (geom mean) Methacholine
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 57 | 53 | 54 | 27 DD Methacholine (median) | 35 DD Methacholine (mean)
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg; salmeterol 100 mcg | 60 | 55 | 54 | 24.5 DD Methacholine (median) | 36 DD Methacholine (mean) | NS | Absolute value, Tx vs. Ctl
Weersink, Douma, Postma, et al., 1997 | FP 500 mcg | 17 | 16 | 6 | 0.17 mg/mL methacholine | 3.0 +/− 1.9 DD methacholine, change
Weersink, Douma, Postma, et al., 1997 | FP 500 mcg; salmeterol 100 mcg | 16 | 14 | 6 | 0.08 mg/mL methacholine | 2.9 +/− 3.0 DD methacholine, change | NS | Absolute value, Tx vs. Ctl
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; placebo | 17 | 13 | | 0.5 mg/mL (geom mean) methacholine +/− 3.1 | 0.5 +/− 5.4 mg/mL methacholine (geom mean) | | | No defined treatment period; lung function values at exacerbation or full withdrawal of ICS
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; salmeterol 100 cg | 17 | 13 | | 0.7 mg/mL (geom mean) methacholine +/− 4.3 | 0.6 +/− 6.4 mg/mL methacholine | NS | Abs. value or Change (?) | No defined treatment period; lung function values at exacerbation or full withdrawal of ICS
Wilding, Clark, Coon, et al., 1997 | ICS; placebo | 100 | 87 | 24 | | 1.46 mcmol methacholine
Wilding, Clark, Coon, et al., 1997 | ICS; salmeterol 100 mcg | 100 | 87 | 24 | | 2.24 mcmol methacholine | =0.0080 | Log absolute value, Tx vs. Ctl | Difference between groups 0.62 mmol (95% CI, 0.18-1.05)
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
van Noord, Schreurs, Mol, et al., 1999 | FP 400 or 1,000 mcg/day | 135 | | 12
van Noord, Schreurs, Mol, et al., 1999 | FP 200 or 500 mcg/day salmeterol 100 mcg | 139 | | 12
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 60 | 54 | 54 | 22.5 DD methacholine | 39.5 DD methacholine
Verberne, Frost, Duiverman, et al., 1998 | BDP 200 mcg; salmeterol 100 mcg | 60 | 55 | 54 | 24.5 DD methacholine | 36 DD methacholine | NS | Absolute value, Tx vs. Ctl
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 2,000 mcg | 251 | | 26 | | 4.3 DD histamine
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 100 mcg | 243 | | 26 | | 7.5 DD histamine | NS | Change, Tx vs. Ctl
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 200 mcg | 244 | | 26 | | 5.7 DD Histamine | NS | Change, Tx vs. Ctl
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 18 | 6 | 1.84 +/− 2.55 mg/mL histamine | 1.26 +/− 1.36 mg/mL histamine
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 17 | 6 | 1.42 +/− 2.25 mg/mL histamine

Evidence Table 3-7. Medication Use Outcomes

Citation | Treatment Arm | N Enrolled | N Evaluable | Baseline Puffs Per Day, Mean ± SD | Final Puffs Per Day, Mean ± SD | p-Value | Oral Steroid Use | p-Value | Titrated Medications | p-Value | Comments
Citation | Treatment Arm | N Enrolled | N Evaluable | Baseline Puffs Per Day, Mean ± SD | Final Puffs Per Day, Mean ± SD | p-Value | Oral Steroid Use | p-Value | Titrated Medications | p-Value | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Boyd, 1995 | ICS 1,500 mcg; placebo | 64 | 62 | 9.7 +/− 4 | 7.2 +/− 4.9
Boyd, 1995 | ICS 1,500 mcg; salmeterol 200 mcg | 55 | 53 | 11.3 +/− 6 | 6.3 +/− 6.2 | =0.0020
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 734 mcg; placebo | 91 | 79 | 1.68 (Mean) | 1.15 (Mean) | | 6 events | | | | Baseline Mean # puffs/night 0.86; final 0.69
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 730 mcg; formoterol 24 mcg; placebo | 89 | 89 | 1.69 (Mean) | 0.53 (Mean) | <0.0500 | 3 events | | | | Baseline Mean # puffs/night 0.70; final 0.18, p<0.05
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg | 90 | 85 | 3.1 +/− 2.6 | −0.4 +/− 1.9 (change)
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg; salmeterol 100 mcg | 92 | 87 | 3.1 +/− 2.7 | −1.9 +/− 2.4 (change) | <0.0250
Kemp, Cook, Incaudo, et al., 1998 | ICS; placebo | 254 | | 4.65 (Mean) | −1.06 +/− 1.9, change | | | | | | Baseline puffs/night 1.25, change −0.18 +/− 1.1; change in % patients not requiring supplemental beta-agonist use 13.6 +/− 28.7 (days) and 9.5 +/− 28.7 (nights)
Kemp, Cook, Incaudo, et al., 1998 | ICS; salmeterol 84 mcg | 252 | | 4.94 (Mean) | −2.73 +/− 2.5, change | <0.0010 | | | | | Baseline puffs/night 1.26; change −0.75 +/− 1.1; change in % patients not requiring supplemental beta-agonist use 38.1 +/− 36.5 (days) and 29.2 +/− 38.1 (nights)
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; placebo | 16 | 16 | 1.5 +/− 1.2 | 1.3 +/− 1.2
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; salmeterol 100 mcg | 13 | 13 | 1.8 +/− 1.1 | 0.7 +/− 1.4
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; placebo | 213 | 694/851 for total study | | 0.91 (Mean)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | 694/851 for total study | | 0.57 (Mean) | <0.001
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; placebo | 214 | 694/851 for total study | | 0.82 (Mean)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; formoterol 24 mcg | 215 | 694/851 for total study | | 0.44 (Mean) | <0.001
Pearlman, Stricker, Weinstein, et al., 1999 | FP 176 mcg | 23 | 23 | 3.3 +/− 2.4 | −1.1 +/− 1.4, change
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 2.5 +/− 2.0 | −1.5 +/− 2.5, change | NS
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 3.1 +/− 2.9 | −1.4 +/− 1.9, change
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 440 mcg | 21 | 21 | 2.5 +/− 2.7 | −1.4 +/− 2.3, change | NS
Russell, Williams, Weller, et al., 1995 | BDP or equiv, avg. 750 mcg; placebo | 107 | 89 | 2 (Median) | −0.3 (Median), change | | | | | | Baseline Puffs/night 0.5, change, −1
Russell, Williams, Weller, et al., 1995 | BDP or equiv, avg. 750 mcg; salmeterol 100 mcg | 99 | 77 | 2 (Median) | −0.8 (Median), change | =0.0320 | | | | | Baseline Puffs/night 0.4, change, −1
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg | 84 | 81 | 3.2 +/− 2.7 | −0.9 +/− 1.8
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg; salmeterol 100 mcg | 84 | 81 | 3.5 +/− 3.7 | −2.3 +/− 3.6 | =0.0020 | Change, Tx vs. Ctl
van der Molen, Postma, Turner, et al., 1997 | ICS; placebo | 114 | 113 | 2 +/− 1.4 | 1.6 (Mean) | | 32 patients used 55 courses | | | | Puffs/night change, −0.2
van der Molen, Postma, Turner, et al., 1997 | ICS; formoterol 48 mcg | 125 | 125 | 2.4 +/− 1.9 | 0.9 (Mean) | <0.0010 | 33 patients used 58 courses | | | | Puffs/night change, −0.9, p 0.001
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 57 | 53 | | 0.15 (Median) | | 13 courses/10 patients
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg; salmeterol 100 mcg | 60 | 55 | | 0.19 (Median) | NS | 13 courses/10 patients
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; placebo | 17 | 13 | 2.9 +/− 1.8 | 3.1 +/− 2.4 | | | | Final ICS dose, 612 mcg | | No specified treatment time; ICS dose was decreased until an exacerbation occurred
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; salmeterol 100 mcg | 17 | 13 | 2.8 +/− 1.9 | 1.9 +/− 2.6 | NS | | | Final ICS dose, 277 mcg | =0.0100 | No specified treatment time; ICS dose was decreased until an exacerbation occurred
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,179 mcg; placebo | 19 | 19 | | | | | | | | Change in daily salbutamol used, 42 +/− 54 mcg
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,280 mcg; salmeterol 100 mcg | 15 | 15 | | | | | | | | Change in daily salbutamol used, 214+/− 102 mcg, p<0.05
Wilding, Clark, Coon, et al., 1997 | ICS; placebo | 100 | 87 | 2.5 (Median) | | | 13 patients | | Final ICS dose, 674 mcg
Wilding, Clark, Coon, et al., 1997 | ICS; salmeterol 100 mcg | 100 | 87 | 2.5 (Median) | | | 9 patients | NS | Final ICS dose, 561 mcg | <0.0010
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | FP 440 mcg; placebo | 223 | 223 | 4.9 +/− 3.0 | −2.4 +/− 3.0, change
Baraniuk, Murray, Nathan, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 231 | 226 | 4.6 +/− 3.0 | −2.9 +/− 3.0, change | <0.0010
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 1,000 mcg | 65 | 58 | 1.2 (Mean) | 0.8 (Mean) | | 5.2% of patients
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 500 mcg; formoterol 24 mcg | 69 | 64 | 1.1 (Mean) | 0.4 (Mean) | <0.0500 | 12.5% of patients | NS | | | Difference in puffs/day for overall treatment period p<0.001
Condemi, Goldstein, Kalberg, et al., 1999 | FP 440 mcg; placebo | 216 | 216 | 4.57 +/− 2.8 | −1.55 +/− 2.2, change
Condemi, Goldstein, Kalberg, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 221 | 221 | 4.66 +/− 3.3 | −2.51 +/− 2.5, change | <0.0010
Greening, Ind, Northfield, et al., 1994 | BDP 1,000 mcg; placebo | 206 | 143 | 3.3 (Mean) | 2.4 (Mean) | | | | | | Baseline mean puffs/night 0.6, final 0.5
Greening, Ind, Northfield, et al., 1994 | BDP 400 mcg; salmeterol 100 mcg | 220 | 152 | 3 (Mean) | 2.1 (Mean) | NS | | | | | Baseline mean puffs/night 0.7, final 0.4
Kelsen, Church, Gillman, et al., 1999 | BDP 672 mcg | 244 | 240 | | | | | | | | Baseline puffs/night, 1.04 +/− 1.6 Change, −0.44 +/− 1.2
Kelsen, Church, Gillman, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 239 | 236 | | | <0.0500 | | | | | Baseline puffs/night, 0.89 +/− 1.1 Change, −0.52 +/− 0.9
Murray, Church, Anderson, et al., 1999 | BDP 672 mcg | 254 | 253 | 4.2 (Mean) | 3.25 (Mean) | | | | | | Baseline puffs/night 1.0; final 0.65
Murray, Church, Anderson, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 260 | 259 | 4 (Mean) | 1.75 (Mean) | <0.0500 | | | | | Baseline puffs/night 0.99; final 0.32, p-Value NS
Pauwels, Lofdahl, Postma, et al., 1997 | BUD 800 mcg; placebo | 214 | | | 0.82 (Mean) | | | | | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pauwels, Lofdahl, Postma, et al., 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | | | 0.57 (Mean) | | | | | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 3.1 +/− 2.9 | −1.4 +/− 1.9, change
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 2.5 +/− 2.0 | −1.5 +/− 2.5, change | NS
van Noord, Schreurs, Mol, et al., 1999 | FP 400 or 1,000 mcg/day | 135 | | | | | 11% of patients
van Noord, Schreurs, Mol, et al., 1999 | FP 200 or 500 mcg/day salmeterol 100 mcg | 139 | | | | | 12% of patients | NS | | | Odds ratio of FP vs. Salmeterol. for daytime alb. use=2.19 (95% CI, 1.42-3.40); nighttime albuterol use=1.47 (41.04−2.10)
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 60 | 54 | | 0.33 (Median) | | 8 courses/7 patients
Verberne, Frost, Duiverman, et al., 1998 | BDP 200 mcg; salmeterol 100 mcg | 60 | 55 | | 0.19 (Median) | NS | 13 courses/10 patients
Vermetten, Boermans, Luiten, et al., 1999 | BDP 800 mcg | 120 | | 0.84 +/− 1 | 0.61 +/− 1.1 | | | | | | Baseline puffs/night, 0.5 +/− 0.6; final 0.37 +/− 0.66
Vermetten, Boermans, Luiten, et al., 1999 | BDP 400 mcg; salmeterol 100 mcg | 113 | | 0.88 +/− 0.9 | 0.48 +/− 0.7 | <0.0500 | | | | | Baseline puffs/night, 0.5 +/− 0.6; 0.30 +/− 0.64, p-Value NS
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 2,000 mcg | 251 | | | | | 39 patients
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 100 mcg | 243 | | | | | 35 patients
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 200 mcg | 244 | | | | | 30 patients

Citation | Treatment Arm | N Enrolled | N Evaluable | Baseline Medications | Baseline Puffs Per Day, Mean ± SD | Final Puffs Per Day, Mean ± SD | p-Value | Oral Steroid Use | p-Value | Comments
Citation | Treatment Arm | N Enrolled | N Evaluable | Baseline Medications | Baseline Puffs Per Day, Mean ± SD | Final Puffs Per Day, Mean ± SD | p-Value | Oral Steroid Use | p-Value | Comments
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; placebo | 37 | 37 | 85.0% on theophylline; 9% on cromolyn/nedocromil | | | | 6 patients
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; theophylline 250 mg | 35 | 35 | 85.0% on theophylline; 9% on cromolyn/nedocromil | | | | 5 patients
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 18 | 100.0% on theophylline | 0.96 +/− 2.2 | 3.64 +/− 8.4
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 17 | 100.0% on theophylline
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; placebo | 22 | 21 | 100.0% on theophylline | | 0.9 +/− 1.4 | | 9 patients | | 6 patients withdrawn due to prednisone use
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; theophylline | 22 | 10 | 100.0% on theophylline | | 0.4 +/− 0.6 | <0.0100 | 2 patients | | 1 patient withdrawn due to prednisone use
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | BUD 1,600 mcg; placebo | 31 | 31 | 0% on theophylline or other asthma tx besides ICS
| BUD 800 mcg; theophylline 750 mg | 31 | 31 | 0% on theophylline or other asthma tx besides ICS | | | 0.57
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 800 mcg; Placebo | 90 | 64 | | 2.4 (Median) | 0.3 (Median) | | | | Baseline puffs/night, 1.0; final 0.1
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 400 mcg; theophylline 750 mg | 100 | 69 | | 2.2 (Median) | 0.5 (Median) | NS | | | Baseline puffs/night, 0.7; final 0.1, p-Value NS

Citation | Treatment Arm | N Enrol-led | N Evaluable | Baseline Medications | Baseline Puffs Per Day, Mean ± SD | Final Puffs Per Day, Mean ± SD | p-Value | Oral Steroid Use | p-Value | Titrated Medications | p-Value | Comments
Citation | Treatment Arm | N Enrol-led | N Evaluable | Baseline Medications | Baseline Puffs Per Day, Mean ± SD | Final Puffs Per Day, Mean ± SD | p-Value | Oral Steroid Use | p-Value | Titrated Medications | p-Value | Comments
Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Tamaoki, Kondo, Sakai, et al., 1997 | BDP 750 mcg; theophylline placebo | 40 | 37 | 91.9% on theophylline | 6 +/− 18.2, puffs/week | 22.5 +/− 33.5, puffs/week | | | | | | Baseline nighttime puffs/week 2 +/− 5.3, change 4.7 +/− 15.8
Tamaoki, Kondo, Sakai, et al., 1997 | BDP 750 mcg; theophylline; pranlukast 900 mg | 43 | 42 | 92.9% on theophylline | 5 +/− 19.4, puffs/week | 7 +/− 19.4, puffs/week | =0.0260 | | | | | Baseline nighttime puffs/week 2.5 +/− 16.2, change 2.0 +/− 18.1, p-Value NS
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg; | 17 | 17 | 0.0% on theophylline; 0% on cromolyn/nedocromil
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg pranlukast 450 mg | 24 | 24 | 0.0% on theophylline; 0% on cromolyn/nedocromil
Virchow, Prasse, Naya, et al., 2000 | ICS; placebo | 188 | 188 | 0.0% on theophylline; 0% on cromolyn/nedocromil | 5.3 +/− 5.5 | −0.2 +/− 4.1 (change)
Virchow, Prasse, Naya, et al., 2000 | ICS; zafirlukast 80 mg | 180 | 180 | 0.0% on theophylline; 0% on cromolyn/nedocromil | 6.1 +/− 5.4 | −1.3 +/− 4.0 (change) | =0.007
Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | ICS; 1,079 mcg; placebo | 113 | 113 | | 2.8 +/− 2.6 | 0.36 (Mean), change | | | | Final ICS dose, 727 mcg
Lofdahl, Reiss, Leff, et al., 1999 | ICS 976 mcg; montelukast sodium 10 mg | 113 | 112 | | 2.4 +/− 2.2 | 0.29 (Mean), change | NS | | | Final ICS dose, 526 mcg | =0.0460

Evidence Table 3-8. Symptom score outcomes

Citation | Treatment Arm | N Enrolled | N Evaluable | Treatment Duration (weeks) | Baseline Daytime Symptom Score | Final Daytime Symptom Score | p-Value | Baseline Nighttime Symptom Score | Final Nighttime Symptom Score | p-Value | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Boulet, Cartier, Milot, et al., 1998 | ICS; placebo | 16 | 15 | 4 | | | | | | | Final mean symptom scores were low and not different from baseline (P>0.05).
Boulet, Cartier, Milot, et al., 1998 | ICS; salmeterol 100 mcg | 16 | 15 | 4 | | | | | | | Final mean symptom scores were low and not different from baseline (P>0.05).
Boyd, 1995 | ICS 1,500 mcg; placebo | 64 | 62 | 12 | 0.94 +/− 0.22 (scale, 0-4) | 0.82 +/− 0.39, (scale, 0-4) | | 0.73 +/− 0.44, (scale, 0-4) | 0.58 +/− 0.5, (scale, 0-4) | | Daytime symptom score change from baseline −0.12+/−0.32; nighttime symptom score change −0.15+/−0.48.
Boyd, 1995 | ICS 1,500 mcg; salmeterol 200 mcg | 55 | 53 | 12 | 0.94 +/− 0.23 (scale, 0-4) | 0.74 +/− 0.45, (scale, 0-4) | NS ^a^ | 0.91 +/− 0.28, (scale, 0-4) | 0.45 +/− 0.5, (scale, 0-4) | =0.0020 ^a^ | Daytime symptom score change from baseline −0.21+/−0.41; nighttime symptom score change −0.45+/−0.49.
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 734 mcg; placebo | 91 | 79 | 24 | 0.93 (Mean; scale, 0-4) | 0.76 (Mean; scale, 0-4) | | 0.12 (Mean; scale, 0-4) | 0.22 (Mean; scale, 0-4)
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 730 mcg; formoterol 24 mcg; placebo | 89 | 89 | 24 | 1.01 (Mean; scale, 0-4) | 0.39 (Mean; scale, 0-4) | <0.0500 ^b^ | 0.13 (Mean; scale, 0-4) | 0.11 (Mean; scale, 0-4) | <0.0500 ^b^
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg | 90 | 85 | 12 | 1.6 +/− 1.0 (scale, 0-5) | −0.2 +/− 0.8, (scale, 0-5; change)
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg; salmeterol 100 mcg | 92 | 87 | 12 | 1.5 +/− 1.1 (scale, 0-5) | −0.7 +/− 1.0, (scale, 0-5; change) | <0.0250
Kemp, Cook, Incaudo, et al., 1998 | ICS; placebo | 254 | | 12 | | −0.3 +/− 0.5 (change; scale, 0-3) | | | −0.26 +/− 0.6 (change; scale, 0-3)
Kemp, Cook, Incaudo, et al., 1998 | ICS; salmeterol 84 mcg | 252 | | 12 | | −0.55 +/− 0.5 (change; scale, 0-3) | <0.0010 ^a^ | | −0.65 +/− 0.6 (change; scale, 0-3) | <0.0010 ^a^
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; placebo | 24 | 23 | 4 | 1 (scale ?) | 1.5 (scale ?)
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; salmeterol 100 mcg | 25 | 24 | 4 | 1 (scale ?) | 0 (scale ?) | =0.0040 ^b^ | | | NS ^b^ | Median daytime usage of ipratropium was reduced in salmeterol treatment arm compared to placebo, p-Value NS.
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; placebo | 16 | 16 | 12 | 1.45 +/− 1.0 (scale, 0-4) | 1.3 +/− 1.2, (scale, 0-4)
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; salmeterol 100 mcg | 13 | 13 | 12 | 1.5 +/− 0.9 (scale, 0-4) | 0.5 +/− 0.9, (scale, 0-4) | | | | | Within-group change for salmeterol treatment arm was significant (p<.05).
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg; Placebo | 213 | 694/851 for total study | 52 | 0.50 (Mean; scale, 0-3) | 0.57 (Mean; scale, 0-6) | | 0.30 (Mean; scale, 0-3) | 0.37 (Mean; scale, 0-6)
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | 694/851 for total study | 52 | 0.52 (Mean; scale, 0-3) | 0.46 (Mean; scale, 0-6) | <0.001 | 0.27 (Mean; scale, 0-3) | 0.31 (Mean; scale, 0-6) | <0.001
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg; placebo | 214 | 694/851 for total study | 52 | 0.49 (Mean; scale, 0-3) | 0.53 (Mean; scale, 0-6) | | 0.26 (Mean; scale, 0-3) | 0.38 (Mean; scale, 0-6)
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg; formoterol 24 mcg | 215 | 694/851 for total study | 52 | 0.52 (Mean; scale, 0-3) | 0.33 (Mean; scale, 0-6) | <0.001 | 0.29 (Mean; scale, 0-3) | 0.20 (Mean; scale, 0-6) | <0.001
Pearlman, Stricker, Weinstein, et al., 1999 | FP 176 mcg | 23 | 23 | 4 | 1.2 +/− 0.5 (scale, 0-3) | −0.1 +/− 0.5 (change; scale, 0-3)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 4 | 1.2 +/− 1.0 (scale, 0-3 | −0.8 +/− 1.0 (change; scale, 0-3) | <0.0500 ^a^ | | | | Symptom score p<0.05 vs. Exp 2; % symptom-free days p<0.05 vs. Exp 2 and Exp 3
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 4 | 1.3 +/− 1.0 (scale, 0-3) | −0.3 +/− 0.5 (change; scale, 0-3)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 440 mcg | 21 | 21 | 4 | 1.1 +/− 0.9 (scale, 0-3 | −0.4 +/− 0.5, change (scale, 0-3) | NS^1^ | | | | % symptom-free days p<0.05 vs. Exp 2 and Exp 3
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg | 84 | 81 | 12 | 1.6 +/− 1.1 (scale, 0-5) | −0.4 +/− 0.8, (scale, 0-5)
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg; salmeterol 100 mcg | 84 | 81 | 12 | 1.4 +/− 1.0 (scale, 0-5) | −0.8 +/− 1.1, (scale, 0-5) | =0.0110 ^a^
van der Molen, Postma, Turner, et al., 1997 | ICS; placebo | 114 | 113 | 24 | 3.6 +/− 3 (scale, 0-21) | −0.64 (Mean change; scale, 0-21)
van der Molen, Postma, Turner, et al., 1997 | ICS; formoterol 48 mcg | 125 | 125 | 24 | 3.7 +/− 2.8 (scale, 0-21) | −1.28 (Mean change; scale, 0-21) | =0.0390 ^b^ | | | | Mean change in total symptom score −1.6+/−2.6 for ICS<=400 mcg and −1.1+/−2.9 for ICS>=1,600 mcg
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 57 | 53 | 54
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg; salmeterol 100 mcg | 60 | 55 | 54 | | | NS
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; placebo | 17 | 13 | | 31.4 +/− 2.9 (scale, 36-1) | 30.3 +/− 3.2, (scale, 36-1) | | | | | Symptom scores represent values at exacerbation or full withdrawal of ICS.
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; salmeterol 100 mcg | 17 | 13 | | 30.9 +/− 4.7 (scale, 36-1) | 29.5 +/− 5.5, (scale, 36-1) | NS ^b^ | | | | Symptom scores represent values at exacerbation or full withdrawal of ICS.
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,179 mcg; placebo | 19 | 19 | | | 0 (median change)
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,280 mcg; salmeterol 100 mcg | 15 | 15 | | | −1 (median change) | <0.01 | | | NS
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | FP 440 mcg; placebo | 223 | 223 | 12 | 1.09 +/− 0.7 (scale, 0-4 | −0.46 +/− 0.7, (change; scale, 0-4)
Baraniuk, Murray, Nathan, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 231 | 231 | 12 | 0.98 +/− 0.6 (scale, 0-4 | −0.44 +/− 0.8, (change; scale, 0-4) | NS ^a^
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 1,000 mcg | 65 | 58 | 12 | 1.1 (Mean; scale, 0-4) | 0.6 (Mean; scale, 0-4) | | 1.34 (Mean; scale, 0-4) | 0.9 (Mean; scale, 0-4)
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 500 mcg; formoterol 24 mcg | 69 | 68 | 12 | 1.2 (Mean; scale, 0-4) | 0.4 (Mean; scale, 0-4) | <0.0500 ^b^ | 1.34 (Mean; scale, 0-4) | 0.5 (Mean; scale, 0-4) | <0.0500 ^b^ | During the entire treatment period, daytime symptom scores p=0.001, nighttime symptom scores p<0.001 both in favor of BDP + formoterol
Condemi, Goldstein, Kalberg, et al., 1999 | FP 440 mcg; placebo | 216 | | 24 | 1.04 (Mean; scale, 0-4) | −0.26 +/− 0.6 (change; scale, 0-4) | | | | | Daytime symptom score=combined scores; daytime symptom scores decreased by 14%, 11%, and 14% for chest tightness, shortness of breath, wheezing
Condemi, Goldstein, Kalberg, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 221 | | 24 | 1.07 (Mean; scale, 0-4) | −0.43 +/− 0.6 (change; scale, 0-4) | <0.0010 ^a^ | | | | Daytime symptom score=combined scores; daytime symptom scores decreased by 35%, 32%, and 28% for chest tightness, shortness of breath, wheezing (p<0.015 overall between groups)
Greening, Ind, Northfield, et al, 1994 (Hyland and Crocker, 1995) | BDP 1,000 mcg; placebo | 206 | 160 | 12 | 1.43 (Median; scale ?) | 1 (Median; scale ?)
Greening, Ind, Northfield, et al, 1994 (Hyland and Crocker, 1995) | BDP 400 mcg; salmeterol 100 mcg | 220 | 175 | 12 | 1.5 (Median; scale ?) | 0.95 (Median; scale ?) | NS ^a^
Kelsen, Church, Gillman, et al., 1999 | BDP 672 mcg | 244 | 240 | 24 | | | | | | | Symptom score decreases of 0.22, 0.28, 0.26 for wheezing, shortness of breath and chest tightness seen after 24 weeks. No difference for comcgh.
Kelsen, Church, Gillman, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 239 | 236 | 24 | | | | | | | Symptom score decreases of 0.35, 0.48, 0.45 for wheezing, shortness of breath and chest tightness seen after 24 weeks (p<0.05 between groups). No difference for comcgh.
Murray, Church, Anderson, et al., 1999 | BDP 672 mcg | 254 | 253 | 24 | 1.1 (Mean; scale, 0-4) | 0.85 (Mean; scale, 0-4) | | | | | Mean decrease from baseline in wheezing, shortness of breath, chest tightness was 0.27, 0.25, 0.33
Murray, Church, Anderson, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 260 | 259 | 24 | 1.15 (Mean; scale, 0-4) | 0.55 (Mean; scale, 0-4) | <0.0500 ^b^ | | | | Mean decrease from baseline in wheezing, shortness of breath, chest tightness was 0.49, 0.71, 0.62 (p<0.05 between groups)
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg; placebo | 214 | | 52 | 0.49 (Mean; scale, 0-3) | 0.53 (Mean; scale, 0-6) | | 0.26 (Mean; scale, 0-3) | 0.38 (Mean; scale, 0-6) | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | | 52 | 0.52 (Mean; scale, 0-3) | 0.46 (Mean; scale, 0-6) | | 0.27 (Mean; scale, 0-3) | 0.31 (Mean; scale, 0-6) | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 4 | 1.3 +/− 1.0 (scale, 0-3) | −0.3 +/− 0.5 (change; scale, 0-3)
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 4 | 1.2 +/− 1.0 (scale, 0-3 | −0.8 +/− 1.0 (change; scale, 0-3) | NS ^a^ | | | | Symptom score p<0.05 vs. Exp 2; % symptom-free days p<0.05 vs. Exp 2 and Exp 3
van Noord, Schreurs, Mol, et al., 1999 | FP 400 or 1,000 mcg/day | 135 | | 12
van Noord, Schreurs, Mol, et al., 1999 | FP 200 or 500 mcg/day salmeterol 100 mcg | 139 | | 12 | | | | | | | Odds ratio of FP vs. Salmeterol for days with symptoms = 1.52 (95% CI, 1.01-2.28)
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 60 | 54 | 54
Verberne, Frost, Duiverman, et al., 1998 | BDP 200 mcg; salmeterol 100 mcg | 60 | 55 | 54 | | | NS
Vermetten, Boermans, Luiten, et al., 1999 | BDP 800 mcg | 120 | | 12 | 0.5 +/− 0.5 (scale, 0-3) | | | 0.7 /- 0.5
Vermetten, Boermans, Luiten, et al., 1999 | BDP 400 mcg; salmeterol 100 mcg | 113 | | 12 | 0.5 +/− 0.5 (scale, 0-3) | | | 0.7 /- 0.5
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; placebo | 37 | 33 | 12 | | 0.22 (Mean; scale, 0-3) | | | 0.2 (Mean; scale, 0-3) | | Daytime symptom score represents wheezing; shortness of breath, 0.17; comcgh, 0.31; activity, 0.12
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; theophylline 250 mg | 35 | 29 | 12 | | 0.13 (Mean; scale, 0-3) | NS ^b^ | | 0.13 (Mean; scale, 0-3) | NS ^b^ | Daytime symptom score represents wheezing; shortness of breath, 0.14; comcgh, 0.20; activity, 0.14; p-Value NS between groups for all
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 18 | 6 | 1.3 +/− 3.1 (scale, 0-9) | 4.19 +/− 6.9, (scale, 0-9) | | | | | Symptom score within-group change p<0.05
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19 | 17 | 6 | 1.2 +/− 3.1 (scale, 0-9) | 1.56 +/− 3.0, (scale, 0-9) | | | | | Symptom score within-group change p-Value NS
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom, et al., 1997 | BUD 1,600 mcg; placebo | 31 | 31 | 12
Evans, Taylor, Zetterstrom, et al., 1997 | BUD 800 mcg; theophylline 750 mg | 31 | 31 | 12 | | | 0.26 | | | 0.59
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 800 mcg; placebo | 90 | 64 | 6 | 1.5 (Median; scale, 0-4) | 0.5 (Median; scale, 0-4) | | 0.6 (Median; scale, 0-4) | 0 (Median; scale, 0-4) | | Within group improvement significant
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 400 mcg; theophylline 750 mg | 100 | 69 | 6 | 1.5 (Median; scale, 0-4) | 0.55 (Median; scale, 0-4) | NS | 0.9 (Median; scale, 0-4) | 0.21 (Median; scale, 0-4) | NS | Within group improvement significant
Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | BDP 400 mcg; placebo | 200 | 200 | 16 | 2.2 +/− 0.8 (scale, 0-6) | −0.02 (95% CI, (−0.10)−0.06), (change; scale, 0-6)
Laviolette, Malmstrom, Lu, et al., 1999 | BDP 400 mcg; Montelukast sodium 10 mg | 193 | 193 | 16 | 2.2 +/− 0.8 (scale, 0-6) | −0.13 (95% CI, (−0.22)-(−0.05), (change; scale, 0-6) | =0.0410 ^a^
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg; | 17 | 17 | 8 | 2.3 +/− 4.0 (scale, ?) | 2.5 +/− 6, (scale, ?)
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg pranlukast 450 mg | 24 | 24 | 8 | 2.7 +/− 4.5 (scale, ?) | 2.3 +/− 4.8, (scale, ?)
Virchow, Prasse, Naya, et al., 2000 | ICS; placebo | 188 | 188 | 6 | 1.8 +/− 0.41 (scale, 0-3) | −0.3 +/− 1.4 (change; scale, 0-3)
Virchow, Prasse, Naya, et al., 2000 | ICS; zafirlukast 80 mg | 180 | 180 | 6 | 1.8 +/− 0.40 (scale, 0-3) | −0.6 +/− 1.3 (change; scale, 0-3) | <0.001
Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | ICS 1,079 mcg; placebo | 113 | 113 | 12 | 1.38 +/− 0.8 (scale, 0-6) | 0.12 (Mean change; scale, 0-6)
Lofdahl, Reiss, Leff, et al., 1999 | ICS 976 mcg; montelukast sodium 10 mg | 113 | 112 | 12 | 1.29 +/− 0.7 (scale, 0-6) | 0.07 (Mean change; scale, 0-6) | NS ^a^

a Statistical comparison of change, treatment vs. control.

b Statistical comparison of absolute value, treatment vs. control.

Evidence Table 3-9. Symptom frequency and exacerbation outcomes

Citation | Treatment Arm | N Enrolled/evaluable | Baseline Daytime Symptom Frequency | Final Daytime Symptom Frequency | p-Value | Baseline Nighttime Symptom Frequency | Final Nighttime Symptom Frequency | p-Value | Exacerbations | p-Value | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; placebo | 165/ | | 28% symptom-free days | | | 52% symptom-free nights | | | | Symptom frequencies reflect overall treatment period.
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; salmeterol 100 mcg; placebo | 167/ | | 38% symptom-free days | | | 58% symptom-free nights | | | | Symptom frequencies reflect overall treatment period.
Boyd, 1995 | ICS 1,500 mcg; placebo | 64/62 | 7 +/− 19% symptom-free days | 20 +/− 31% symptom-free days | | 29 +/− 33% symptom-free nights | 42 +/− 38% symptom-free nights | | # patients with exacerbations, 15
Boyd, 1995 | ICS 1,500 mcg; salmeterol 200 mcg | 55/53 | 8 +/− 17% symptom-free days | 30 +/− 36% symptom-free days | NS ^a^ | 20 +/− 25% symptom-free nights | 53 +/− 38% symptom-free nights | =0.0010^1^ | # patients with exacerbations, 19 | NS
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 734 mcg; placebo | 91/79 | | | | | | | Total # exacerbations, 15
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 730 mcg; formoterol 24 mcg; placebo | 89/89 | | | | | | | Total # exacerbations, 16 | =0.0460 ^b^
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg | 90 | 19.4+/−34.5% symptom-free days | 7.2+/−37.7% symptom-free days (change) | | 91.3+/−16.5% symptom-free nights | 2.4+/−21.6% symptom-free nights (change)
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg; salmeterol 100 mcg | 92 | 25.2+/−37.3% symptom-free days | 22.6+/−42.8% symptom-free days (change) | <0.0250 | 91.7+/−14.7% symptom-free nights | 4.6+/−16.1% symptom-free nights (change) | NS
Kemp, Cook, Incaudo, et al., 1998 | ICS; placebo | 254/ | 4% symptom-free days | 22% symptom-free days | | | 30% increase in symptom-free nights | | # patients with exacerbations, 59
Kemp, Cook, Incaudo, et al., 1998 | ICS; salmeterol 84 mcg | 252/ | 5% symptom-free days | 43% symptom-free days | <0.0010 ^a^ | | 61% increase in symptom-free nights | <0.0010 ^a^ | # patients with exacerbations, 53
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; placebo | 24/23 | 19.8% symptom-free days | 29.4% symptom-free days
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; salmeterol 100 mcg | 25/24 | 30.3% symptom-free days | 69.4% symptom-free days | =0.0020 ^b^
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg; placebo | 213 | 694/851 for total study | 41.7% episode-free days | | | 0.14 awakenings/night | | Severe - 0.91/pt/yr Mild - 35.4/pt/yr | | Episode-free day defined as days with no symptoms, no use of rescue medication, and a PEF >80% of baseline
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | 694/851 for total study | 51.1% episode-free days | =0.001 | | 0.11 awakenings/night | 0.03 | Severe - 0.67/pt/yr Mild - 21.3/pt/yr | =0.01 <0.001 | Episode-free day defined as days with no symptoms, no use of rescue medication, and a PEF >80% of baseline
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg; placebo | 214 | 694/851 for total study | 45.7% episode-free days | | | 0.10 awakenings/night | | Severe - 0.46/pt/yr Mild - 22.3/pt/yr | | Episode-free day defined as days with no symptoms, no use of rescue medication, and a PEF >80% of baseline
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg; formoterol 24 mcg | 215 | 694/851 for total study | 54.8% episode-free days | =0.001 | | 0.05 awakenings/night | 0.03 | Severe - 0.34/pt/yr Mild - 13.4/pt/yr | =0.01 <0.001 | Episode-free day defined as days with no symptoms, no use of rescue medication, and a PEF >80% of baseline
Pearlman, Stricker, Weinstein, et al., 1999 | FP 176 mcg | 23/23 | 11 +/− 24% symptom-free days | 5 +/− 29% symptom-free days, change | | 88 +/− 24% symptom-free nights | 4 +/− 14% symptom-free nights, change
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25/25 | 29 +/− 35% symptom-free days | 34 +/− 45% symptom-free days, change | <0.0500 ^a^ | 90 +/− 15% symptom-free nights | 2 +/− 20% symptom-free nights, change | NS ^a^
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23/23 | 22 +/− 38% symptom-free days | 12 +/− 34% symptom-free days, change | | 90 +/− 14% symptom-free nights | 1 +/− 14% symptom-free nights, change
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 440 mcg | 21/21 | 27 +/− 37% symptom-free days | 24 +/− 37% symptom-free days, change | <0.0500 ^a^ | 92 +/− 14% symptom-free nights | 7 +/− 9% symptom-free nights, change | NS ^a^
Russell, Williams, Weller, et al., 1995 | BDP or equiv, avg. 750 mcg; placebo | 107/89 | 8% symptom-free days | 26% symptom-free days | | 38% symptom-free nights | 59% symptom-free nights, change
Russell, Williams, Weller, et al., 1995 | BDP or equiv, avg. 750 mcg; salmeterol 100 mcg | 99/77 | 15% symptom-free days | 60% symptom-free days | =0.0080 ^a^ | 57% symptom-free nights | 81% symptom-free nights, change | | | | % symptom-free nights reported is maximum value with a significant difference between groups during the first 4 weeks -- not stated if significant difference at 12 wks.
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg | 84/81 | % symptom-free days, 23.5 | % symptom-free days, 15.4 | | % symptom-free nights, 90.5 | % symptom-free nights, 2.8
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg; salmeterol 100 mcg | 84/81 | % rescue-free days, 26.5 | % symptom-free days, 33.8 | <0.0040 ^a^ | % symptom-free nights, 90.7 | % symptom-free nights, 7.2 | <0.0160 ^a^
van der Molen, Postma, Turner, et al., 1997 | ICS; placebo | 114/113 | | | | | | | # patients with exacerbations, 32
van der Molen, Postma, Turner, et al., 1997 | ICS; formoterol 48 mcg | 125/125 | | | | | | | # patients with exacerbations, 33 | NS ^b^
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 57/53 | 11% patients without symptoms | 35% patients without symptoms
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg; salmeterol 100 mcg | 60/55 | | 34% patients without symptoms
Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,179 mcg; placebo | 19/19
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,280 mcg; salmeterol 100 mcg | 15/15 | | % symptom-free days | <0.001 | | | | | | Salmeterol treatment group experienced fewer symptoms during daytime (P<0.01) and more days w/out symptoms (P<0.001).
Wilding, Clark, Coon, et al., 1997 | ICS; placebo | 100/87 | 56% symptom-free days | 64% symptom-free days | | 93% symptom-free nights | 86% symptom-free nights | | # patients with exacerbations, 25 | | Baseline % rescue-free days 8, final 58
Wilding, Clark, Coon, et al., 1997 | ICS; salmeterol 100 mcg | 100/87 | 56% symptom-free days | 82% symptom-free days | <0.0010 ^b^ | 93% symptom-free nights | 96% symptom-free nights | <0.0010 ^b^ | # patients with exacerbations, 16 | NS ^b^ | Baseline % rescue-free days 8, final 73, p<0.001
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | FP 440 mcg; placebo | 223/223 | 11.6 +/− 23.9% symptom-free days | 22.6 +/− 38.8% symptom-free days, change | | 0.47 +/− 0.60 nighttime awakenings | −0.32 +/− 0.60 nighttime awakenings, change | | | | 12.5 +/−26.9% rescue-free days at baseline; Change at end of treatment, 28.9 +/− 40.3%.
Baraniuk, Murray, Nathan, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 231/231 | 11.7 +/− 24.3% symptom-free days | 29.2 +/− 44.1% symptom-free days, change | NS ^a^ | 0.47 +/− 0.61 nighttime awakenings | −0.31+/− 0.61 nighttime awakenings, change | NS ^a^ | | | 10.9 +/− 24.3% rescue-free days at baseline; Change at end of treatment, 45.0 +/− 44.1%., p<0.001
Condemi, Goldstein, Kalberg, et al., 1999 | FP 440 mcg; placebo | 216/ | 15.3 +/− 29.4% symptom-free days | 17.5 +/− 29.4% symptom-free days, change | | 76.6 +/− 32.3% symptom-free nights | 10.1 +/− 26.4% symptom-free nights, change | | # patients with >1 exacerbation, 31 | | # patients with >1 exacerbation, 7
Condemi, Goldstein, Kalberg, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 221/ | 10 +/− 22.3% symptom-free days | 30 +/− 37.2% symptom-free days, change | <0.0140 ^a^ | 71.7 +/− 35.7% symptom-free nights | 14.9 +/− 28.2% symptom-free nights, change | =0.0080 ^a^ | # patients with >1 exacerbation, 21 | =0.1400 | # patients with >1 exacerbation, 4, p-Value NS
Greening, Ind, Northfield, et al., 1994 | BDP 1,000 mcg; placebo | 206/206 | 87% days with symptoms | 61% days with symptoms | | 35% nights with symptoms | 24% nights with symptoms | | % patients with exacerbations, 22 | | Symptom frequencies reflect overall treatment period.
Greening, Ind, Northfield, et al., 1994 | BDP 400 mcg; salmeterol 100 mcg | 220/220 | 87% days with symptoms | 56% days with symptoms | NS ^a^ | 41% nights with symptoms | 20% nights with symptoms | NS ^a^ | % patients with exacerbations, 21 | NS | Symptom frequencies reflect overall treatment period.
Kelsen, Church, Gillman, et al., 1999 | BDP 672 mcg | 244/240 | 10% symptom-free days | 27 +/− 39% symptom-free days | | 68 +/− 34% symptom-free nights | 13.4 +/− 24.8% symptom-free nights, change | | 18% patients with exacerbations | | Mean overall change in % nights with no supplemental beta-agonist use, 14.7 +/− 29.4
Kelsen, Church, Gillman, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 239/236 | 9.5% symptom-free days | 43 +/− 46% symptom-free days | <0.0500 ^a^ | 67 +/− 35% symptom-free nights | 18.8 +/− 26.1% symptom-free nights, change | =0.0010 ^a^ | 16% patients with exacerbations | NS | Mean overall change in % nights with no supplemental beta-agonist use, 23.2 +/− 30.7, p<
Murray, Church, Anderson, et al., 1999 | BDP 672 mcg | 254/253 | 12 +/− 24% symptom-free days | 24 +/− 32% symptom-free days | | 61.5+/− 32% symptom-free nights | 75 +/− 32% symptom-free nights | | 45 patients with 56 exacerbations | | Symptom-free nights represents % of nights with no supplemental beta-agonist use; % days with no supplemental beta-agonist use, 28
Murray, Church, Anderson, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 260/259 | 10 +/− 24% symptom-free days | 42.5 +/− 40% symptom-free days | <0.0010 ^b^ | 61 +/− 32% symptom-free nights | 85 +/− 32% symptom-free nights | <0.0500 ^b^ | 43 patients with 52 exacerbations | | Symptom-free nights represents % of nights with no supplemental beta-agonist use; % days with no supplemental beta-agonist use, 51, p<0.05; no statistically significant between-group differences for # of nighttime awakenings and amount of sleep lost
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg; placebo | 214 | | 45.7% episode-free days | | | 0.10 awakenings/night | | Severe - 0.46/pt/yr Mild - 22.3/pt/yr | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg; formoterol 24 mcg | 210 | | 51.1% episode-free days | | | 0.11 awakenings/night | | Severe - 0.67/pt/yr Mild - 21.3/pt/yr | | Statistical comparisons NR for low dose ICS + formoterol compared to high dose ICS
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23/23 | 22 +/− 38% symptom-free days | 12 +/− 34% symptom-free days, change | | 90 +/− 14% symptom-free nights | 1 +/− 14% symptom-free nights, change
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25/25 | 29 +/− 35% symptom-free days | 34 +/− 45% symptom-free days, change | <0.0500 ^a^ | 90 +/− 15% symptom-free nights | 2 +/− 20% symptom-free nights, change | NS ^a^
van Noord, Schreurs, Mol, et al., 1999 | FP 400 or 1,000 mcg/day | 135/ | 9 days/2 wk with symptoms | 7 days/2 wk with symptoms | | 5.9 nights/2 wk with symptoms | 5.5 nights/2 wk with symptoms | | | | Mean # days with supplemental beta-agonist use, 6.5; nights, 4.5
van Noord, Schreurs, Mol, et al., 1999 | FP 200 or 500 mcg/day salmeterol 100 mcg | 139/ | 9 days/2 wk with symptoms | 6.5 days/2 wk with symptoms | | 6.8 nights/2 wk with symptoms | 5 nights/2 wk with symptoms | | | | Mean # days with supplemental beta-agonist use, 4.5; nights, 4.9; Odds ratio of Salmeterol vs. FP for days with symptoms=1.52 (1.01-2.28)
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 60/54 | 13% patients without symptoms | 39% patients without symptoms
Verberne, Frost, Duiverman, et al., 1998 | BDP 200 mcg; salmeterol 100 mcg | 60/55 | | 34% patients without symptoms
Vermetten, Boermans, Luiten, et al., 1999 | BDP 800 mcg | 120/ | 54 +/− 33% days/wk with symptoms | 38 +/− 44% days/wk with symptoms | | 41 +/−33% nights/week with symptoms | 34 +/− 44% nights/week with symptoms | | # patients with exacerbations, 17
Vermetten, Boermans, Luiten, et al., 1999 | BDP 400 mcg; salmeterol 100 mcg | 113/ | 56 +/− 42% days/wk with symptoms | 37 +/− 42% days/wk with symptoms | NS ^a^ | 43 +/− 42% nights/week with symptoms | 33 +/− 42% nights/week with symptoms | NS ^a^ | # patients with exacerbations, 9 | NS ^b^
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 2,000 mcg | 251/ | 0% symptom-free days | 42% symptom-free days | | 29% symptom-free nights | 86% symptom-free nights | | % patients with exacerbations, 20 | | Final median % rescue-free days, 57; final median % rescue-free nights 100
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 100 mcg | 243/ | 0% symptom-free days | 85% symptom-free days | <0.0010 ^b^ | 43% symptom-free nights | 100% symptom-free nights | <0.0500 ^b^ | % patients with exacerbations, 20 | NS ^b^ | Final median % rescue-free days, 100, p<0.001; final median % rescue-free nights 100
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 200 mcg | 244/ | 0% symptom-free days | 84% symptom-free days | <0.0010 ^b^ | 43% symptom-free nights | 100% symptom-free nights | <0.0500 ^b^ | % patients with exacerbations, 16 | NS ^b^ | Final median % rescue-free days, 86, p<0.001; final median % rescue-free nights 100
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; placebo | 37/33 | | | | 80% patients with score 0/1 | 84% patients with score 0/1 | | # patients with >1 exacerbations, 5
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; theophylline 250 mg | 35/29 | | | | 72% patients with score 0/1 | 85% patients with score 0/1 | | # patients with >1 exacerbations, 3
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; placebo | 22/21 | | 50% symptom-free days | | | 12.5% nights/week with symptoms | | | | Mean % days symptom-free for Activity 18, for Comcgh 26, for Wheeze, 32.5; % total patient-days without any asthmatic symptoms 42+/−28; % days beta-agonist used >2x/day, 11.6 +/− 17.0
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; theophylline | 22/21 | | 71% symptom-free days | <0.0100 ^b^ | | 7% nights/week with symptoms | | | | Mean % days symptom-free for Activity 9, for Comcgh 9, for Wheeze, 7.5; % total patient-days without any asthmatic symptoms 63+/− ?, p<0.01; % days beta-agonist used >2x/day, 0.4 +/− 1.8, p<0.01
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | BUD 1,600 mcg; placebo | 31/31 | | | | | | | 11 mild and 2 severe exacerbations
Evans, Taylor, Zetterstrom et al., 1997 | BUD 800 mcg; theophylline 750 mg | 31/31 | | | | | | | 13 mild and 1 severe exacerbations
Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | BDP 400 mcg; Placebo | 200/200 | | | | | −0.45 nights/week with symptoms, change | | % patients with exacerbations, 12 | | % days with exacerbations, 17.92 (95% CI 14.61-21.23)
Laviolette, Malmstrom, Lu, et al., 1999 | BDP 400 mcg; montelukast sodium 10 mg | 193/193 | | | | | −1.04 nights/week with symptoms, change | =0.0100 ^a^ | % patients with exacerbations, 6.2 | =0.5500 | % days with exacerbations, 13.37 (95% CI 9.97-16.77), p=0.041
Tamaoki, Kondo, Sakai, et al., 1997 | BDP 750 mcg; theophylline placebo | 40/37 | 3.5 +/− 6.1 symptom episodes/wk | 6.3 +/− 15.2 symptom episodes/wk, change | | 1.4 +/− 2.4 symptom episodes/wk | 3 +/− 9.7 symptom episodes/wk, change
Tamaoki, Kondo, Sakai, et al., 1997 | BDP 750 mcg; theophylline; pranlukast 900 mg | 43/42 | 2.7 +/− 5.2 symptom episodes/wk | −0.2 +/− 11.7 symptom episodes/wk, change | =0.0330 ^a^ | 1.5 +/− 1.9 symptom episodes/wk | 2.1 +/− 8.4 symptom episodes/wk, change | NS ^a^
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg; | 17/17
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP 400 mcg pranlukast 450 mg | 24/24
Virchow, Prasse, Naya, et al., 2000 | ICS; placebo | 188 | 0.2 +/− 1.0 symptom-free days/mo | 3.68 +/− 9.7 symptom-free days/mo | | 3.7 +/− 5, 5 awakenings/wk | −0.4 +/− 4.1 awakenings/wk (change) | | % patients with exacerbations, 29 | | 0.45 total exacerbations/patient; 13% of patients required an increase in ICS
Virchow, Prasse, Naya, et al., 2000 | ICS; zafirlukast 80 mg | 180 | 0.67 +/− 2.0 symptom-free days/mo | 6.86 +/− 12.6 symptom-free days/mo | NS | 3.6 +/− 5.4 awakenings/wk | −0.9 +/− 4.0 awakenings/wk (change) | NS | % patients with exacerbations, 20 | =0.046 | 0.25 total exacerbations/patient, p=0.053; 5.6% of patients required an increase in ICS, p=0.017
Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | ICS 1,079 mcg; placebo | 113/113 | | | | | | | % patients with exacerbations, 30
Lofdahl, Reiss, Leff, et al., 1999 | ICS 976 mcg; montelukast sodium 10 mg | 113/112 | | | | | | | % patients with exacerbations, 16

a Statistical comparison of change, treatment vs. control.

b Statistical comparison of absolute value, treatment vs. control.

Evidence Table 3-10. Quality of life outcomes

Citation | QOL Instrument | Treatment Arm | # Eval Pts | Scale(s) result | Result | p-Value | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Kemp, Cook, Incaudo, et al., 1998 | AQLQ | Corticosteroid, inhaled; placebo | | Global Activity limitation Asthma symptoms Emotional function Environmental exposure | 0.61 0.54 0.71 0.65 0.47 | | Results reported as change from baseline.
Kemp, Cook, Incaudo, et al., 1998 | AQLQ | Corticosteroid, inhaled; salmeterol 84 mcg; | | Global Activity limitation Asthma symptoms Emotional function Environmental exposure | 1.08 0.91 1.28 1.17 0.84 | <0.0160 <0.0160 <0.0160 <0.0160 <0.0160 | Results reported as change from baseline.
Pauwels, Lofdahl, Postma, et. al., 1997 (QOL data reported by Juniper, Svensson, O'Byrne, et al., 1999) | AQLQ | Budesonide 200 mcg; placebo | | Overall change AQLQ Change activity Change symptoms Change emotional Environmental, change | 0 0.02 0.03 0.05 0.05 | | Run-in period there was improv. In QOL in all domains & overall score; improvements were stat. Sig (P<.0001) with a change in mean score of ~.50. Scores in all grps were maintained at same level, no evidence of deterioration; 356 pts completed 12 M
Pauwels, Lofdahl, Postma, et. al., 1997 (QOL data reported by Juniper, Svensson, O'Byrne, et al., 1999) | AQLQ | Budesonide 200 mcg; formoterol 24 mcg | | Overall change AQLQ Change activity Change symptoms Change emotional Environmental, change | 0.06 0 0 -0.06 -0.25 | | Following randomization, only the Bud800+F group showed further improvement in AQLQ scores. The mean improvement of 0.2 was less than the minimal important difference of 0.5. In all 4 groups, the QOL achieved 1 month after randomization sustained
Pauwels, Lofdahl, Postma, et. al., 1997 (QOL data reported by Juniper, Svensson, O'Byrne, et al., 1999) | AQLQ | Budesonide 800 mcg; placebo | | Overall change AQLQ Change activity Change symptoms Change emotional Environmental, change | 0.1 -0.1 0 0 -0.2
Pauwels, Lofdahl, Postma, et. al., 1997 (QOL data reported by Juniper, Svensson, O'Byrne, et al., 1999) | AQLQ | Budesonide 800 mcg; formoterol 24 mcg | | Overall change AQLQ Change activity Change symptoms Change emotional Environmental, change | 0.21 -0.3 -0.1 -0.3 -0.3 | 0.028 | Correlations btwn change in AQLQ scores and change in clinical measures over randomization period were only weak to moderate. 356 out of 466 completed study. Don't give n by study group for outcomes
Addition of Long-Acting Beta-2 Agonists
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Greening, Ind, Northfield, et al., 1994 (QOL reported by Hyland and Crocker, 1995) | Living with Asthma Questionnaire | Beclomethasone dipropionate 1,000 mcg; placebo | 160 | Questionnaire Functional limitation Distress Diary Problem incidence Problem severity | 0.85 0.5 0.35 0.90 | | Functional limitation baseline 0.94; Distress baseline 0.61; Problem incidence baseline 0.50; Problem severity baseline 1.00
Greening, Ind, Northfield, et al., 1994 (QOL reported by Hyland and Crocker, 1995) | Living with Asthma Questionnaire | Beclomethasone dipropionate 400 mcg; salmeterol 100 mcg | 175 | Questionnaire Functional limitation Distress Diary Problem incidence Problem severity | 0.85 0.56 0.42 0.80 | NS NS 0.02 0.03 | Functional limitation baseline 0.95; Distress baseline 0.63; Problem incidence baseline 0.67; Problem severity baseline 1.25
Vermetten, Boermans, Luiten, et al., 1999 | Hyland Quality of Life Questionnaire | Beclomethasone dipropionate 800 mcg; | | A cold does not hurt me very much I can run as fast as other people my age I can climb a hill as fast as other people my age I can go out at night to a bar without problems Apart from exacerbations I am not troubled by asthma That I cannot do sports frustrates me | NR NR NR NR NR NR | | Within group improvement for items 1-5; "A smoky restaurant can spoil a dinner completely" p sig within group; "I never worry about the possibility that my asthma problems may worsen by going on holiday" p sig within group
Vermetten, Boermans, Luiten, et al., 1999 | Hyland Quality of Life Questionnaire | Beclomethasone dipropionate 400 mcg; salmeterol 100 mcg | | A cold does not hurt me very much I can run as fast as other people my age I can climb a hill as fast as other people my age I can go out at night to a bar without problems Apart from exacerbations I am not troubled by asthma That I cannot do sports frustrates me | NR NR NR NR NR NR | NS NS NS NS NS NS | Within-group improvement for items 1-6; "A smoky restaurant can spoil a dinner completely" p NS within or between group; "I never worry about the possibility that my asthma problems may worsen by going on holiday: p NS within or between grp

Evidence Table 3-11. Adverse events summary

Citation | Treatment | Enrolled | Evalu-able | AE Dropouts (p-Value) ^a^ | Total Pts w/AE (p-Value) ^a^ | Total Pts w/Tx-related AE (p-Value) ^a^ | Total patients reporting a specific adverse event, or the sum of patients reporting one or more adverse events within a category of adverse events | | | | | | | Comments
Citation | Treatment | Enrolled | Evalu-able | AE Dropouts (p-Value) ^a^ | Total Pts w/AE (p-Value) ^a^ | Total Pts w/Tx-related AE (p-Value) ^a^ | Head-ache | CNS ^b^ | Cardiac ^c^ | GI Distress ^d^ | Infec-tion ^e^ | Throat Problems ^f^ | Liver Toxicity | Comments
Addition of Long-Acting Beta-2 Agonists
Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; placebo | 165 | 165 | 22 | | 32 | 2 | | | | | 11
Aubier, Pieters, Schlosser, et al., 1999 | FP 1,000 mcg; salmeterol 100 mcg; placebo | 167 | 167 | 16 (NS) | | 28 (NS) | 3 | | | | | 6
Boulet, Cartier, Milot, et al., 1998 | ICS; placebo | 16
Boulet, Cartier, Milot, et al., 1998 | ICS; salmeterol 100 mcg | 16
Boyd, 1995 | ICS 1,500 mcg; placebo | 64 | 64 | | 60 | | 17 | 3 | 2 | | 47
Boyd, 1995 | ICS 1,500 mcg; salmeterol 200 mcg | 55 | 55 | | 51 (NS) | | 17 | 3 | 3 | | 40
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 734 mcg; placebo | 91 | 91 | | 9
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS 730 mcg; formoterol 24 mcg; placebo | 89 | 89 | | 13 (NS)
Grutters, Brinkman, Aslander, et al., 1999 | BDP 800 mcg | 15
Grutters, Brinkman, Aslander, et al., 1999 | BDP 800 mcg; salmeterol 100 mcg; | 12
Studies Using a Fixed ICS Dose in All Study Arms
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; placebo | 118 | | 6 | | | | | | | | | | Study states that "The proportion of patients reporting adverse events was similar in the 4 treatment groups."
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; formoterol 24 mcg | 116 | | 6 (NS)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; Placebo | 115 | | 8
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; formoterol 24 mcg | 117 | | 9 (NS)
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg | 90 | 90 | 1 | | | 0 | | | | 3 | 3
Kavuru, Melamed, Gross, et al., 2000 | FP 200 mcg; salmeterol 100 mcg | 92 | 92 | 0 (NS) | | | 2 | | | | 4 | 7
Kemp, Cook, Incaudo, et al., 1998 | ICS; placebo | 254 | 254 | 5 | 130 | 13
Kemp, Cook, Incaudo, et al., 1998 | ICS; Salmeterol 84 mcg | 252 | 252 | 7 (NS) | 134 (NS) | 11 (NS)
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; placebo | 24 | 24 | | 12
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; salmeterol 100 mcg | 25 | 25 | | 14 (NS)
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; placebo | 16
Li, Ward, Thien, et al., 1999 | BDP or BUD 400 mcg; salmeterol 100 mcg | 13
Pearlman, Stricker, Weinstein, et al., 1999 | FP 176 mcg | 23 | 23 | 0 | | | 0 | 0 | 0 | | 0 | 0 | | No statistically significant differences among treatment groups
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 0 | | | 0 | 2 | 2 | | 1 | 1 | | No statistically significant differences among treatment groups
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 0 | | | 0 | 0 | 0 | | 0 | 0 | | No statistically significant differences among treatment groups
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 440 mcg | 21 | 21 | 0 | | | 1 | 0 | 0 | | 0 | 0 | | No statistically significant differences among treatment groups
Russell, Williams, Weller, et al., 1995 | BDPor equiv, avg. 750 mcg; placebo | 107 | | 2 | 94 | | 9 | 3 | | 12 | 82
Russell, Williams, Weller, et al., 1995 | BDPor equiv, avg. 750 mcg; salmeterol 100 mcg | 99 | | 4 (NS) | 84 (NS) | | 21 | 2 | | 17 | 75
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg | 84 | 81 | 0 | | | | | | | 5
Shapiro, Lumry, Wolfe, et al., 2000 | FP 500 mcg; salmeterol 100 mcg | 84 | 81 | 0 | | | | | | | 5
van der Molen, Postma, Turner, et al., 1997 | ICS; placebo | 114 | 113 | 1
van der Molen, Postma, Turner, et al., 1997 | ICS; formoterol 48 mcg | 125 | 125 | 5 (NS) | | | | 3
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 57 | 57 | 0 | 52 | | 23 | | | 11 | 37
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg; salmeterol 100 mcg | 60 | 60 | 2 (NS) | 59 (NS) | | 25 | | | 19 | 54
Weersink, Douma, Postma, et al., 1997 | FP 500m cg | 17 | | 0
Weersink, Douma, Postma, et al., 1997 | FP 500 mcg; salmeterol 100 mcg | 16 | | 0
Studies that titrated ICS dose after Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; placebo | 17
McIvor, Pizzichini, Turner, et al., 1998 | ICS 1,500 mcg; salmeterol 100 mcg | 17
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,179 mcg; placebo | 19 | 19 | | | | | | | | | | | Reported no difference between the 2 tx groups in the incidence of adverse events during the study
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP avg. 1,280 mcg; salmeterol 100 mcg | 15 | 15 | | | | | | | | | | | Reported no difference between the 2 tx groups in the incidence of adverse events during the studies
Wilding, Clark, Coon, et al., 1997 | ICS; placebo | 100 | 87 | 1 | | | 1 | 1 | 1 | | | | | No sig differences in mean or max 24 hr heart rate and no diff in frequency distribution of ventricular and supraventricular ectopic beats
Wilding, Clark, Coon, et al., 1997 | ICS; salmeterol 100 mcg | 100 | 87 | 2 (NS) | | | 0 | 0 | 4 | | | | | No sig differences in mean or max 24 hr heart rate and no diff in frequency distribution of ventricular and supraventricular ectopic beats
Studies using an increased ICS dose alone vs. a lower ICS dose + added medication
Baraniuk, Murray, Nathan, et al., 1999 | FP 440 mcg; placebo | 223 | | 3 | | 30 | | | | | | 12
Baraniuk, Murray, Nathan, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 231 | 231 | 9 (0.05) | | 33 (NS) | | | | | | 14
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 1,000 mcg | 65 | 58 | 0
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP 500 mcg; formoterol 24 mcg | 69 | 64 | 0 | | | | | | | | | | Investigators report no differences between treatment groups.
Studies using an increased ICS dose alone vs. a lower ICS dose + added medication
Condemi, Goldstein, Kalberg, et al., 1999 | FP 440 mcg; placebo | 216 | 216 | 5 | 186 | 31 | | | | | 11 | 9
Condemi, Goldstein, Kalberg, et al., 1999 | FP 176 mcg; salmeterol 84 mcg | 221 | 221 | 0 (0.03) | 190 (NS) | 22 (NS) | | | | | 1 | 7
Greening, Ind, Northfield, et al., 1994 | BDP 1,000 mcg; placebo | 206 | | 22
Greening, Ind, Northfield, et al., 1994 | BDP 400 mcg; salmeterol 100 mcg | 220 | | 18 (NS)
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 800 mcg; placebo | 115 | | 8 | | | | | | | | | | "The proportion of patients reporting adverse events was similar in the 4 treatment groups."
Pauwels, Lofdahl, Postma, et al, 1997 | BUD 200 mcg; formoterol 24 mcg | 116 | | 6 (NS) | | | | | | | | | | "The proportion of patients reporting adverse events was similar in the 4 treatment groups."
Kelsen, Church, Gillman, et al., 1999 | BDP 672 mcg | 244 | 244 | 16 | | 34 | 17 | | | 13 | 99 | 20 | | 6 dropouts due to drmcg-related AE
Kelsen, Church, Gillman, et al., 1999 | BDP 336 mcg; salmeterol 84 mcg | 239 | 239 | 16 (NS) | | 26 (NS) | 20 | | | 6 | 89 | 17 | | 7 dropouts due to drmcg-related AE
Murray, Church, Anderson, et al., 1999 | BDP 672 mcg | 254 | 254 | 4
Murray, Church, Anderson, et al., 1999 | BDP 336 mcg; Salmeterol 84 mcg | 260 | 260 | 8 (NS) | | | | | | | | | | Total # AE as well as those considered possibly drmcg-related reported as similar between treatment groups
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23 | 23 | 0 | 0 | | 0 | 0 | 0 | | 0 | 0
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol 84 mcg; FP 176 mcg | 25 | 25 | 0 | | | 0 | 1 | 2 | | 1 | 1 | | No statistically significant differences among treatment groups for total AE or continuous 24-hr ambulatory ECG
Studies using an increased ICS dose alone vs. a lower ICS dose + added medication
van Noord, Schreurs, Mol, et al., 1999 | FP 400 or 1,000 mcg/day | 135 | | 4
van Noord, Schreurs, Mol, et al., 1999 | FP 200 or 500 mcg/day salmeterol 100 mcg | 139 | | 0 (NS) | | | | | | | | | | "The number of pts. reporting adverse events at the scheduled visits were not sig. diff in the 2 groups."
Verberne, Frost, Duiverman, et al., 1998 | BDP 400 mcg | 60 | 60 | 1 | 52 | | 16 | | | 7 | 53
Verberne, Frost, Duiverman, et al., 1998 | BDP 200 mcg; salmeterol 100 mcg | 60 | 60 | 2 (NS) | 59 (0.015) | | 25 | | | 19 | 54
Vermetten, Boermans, Luiten, et al., 1999 | BDP 800 mcg | 120 | | | | | 14 | 4 | 4
Vermetten, Boermans, Luiten, et al., 1999 | BDP 400 mcg; salmeterol 100 mcg | 113 | | | | | 16 | 0 | 0
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 2,000 mcg | 251 | 251 | 15 | | | 43 | 2 | 6 | | 46 | | | No clinically significant changes in systolic or diastolic blood pressure, pulse rate, or in ECGs
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 100 mcg | 243 | 243 | 14 (NS) | | | 26 | 6 | 8 | | 42 | | | No clinically significant changes in systolic or diastolic blood pressure, pulse rate, or in ECGs
Woolcock, Lundback, Ringdal, et al., 1996 | BDP 1,000 mcg; salmeterol 200 mcg | 244 | 244 | 14 (NS) | | | 38 | 19 | 11 | | 52 | | | No clinically significant changes in systolic or diastolic blood pressure, pulse rate, or in ECGs; Tremor significantly higher in Exp 2 than in Exp 1 or Control (p<0.001)
Addition of Theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 | BDP 500 mcg; Placebo | 40 | 40 | | | | | 0
Emad, 1996 | BDP 500 mcg; theophylline 250 mg | 40 | | | | | | 2
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; placebo | 37 | 37 | 1 | | | 15 | 17 | | 12 | | 21
Meltzer, Orgel, Ellis, et al., 1992 | albuterol (salbutamol) 180 mcg; BDP 336 mcg; theophylline 250 mg | 35 | 35 | 0 (NS) | | | 11 | 6 | | 14 | | 10
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19
Minoguchi, Kohno, Oda, et al., 1998 | BDP 400 mcg; theophylline 400 mg | 19
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; placebo | 22 | | 0 | | | | | | | | | | Adverse effects among the patients were infrequent, mild, transient, and associated exclusively with change from placebo to theophylline.
Nassif, Weinberger, Thompson, et al., 1981 | BDP 200 mcg; theophylline | 22 | | 0 | | | | | | | | | | Adverse effects among the patients were infrequent, mild, transient, and associated exclusively with change from placebo to theophylline.
Studies using an increased ICS dose alone vs. a lower ICS dose + added medication
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 800 mcg; placebo | 90 | 90 | 1 | | | | | 2 | 4 | 11
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP 400 mcg; theophylline 750 mg | 100 | 100 | 6 (NS) | | | | | 6 | 15 | 6

a Chi-square or Fisher's exact test.

b Sum of patients reporting CNS adverse events and/or tremors.

c Sum of patients reporting one or more cardiac symptoms.

d Sum of patients reporting dyspepsia, nausea, vomiting, and/or diarrhea.

e Sum of patients reporting upper respiratory infection, rhinitis, and/or sinusitis.

f Total patients reporting throat irritation, hoarseness/dysphonia, and/or unpleasant taste.

Meta-Analysis Results

Meta-Analysis Table 3-12. FEV1. Studies comparing the addition of long-acting beta-agonists to a fixed ICS dose

Study | Tx Dur (wks) | # Patients (Ctl/Exp) | FEV1 Reporting Units | Effect Size Estimate | 95% CI
Aubier^b^ | 28 | 165/167 | L | 0.162 | −0.054, 0.378
Pearlman (176 mcg FP)^b^ | 4 | 23/25 | L | 0.687 | 0.105, 1.270
Pearlman (440 mcg FP)^b^ | 4 | 23/21 | L | 0.710 | 0.100, 1.320
Boyd^a, b^ | 12 | 52/48 | L | 0.083 | −0.310, 0.475
Kemp | 12 | 254/252 | L | 0.294 | 0.119, 0.470
Langley^b^ | 4 | 23/24 | L | 0.166 | −0.407, 0.739
van der Molen^a^, ^b^ | 24 | 113/125 | L | 0.163 | −0.092, 0.418
Kavuru^a^, ^b^ | 12 | 85/87 | L | 0.494 | 0.190, 0.797
Shapiro^a^, ^b^ | 12 | 81/81 | L | 0.509 | 0.196, 0.822
Fitzgerald | 24 | 72/72 | L | 0.218 | −0.110, 0.546
Weersink | 6 | 16/14 | % Predicted | −0.480 | −1.208, 0.247
Boulet^b^ | 4 | 15/15 | % Predicted | 0.325 | −0.395, 1.046
Grutters^b^ | 8 | 15/12 | % Predicted | 0.545 | −0.228, 1.318
Li^b^ | 12 | 16/13 | % Predicted | 0.106 | −0.626, 0.839
Pauwels (200 mcg BUD)^b^ | 52 | 213/210 | % Predicted | 0.515 | 0.322, 0.709
Pauwels (800 mcg BUD)^b^ | 52 | 214/215 | % Predicted | 0.448 | 0.256, 0.639
Combined studies | | | L | 0.291 (Test for homogeneity p=0.26) | 0.192, 0.390
Combined studies | | | % Predicted | 0.428 (Test for homogeneity p=0.10) | 0.292, 0.564
Combined studies | | | L + % Predicted | 0.334 (Test for homogeneity p=0.10) | 0.241, 0.428
^a^Sensitivity analysis by quality: studies that meet strict or modified criteria and most of asthma-specific indicators | | | | 0.319 (Test for homogeneity p=0.14) | 0.139, 0.499
^b^ Sensitivity analysis by quality: studies that meet modified criteria | | | | 0.368 (Test for homogeneity p=0.20) | 0.257, 0.478

Interpretation: Treatment effect (all studies) = 0.17 L (95% CI, 0.12-0.22) or 3.71% predicted (95% CI, 2.67-4.75)

Meta-Analysis Table 3-13. PEF. Studies comparing the addition of long-acting beta-agonists to a fixed ICS dose

Study | Tx Dur (wks) | # Patients (Ctl/Exp) | PEF Reporting Units | Effect Size Estimate | 95% CI
Aubier^b^ | 28 | 165/167 | L/min | 0.500 | 0.281, 0.718
Pearlman (176 mcg FP)^b^ | 4 | 23/25 | L/min | 1.032 | 0.429, 1.634
Pearlman (440mcg FP)^b^ | 4 | 23/21 | L/min | 0.133 | −0.459, 0.725
Boyd^a,b^ | 12 | 52/48 | L/min | 0.562 | 0.162, 0.962
Kemp | 12 | 254/252 | L/min | 0.294 | 0.119, 0.470
Langley^b^ | 4 | 23/24 | L/min | 1.246 | 0.621, 1.871
van der Molen^a,b^ | 24 | 113/125 | L/min | 0.432 | 0.175, 0.690
Kavuru^a,b^ | 12 | 85/87 | L/min | 0.774 | 0.464, 1.084
Li^b^ | 12 | 16/13 | L/min | 0.448 | −0.293, 1.189
Shapiro^a,b^ | 12 | 81/81 | % Predicted | 0.851 | 0.529, 1.173
Combined studies | | | L/min | 0.536 (Test for homogeneity p=0.01) | 0.376, 0.697
Combined studies | | | L/min + % Predicted | 0.581 (Test for homogeneity p=0.0034) | 0.417, 0.745
^a^Sensitivity analysis by quality: studies that meet strict or modified criteria and most of asthma-specific indicators | | | | 0.643 (Test for homogeneity p=0.17) | 0.460, 0.826
^b^ Sensitivity analysis by quality: studies that meet modified criteria | | | | 0.630 (Test for homogeneity p=0.06) | 0.478, 0.781

Interpretation: Treatment effect = 24.68 L/min (95% CI, 17.70-31.65) or 7.26% predicted (95% CI, 5.21-9.31)

Meta-Analysis Table 3-14. Puffs/day. Studies comparing the addition of long-acting beta-agonists to a fixed ICS dose

Study | # Patients (Ctl/Exp) | Treatment Effect Estimate | 95% CI
Boyd^a,b^ | 62/53 | −2.60 | −4.21, −0.99
Kemp | 254/252 | −1.67 | −2.06, −1.28
Pearlman (176mcg FP)^b^ | 23/25 | −0.40 | −1.60, 0.80
Pearlman (440mcg FP)^b^ | 23/21 | 0 | −1.28, 1.28
Shapiro^a,b^ | 81/81 | −1.40 | −2.28, −0.52
van der Molen^a,b^ | 113/125 | −1.10 | −1.75, −0.45
Li^b^ | 16/13 | −0.90 | −1.40, −0.40
Combined studies | | −1.18 (Test for homogeneity p=0.018) | −1.56, −0.80
^a^Sensitivity analysis by quality: studies that meet strict or modified criteria and most of asthma-specific indicators | | −1.34 (Test for homogeneity p=0.20) | −1.87, −0.84
^b^ Sensitivity analysis by quality: studies that meet modified criteria | | −1.00 (Test for homogeneity p=0.14) | −1.34, −0.66

Interpretation: Treatment effect = −1.18; i.e., the treated group decreased from baseline by −1.18 puffs/day more than the control group decreased from baseline.

Meta-Analysis Table 3-15. FEV1. Studies comparing a lower ICS Dose + long-acting beta-agonists vs. an increased ICS dose

Study | Tx Dur (wks) | # Patients (Ctl/Exp) | FEV1 Reporting Units | Effect Size Estimate | 95% CI
Condemi^a,b^ | 24 | 216/221 | L | .190 | .002, 0.378
Murray^a,b^ | 24 | 253/259 | L | .246 | 0.072, 0.420
Pearlman^b^ | 4 | 23/25 | L | 0.609 | 0.030, 1.188
van Noord^a,b^ | 12 | 135/139 | L | 0.162 | −0.075, 0.400
Bouros | 12 | 58/64 | L | 0.139 | −0.217, 0.495
Kelsen^a,b^ | 24 | 244/239 | L | 0.193 | 0.014, 0.372
Baraniuk^b^ | 12 | 223/231 | % Predicted | 0.188 | 0.003, 0.372
Pauwels^b^ | 52 | 214/210 | % Predicted | 0.228 | 0.037, 0.419
Combined studies | | | L | 0.209 (Test for homogeneity p=0.78) | 0.117, 0.302
Combined studies | | | L + % Predicted | 0.209 (Test for homogeneity p=0.93) | 0.133, 0.285
^a^Sensitivity analysis by quality: studies that meet strict or modified criteria and most of asthma-specific indicators | | | | 0.203 (Test for homogeneity p=0.94) | 0.107, 0.299
^b^ Sensitivity analysis by quality: studies that meet modified criteria | | | | 0.212 (Test for homogeneity p=0.88) | 0.134, 0.290

Interpretation: Treatment effect (all studies) = 0.11 L (95% CI, 0.07-0.15) or 2.32% predicted (95% CI, 1.48-3.16)

Meta-Analysis Table 3-16. PEF. Studies comparing a lower ICS dose + long-acting beta-agonists vs. an increased ICS dose

Study | Tx Dur (wks) | #Patients (Ctl/Exp) | PEF Reporting Units | Effect Size Estimate | 95% CI
Greening^a,b^ | 21 | 126/137 | L/min | 0.396 | 0.151, 0.640
Kelsen^a,b^ | 24 | 244/239 | L/min | 0.658 | 0.475, 0.841
Pearlman^b^ | 4 | 23/25 | L/min | 0.672 | 0.898, 1.254
Bouros | 12 | 58/64 | L./min | 0.573 | 0.210, 0.935
Condemi^a,b^ | 24 | 216/221 | L/min | 0.220 | 0.318, 0.408
van Noord^a,b^ | 12 | 135/139 | L/min | −0.098 | −0.335, 0.139
Murray^a,b^ | 24 | 253/259 | L/min | 0.327 | 0.153, 0.501
Baraniuk^b^ | 12 | 223/231 | % Predicted | 0.132 | −0.052, 0.317
Vermetten | 12 | 120/113 | % Predicted | 0.242 | −0.016, 0.500
Woolcock (50 mcg salmeterol)^b^ | 26 | 251/243 | % Predicted | 0.298 | 0.121, 0.475
Woolcock (100 mcg salmeterol)^b^ | 26 | 251/244 | % Predicted | 0.298 | 0.120, 0.475
Combined studies | | | L/min | 0.363 (Test for homogeneity p=0.000054) | 0.175, 0.550
Combined studies | | | % Predicted | 0.245 (Test for homogeneity p=0.549) | 0.146, 0.343
Combined studies | | | L/min + % Predicted | 0.310 (Test for homogeneity p=0.0002) | 0.192, 0.429
^a^Sensitivity analysis by quality: studies that meet strict or modified criteria and most of asthma-specific indicators | | | | 0.306 (Test for homogeneity p=0.000025) | 0.094, 0.519
^b^ Sensitivity analysis by quality: studies that meet modified criteria | | | | 0.299 (Test for homogeneity p=0.00011) | 0.166, 0.432

Interpretation: Treatment effect = 11.6 L/min (95% CI, 5.2-18.0) or 3.4% predicted (95% CI, 1.5-5.3)

Meta-Analysis Table 3-17. Puffs/day. Studies comparing a lower ICS dose + long-acting beta-agonists vs. an increased ICS dose

Study | # Patients (Ctl/Exp) | Treatment Effect Estimate | 95% CI
Vermetten | 120/113 | −0.17 | −0.29, −0.05
Baraniuk | 223/226 | −0.50 | −1.06, 0.06
Pearlman | 23/25 | −0.10 | −1.40, 1.20
Combined studies | | −0.19 (Test for homogeneity p=0.44) | −0.31, −0.06
NOTE: insufficient studies for sensitivity analysis by quality

Interpretation:Treatment effect = −0.19 i.e. the treated group decreased from baseline by −0.19 puffs/day more than the control group decreased from baseline.

Meta-Analysis Table 3-18. Stratification by treatment duration, age, and baseline FEV1 for studies comparing the addition of long-acting beta-agonists to a fixed ICS dose (see Table III-19 for identification of studies in each stratum)

Meta-Analysis | Effect Size Estimate | 95% CI | Test for Homogeneity p-Value | Treatment Effect Estimate | 95% CI
FEV1: Combined studies | 0.334 | 0.241, 0.428 | 0.10 | 0.17 L 3.71%pred | 0.12, 0.22 2.67, 4.75
Baseline ICS dose: Low (NHLBI classification) | 0.502 | 0.345, 0.660 | 0.66 | 0.262 L 5.57%pred | 0.180, 0.344 3.83, 7.33
Baseline ICS dose: Other ^a^ (NHLBI classification) | 0.284 | 0.186, 0.382 | 0.19 | 0.15 L 3.15%pred | 0.10, 0.20 2.06, 4.24
Treatment duration <=12 wks | 0.343 | 0.218, 0.468 | 0.24 | 0.18 L 3.81%pred | 0.11, 0.24 2.42, 5.20
Treatment duration >24 wks | 0.322 | 0.181, 0.463 | 0.05 | 0.17L 3.57%pred | 0.09, 0.24 2.00, 5.14
Mean Age (control) <=40 yr | 0.383 | 0.222, 0.543 | 0.20 | 0.20 L 4.25%pred | 0.12, 0.28 2.47, 6.03
Mean Age (control) >40 yr | 0.311 | 0.194, 0.428 | 0.095 | 0.16 L 3.45%pred | 0.10, 0.22 2.15, 4.75
Baseline FEV1 (control) <2.35 L | 0.276 | 0.168, 0.384 | 0.23 | 0.14 L 3.06%pred | 0.09, 0.20 1.87, 4.26
Baseline FEV1 (control) >2.35 L | 0.409 | 0.287, 0.532 | 0.20 | 0.21 L 4.54%pred | 0.15, 0.28 3.18, 5.91
PEF: Combined studies | 0.581 | 0.417, 0.745 | 0.0034 | 24.7 L/min 7.3%pred | 17.7, 31.6 5.2, 9.3
Baseline ICS dose: Low ^b^
Baseline ICS dose: Other^a,b^
Treatment duration <=12 wks ^c^
Treatment duration >21 wks ^c^
Mean Age (control) <=40 yr | 0.779 | 0.582, 0.975 | 0.14 | 33.1 L/min 9.7%pred | 24.7, 41.4 7.3, 12.3
Mean Age (control) >40 yr | 0.406 | 0.284, 0.527 | 0.39 | 17.2 L/minm 5.1%pred | 12.1, 22.4 3.6, 6.6
Mean Age (control) <=42 | 0.658 | 0.399, 0.916 | 0.0004 | 27.9 L/min 8.2%pred | 16.9, 39.0 5.0, 11.4
Mean Age (control) >42 | 0.485 | 0.330, 0.641 | 0.85 | 20.6 L/min 6.1%pred | 14.0, 27.2 4.1, 8.0
Baseline FEV1 (control) <2.3 L | 0.553 | 0.355, 0.751 | 0.0074 | 23.5 L/min 6.9%pred | 15.1, 31.9 4.4, 9.4
Baseline FEV1 (control) >2.3 L | 0.638 | 0.332, 0.943 | 0.046 | 27.1 L/min 8.0%pred | 14.1, 40.1 4.2, 11.8

a Low-high, Low-med, Med, Med-high, High

b Only 3 small studies with low baseline ICS dose (see Meta-Analysis Table 3-17), therefore no stratification performed.

c Only 1 study with treatment duration >12 weeks (van der Molen, 24 weeks), therefore no stratification performed.

Meta-Analysis Table 3-19. Identification of studies by stratum for analysis results presented in Table 3-18

Study | # Patients Ctl/Exp | Baseline ICS Dose | | Treatment Duration | | Mean Age | | | | Baseline FEV1
Study | # Patients Ctl/Exp | Low | Other | < 12 wks | >21-24 wks | < 40 yr | >40 yr | < 42 yr | >42 yr | <2.3-2.35 L | >2.3-2.35 L
FEV
Aubier | 165/167 | | X | | X | | X | | | X
Pearlman (176 mcg FP) | 23/25 | X | | X | | X | | | | | X
Pearlman (440 mcg FP) | 23/21 | | X | X | | X | | | | | X
Boyd | 52/48 | | X | X | | | X | | | X
Kemp | 254/252 | | X | X | | | X | | | X
Langley | 23/24 | | X | X | | X | | | | | X
van der Molen | 113/125 | | X | | X | | X | | | X
Kavuru | 85/87 | X | | X | | X | | | | X
Shapiro | 81/81 | | X | X | | X | | | | X
Fitzgerald | 72/72 | | X | | | X | | | | | X
Weersink | 16/14 | | X | X | | X | | | | | X
Boulet | 15/15 | | X | X | | | X | | | | X
Grutters | 15/12 | | X | X | | X | | | | | X
Li | 16/13 | X | | X | | X | | | | | X
Pauwels (200 mcg BUD) | 213/210 | X | | | X | | X | | | | X
Pauwels (800 mcg BUD) | 214/215 | | X | | X | | X | | | | X
PEF
Aubier | 165/167 | | X | | | | X | | X | | X
Pearlman (176 mcg FP) | 23/25 | X | | | | X | | X | | | X
Pearlman (440 mcg FP) | 23/21 | | X | | | X | | X | | | X
Boyd | 52/48 | | X | | | | X | | X | X
Kemp | 254/252 | | X | | | | X | X | | X
Langley | 23/24 | | X | | | X | | X | | | X
van der Molen | 113/125 | | X | | | | X | | X | X
Kavuru | 85/87 | X | | | | X | | X | | X
Li | 16/13 | X | | | | X | | X | | | X
Shapiro | 81/81 | | X | | | X | | X | | X

Meta-Analysis Table 3-20. Stratification by treatment duration, age, and baseline FEV1 for studies comparing a lower ICS dose + long-acting beta-agonists vs. an increased ICS dose (see Table III-21 for identification of studies in each stratum)

Meta-Analysis | Effect Size Estimate | 95% CI | Test for Homogeneity p-Value | Treatment Effect Estimate | 95% CI
FEV1: Combined studies | 0.209 | 0.133, 0.285 | 0.93 | 0.11 L 2.32% pred | 0.07, 0.15 1.48-3.16
Baseline ICS dose ^a^ : Low
Baseline ICS dose ^a^ : Other
Treatment duration <=12 wks | 0.197 | 0.063, 0.330 | 0.51 | 0.10 L 2.19%pred | 0.03, 0.17 0.70, 3.66
Treatment duration >24 wks | 0.215 | 0.123, 0.307 | 0.97 | 0.11 L 2.39%pred | 0.06, 0.16 1.36, 3.41
Mean Age (control) <=40 yr | 0.212 | 0.081, 0.343 | 0.32 | 0.11 L 2.35%pred | 0.04, 0.18 0.90, 3.8
Mean Age (control) >40 yr | 0.207 | 0.114, 0.301 | 0.97 | 0.11 L 2.30%pred | 0.06, 0.16 1.26, 3.34
Baseline FEV1 (control) <2.35 L | 0.204 | 0.102, 0.306 | 0.94 | 0.11 L 2.26%pred | 0.05, 0.16 1.13, 3.39
Baseline FEV1 (control) >2.35 L | 0.215 | 0.101, 0.329 | 0.52 | 0.11 L 2.39%pred | 0.05, 0.17 1.12, 3.65
PEF: Combined studies | 0.310 | 0.192, 0.429 | 0.0002 | 11.6 L/min 3.4%pred | 5.2, 18.0 1.5, 5.3
Baseline ICS dose ^b^ : Low
Baseline ICS dose ^b^ : Other
Treatment duration <=12 wks | 0.230 | 0.015, 0.446 | 0.008 | 9.8 L/min 2.9% pred | 0.64, 18.9 0.19, 5.6
Treatment duration >21 wks | 0.364 | 0.249, 0.480 | 0.019 | 15.1 L/min 4.6%pred | 10.6, 20.4 3.1, 6.0
Mean Age (control) <=40 yr | 0.202 | 0.070, 0.333 | 0.17 | 8.6 L/min 2.52%pred | 3.0, 14.2 0.88, 4.16
Mean Age (control) >40 yr | 0.333 | 0.189, 0.476 | 0.00027 | 14.1 L/min 4.2%pred | 8.0, 20.2 2.4, 6.0
Mean Age (control) <=42 yr | 0.340 | 0.180, 0.500 | 0.0013 | 14.4 L/min 4.2%pred | 7.6, 21.3 2.2, 6.2
Mean Age (control) >42 yr | 0.274 | 0.104, 0.445 | 0.010 | 11.7 L/min 3.4%pred | 4.4, 18.9 1.3, 5.6
Baseline FEV1 (control) <2.3 L | 0.260 | 0.151, 0.370 | 0.18 | 11.1 L/min 3.3%pred | 6.4, 15.7 1.9, 4.6
Baseline FEV1 (control) >2.3 L | 0.332 | 0.139, 0.525 | 0.00008 | 14.1 L/min 4.2%pred | 5.9, 22.3 1.7, 6.6

a Only 1 study reporting FEV1 with baseline ICS dose >low (van Noord), therefore no stratification performed.

b Only 2 studies reporting PEF with baseline ICS dose >low (van Noord, Woolcock), therefore no stratification performed.

Meta-Analysis Table 3-21. Identification of studies by stratum for analysis results presented in Table 3-20

Study | # Patients Ctl/Exp | Baseline ICS Dose | | Treatment Duration | | Mean Age | | | | Baseline FEV1
| | Low | Other | < 12 wks | >21-24 wks | < 40 yr | >40 yr | < 42 yr | >42 yr | <2.3-2.35 L | >2.3-2.35 L
FEV1
Condemi | 216/221 | X | | | X | X | | | | X
Murray | 253/259 | X | | | X | | X | | | X
Pearlman | 23/25 | X | | X | | X | | | | | X
van Noord | 135/139 | | X | X | | | X | | | | X
Bouros | 58/64 | X | | X | | | X | | | X
Kelsen | 244/239 | X | | | X | | X | | | | X
Baraniuk | 223/231 | X | | X | | X | | | | X
Pauwels | 214/210 | X | | | X | | X | | | | X
PEF
Greening | 126/137 | X | | | X | | X | | X | X
Kelsen | 244/239 | X | | | X | | X | X | | | X
Pearlman | 23/25 | X | | X | | X | | X | | | X
Bouros | 58/64 | X | | X | | | X | | X | X
Condemi | 216/221 | X | | | X | X | | X | | X
van Noord | 135/139 | | X | X | | | X | | X | | X
Murray | 253/259 | X | | | X | | X | X | | | X
Baraniuk | 223/231 | X | | X | | X | | X | | X
Vermetten | 120/113 | X | | X | | | X | X | | X
Woolcock (50 mcg salmeterol) | 251/243 | | X | | X | | X | | X | | X
Woolcock (100 mcg salmeterol) | 251/244 | | X | | X | | X | | X | | X

Evidence Table 4-1. Study characteristics

Citation | Study Design | Study Setting | Asthma Severity | Eligibility
Graham, Milton, Knowles, et al, 1982 | Randomized, double-blind, placebo-controlled, parallel group trial | Country: United Kingdom Funding: government grant Tx setting: University Hospital, inpatient setting | Stated: Not specified Estimated: Unable to estimate | Eligibility assessed on admission to hospital with asthma exacerbation:; 1. FEV1 of 1.5 L or less and/or PEF of 150 l/min; 2. Reversibility of FEV1 at least 15% spontaneously or after inhalation of BETA-2 agonist; Exclusions: Evidence of pneumonia on CXR, history of penicillin allergy
Shapiro, Eggleston, Pierson, et al, 1974 | Randomized, double-blind, placebo-controlled, parallel group trial | Country: United States Funding: Pharm Industry and government grant Tx setting: Hospital, inpatient setting | Stated: Not specified Estimated: Unable to estimate | Eligibility assessed on admission to hospital with asthma exacerbation:; 1. Severe bronchospasm, lack of response to subcutaneous epinephrine; Exclusions: Clinical evidence of bacterial infection; recent use of antibiotics

Evidence Table 4-2. Study parameters

Citation | Study Arm | Treatment | Comments
Graham, Milton, Knowles, et al, 1982 | Placebo | Placebo tablet three times per day Oral prednisolone (20-60 mg/day) and/or IV hydrocortisone (100-200 mg every 4 to 6 hours) Regularly scheduled beta-2 agonists and/or phosphodiesterase inhibitors Chest physiotherapy | 60 patients enrolled with 71 exacerbations. Unit of analysis by exacerbations. Culture-proven bacterial source of infection found in two patients on admission, and three patients on discharge
Graham, Milton, Knowles, et al, 1982 | Antibiotics | amoxicillin 500 mg three times per day Oral prednisolone (20-60 mg/day) and/or IV hydrocortisone (100-200 mg every 4 to 6 hours) Regularly scheduled beta-2 agonists and/or phosphodiesterase inhibitors Chest physiotherapy | Culture-proven bacterial source of infection found in two patients on admission, and two patients on discharge
Shapiro, Eggleston, Pierson, et al, 1974 | Placebo | Placebo four times per day for 6 days. IV hydrocortisone (7mg/kg/24hr) for 24 hrs, followed by oral prednisone IV aminophylline (15mg/kg/24hr) for 24 hrs, followed by oral theophylline Nebulised beta-2 agonists q30 min x 4, then as needed | 37 patients enrolled with 44 exacerbations, unit of analysis by exacerbation
Shapiro, Eggleston, Pierson, et al, 1974 | Antibiotics | Hetacillin 100 mg/kg/24 hr for at least 24 hrs, followed by oral hetacillin 225mg four times per day for 6 days IV hydrocortisone (7mg/kg/24hr) for 24 hrs, followed by oral prednisone IV aminophylline (15mg/kg/24hr) for 24 hrs, followed by oral theophylline Nebulized beta-2 agonists q30 min x 4, then as needed

Evidence Table 4-3. Population characteristics

Citation | Study Arm | Pop Age (mean/range) | % Male/Female | Avg Duration of Asthma (years/range) | % with Recent Treatment abx steroids | % with Purulent Sputum | % Atopic Patients | Baseline Lung Function (% predicted) FEV1 PEF | | Baseline Symptom Values (median/range)
Graham, Milton, Knowles, et al, 1982 | Placebo | 37.4 (19-77) | 35%/65% | 16 (0.1-53) | 17.6 50 | 52 | 70.6 | 20.9 (<7.3-63) | 23.8 (<9.4-83.9) | 11 (median) (range 6-12) (4-12 point scale)
Graham, Milton, Knowles, et al, 1982 | Antibiotics | 41.2 (13-82) | 49%/51% | 8 (0.1-53) | 24.3 37.8 | 59.4 | 75.7 | 23.1 (<7.3-45.5) | 23.8 (<9.4-47.3) | 11 (median) (range 5-12) (4-12 point scale)
Shapiro, Eggleston, Pierson, et al, 1974 | Placebo | 7.9 (1.3-18.1) | NR | 5.2 (0.3-17) | 0% 25% | NR | NR | 26.5 (SD 15) | NR | 7.1 (mean) (SD 2.2) (0-12 point scale)
Shapiro, Eggleston, Pierson, et al, 1974 | Antibiotics | 9.3 (1.7-16.3) | NR | 4.9 (0.7-10) | 0% 37.5% | NR | NR | 28.3 (SD 11) | NR | 7.1 (mean) (SD 1.8) (0-12 point scale)

Evidence Table 4-4. Lung function outcomes

Citation | Study Arm | # Enrolled | # Evaluable | Study Duration (days) (median/range) | FEV1 Baseline (mean) | FEV1 Final (mean) | p-Value | PEF Baseline (mean/range) | PEF Final (mean/range) | p-Value
Graham, Milton, Knowles, et al, 1982 | Placebo | (71) ^a^ | 32 ^a^ | 8 (3-16) | 20.9 (<7.3-63) | 65.6 (31.5-108.5) | | 23.8 (<9.4-83.9) | 72.8 (32.8-108.1)
Graham, Milton, Knowles, et al, 1982 | Antibiotics | (71) ^a^ | 37 ^a^ | 7 (3-25) | 23.1 (<7.3-45.5) | 52.3 (10-92.9) | 0.039 | 23.8 (<9.4-47.3) | 59 (16.7-95) | 0.052
Shapiro, Eggleston, Pierson, et al, 1974 | Placebo | (50) ^a^ | 24 ^a^ | 2.9 (SD 1.4) | 26.5 (SD 15) | 49 (SD 17) | | NR | NR
Shapiro, Eggleston, Pierson, et al, 1974 | Antibiotics | (50) ^a^ | 20 ^a^ | 2.5 (SD 0.8) | 28.3 (SD 11) | 61 (SD 19) | NR | NR | NR

a Unit of analysis was admission. Number enrolled represented total admissions in both groups, information not provided by group. Number evaluated represents total number of admissions included in analysis.

Evidence Table 4-5. Symptoms/utilization outcomes

Citation | Study Arm | Enrolled | Pts Eval | Study Duration (days) (median/range) | Baseline Symptom Score (median/range) | Final Symptom Score (median/range | p-Value | Hospital Length of Stay | p-Value
Graham, Milton, Knowles, et al, 1982 | Placebo | 34 | 32 | 8 (3-16) | 11 (6-12) | 4 (4-8) | | 8 (3-16)
Graham, Milton, Knowles, et al, 1982 | Antibiotics | 37 | 37 | 7 (3-25) | 11 (5-12) | 5 (4-9) | NS | 7 (3-25) | NS
Shapiro, Eggleston, Pierson, et al, 1974 | Placebo | 24 | 24 | 2.9 (SD 1.4) | 7.1 (mean) (SD 2.2) | 2.5 (SD 2.0) | | 2.9 (SD 1.4)
Shapiro, Eggleston, Pierson, et al, 1974 | Antibiotics | 20 | 20 | 2.5 (SD 0.8) | 7.1 (mean) (SD 1.8) | 2.0 (SD 2.0) | NR | 2.5 (SD 0.8)

Evidence Table 5-1. Study characteristics

Citation | Study Design | Study Setting | Eligibility | Comments
Optimal medical management vs. optimal medical management + PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Randomized; Parallel, controlled | Country: United Kingdom Funding: Pharm. Ind., grant Tx Setting: Primary/specialty combination, university Multicenter | Pt eligibility based on symptoms only Included pts using ICS < 1,000 mcg per day for at least 1 month Exclusions: patients on oral steroids or using peak flow meters at home were not allowed | Power based on several outcomes (FEV needed 23 pts, 6-fold reduction in night wakening needed 21 per group, eightfold reduction in days off work or school needed 37 per groups) 2 wk. course of oral steroids given before randomization to optimize lung function
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Randomized; Parallel, controlled | Country: United Kingdom Funding: Academic grant Tx Setting: Specialty care, nonuniversity Multicenter | Patient eligibility based on lung function and utilization Inclusion: FEV1 reversibility 20% or greater Exclusions: pts who already owned a PFM | Power based on the 569 randomized, but n varies for each outcome and in some cases is not specified as to exact n, just that n was >=250; may not be powered for all outcomes Pts included had less severe asthma on entry than those who already owned a PFM and were excluded, especially with regard to social and physical functioning
Ayres, Campbell and Follows, 1995 | Randomized; Parallel, controlled | Country: United Kingdom Funding: Pharm. Ind., grant Tx Setting: Unknown Multicenter | Patient eligibility based on lung function, symptoms, utilization; Inclusions: PEF variability maximum 0.15%; Nights/week with symptoms minimum 3; use of ICS or sodium cromoglycate for a minimum of 3 mos | Dr. also graded the overall & individual severity of symptoms as 0=none and 3=severe
Cowie, Revitt, Underwood, et al., 1997 | Randomized; Parallel, controlled | Country: Canada Funding: Hospital Tx Setting: Primary/specialty combination, university; Multicenter | Patient eligibility based on symptoms and utilization Inclusions: treatment for an exacerbation of asthma in an ER or attending a university asthma clinic; history of receiving urgent treatment for asthma in the previous 12 mo | Subjects were recruited by contacting those who had been treated for an exacerbation of asthma in an ER or those attending a university asthma clinic with a history of having received urgent treatment for their asthma in the previous 12 mos
Cote, Cartier, Robichaud, et al., 1997 | Randomized; Parallel, controlled | Country: Canada Funding: Pharm. Ind., grant; Tx Setting: Specialty care, nonuniversity; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 Postbronchodilator 85-100% of predicted; PEF minimum 85% of predicted; PEF variability minimum 0%; Methacholine Exclusions: pts having previously taken part in an asthma educational program | In discussion "although the control group received more than the usual care treatment, none received book, none had written action plan, none had structured education or PFM at home after run-in"; Run-in=2-6 wks; diagnosis of asthma included need to take daily anti-inflammatory agents; were excluded
Optimal medical management + PFM use (without action plan) vs. optimal medical management + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Randomized; Parallel, controlled | Country: Spain Funding: Not specified; Tx Setting: Specialty care, nonuniversity | Patient eligibility based on utilization only Inclusions: pts from outpt. asthma clinic with asthma for 2 yrs | One dr. aware of the group assignment was responsible for assessment of all pts' conditions but paper also says "in ctl group, dr. assessing pt was blinded with regard to registers of PF monitoring until end of study"; random allocation by order of recruitment
Charlton, Antoniou, Atkinson, et al., 1994 | Randomized; Parallel, controlled | Country: Australia Funding: Pharm. Ind. + Gov't and University funding; Tx Setting: Specialty care, nonuniversity | Patient eligibility based on utilization only Inclusion: pts who required admission for asthma or attended the outpt. dept. | Randomization was on age, sex, whether they used asthma prophylaxis before study
Ignacio-Garcia and Gonzalez-Santos, 1995 | Randomized; Parallel, controlled | Country: Spain Funding: Not specified; Tx Setting: Specialty care, nonuniversity | Patient eligibility based on utilization only Inclusions: pts from outpt. asthma clinic with asthma for 2 yrs | One dr. aware of the group assignment was responsible for assessment of all pts' conditions but paper also says "in ctl group, dr. assessing pt was blinded with regard to registers of PF monitoring until end of study"; random allocation by order of recruitment
Charlton, Antoniou, Atkinson, et al., 1994 | Randomized; Parallel, controlled | Country: Australia Funding: Pharm. Ind. + Gov't and University funding; Tx Setting: Specialty care, nonuniversity | Patient eligibility based on utilization only Inclusion: pts who required admission for asthma or attended the outpt. dept. | Randomization was on age, sex, whether they used asthma prophylaxis before study
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Randomized; Parallel, controlled | Country: Canada Funding: Pharm. Ind. + other, not specified; Tx Setting: Primary care, non-university | Patient eligibility based on lung function and symptoms Inclusions: Methacholine PC20 maximum 7.9; using ICS Exclusions: previous PFM use; significant comorbid conditions | Pts were randomized after stratification for severity of airway responsiveness using values of PC20 methacholine <2mg/ml or >= 2 mg/ml; 150 screened, 117 enrolled
Charlton, Charlton, Broomfield, et al., 1990 | Randomized; Parallel, controlled | Country: United Kingdom Funding: Clare Wand Fund, Scientific Foundation of RCP Vitalogap; Tx Setting: Specialty care, nonuniversity | Patient eligibility based on symptoms only Inclusions: pts on repeat prescribing register | Pts were not randomly selected for participation. Letters were sent to pts. on the repeat prescribing register and invited to make an appointment with a nurse
Cowie, Revitt, Underwood, et al., 1997 | Randomized; Parallel, controlled | Country: Canada Funding: Foothills Hospital, Calgary Tx Setting: Primary/specialty combination, university; Multicenter | Patient eligibility based on symptoms and utilization Inclusions: treatment for an exacerbation of asthma in an ER or attending a university asthma clinic; history of receiving urgent treatment for asthma in the previous 12 mo | Subjects were recruited by contacting those who had been treated for an exacerbation of asthma in an ER or those attending a university asthma clinic with a history of having received urgent treatment for their asthma in the previous 12 mos
Cote, Cartier, Robichaud, et al., 1997 | Randomized; Parallel, controlled | Country: Canada Funding: Pharm. Ind., grant; Tx Setting: Specialty care, nonuniversity; Multicenter | Patient eligibility based on lung function and symptoms; FEV1 Postbronchodilator 85-100% of predicted; PEF minimum 85% of predicted; PEF variability minimum 0%; Methacholine Exclusions: previous enrollment in an asthma educational program | In discussion "although the control grp received more than the usual care treatment, none received book, none had written action plan, none had structured education or PFM at home after run-in"; Run-in=2-6 wks; diagnosis of asthma included need to take daily anti-inflammatory agents; were excluded

Evidence Table 5-2. Study parameters

Citation | Study Arm | N Enrolled | Medication (other than beta-agonists) | Intervention Components | | | | | | | | Treatment Duration (weeks)
Citation | Study Arm | N Enrolled | Medication (other than beta-agonists) | PFM Use (freq) | Action Plan | Education | Symptom Diary | Follow-Up | Pt Counseling | Behavior Mod | Environ-Mod | Treatment Duration (weeks)
Optimal medical management vs. optimal medical management + PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64 | ICS, <1,000 mcg/day | | | | X | X | | | | 24
Jones, Mullee, Middleton, et al., 1995 | PFM-based action plan | 63 | ICS, <1,000 mcg/day | X 1x/day | X | | X | X | | | | 24
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284 | Not stated | | | | | X | | | | 52
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM-based action plan | 285 | Not stated | X (not specified) | X | | | X | | | | 52
Ayres, Campbell and Follows, 1995 | Usual care | 64 | BUD, 490 mcg/day | | | | X | X | | | | 24
Ayres, Campbell and Follows, 1995 | PFM-based action plan | 61 | BUD, 446 mcg/day | X 2x/day | X | | X | X | | | | 24
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48 | ICS, 1,066 mcg/day | | | X | | X | X | | | 24
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | ICS, 908 mcg/day | X (not specified) | X | X | | X | X | | | 24
Cote, Cartier, Robichaud, et al., 1997 | Usual care | 54 | BDP, 1,370 mcg/day | | | X | | | | | | 52
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50 | BDP, 1,380 mcg/day | X 2x/day | X | X | | | X | | | 52
Usual care + PFM use alone vs. usual care + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44 | Included BUD, oral beta-agonists, theophylline, prednisone | X 1x/day | | | X | X | | | | 28
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM-based action plan | 50 | Included BUD, oral beta-agonists, theophylline, prednisone | X 1x/day | X | X | X | X | | | | 28
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43 | Not stated | X 2x/day | | X | X | X | | | | 52
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM-based action plan | 48 | Not stated | X 2x/day | X | X | X | X | | | | 52
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom-based action plan | 48 | ICS, ~460 mcg/day | | X | X | X | | X | X | X | 24
Turner, Taylor, Bennett, et al., 1998 | PFM-based action plan | 44 | ICS, ~370 mcg/day | X (not specified) | X | X | X | | X | X | X | 24
Charlton, Charlton, Broomfield, et al., 1990 | Symptom-based action plan | 64 | Not stated | | X | X | | X | | | | 52
Charlton, Charlton, Broomfield, et al., 1990 | PFM-based action plan | 51 | Not stated | X (not specified) | X | X | | X | X | | | 52
Cowie, Revitt, Underwood, et al., 1997 | Symptom-based action plan | 45 | ICS, 870 mcg/day | | X | X | | X | X | | | 24
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | ICS, 908 mcg/day | X (not specified) | X | X | | X | X | | | 24
Cote, Cartier, Robichaud, et al., 1997 | Symptom-based action plan | 45 | BDP, 1,522 mcg/day | | X | X | X | | X | | | 52
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50 | BDP, 1,380 mcg/day | X 2x/day | X | X | | | X | | | 52

"X" = outcome reported

Evidence Table 5-3. Population characteristics

Citation | Study Arm | Pop Age | % Male/Female | Avg. Duration (years) | % Atopic Patients | Baseline FEV1 ^a^ | Baseline PEF | Baseline Symptoms | Comments
Optimal medical management vs. optimal medical management + PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 28.6 (Mean) +/− 7 | 33.3 / 66.7 | | | 85.4 +/− 17.5% of predicted | 89.7 +/− 15.6% of predicted (clinic) | | # enrolled per group not given; dropouts described only for entire population, 55/127, divided 55 in half and added this to # provided to get n; d/o were younger, more likely male, had lower FVC% pred values, (stat. sig., P<0.05)
Jones, Mullee, Middleton, et al., 1995 | PFM-based action plan | 30.4 (Mean) +/− 11.5 | 42.4 / 57.6 | | | 87.1 +/− 16.9% of predicted | 90.6 +/− 14.5% of predicted (clinic)
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 50.5 (Mean) (95% CI 48.4-52.6) | 40.1 / 59.9 | 8.9 | | 78.1% of predicted (95% CI 74.8-81.4) | 341.6 L/min (95% CI 326-358) | | exact n unclear; 284 were randomized to control and 285 to exp 1, but tables say ">=251" for control and >= 254 for exp 1 for baseline characteristics
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM-based action plan | 51.1 (Mean) (95% CI 49.2-53.0) | 47.7 / 52.3 | 9.5 | | 77.3% of predicted (95% CI 74.1-80.5) | 344.5 L/min (95% CI 330-359)
Ayres, Campbell and Follows, 1995 | Usual care | 47 (Mean) +/− 16.0 | 43.8 / 56.2 | 13 | | 2 +/− 0.1 L (Type Predose) | 365 +/− 14 L/min (clinic) | Daytime score, 1.91 +/− 0.6 (scale, 0 - 3); Nights/week with symptoms, 5.2 | PEF % predicted at baseline was 72 +− 2 Sleep disturbance score at baseline was 1.89 +−0.10: Baseline cough at rest was 1.08, wheeze at rest was 1.25, Difficulty breathing was 1.47; cough on activity=1.75
Ayres, Campbell and Follows, 1995 | PFM-based action plan | 44 (Mean) +/− 15.6 | 37.7 / 62.3 | 10.1 | | 2.3 +/− 0.1 L (Type Predose) | 395 +/− 13 L/min (clinic) | Daytime score, 1.77 +/− 0.6 (scale, 0-3); Nights/week with symptoms, 5.2 | PEF % predicted at baseline was 79 +− 2 Sleep disturbance score at baseline was 1.79 +− 0.09; Baseline cough at rest was 1.00, wheeze at rest was 0.97 Difficulty breathing was 1.41; cough on activity was 1.48
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 36.4 (Mean) +/− 12.76 | 39.6 / 60.4 | 16.8 | | 78 +/− 21.3% of predicted | | Nights/week with symptoms, 4.9 +/− 5.7 | No of subjects with <60% predicted was 10 in ctl, 8 in exp1 and 9 in exp 2
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 39.1 (Mean) +/− 14.41 | 37.0 / 63.0 | 12.8 | | 82 +/− 20.5% of predicted | | Nights/week with symptoms, 4.9 +/− 6.07 | No of subjects with <60% predicted was 10 in ctl, 8 in exp 1 and 9 in exp 2
Cote, Cartier, Robichaud, et al., 1997 | Usual care | 36 (Mean) +/− 22.0 | 29.6 / 70.4 | 12 | 78.0 | | 95 +/− 14.7% of predicted (a.m., home) | | PEF in evening: 100 +−3,
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 37 (Mean) +/− 14.1 | 44.0 / 56.0 | 14 | 76.0 | | 94 +/− 21.2% of predicted (a.m., home) | | PEF in evening: 95 +−3
Usual care + PFM use alone vs. usual care + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 43 (Mean) +/− 16.1 | 45.7 / 54.3 | 13.4 | 54.3 | 65.34 +/− 16.6% of predicted (Type Predose) | 316 +/− 99.5 L/min (a.m., home) | | Enrolled 44 but w/ 9 dropouts; baseline data reported on the 35
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM-based action plan | 40.88 (Mean) +/− 18.1 | 45.7 / 54.3 | 10.4 | 45.7 | 69.03 +/− 24.0% of predicted (Type Predose) | 370 +/− 134.4 L/min (a.m., home) | | Enrolled 50 had 15 drop out; baseline data on the 35 "all measurements were made before the use of inhalers"
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 6.2 (Mean); Range: 3-16 | 55.8 / 44.2 | 4.3 | 70.0 | | | Number with wheeze attacks = 14; number with nocturnal attacks = 10 | PEF values reported as % of time readings were >70% of personal best = 88%; 50-70%=10%; 30-50%=1%; <30%=0.2%; day and night symptom frequency are among children with > 2 attacks per wk
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM-based action plan | 6.8 (Mean); Range: 3-16 | 58.3 / 41.7 | 4.3 | 76.0 | | | | PEF values reported as % of time readings were >70% of personal best = 94%; 50-70%=5%; 30-50%=0.4%; <30%=0%
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom-based action plan | 34.1 (Mean) +/− 9.4 | 43.8 / 56.2 | 17.2 | 79.0 | 78.7 +/− 18.9% of predicted | 370 L/min (home) | Daytime score, 9.1 (Mean; scale, 0-24) | FEV1 in L, mean (SD) was 2.86 (0.88) unclear if reported score is actually a mean; daytime score is really overall score where 24 is max and higher value = more athma symptoms
Turner, Taylor, Bennett, et al., 1998 | PFM-based action plan | 34.1 (Mean) +/− 10.5 | 50.0 / 50.0 | 17.9 | 77.0 | 78.1 +/− 19.7% of predicted | 368 L/min (home) | Daytime score, 8.2 (Mean; scale, 0-24) | FEV1 in L, mean (SD) was (0.86) unclear if reported score is actually a mean; daytime score is really overall score where 24 is max and higher value = more athma symptoms
Charlton, Charlton, Broomfield, et al., 1990 | Symptom-based action plan
Charlton, Charlton, Broomfield, et al., 1990 | PFM-based action plan
Cowie, Revitt, Underwood, et al., 1997 | Symptom-based action plan | 36.8 (Mean) +/− 16.5 | 44.4 / 55.6 | 13.7 | | 79 +/− 18% of predicted | | Nights/week with symptoms, 3.6 +/− 7.11 | No of subjects with <60% predicted was 9
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 39.1 (Mean) +/− 14.41 | 37.0 / 63.0 | 12.8 | | 82 +/− 20.5% of predicted | | Nights/week with symptoms, 4.9 +/− 6.07 | No of subjects with <60% predicted was 8
Cote, Cartier, Robichaud, et al., 1997 | Symptom-based action plan | 39 (Mean) +/− 13.4 | 33.3 / 66.7 | 14 | 82.0 | | 91 +/− 20.1% of predicted (a.m., home) | | PEF in evening: 99+−3
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 37 (Mean) +/− 14.1 | 44.0 / 56.0 | 14 | 76.0 | | 94 +/− 21.2% of predicted (a.m., home) | | PEF in evening: 95 +−3

a FEV1 pre- or post-bronchodilator status unknown unless otherwise indicated.

Evidence Table 5-4. Lung function outcomes. FEV1

Citation | Study Arm | N Enrolled | N Evaluable | Treatment Duration (weeks) | Baseline FEV1 ^a^ | Final FEV1 | p-Value | p-Value Comparison | Comments
Usual care vs. PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64 | 39 | 26 | 85.4 +/− 17.5% of predicted | 81.2 +/− 18.3% of predicted
Jones, Mullee, Middleton, et al., 1995 | PFM-based action plan | 63 | 33 | 26 | 87.1 +/− 16.9% of predicted | 83.2 +/− 18% of predicted | NS | Absolute value, Tx vs. Ctl
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284 | 260 | 52 | 78.1% of predicted | 75.4 +/− 27.7% of predicted | | | 95% CI for baeline FEV is 74.8-81.4
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM-based action plan | 285 | 250 | 52 | 77.3% of predicted | 74.6 +/− 27.8% of predicted | NS | Change, Tx vs. Ctl | 95% CI for baseline FEV is 74.1-80.5
Ayres, Campbell and Follows, 1995 | Usual care | 64 | 64 | 24 | 2 +/− 0.1 L (Type Predose) | 2.2 +/− 0.1 L (Type Predose) | | | Unclear number of patients analyzed on each endpoint
Ayres, Campbell and Follows, 1995 | PFM-based action plan | 61 | 61 | 24 | 2.3 +/− 0.1 L (Type Predose) | 2.3 +/− 0.2 L (Type Predose) | NS | Absolute value, Tx vs. Ctl | Unclear number of patients analyzed on each endpoint
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48 | | | 78 +/− 21.3% of predicted | | | | No of subjects with <60% predicted was 10
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | | | 82 +/− 20.5% of predicted | | | | No of subjects with <60% predicted was 9
Cote, Cartier, Robichaud, et al., 1997 | Usual care | 54
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50
Usual care + PFM use alone vs. usual care + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44 | 35 | 28 | 65.34 +/− 16.6% of predicted (Type Predose) | 65.48 +/− 24.7% of predicted
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM-based action plan | 50 | 35 | 28 | 69.03 +/− 24.0% of predicted (Type Predose) | 80.45 +/− 23.3% of predicted | <0.0040 | Absolute value, Tx vs. Ctl
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM-based action plan | 48
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom-based action plan | 48 | 48 | 24 | 78.7 +/− 18.9% of predicted | 86.1 (Mean) % of predicted | | | FEV1 in L, mean (SD) was 2.86 (0.88)
Turner, Taylor, Bennett, et al., 1998 | PFM-based action plan | 44 | 44 | 24 | 78.1 +/− 19.7% of predicted | 83 (Mean) % of predicted | NS | Absolute value, Tx vs. Ctl | FEV1 in L, mean (SD) was 2.84 (0.86)
Charlton, Charlton, Broomfield, et al., 1990 | Symptom-based action plan
Charlton, Charlton, Broomfield, et al., 1990 | PFM-based action plan
Cowie, Revitt, Underwood, et al., 1997 | Symptom-based action plan | 45 | | | 79 +/− 18% of predicted | | | | No of subjects with <60% predicted was 8
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | | | 82 +/− 20.5% of predicted | | | | No of subjects with <60% predicted was 9
Cote, Cartier, Robichaud, et al., 1997 | Symptom-based action plan | 45
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50

a FEV1 pre- or post-bronchodilator status unknown unless otherwise indicated.

Evidence Table 5-5. Lung function outcomes. PEF

Citation | Study Arm | N Enrolled | N Evaluable | Treatment Duration (weeks) | Baseline PEF | PEF Final | p-Value | p-Value Comparison | Comments
Usual care vs. PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64 | 39 | 26 | 89.7 +/− 15.6% of predicted (clinic) | 87.7 +/− 16.7% of predicted (clinic)
Jones, Mullee, Middleton, et al., 1995 | PFM-based action plan | 63 | 33 | 26 | 90.6 +/− 14.5% of predicted (clinic) | 89.8 +/− 17.5% of predicted (clinic) | NS | Absolute value, Tx vs. Ctl
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284 | 260 | 52 | 341.6 L/min | 345 +/− 130 L/min | | | 95% CI for baseline PEF was 326-358
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM-based action plan | 285 | 250 | 52 | 344.5 L/min | 350 +/− 120 L/min | NS | Change, Tx vs. Ctl | 95% CI for baseline was 330-359
Ayres, Campbell and Follows, 1995 | Usual care | 64 | 64 | 24 | 365 +/− 112 L/min (clinic) | 393 +/− 144 L/min (clinic) | | | PEF % predicted at baseline was 72 +- 2 Unclear number of patients analyzed on each endpoint
Ayres, Campbell and Follows, 1995 | PFM-based action plan | 61 | 61 | 24 | 395 +/− 102 L/min (clinic) | 405 +/− 140 L/min (clinic) | NS | Absolute value, Tx vs. Ctl | PEF % predicted at baseline was 79 +- 2 Unclear number of patients analyzed on each endpoint
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48 | | | | | | | No of subjects with <60% predicted was 10
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | | | | | | | No of subjects with <60% predicted was 8
Cote, Cartier, Robichaud, et al., 1997 | Usual care | 54 | | | 95 +/− 14.7% of predicted (a.m., home) | | | | PEF in evening = 100 +-3% predicted
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50 | | | 94 +/− 21.2% of predicted (a.m., home) | | | | PEF in evening = 95 +-3% predicted
Usual care + PFM use alone vs. usual care + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44 | 35 | 28 | 316 +/− 88.7 L/min (a.m., home) | 321 +/− 94.6 L/min (a.m., home)
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM-based action plan | 50 | 35 | 28 | 370 +/− 112.4 L/min (a.m., home) | 401 +/− 106.5 L/min (a.m., home) | <0.0030 | Absolute value, Tx vs. Ctl
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43 | | | | | | | PEF values reported as % of time readings were >70% of personal best = 88%; 50-70%=10%; 30-50%=1%; <30%=0.2%
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM-based action plan | 48 | | | | | | | PEF values reported as % of time readings were >70% of personal best = 94%; 50-70%=5%; 30-50%=0.4%; <30%=0%
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom-based action plan | 48 | 48 | 24 | 370 L/min (home) | 410 (Mean) L/min (home)
Turner, Taylor, Bennett, et al., 1998 | PFM-based action plan | 44 | 44 | 24 | 368 L/min (home) | 406 (Mean) L/min (home) | NS | Absolute value, Tx vs. Ctl
Charlton, Charlton, Broomfield, et al., 1990 | Symptom-based action plan
Charlton, Charlton, Broomfield, et al., 1990 | PFM-based action plan
Cowie, Revitt, Underwood, et al., 1997 | Symptom-based action plan | 45 | | | | | | | No of subjects with <60% predicted was 9
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | | | | | | | No of subjects with <60% predicted was 8
Cote, Cartier, Robichaud, et al., 1997 | Symptom-based action plan | 45 | | | 91 +/− 20.1% of predicted (a.m., home) | | | | PEF in evening = 99+-3% predicted
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50 | | | 94 +/− 21.2% of predicted (a.m., home) | | | | PEF in evening = 95 +-3% predicted

a FEV1 pre- or post-bronchodilator status unknown unless otherwise indicated.

Evidence Table 5-6. Medication Outcomes

Citation | Study Arm | N Enrolled | N Evaluable | Baseline Puffs Per Day | Final Puffs Per Day | p-Value | Oral Steroid Use | p-Value | Comments
Usual care vs. PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64
Jones, Mullee, Middleton, et al., 1995 | PFM-based action plan | 63
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284 | 228 | | | | 1.4 courses/pt | | Mean (95% CI) # of inhaled steroids prescribed/pt =6.5 (CI 6.0-7.1) # bronchodilators prescribed/pt = 9.0 (CI 8.1-10.1) For "severe asthma pts," # of oral steroid prescriptions was 1.52/pt (CI 0.84-2.76)
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM-based action plan | 285 | 230 | | | | 1.4 courses/pt | NS ^b^ | Mean (95% CI) # of inhaled steroids prescribed/pt =6.5 (CI 6.0-7.1), NS # bronchodilators prescribed/pt = 10.1 (CI 9.1-11.3) NS; For "severe asthma pts," # of oral steroid prescriptions was 3.38/pt (CI 2.23-5.12) P<0.05
Ayres, Campbell and Follows, 1995 | Usual care | 64 | 64 | | | | | | Analysis of budesonide use (mean dose +- sd) throughout study was 970 +- 52 mcg/day; analysis of terbutaline use during study did not demonstrate a sig. diff btwn groups
Ayres, Campbell and Follows, 1995 | PFM-based action plan | 61 | 61 | | | | | | Analysis of budesonide use (mean dose +- sd) throughout study was 926 +- 56 tg/day; p=.72; analysis of terbutaline use during study did not demonstrate a sig. diff btwn groups
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48 | 48 | 4.8 +/− 4.02 | | | | | Puffs day=doses/day No sig diff among groups in # of courses of prednisone taken at both entry and at 6 months
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | 46 | 5.6 +/− 4.54 | | | | | No sig diff among groups in # of courses of prednisone taken at both entry and at 6 months
Cote, Cartier, Robichaud, et al., 1997 | Usual care | 54 | 54 | 3.1 +/− 2.9 | | | 0.5 courses/pt | | 3.7% on theophylline Oral steroids in year prior to study was 1.3
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50 | 50 | 3.2 +/− 2.8 | | | 0.7 courses/pt | NS ^b^ | 3.7% on theophylline Oral steroids in year prior to study was 1.3
Usual care + PFM use alone vs. usual care + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44 | 35 | 152 +/− 169.9 | 153 +/− 87.6 | | 1,350 mg total | | Puffs/day=? doses/patient over 6 mos; orlstd = ? mg over study; Before study, total prednisone was 909 +- 171
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM-based action plan | 50 | 35 | 153 +/− 97.9 | 106 +/− 76.7 | NS ^b^ | 927 mg total | NS ^b^ | Puffs/day=? doses/patient over 6 mos; orlstd = ? mg over study; Before study, total prednisone was 884 +- 97
Usual care + PFM use alone vs. usual care + PFM-based action plan
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43 | 37 | | 1.7 (Median) | | 0 days used/patient/year | | Puffs of inhaled steroid was 1.9 Oral steroid use reported as days of oral steroid used/pt/year
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM-based action plan | 48 | 42 | | 1.9 (Median) | NS ^a^ | 2.0 days used/patient/year | NS ^a^ | Puffs of inhaled steroid was 2.4 Oral steroid use reported as days of oral steroid used/pt/year
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom-based action plan | 48 | 48 | (740 mcg) | (400 mcg, Mean) | | 6 patients treated | | 12 pts were newly prescribed ICSs. These pts had higher baseline FEV1; BPuffsDay estim. From Fig. And =mcg/day there was a decrease in the use of inhaled B=agonista and an increase in the use of inhaled steroids. "There was no sig. diff btwn the groups...";
Turner, Taylor, Bennett, et al., 1998 | PFM-based action plan | 44 | 44 | (500 mcg) | | NS ^a^ | 3 patients treated | | 14 pts were newly prescribed ICSs. BPuffsDay estim. from Fig. Oral steroids = use of prednisone during study compared to # pts. on steroids 6 months before
Charlton, Charlton, Broomfield, et al., 1990 | Symptom-based action plan | | 64 | | | | 12% treated | | Baseline (12 mos. before study) for oral steroid use was 52% of pts. # of pts. requiring nebulized salbutamol for exacerbations was 9% at baseline
Charlton, Charlton, Broomfield, et al., 1990 | PFM-based action plan | | 51 | | | | 47% treated | NS ^b^ | Baseline (12 mos. before study) for oral steroid use was 73% of pts # of pts. requiring nebulized salbutamol for exacerbations was 33% at baseline. Results were not significant when broken out by adults or children.
Cowie, Revitt, Underwood, et al., 1997 | Symptom-based action plan | 45 | 45 | 4.3 +/− 4.23 | | | | | No sig diff among groups in # of courses of prednisone taken at both entry and at 6 months
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | 46 | 5.6 +/− 4.54 | | | | | No sig diff among groups in # of courses of prednisone taken at both entry and at 6 months
Cote, Cartier, Robichaud, et al., 1997 | Symptom-based action plan | 45 | 45 | 3.2 +/− 2.7 | | | 0.9 courses/pt | NS ^b^ | 8.9% on theophylline; 6.7% on cromolyn/nedocromil
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50 | 50 | 3.2 +/− 2.8 | | | 0.7 courses/pt | NS | 6.0% on theophylline; 6% on cromolyn/nedocromil Oral steroids in year prior to study was 1.3 in control, 1.3 for exp 1 and 1.2 for exp 2; p values is difference between 3 groups,

a Treatment comparison - absolute value, Tx vs. Ctl

b Treatment comparison not specified

Evidence Table 5-7. Symptom score outcomes

Citation | Study Arm | N Enrolled | N Evaluable | Treatment Duration (weeks) | Baseline Daytime Symptom Score | Final Daytime Symptom Score | p-Value | Final Nighttime Symptom Score | p-Value | Comments
Usual care vs. PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64 | 45 | 26 | | 4.95 (Median; scale, 0-3) | | 0.75 (Median; scale, 0-3) | | Symptom score across study was divided by # of days w/diary data X 28 to give a monthly rate; sxscoreday=cough; sxscorenight=wakening at night; median wheeze=5.46; shortness of breath=7.88; asthma restricting normal daily activities=0.0
Jones, Mullee, Middleton, et al., 1995 | PFM-based action plan | 63 | 39 | 26 | | 2.85 (Median; scale, 0-3) | NS ^a^ | 0.35 (Median; scale, 0-3) | NS ^a^ | Symptom score across study was divided by # of days w/diary data X 28 to give a monthly rate; sxscoreday=cough; sxscorenight=wakenings at night; median wheeze=4.39; shortness of breath=6.50; asthma restricting normal daily activities=0.17
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284 | 67 | 52 | | | | | | Night & day sx score outcome is only on a subgroup of pts reporting variation in outcome; 112/246 never reported sleep disturbances; 15/246 reported that their sleep was disturbed every night
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM-based action plan | 285 | 54 | 52 | | | | | | Night & day outcome is only on a subgroup of pts reporting variation in outcome, controlled for peak flow, FEV1, duration of asthma; 114/239 never reported sleep disturbances; 14/239 reported that their sleep was disturbed every night
Ayres, Campbell and Follows, 1995 | Usual care | 64 | 64 | 24 | 1.91 +/− 0.6 (scale, 0-3) | 1.39 +/− 1.11, (scale, 0-3) | | 0.69 +/− 0.13, (scale, 0-3) | | SxScoreDay=overall severity of asthma; Changes in: sleep disturbance scores 1.89 → 0.69; cough at rest 1.08 → 0.69; wheeze at rest was 1.25 → 0.67; difficulty breathing 1.47 → 0.96; cough with activity=1.75 → 1.30
Ayres, Campbell and Follows, 1995 | PFM-based action plan | 61 | 61 | 24 | 1.77 +/− 0.6 (scale, 0-3) | 1.38 +/− 0.12, (scale, 0-3) | NS ^a^ | 0.67 +/− 0.14, (scale, 0-3) | | SxScoreDay=overall severity of asthma Changes in: sleep disturbance scores 1.79 → 0.67; cough at rest 1.00 → 0.87; wheeze at rest was 0.97 → 0.74; difficulty breathing 1.41 → 0.85; cough with activity=1.48 → 1.28. All comparisons in sx scores between groups NS
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48 | 48 | 24 | | | | | | No significant differences in other indexes of asthma control, including waking with asthma, beta-2 agonist use, or self-rating of asthma severity differed among the groups at 3 mos or at 6 mos. after entry;
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | 46 | 24 | | | | | | No significant differences in other indexes of asthma control, including waking with asthma, beta-2 agonist use, or self-rating of asthma severity differed among the groups at 3 mos or at 6 mos. after entry;
Cote, Cartier, Robichaud, et al., 1997 | Usual care | 54
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50
Usual care + PFM use alone vs. usual care + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44 | 35 | 28 | | | | | | Nightime symptoms and total nighttime awakenings over total study??(where are values)
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM-based action plan | 50 | 35 | 28 | | | | | | Nightime symptoms are total nighttime awakenings over total study
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43 | 37 | 52 | | 0.22 (Median; scale, 0-3) | | 0.25 (Median; scale, 0-3) | | SxScoreday=wheeze day; SxScorenight=wheeze night; daily score for activity restriction was 0.13
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM-based action plan | 48 | 42 | 52 | | 0.26 (Median; scale, 0-3) | NS ^a^ | 0.15 (Median; scale, 0-3) | NS ^a^ | SxScoreday=wheeze day; SxScorenight=wheeze night; Daily score for activity restriction was 0.06, p<0.05 compared to control
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom-based action plan | 48 | 48 | 24 | 9.1 (Mean; scale, 0-24) | 5.2 (Mean; scale, 0-24) | | | | Not sure if reported score is actually a mean; daytime score is really overall score where 24 is max and higher value = more asthma symptoms
Turner, Taylor, Bennett, et al., 1998 | PFM-based action plan | 44 | 44 | 24 | 8.2 (Mean; scale, 0-24) | 3.2 (Mean; scale, 0-24) | NS ^a^ | | | Not sure if reported score is actually a mean; daytime score is really overall score where 24 is max and higher value = more athma symptoms
Charlton, Charlton, Broomfield, et al., 1990 | Symptom-based action plan
Charlton, Charlton, Broomfield, et al., 1990 | PFM-based action plan
Cowie, Revitt, Underwood, et al., 1997 | Symptom-based action plan | 45 | 45 | 24
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | 46 | 24
Cote, Cartier, Robichaud, et al., 1997 | Symptom-based action plan | 45
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50

a Treatment comparison - absolute value, Tx vs. Ctl

b Treatment comparison not specified

Evidence Table 5-8. Symptom frequency and exacerbation outcomes

Citation | Study Arm | N Enrolled | N Evaluable | Treatment Duration (weeks) | Baseline Daytime Symptom Frequency | Final Daytime Symptom Frequency | p-Value | Baseline Nighttime Symptom Frequency | Final Nighttime Symptom Frequency | p-Value | Comments
Usual care vs. PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64 | 45 | 26
Jones, Mullee, Middleton, et al., 1995 | PFM-based action plan | 63 | 39 | 26
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284 | 67 | 52 | | 5.3 days/month of restricted activity, | | | 2.6 nights/week with symptoms | | Sx freq outcomes reported for subset of pts "who showed variation"
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM-based action plan | 285 | 54 | 52 | | 4.6 days/month of restricted activity | NS ^a^ | | 2.3 nights/week with symptoms | NS ^a^
Ayres, Campbell and Follows, 1995 | Usual care | 64 | 64 | 24 | | | | 5.2 nights/week with symptoms | 1.3 nights/week with symptoms | | FreqnightType=# of sleep-disturbed nights est. from Fig. 1, SEM=0.3;
Ayres, Campbell and Follows, 1995 | PFM-based action plan | 61 | 61 | 24 | | | | 5.2 nights/week with symptoms | 1.3 nights/week with symptoms | NS ^a^ | FreqnightType=# of sleep-disturbed nights estimated from Fig. 1
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48 | 48 | 24 | | | | 4.9 nights/week with symptoms | | | Freqnightype=nights/wk with night waking; SD =5.70, exp 1=6.07, exp 2=7.11
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | 46 | 24 | | | | 4.9 nights/week with symptoms | | | Freqnightype=nights/wk with night waking; SD =6.07
Cote, Cartier, Robichaud, et al., 1997 | Usual care | 54
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50
Usual care + PFM use alone vs. usual care + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44 | 35 | 28 | | | | | Nights with sx, 37.94 | | 3.14 exacerbations/patient Nighttime sx is total nighttime awakenings over total study
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM-based action plan | 50 | 35 | 28 | | | | | 16.45 nights with symptoms | <0.001 ^a^ | 2.26 exacerbations/patient p <0. ?? ^a^ Nighttime sx is total nighttime awakenings over total study
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43 | 37 | 52 | 14 number of children w/wheeze attacks | | | 10 number of children w/nocturnal attacks | | | Day and night symptom frequency are among children with > 2 attacks per wk
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM-based action plan | 48 | 42 | 52
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom-based action plan | 48 | 48 | 24
Turner, Taylor, Bennett, et al., 1998 | PFM-based action plan | 44 | 44 | 24
Charlton, Charlton, Broomfield, et al., 1990 | Symptom-based action plan | | | | | | | | | | 3% patients with exacerbations
Charlton, Charlton, Broomfield, et al., 1990 | PFM-based action plan | | | | | | | | | | 11% patients with exacerbations, p value not reported
Cowie, Revitt, Underwood, et al., 1997 | Symptom-based action plan | 45 | 45 | 24 | | | | 3.6 Nights/week with sx | | | Freqnightype=nights/wk with night waking; sd =7.11
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | 46 | 24 | | | | 4.9 Nights/week with sx | | | Freqnightype=nights/wk with night waking; sd =6.07
Cote, Cartier, Robichaud, et al., 1997 | Symptom-based action plan | 45
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50

a Treatment comparison - absolute value, Tx vs. Ctl;

b Treatment comparison not specified

Evidence Table 5-9. Utilization outcomes (continued)

Citation | Study Arm | N Enrolled | N Evaluable | Office Visit | p-Value | ER Visit | p-Value | Hospital Visit | p-Value | Missed Days | p-Value | Comment
Usual care vs. PFM-based action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64 | 45 | 24 (total pts with any visit) | | | | | | 21(total pts with any missed days) | | Ofcvisit= "seen doctor or hospital doctor" and is the actual # of cases with this outcome. 21 patients had no visits.
Jones, Mullee, Middleton, et al., 1995 | PFM-based action plan | 63 | 39 | 17 (total pts with any visit) | | | | | | 18 (total pts with any missed days) | NS ^a^ | Ofcvisit= "seen doctor or hospital doctor" and is the actual # of cases with this outcome. 22 patients had no visits.
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284 | 228 | 2.2 (Mean) | | | | 0.12 (Mean) | | | | In subgroup of pts randomised to integrated care (less severe) & had variation in restricted activity/mnth, restricted activity/mnth= 8.65 (CI 6.3-11.84)
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM-based action plan | 285 | 230 | 2.6 (Mean) | NS | | | 0.13 (Mean) | NS ^b^ | | | In subgroup of pts randomised to integrated care (less severe) & had variation in restricted activity/mnth, restricted activity/mnth= 3.55 (CI 2.08-6.07), p<0.05
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48 | 48 | | | 55 | | 6 | | | | ER visits=total 6 mos. visits; total urgent visits in 1 yr before study was 168; total admissions in 1 yr was 23; # pts w/urgent treatment in 6 mos was 19
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | 46 | | | 5 | =0.002 ^c^ | 2 | NS ^c^ | | | ER visits=total 6 mos. visits; total urgent visits in 1 yr before study was 152; total admissions in 1 yr was 16; # pts w/urgent treatment in 6 mos was 5; differences between groups NS
Cote, Cartier, Robichaud, et al., 1997 | Usual care | 54 | 54 | | | 0.8 +/− 1.5 | | 0.04 +/− 0.3 | | 5.2 +/− 12.5 | | Paper reports data for 1 yr. before study; hospitalizations = 0.21 +/− 0.06; ER visits=2.4 +/− 0.4; days lost=9.6 +/−3.1
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50 | 50 | | | 0.7 +/− 1.4 | NS ^c^ | 0.04 +/− 0.3 | NS ^c^ | 2.2 +/− 12.7 | NS ^c^ | Paper reports data for 1 yr. before study; hospitalizations = 0.24 +/− 0.07; ER visits=2.3 +/− 0.4; days lost=8.8 +/− 3.0; all groups had a marked improvement in asthma morbidity (p=0.001) but no sig diff between groups
Usual care + PFM use alone vs. usual care + PFM-based action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44 | 35 | 4.51 +/− 4.0 | | 1.91 +/− 2.8 | | 5 (Mean) | | 20 +/− 28.9 | | Baseline for: days lost = 25.37 +/− 5.13; Dr. consults=7.20 +/− 0.92; ER admissions=2.08 +/−0.35; # hosp admissions=4
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM-based action plan | 50 | 35 | 1.51 +/− 1.1 | <0.001 ^b^ | 0.65 +/− 0.7 | <0.05 ^b^ | 0 (Mean) | NS ^b^ | 4.92 +/− 6.6 | <0.008 ^b^ | Baseline for: days lost = 22.20 +/− 6.23; Dr. consults=5.77 +/− 0.91; ER admissions=1.94 +/− 0.22; # hosp admissions= 4
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43 | 37 | 2 (Median) | | | | 1 (Median) | | 4.7 (Median) | | Hospital visits derived from %; at baseline (median): absence from school was 24; GP home visit=24; hospital admission was 23
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM-based action plan | 48 | 42 | 2.3 (Median) | NS | | | 5 (Median) | NS ^d^ | 2.1 (Median) | NS ^d^ | Hospital visits derived from %; at baseline (median): absence from school was 33; GP home visit = 30; hospital admission was 27
PFM-based action plan vs. symptom-based action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom-based action plan | 48 | 48 | 12 | | 2 | | 1 | | 8 | | Outcomes are number of pts. with an event
Turner, Taylor, Bennett, et al., 1998 | PFM-based action plan | 44 | 44 | 17 | NS ^c^ | 6 | NS | 0 | NS ^c^ | 9 | NS ^c^ | Excludes one pt who was an outlier who was off work for 120 days; Outcomes are number of pts. with an event
Charlton, Charlton, Broomfield, et al., 1990 | Symptom-based action plan | | 64 | 0.53
Charlton, Charlton, Broomfield, et al., 1990 | PFM-based action plan | | 51 | 0. | NS ^e^
Cowie, Revitt, Underwood, et al., 1997 | Symptom-based action plan | 45 | 45 | | | 45 | =0.006 ^b^ | 2 | NS | | | ER visits=total 6 mos;
Cowie, Revitt, Underwood, et al., 1997 | PFM-based action plan | 46 | 46 | | | 5 | =0.006 ^b^ | 2 | NS ^c^ | | | ER visits=total 6 mos.
Cote, Cartier, Robichaud, et al., 1997 | Symptom-based action plan | 45 | 45 | | | 0.7 +/− 1.3 | NS | 0.09 +/− 0.3 | NS | 2.9 +/− 12.7 | NS
Cote, Cartier, Robichaud, et al., 1997 | PFM-based action plan | 50 | 50 | | | 0.7 +/− 1.4 | NS ^c^ | 0.04 +/− 0.3 | NS ^c^ | 2.2 +/− 12.7 | NS ^c^

a Comparison of outcomes is total/mth;

b Comparison of outcomes is total/pt;

c Comparison of outcomes is total over course of study;

d Comparison of outcomes is total/pt/yr;

e Comparison of outcomes is % of patients