# Bibliography

Aaronson D, Kaiser H, Dockhorn R, et al Effects of budesonide by means of the Turbuhaler on the hypothalmic-pituitary-adrenal axis in asthmatic subjects: a dose-response study J Allergy Clin Immunol 1998 101(3):312 9 9525445
Abbott Laboratories. Zyflo® (zileuton) Filmtab® tablets prescribing information. North Chicago, IL. 1998 March. [pmcid: 325579].
Abdulwadud O, Abramson M, Forbes A, et al Evaluation of a randomised controlled trial of adult asthma education in a hospital setting Thorax 1999 54(6):493 500 10335002
Abdulwadud OA, Abramson MJ, Light L, et al Comparison of patients with asthma managed in general practice and in a hospital clinic Med J Aust 1999 171(2):72 5 10474579
Abuekteish F, Kirkpatrick JNP, Russell G Posterior subcapsular cataract and inhaled corticosteroid therapy Thorax 1995 50(6):674 6 7638813
Adinoff AD, Schwartz HJ, Rickard KA, et al Salmeterol compared with current therapies in chronic asthma J Fam Pract 1998 47(4):278 84 9789513
Adkins JC, Brogden RN Zafirlukast: a review of its pharmacological properties and therapeutic potential in the management of asthma Drugs 1998 55(1):121 44 9463793
Adkins JC, McTavish D Salmeterol. A review of its pharmacological properties and clinical efficacy in the management of children with asthma Drugs 1997 54(2):331 54 9257086
Afilalo M, Guttman A, Colacone A, et al Efficacy of inhaled steroids (beclomethasone dipropionate) for treatment of mild to moderately severe asthma in the emergency department: a randomized clinical trial Ann Emerg Med 1999 33(3):304 9 10036345
Agertoft L, Larsen FE, Pedersen S Posterior subcapsular cataracts, bruises and hoarseness in children with asthma receiving long-term treatment with inhaled budesonide Eur Respir J 1998 12(1):130 5 9701427
Agertoft L, Pedersen S Bone mineral density in children with asthma receiving long-term treatment with inhaled budesonide Am J Respir Crit Care Med 1998 157(1):178 83 9445297
Agertoft L, Pedersen S Effects of long-term treatment with an inhaled corticosteroid on growth and pulmonary function in asthmatic children Respir Med 1994 88(5):373 81 8036306
Agertoft L, Pedersen S Effect of long-term treatment with inhaled budesonide on adult height in children with asthma N Engl J Med 2000 343(15):1064 9 11027740
Agrawal M, French L Oral versus i. v. steroids for children hospitalized with asthma J Fam Pract 1999 48(8):578 9 10496630
Aldridge RE, Hancox RJ, Robin Taylor D, et al Effects of terbutaline and budesonide on sputum cells and bronchial hyperresponsiveness in asthma Am J Resp Crit Care Med 2000 161(5):1459 64 10806139
Allen DB, Bronsky EA, LaForce CF, et al Growth in asthmatic children treated with fluticasone propionate. Fluticasone Propionate Asthma Study Group J Pediatr 1998 132(3 Pt 1):472 7 9544904
Allen DB, Mullen M, Mullen B A meta-analysis of the effect of oral and inhaled corticosteroids on growth J Allergy Clin Immunol 1994 93(6):967 76 8006318
Allen HD, Thong IG, Clifton-Bligh P, et al Effects of high-dose inhaled corticosteroids on bone metabolism in prepubertal children with asthma Pediatr Pulmonol 2000 29(3):188 93 10686039
Allen RM, Jones MP, Oldenburg B Randomised trial of an asthma self-management programme for adults Thorax 1995 50(7):731 8 7570406
Alvarez Sintes R, Alvarez Sintes R, Alvarez Castro MR [Sympathomimetics and theophylline: combined use]? An Med Interna 1995 12(9):438 41 (Spanish with English abstract) 8924548
American Thoracic Society Standardization of Spirometry, 1994 Update Am J Respir Crit Care Med 1995 152(3):1107 36 7663792
Anonymous Drugs for asthma Med Lett Drugs Ther 2000 42(1073):19 24 10755001
Anonymous Effectiveness of routine self monitoring of peak flow in patients with asthma. Grampian Asthma Study of Integrated Care BMJ 1994 308(6928):564 7 8148679
Anonymous Peak flow monitoring Lippincotts Prim Care Pract 1997 1(2):229 30 9166633
Armenio L, Baldini G, Bardare M, et al Double blind, placebo controlled study of nedocromil sodium in asthma Arch Dis Child Feb 1993 68(2):193 7
Aronson N, Seidenfeld J, Piper MA, et al. Use of Epoetin for Anemia in Oncology. In press.
Aronson N, Seidenfeld J, Samson DJ, et al. Relative Effectiveness and Cost-Effectiveness of Methods of Androgen Suppression in the Treatment of Advanced Prostate Cancer. Evidence Report/Technology Assessment No. 4. (Prepared by Blue Cross/Blue Shield Association Evidence-based Practice Center under Contract No. 290-97-0015. AHCPR Publication No. 99-E0012. Rockville, MD: Agency for Health Care Policy and Research. May 1999.
The General Practitioner in Asthma Group, the British Association of Accident and Emergency Medicine, the British Paediatric Respiratory Society and the Royal College of Paediatrics and Child Health [see comments] Thorax 1997 52(Suppl 1):S9 10, S18-21
AstraZeneca. "Dear Health Care Provider" letter on Accolate® and Churg-Strauss syndrome. 22 July 1997. Wilmington, DE.
Aubier M, Pieters WR, Schlosser NJ, et al Salmeterol/fluticasone propionate (50/500 microg) in combination in a Diskus inhaler (Seretide) is effective and safe in the treatment of steroid-dependent asthma Respir Med 1999 93(12):876 84 10653049
Ayres JG, Campbell LM A controlled assessment of an asthma self-management plan involving a budesonide dose regimen OPTIONS Research Group. Eur Respir J 1996 9(5):886 92
An evaluation of the efficacy and safety of azelastine in patients with chronic asthma. Azelastine-Asthma Study Group J Allergy Clin Immunol 1996 97(6):1218 24 8648016
Bailey WC, Richards JM Jr, Brooks CM, et al A randomized trial to improve self-management practices of adults with asthma Arch Intern Med 1990 150(8):1664 8 2200380
Bailey WC, Richards JM Jr, Manzella BA, et al Promoting self-management in adults with asthma: an overview of the UAB program Health Educ Q 1987 14(3):345 55 3654238
Baker JW, Mellon M, Wald J, et al A multiple-dosing, placebo-controlled study of budesonide inhalation suspension given once or twice daily for treatment of persistent asthma in young children and infants Pediatrics 1999 103(2):414 21 9925834
Baldaia L An educational approach to successful management of childhood asthma as a chronic illness J Pediatr Nurs 1996 11(5):335 6 8908902
Balfour-Lynn I Difficult asthma: beyond the guidelines Arch Dis Child 1999 80(2):201 6 10325744
Baraldi E, Bollini MC, De Marchi A, et al Effect of beclomethasone dipropionate on bone mineral content assessed by X-ray densitometry in asthmatic children: a longitudinal evaluation Eur Respir J 1994 7(4):710 4 8005253
Baraniuk J, Murray JJ, Nathan RA, et al Fluticasone alone or in combination with salmeterol vs triamcinolone in asthma Chest 1999 116(3):625 32 10492263
Barnes N Relative safety and efficacy of inhaled corticosteroids J Allergy Clin Immunol 1998 101(4 Pt 2):S460 4 9563373
Barnes PJ Inhaled glucocorticoids for asthma N Engl J Med 1995 332(13):868 75 7870143
Bartow RA, Brogden RN Formoterol. An update of its pharmacological properties and therapeutic efficacy in the management of asthma Drugs 1998 55(2):303 22 9506248
Bateman ED, Britton M, Carrillo J, et al Salmeterol/fluticasone combination inhaler. A new, effective and well tolerated treatment for asthma Clin Drug Invest 1998 16(3):193 201
Bauman LJ, Drotar D, Leventhal JM, et al A review of psychosocial interventions for children with chronic health conditions Pediatrics 1997 100(2 Pt 1):244 51 9240807
Beasley R, D'Souza W, Te Karu H, et al Trial of an asthma action plan in the Maori community of the Wairarapa N Z Med J 1993 106(961):336 8 8341475
Begg C, Cho M, Eastwood S, et al Improving the quality of reporting of randomized trials: the CONSORT Statement JAMA 1996 276(8):637 9 8773637
Behrman RE, Kliegman RM, Jensen HB. Chapter 145: Asthma. n: Nelson Textbook of Pediatrics, 16th ed. 2000 Behrman RE, Kliegman RM, Jensen HB, eds. Philadelphia: W.B. Saunders. pp 664-679.
Bender BG, Ikle DN, DuHamel T, et al Neuropsychological and behavioral changes in asthmatic children treated with beclomethasone dipropionate versus theophylline Pediatrics 1998 101(3 Pt 1):355 60 9480997
Bender BG, Ikle DN, DuHamel T, et al Retention of asthmatic patients in a longitudinal clinical trial J Allergy Clin Immunol 1997 99(2):197 203 9042045
Bennati D, Piacentini GL, Peroni DG, et al Changes in bronchial reactivity in asthmatic children after treatment with beclomethasone alone or in association with salbutamol J Asthma 1989 26(6):359 64 2702243
Benson K, Hartz AJ A comparison of observational studies and randomized controlled trials N Engl J Med 2000 342(25):1878 86 10861324
Berg IM, Berg T, Ringqvist I Salbutamol in the treatment of asthmatic children. A comparison of oral and inhalation therapy alone and in combination Eur J Respir Dis 1982 63(4):305 9 7117428
Berg J, Dunbar-Jacob J, Sereika SM An evaluation of a self-management program for adults with asthma Clin Nurs Res 1997 6(3):225 38 9281927
Bergmann KC, Bauer CP, Overlack A A placebo-controlled, blind comparison of nedocromil sodium and beclomethasone dipropionate in bronchial asthma Curr Med Res Opin 1989 11(8):533 42 2553335
Berlin JA, Rennie D Measuring the quality of trials: the quality of the quality scales JAMA 1999 282(11):1083 5 10493209
Bernard-Bonnin AC, Stachenko S, Bonin D, et al Self-management teaching programs and morbidity of pediatric asthma: a meta-analysis J Allergy Clin Immunol 1995 95(1 Pt 1):34 41 7822662
Bernstein DI, Berkowitz RB, Chervinsky P, et al Dose-ranging study of a new steroid for asthma: mometasone furoate dry powder inhaler Respir Med 1999 93(9):603 12 10542973
Bernstein IL Cromolyn sodium in the treatment of asthma: coming of age in the United States J Allergy Clin Immunol 1985 76(2 Pt 2):381 8 3926853
Bernstein IL, Bernstein DI, Dubb JW, et al A placebo-controlled multicenter study of auranofin in the treatment of patients with corticosteroid-dependent asthma. Auranofin Multicenter Drug Trial J Allergy Clin Immunol 1996 98(2):317 24 8757209
Bernstein IL, Chervinsky P, Falliers CJ Efficacy and safety of triamcinolone acetonide aerosol in chronic asthma. Results of a multicenter, short-term controlled and long-term open study Chest 1982 81(1):20 6 7032852
Beswick KB, Pover GM, Sampson S Long-term regularly inhaled salbutamol Curr Med Res Opin 1986 10(4):228 34 3780287
Bianco S, Del Bono N, Grassi V, et al Effectiveness of nedocromil sodium versus placebo as additions to routine asthma maintenance therapy: a multicentre, double-blind, group comparative trial Respiration 1989 56(3-4):204 11 2561409
Bien JP, Bloom MD, Evans RL, et al Intravenous theophylline in pediatric status asthmaticus. A prospective, randomized, double-blind, placebo-controlled trial Clin Pediatr (Phila) 1995 34(9):475 81 358331 7586920
Birkebaek NH, Esberg G, Andersen K, et al Bone and collagen turnover during treatment with inhaled dry powder budesonide and beclomethasone dipropionate Arch Dis Child Dec 1995 73(6):524 7
Bisgaard H, Damkjaer Nielsen M, Andersen B, et al Adrenal function in children with bronchial asthma treated with beclomethasone dipropionate or budesonide J Allergy Clin Immunol 1988 81(6):1088 95 3288682
Bisgaard H, Nikander K, Munch E Comparative study of budesonide as a nebulized suspension vs pressurized metered-dose inhaler in adult asthmatics Respir Med 1998 92(1):44 9 9519224
Bjermer L, Bisgaard H, Bousquet J, et al Montelukast or salmeterol combined with an inhaled steroid in adult asthma: design and rationale of a randomized, double-blind comparative study (The IMPACT Investigation of Montelukast as a Partner Agent for Complementary Therapy-trial) Respir Med 2000 94(6):612 21 10921768
Bjorkander J, Formgren H, Johansson SA, et al. Methodological aspects on clinical trials with inhaled corticosteroids: results of two comparisons between two steroid aerosols in patients with asthma. Eur J Respir Dis Suppl. 1982;122:108-17. [pmid: 6958474].
Black PN Anti-inflammatory effects of macrolide antibiotics Eur Respir J 1997 10(5):971 2 9163632
Blais L, Suissa S, Boivin JF, et al First treatment with inhaled corticosteroids and the prevention of admissions to hospital for asthma Thorax 1998 53(12):1025 9 10195073
Blake K, Pearlman DS, Scott C, et al Prevention of exercise-induced bronchospasm in pediatric asthma patients: a comparison of salmeterol powder with albuterol Ann Allergy Asthma Immunol 1999 82(2):205 11 10071526
Blake KV Montelukast: data from clinical trials in the management of asthma Ann Pharmacother 1999 33(12):1299 314 10630831
Blanc PD, Katz PP, Henke J, et al Pulmonary and allergy subspecialty care in adults with asthma. Treatment, use of services, and health outcomes West J Med 1997 167(6):398 407 9426478 1304718
Bleecker ER, Welch MJ, Weinstein SF, et al Low-dose inhaled fluticasone propionate versus oral zafirlukast in the treatment of persistent asthma J Allergy Clin Immunol 2000 105(6 Pt 1):1123 9 10856145
Bloch H, Silverman R, Mancherje N, et al Intravenous magnesium sulfate as an adjunct in the treatment of acute asthma Chest 1995 107(6):1576 81 7781349
Boe J, Bakke P, Rodolen T, et al High-dose inhaled steroids in asthmatics: moderate efficacy gain and suppression of the hypothalamic-pituitary-adrenal (HPA) axis. Research Council of the Norwegian Thoracic Society Eur Respir J 1994 7(12):2179 84 7713201
Bone MF, Kubik MM, Keaney NP, et al Nedocromil sodium in adults with asthma dependent on inhaled corticosteroids: a double blind, placebo controlled study Thorax 1989 44(8):654 9 2552600
Bonnaud F, Desfougeres JL [Treatment of asthma in the adult using a combination of salbutamol 100 micrograms -- beclomethasone 50 micrograms. Results of a study on 1917 patients seen in general medicine] Allerg Immunol (Paris) 1991 Sep 23(7):295 300 (French with English abstract) 267442 1741929
Booth H, Bish R, Walters J, et al Salmeterol tachyphylaxis in steroid treated asthmatic subjects Thorax 1996 51(11):1100 4 8958892
Booth H, Fishwick K, Harkawat R, et al Changes in methacholine induced bronchoconstriction with the long acting beta 2 agonist salmeterol in mild to moderate asthmatic patients Thorax 1993 48(11):1121 4 8296255
Booth PC, Wells NEJ, Morrison AK A comparison of the cost effectiveness of alternative prophylactic therapies in childhood asthma Pharmacoeconomics 1996 10(3):262 8 10163573
Bootsma GP, Dekhuijzen PN, Festen J, et al Fluticasone propionate does not influence bone metabolism in contrast to beclomethasone dipropionate Am J Respir Crit Care Med 1996 153(3):924 30 8630574
Bose B, Cater JI, Clark RA A once daily theophylline preparation in prevention of nocturnal symptoms in childhood asthma Eur J Pediatr 1987 146(5):524 7 3315687
Bosman HG, van Uffelen R, Tamminga JJ, et al Comparison of inhaled beclomethasone dipropionate 1000 micrograms twice daily and oral prednisone 10 mg once daily in asthmatic patients Thorax 1994 49(1):37 40 8153939
Boulet LP, Boutin H, Cote J, et al Evaluation of an asthma self-management education program J Asthma 1995 32(3):199 206 7759459
Boulet LP, Cartier A, Milot J, et al Tolerance to the protective effects of salmeterol on methacholine-induced bronchoconstriction: influence of inhaled corticosteroids Eur Respir J 1998 11(5):1091 7 9648961
Boulet LP, Giguere MC, Milot J, et al Effects of long-term use of high-dose inhaled steroids on bone density and calcium metabolism J Allergy Clin Immunol 1994 94(5):796 803 7963147
Boulet LP, Laviolette M, Boucher S, et al A twelve-week comparison of salmeterol and salbutamol in the treatment of mild-to-moderate asthma: a Canadian multicenter study J Allergy Clin Immunol 1997 99(1 Pt 1):13 21 9003206
Boulet LP, Milot J, Gagnon L, et al Long-term influence of inhaled corticosteroids on bone metabolism and density. Are biological markers predictors of bone loss? Am J Respir Crit Care Med 1999 159(3):838 44 10051260
Boulet LP, Becker A, Berube D et al Canadian Asthma Consensus Report, 1999. Canadian Asthma Consensus Group CMAJ 1999 161(11 Suppl):S1 61
Bouros D, Bachlitzanakis N, Kottakis J, et al Formoterol and beclomethasone versus higher dose beclomethasone as maintenance therapy in adult asthma Eur Respir J 1999 14(3):627 32 10543286
Boyd G Salmeterol xinafoate in asthmatic patients under consideration for maintenance oral corticosteroid therapy. UK Study Group Eur Respir J 1995 8(9):1494 8 8575574
Bradding P, Rushby I, Scullion J, et al As-required versus regular nebulized salbutamol for the treatment of acute severe asthma Eur Respir J 1999 13(2):290 4 10065670
Brambilla C, Benhamou D, Guerin JC et al [Comparative trial of the clinical efficacy and tolerance of cefatrizine (Cefaperos) and cefpodoxime proxetil (Orelox) in superinfections of chronic obstructive bronchopneumopathies in adults in urban practice] Pathol Biol (Paris) 1995 Nov 43(9):815 24 (French with English abstract) 8746104
Brambilla C, Chastang C, Georges D, et al Salmeterol compared with slow-release terbutaline in nocturnal asthma. A multicenter, randomized, double-blind, double-dummy, sequential clinical trial. French Multicenter Study Group Allergy 1994 49(6):421 6 7915501
Bramson R Self-management of asthma J Fam Pract 1996 43(1):21 2 8691172
Brand PL, Waalkens HJ, Duiverman EJ, et al Inaccuracy of portable peak flow meters: correction is not needed. Dutch CNSLD Study Group Acta Paediatr 1997 86(8):888 9 9307172
Brand PLP, Duiverman EJ, Waalkens HJ, et al. Peak flow variation in childhood asthma: Correlation with symptoms, airways obstruction, and hyperresponsiveness during long term treatment with inhaled corticosteroids. Thorax. 1999;54:103-7. [pmid: 10325912].
Brandt HD, Muntingh GL. Decreasing asthma morbidity. S Afr Med J. 1994;84:842-4. [pmid: 7570234].
Breznay JB, Ellsworth A New oral therapy for childhood asthma J Fam Pract 1998 47(1):15 6 9673601
Britton MG, Earnshaw JS, Palmer JB A twelve month comparison of salmeterol with salbutamol in asthmatic patients. European Study Group Eur Respir J 1992 5(9):1062 7 1426215
Brogden RN, Faulds D Salmeterol xinafoate. A review of its pharmacological properties and therapeutic potential in reversible obstructive airways disease Drugs 1991 42(5):895 912 1723379
Brogden RN, Sorkin EM Nedocromil sodium. An updated review of its pharmacological properties and therapeutic efficacy in asthma Drugs 1993 45(5):693 715 7686465
Bronsky E, Ekholm BP, Klinger NM, et al Switching patients with asthma from chlorofluorocarbon (CFC) albuterol to hydrofluoroalkane-134a (HFA) albuterol J Asthma 1999 36(1):107 14 10077140
Bronsky E, Korenblat P, Harris AG, et al Comparative clinical study of inhaled beclomethasone dipropionate and triamcinolone acetonide in persistent asthma Ann Allergy Asthma Immunol 1998 80(4):295 302 9564977
Bronsky EA, Kemp JP, Orgel HA, et al A 1-week dose-ranging study of inhaled salmeterol in patients with asthma Chest 1994 105(4):1032 7 7909285
Brown DC, Savacool AM, Letizia CM A retrospective review of the effects of one year of triamcinolone acetonide aerosol treatment on the growth patterns of asthmatic children Ann Allergy 1989 63(1):47 51 2662835
Brown PH, Greening AP, Crompton GK Hypothalamo-pituitary-adrenal axis suppression in asthmatic adults taking high dose beclomethasone dipropionate Br J Clin Pract 1992 46(2):102 4 1457295
Bryan S Salmeterol for nocturnal asthma J Fam Pract 1999 48(6):415 6 10386478
Buchner DA, Butt LT, De SA, et al Effects of an asthma management program on the asthmatic member: Patient-centered results of a 2-year study in a managed care organization Am J Managed Care 1998 4(9):1288 97
Burns RB A multicenter study with ketotifen (Zaditen) N Engl Reg Allergy Proc 1985 6(1):78 83 3939673
Busse WW, Brazinsky S, Jacobson K, et al Efficacy response of inhaled beclomethasone dipropionate in asthma is proportional to dose and is improved by formulation with a new propellant J Allergy Clin Immunol 1999 104(6):1215 22 10589004
Busse WW, Casale TB, Murray JJ, et al Efficacy, safety, and impact on quality of life of salmeterol in patients with moderate persistent asthma Am J Managed Care 1998 4(11):1579 87
Busse WW, Middleton E, Storms W, et al Corticosteroid-sparing effect of azelastine in the management of bronchial asthma Am J Respir Crit Care Med 1996 153(1):122 7 8542104
Busse WW, Smith A, Bush RK The use of a single daily theophylline dose and metered-dose albuterol in asthma treatment J Allergy Clin Immunol 1986 78(4 Pt 1):577 82 3771949
Cabana MD, Ebel BE, Cooper-Patrick L, et al Barriers pediatricians face when using asthma practice guidelines Arch Pediatr Adolescent Med 2000 154(7):685 93
Calvo GM, Calvo AM, Marin HF, et al Is it useful to add an anticholinergic treatment to beta 2-adrenergic medication in acute asthma attack? J Investig Allergol Clin Immunol 1998 8(1):30 4
Campbell LM, Anderson TJ, Parashchak MR, et al A comparison of the efficacy of long-acting beta 2-agonists: eformoterol via Turbohaler and salmeterol via pressurized metered dose inhaler or Accuhaler, in mild to moderate asthmatics. Force Research Group Respir Med 1999 93(4):236 44
Cave A, Arlett P, Lee E Inhaled and nasal corticosteroids: factors affecting the risks of systemic adverse effects Pharmacol Ther 1999 83(3):153 79 10576291
Chalmers TC, Smith H Jr, Blackburn B, et al A method for assessing the quality of a randomized control trial Control Clin Trials 1981 2(1):31 49 7261638
Chapman KR, Ljungholm K, Kallen A Long-term xanthine therapy of asthma. Enprofylline and theophylline compared. International Enprofylline Study Group Chest 1994 106(5):1407 13 7956392
Charlton I Self-management plans for asthma control Nurs Times 1991 87(20):
Charlton I, Antoniou AG, Atkinson J, et al Asthma at the interface: bridging the gap between general practice and a district general hospital Arch Dis Child 1994 70(4):313 8 8185365
Charlton I, Charlton G, Broomfield J, et al Evaluation of peak flow and symptoms only self management plans for control of asthma in general practice BMJ 1990 301(6765):1355 9 2148702 1664498
Chee CBE The utility of peak flow measurements in guiding asthma management - what is the evidence? Singapore Med J 1998 39(11):476 7 10067380
Chervinsky P, Goldberg P, Galant S, et al Long-term cardiovascular safety of salmeterol powder pharmacotherapy in adolescent and adult patients with chronic persistent asthma: a randomized clinical trial Chest 1999 115(3):642 8 10084469
Chervinsky P, van As A, Bronsky EA, et al Fluticasone propionate aerosol for the treatment of adults with mild to moderate asthma. The Fluticasone Propionate Asthma Study Group [see comments] J Allergy Clin Immunol 1994 94(4):676 83 7930300
The Childhood Asthma Management Program (CAMP): design, rationale, and methods Control Clin Trials 1999 20(1):91 120 10027502
Long-term effects of budesonide or nedocromil in children with asthma N Engl J Med 2000a Oct 12 343(15):1054 63
Supplementary material: Long-term effects of budesonide or nedocromil in children with asthma. NAPS Document no. 05569. Obtained from National Auxiliary Publications Service, c/o Microfiche Publications, West Hempstead (NY); Printed 2000b Sept 8.
Chodosh S Comparison of bacampicillin twice daily and ampicillin four times daily in treatment of acute exacerbations of chronic bronchitis Rev Infect Dis 1981 3(1):140 9 7012995
Chodosh S, Tuck J, Stottmeier KD, et al Comparison of ciprofloxacin with ampicillin in acute infectious exacerbations of chronic bronchitis. A double-blind crossover study Am J Med 1989 87(5A):107S 112S 2686409
Choy DK, Tong M, Ko F, et al Evaluation of the efficacy of a hospital-based asthma education programme in patients of low socioeconomic status in Hong Kong Clin Exp Allergy 1999 29(1):84 90 10051706
Christian Virchow J, Prasse A, Naya I, et al Zafirlukast improves asthma control in patients receiving high-dose inhaled corticosteroids Am J Respir Crit Care Med 2000 Aug 162(2 Pt 1):578 85 10934090
Cicutto LC, Llewellyn-Thomas HA, Geerts WH Physicians' approaches to providing asthma education to patients and the level of patient involvement in management decisions J Asthma 1999 36(5):427 39 10461932
Clancy L, Keogan S Treatment of nocturnal asthma with nedocromil sodium Thorax 1994 49(12):1225 7 7878557
Clark NM, Evans D, Zimmerman BJ, et al Patient and family management of asthma: theory-based techniques for the clinician J Asthma 1994 31(6):427 35 7961319
Clark NM, Feldman CH, Evans D, et al Changes in children's school performance as a result of education for family management of asthma J Sch Health 1984 54(4):143 5 6562287
Clark NM, Feldman CH, Evans D, et al The impact of health education on frequency and cost of health care use by low income children with asthma J Allergy Clin Immunol 1986 78(1 Pt 1):108 15 3088085
Cluzel M, Bousquet J, Daures JP, et al Ambulatory long-term subcutaneous salbutamol infusion in chronic severe asthma J Allergy Clin Immunol 1990 85(3):599 606 2179366
Cockcroft DW Pharmacologic therapy for asthma: overview and historical perspective J Clin Pharmacol 1999 39(3):216 22 10073318
Cockcroft DW, Swystun VA, Bhagat R Interaction of inhaled beta 2 agonist and inhaled corticosteroid on airway responsiveness to allergen and methacholine Am J Respir Crit Care Med 1995 152(5 Pt 1):1485 9 7582281
Cogswell JJ, Simpkiss MJ Nebulised sodium cromoglycate in recurrently wheezy preschool children Arch Dis Child 1985 60(8):736 8 3929698
Cohen J. Statistical Power Analysis for the Behavioral Sciences. New York: Academic Press. 1977:8-17. [pmcid: 333326].
Colland VT Learning to cope with asthma: a behavioural self-management program for children Patient Educ Couns 1993 22(3):141 52 8153036
Concato J, Shah N, Horwitz RI Randomized, controlled trials, observational studies, and the hierarchy of research designs N Engl J Med 2000 342(25):1887 92 10861325 1557642
Condemi JJ, Chervinsky P, Goldstein MF, et al Fluticasone propionate powder administered through Diskhaler versus triamcinolone acetonide aerosol administered through metered-dose inhaler in patients with persistent asthma J Allergy Clin Immunol 1997 Oct 100(4):467 74 9338539
Condemi JJ, Goldstein S, Kalberg C, et al The addition of salmeterol to fluticasone propionate versus increasing the dose of fluticasone propionate in patients with persistent asthma. Salmeterol Study Group Ann Allergy Asthma Immunol 1999 82(4):383 9 10227337
Connett GJ, Warde C, Wooler E, et al Use of budesonide in severe asthmatics aged 1-3 years Arch Dis Child 1993 69(3):351 5 8215545
Connolly CK, Murthy NK, Prescott RJ, et al Infection in exacerbations of asthma: views of different groups of practitioners Postgrad Med J 1991 67(792):892 6 1758798
Convery RP, Leitch DN, Bromly C, et al Effect of inhaled fluticasone propionate on airway responsiveness in treatment-naive individuals -- a lesser benefit in females Eur Resp J 2000 15(1):19 24
Conway SP, Houlsby WT Slow release theophylline in preschool asthmatics Arch Dis Child 1986 61(10):1024 6 3535686
Cote J, Cartier A, Malo JL, et al Compliance with peak expiratory flow monitoring in home management of asthma Chest 1998 113(4):968 72 9554633
Cote J, Cartier A, Robichaud P, et al Influence on asthma morbidity of asthma education programs based on self-management plans following treatment optimization Am J Respir Crit Care Med 1997 155(5):1509 14 9154850
Cotter TP, Hood PP, Costello JF, et al Exposure to systemic prednisolone for 4 hours reduces ex vivo synthesis of GM-CSF by bronchoalveolar lavage cells and blood mononuclear cells of mild allergic asthmatics Clin Exp Allergy 1999 29(12):1655 62 10594542
Cowie RL, Revitt SG, Underwood MF, et al The effect of a peak flow-based action plan in the prevention of exacerbations of asthma Chest 1997 112(6):1534 8 9404750
Creer TL, Kotses H, Reynolds RV Living with asthma: Part II. Beyond CARIH J Asthma 1989 26(1):31 52 2702214
Creticos P, Burk J, Smith L, et al The use of twice daily nedocromil sodium in the treatment of asthma J Allergy Clin Immunol 1995 95(4):829 36 7722163
Creticos PS, Freidhoff LR, Bernstein DI, et al Comparison of an inhaled corticosteroid (triamcinolone acetonide) to a long-acting bronchodilator (salmeterol), the combination, and placebo in mild-moderate adult asthmatic patients Int Arch Allergy Immunol 1999 118(2-4):345 6 10224440
Crimi E, Orefice U, De Benedetto F, et al Nedocromil sodium versus theophylline in the treatment of reversible obstructive airway disease Ann Allergy Asthma Immunol 1995 74(6):501 8 7788518
Crompton GK, Ayres JG, Basran G, et al Comparison of oral bambuterol and inhaled salmeterol in patients with symptomatic asthma and using inhaled corticosteroids Am J Respir Crit Care Med 1999 159(3):824 8 10051257
Crowley S, Hindmarsh PC, Matthews DR, et al Growth and the growth hormone axis in prepubertal children with asthma J Pediatr 1995 126(2):297 303 7844682
Crowley S, Trivedi P, Risteli L, et al Collagen metabolism and growth in prepubertal children with asthma treated with inhaled steroids J Pediatr 1998 132(3 Pt 1):409 13 9544892
Cua-Lim F, Agbayani BF, Lachica D. A double-blind comparative trial of nedocromil sodium and placebo in the management of bronchial asthma in patients routinely using oral bronchodilators. Eur J Respir Dis Suppl. 1986;147:306-10. [pmid: 3021498].
Cumming RG, Mitchell P, Leeder SR Use of inhaled corticosteroids and the risk of cataracts N Engl J Med 1997 337(1):8 14 9203425
Cypcar D, Stark J, Lemanske RF Jr The impact of respiratory infections on asthma Pediatr Clin North Am 1992 39(6):1259 76 1437319
Czerniawska-Mysik G, Adamek-Guzik T, Dyczek A, et al Double-blind clinical study with broncho-vaxom in the treatment of recurrent acute bronchitis and bronchial asthma Int J Immunother 1992 8(3):153 159
Dahl R, Earnshaw JS, Palmer JB Salmeterol: a four week study of a long-acting beta-adrenoceptor agonist for the treatment of reversible airways disease Eur Respir J 1991 4(10):1178 84 1687131
Dahl R, Johansson SA. Effect on lung function of budesonide by inhalation, terbutaline s. c. and placebo given simultaneously or as single treatments. Eur J Respir Dis Suppl. 1982;122:(132-7). [pmid: 6958477].
Dahlen B Treatment of aspirin-intolerant asthma with antileukotrienes Am J Respir Crit Care Med 2000 161(2 Pt 2):S137 41 10673243
Dahlen B, Nizankowska E, Szczeklik A, et al Benefits from adding the 5-lipoxygenase inhibitor zileuton to conventional therapy in aspirin-intolerant asthmatics Am J Respir Crit Care Med 1998 157(4 Pt 1):1187 94 9563738
D'Alonzo GE, Nathan RA, Henochowicz S, et al Salmeterol xinafoate as maintenance therapy compared with albuterol in patients with asthma JAMA 1994 271(18):1412 6 7909853
D'Alonzo GE Efficacy of inhaled salmeterol in the treatment of asthma Eur Respir Rev 1995 5(27):128 32
Damsbo N [Budesonide in the treatment of mild asthma. A placebo-controlled multicenter study in general practice] Ugeskr Laeger 1994 156(43):6384 8 (Danish with English abstract) 7810015
Davies B, Brooks G, Devoy M The efficacy and safety of salmeterol compared to theophylline: meta-analysis of nine controlled studies Respir Med 1998 92(2):256 63 9616522
Davis T Home environment must be included in pediatric asthma self-management Pediatr Nurs 1997 23(1):
Davis KC, Small RE Budesonide inhalation powder: a review of its pharmacologic properties and role in the treatment of asthma Pharmacotherapy 1998 18(4):720 8 9692646
Deaves DM An assessment of the value of health education in the prevention of childhood asthma J Adv Nurs 1993 18(3):354 63 8450129
Demedts M, Cohen R, Hawkinson R Switch to non-CFC inhaled corticosteroids: a comparative efficacy study of HFA-BDP and CFC-BDP metered-dose inhalers Int J Clin Pract 1999 53(5):331 8 10695095
Dempsey OJ, Wilson AM, Sims EJ, et al Additive bronchoprotective and bronchodilator effects with single doses of salmeterol and montelukast in asthmatic patients receiving inhaled corticosteroids Chest 2000 117(4):950 3 10767223
DerSimonian R, Laird N Meta-analysis in clinical trials Control Clin Trials 1986 7(3):177 88 3802833
Childhood Asthma Management Program Research Group Ann Allergy Asthma Immunol 1998 81(6):571 81 9892029
Dessanges JF, Prefaut C, Taytard A, et al The effect of zafirlukast on repetitive exercise-induced bronchoconstriction: the possible role of leukotrienes in exercise-induced refractoriness J Allergy Clin Immunol 1999 104(6):1155 61 10588995
Detwiler DA, Boston LM, Verhulst SJ Evaluation of an educational program for asthmatic children ages 4-8 and their parents Respir Care 1994 39(3):204 212 10145989
Devine EC Meta-analysis of the effects of psychoeducational care in adults with asthma Res Nursing Health 1996 19(5):367 76
Dhand R, Malik SK, Garg SK, et al Clinical trial of a sustained release theophylline tablet in adult asthmatics Indian J Chest Dis Allied Sci 1986 28(4):212 21 3301644
Di Franco A, Giannini D, Bacci E, et al Comparison of different long-term asthma treatments in subjects with mild-to-moderate asthma Monaldi Arch Chest Dis 1999 54(5):390 3 10741095
Didier A, Campos OR A two-month comparison of salmeterol/beclomethasone and slow-release terbutaline/budesonide in moderate asthma management Clin Drug Invest 1997 14(1):1 11
Dluhy RG Effect of inhaled beclomethasone dipropionate and budesonide on adrenal function, skin changes and cataract formation Respir Med 1998 92(Suppl B):15 23 10193531
Dolan LM, Kesarwala HH, Holroyde JC, et al Short-term, high-dose, systemic steroids in children with asthma: the effect on the hypothalamic-pituitary-adrenal axis J Allergy Clin Immunol 1987 80(1):81 7 3598031
Dompeling E, van Schayck CP, Molema J, et al Inhaled beclomethasone improves the course of asthma and COPD Eur Respir J 1992 5(8):945 52 1426202
Dompeling E, van Schayck CP, van Grunsven PM, et al Slowing the deterioration of asthma and chronic obstructive pulmonary disease observed during bronchodilator therapy by adding inhaled corticosteroids. A 4-year prospective study Ann Intern Med 1993 118(10):770 8 8470851
Donahue JG, Weiss ST, Livingston JM, et al Inhaled steroids and the risk of hospitalization for asthma JAMA 1997 277(11):887 91 9062326
Dorow P, Schenk H, Dougherty C Effect of a methylxanthine preparation in the form of a retention enema on pulmonary function and theophylline levels in patients with acute bronchospasm Arzneimittelforschung 1986 36(6):974 6 3741533
Doull I, Freezer N, Holgate S Osteocalcin, growth, and inhaled corticosteroids: A prospective study Arch Dis Child 1996 74(6):497 501 8758124
Doull IJ, Campbell MJ, Holgate ST Duration of growth suppressive effects of regular inhaled corticosteroids Arch Dis Child 1998 78(2):172 3 9579164
Doull IJ, Freezer NJ, Holgate ST Growth of prepubertal children with mild asthma treated with inhaled beclomethasone dipropionate Am J Respir Crit Care Med 1995 151(6):1715 9 7767512
Drazen JM, Israel E, O'Byrne PM Treatment of asthma with drugs modifying the leukotriene pathway N Engl J Med 1999 340(3):197 206 9895400
Drummond N, Abdalla M, Beattie JAG, et al Effectiveness of routine self monitoring of peak flow in patients with asthma. Grampian Asthma Study of Integrated Care GRASSIC) BMJ 1994 Feb 26 308(6928):564 7
Drummond N, Abdalla M, Buckingham JK, et al Integrated care for asthma: a clinical, social, and economic evaluation. Grampian Asthma Study of Integrated Care (GRASSIC) BMJ 1994 Feb 26 308(6928):559 64
D'Souza W, Burgess C, Ayson M, et al Trial of a "credit card" asthma self-management plan in a high-risk group of patients with asthma J Allergy Clin Immunol 1996 97(5):1085 92 8626986
D'Souza W, Crane J, Burgess C, et al Community-based asthma care: Trial of a 'credit card' asthma self-management plan Eur Respir J 1994 7(7):1260 5 7925904
D'Souza WJ, Te Karu H, Fox C, et al Long-term reduction in asthma morbidity following an asthma self-management programme Eur Respir J 1998 11(3):611 6 9596111
Dube LM, Swanson LJ, Awni W Zileuton, a leukotriene synthesis inhibitor in the management of chronic asthma. Clinical pharmacokinetics and safety Clin Rev Allergy Immunol 1999 17(1-2):213 21 10436867
Ducharme FM, Davis GM Randomized controlled trial of ipratropium bromide and frequent low doses of salbutamol in the management of mild and moderate acute pediatric asthma J Pediatr 1998 133(4):479 85 9787684
Dutoit JI, Salome CM, Woolcock AJ Inhaled corticosteroids reduce the severity of bronchial hyperresponsiveness in asthma but oral theophylline does not Am Rev Respir Dis 1987 136(5):1174 8 3674580
Dykewicz MS, Greenberger PA, Patterson R, et al Natural history of asthma in patients requiring long-term systemic corticosteroids Arch Intern Med 1986 146(12):2369 72 3778071
Ebeling PR, Erbas B, Hopper JL, et al Bone mineral density and bone turnover in asthmatics treated with long-term inhaled or oral glucocorticoids J Bone Miner Res 1998 13(8):1283 9 9718197
Eddy DM, Hasselblad V. FAST*PRO Software for Meta-analysis by the Confidence Profile Method. Orlando: Academic Press. 1992. [pmcid: 402151].
Edelman JM, Turpin JA, Bronsky EA, et al Oral montelukast compared with inhaled salmeterol to prevent exercise-induced bronchoconstriction. A randomized, double-blind trial. Exercise Study Group Ann Intern Med 2000 132(2):97 104 10644288
Edmunds AT, Carswell F, Robinson P, et al Controlled trial of cromoglycate and slow-release aminophylline in perennial childhood asthma Br Med J 27 1980 281(6244):
Edwards AM, Lyons J, Weinberg E, et al Early use of inhaled nedocromil sodium in children following an acute episode of asthma Thorax 1999 54(4):308 15 10092691
Edwards TB, Dockhorn RJ, Wagner DE, et al Efficacy of once daily extended-release theophylline in decreasing the use of inhaled beta 2-agonists in stable, mild-to-moderate asthma patients Ann Allergy Asthma Immunol 1995 75(5):409 16 7583862
Egan JJ, Maden C, Kalra S, et al A randomized, double-blind study comparing the effects of beclomethasone and fluticasone on bone density over two years Eur Respir J 1999 13(6):1267 75 10445600
Eigen H, Reid JJ, Dahl R, et al Evaluation of the addition of cromolyn sodium to bronchodilator maintenance therapy in the long-term management of asthma J Allergy Clin Immunol 1987 80(4):612 21 3117864
Elegant VA Quality of life in multi-centre trials Respir Med 1991 85(Suppl B):39 41 discussion 57 8 1661906
Emad A Effectiveness of adding alternate-day theophylline to the treatment regimen of patients with moderate-to-severe asthma Respir Care 1996 41(6):520 3
Emond SD, Woodruff PG, Lee EY, et al Effect of an emergency department asthma program on acute asthma care Ann Emerg Med 1999 34(3):321 5 10459087
Eriksson NE, Haglind K, Ewald U Combined theophylline/beta-agonists maintenance therapy in chronic asthma Eur J Respir Dis 1983 64(3):172 7 6132832
Ernst P, Spitzer WO, Suissa S, et al Risk of fatal and near-fatal asthma in relation to inhaled corticosteroid use JAMA 1992 268(24):3462 4 1460737
Evans D, Clark NM, Feldman CH, et al A school health education program for children with asthma aged 8-11 years Health Educ Q 1987 14(3):267 79 3654234
Evans DJ, Taylor DA, Zetterstrom O, et al A comparison of low-dose inhaled budesonide plus theophylline and high-dose inhaled budesonide for moderate asthma N Engl J Med 1997 337(20):1412 8 9358138
Faurschou P, Bing J, Edman G, et al Comparison between sodium cromoglycate (MDI: metered-dose inhaler) and beclomethasone dipropionate (MDI) in treatment of adult patients with mild to moderate bronchial asthma. A double-blind, double-dummy randomized, parallel-group study Allergy 1994 49(8):659 63 7653745
Faurschou P, Engel AM, Haanaes OC Salmeterol in two different doses in the treatment of nocturnal bronchial asthma poorly controlled by other therapies Allergy 1994 49(10):827 32 7709991
Faurschou P, Steffensen I, Jacques L Effect of addition of inhaled salmeterol to the treatment of moderate-to-severe asthmatics uncontrolled on high-dose inhaled steroids. European Respiratory Study Group Eur Respir J 1996 9(9):1885 90 8880107
Ferguson AC, Spier S, Manjra A, et al Efficacy and safety of high-dose inhaled steroids in children with asthma: a comparison of fluticasone propionate with budesonide J Pediatr 1999 134(4):422 7 10190915
Fernandez-Rivas M, Perez-Carral C, Senent CJ Occupational asthma and rhinitis caused by ash (Fraxinus excelsior) wood dust Allergy 1997 52(2):196 9 9105524
Field HV, Jenkinson PM, Frame MH, et al Asthma treatment with a new corticosteroid aerosol, budesonide, administered twice daily by spacer inhaler Arch Dis Child 1982 57(11):864 6 6756319
Fireman P, Friday GA, Gira C, et al Teaching self-management skills to asthmatic children and their parents in an ambulatory care setting Pediatrics 1981 68(3):341 8 6792585
Fishwick D, D'Souza W, Beasley R The asthma self-management plan system of care: what does it mean, how is it done, does it work, what models are available, what do patients want and who needs it? Patient Educ Couns 1997 32(1 Suppl):S21 33 9516757
Fitzgerald D, Van Asperen P, Mellis C, et al Fluticasone propionate 750 micrograms/day versus beclomethasone dipropionate 1500 micrograms/day: comparison of efficacy and adrenal function in paediatric asthma Thorax 1998 53(8):656 61 9828851
FitzGerald JM, Chapman KR, Della Cioppa G, et al Sustained bronchoprotection, bronchodilatation, and symptom control during regular formoterol use in asthma of moderate or greater severity. The Canadian FO/OD1 Study Group J Allergy Clin Immunol 1999 103(3 Pt 1):427 35 10069876
Fitzpatrick SB, Weir C, Coughlin S, et al Use of peak flow monitoring among urban black children with asthma [editorial] J Natl Med Assoc 1992 84(6):477 9 1608058
Flint K, Hockley B, Johnson NM Salbutamol versus Duovent (a combination of fenoterol and ipratropium bromide) in asthma Eur J Respir Dis Suppl 1983 128(Pt 2):548 50 6225674
Flint KC, Hockley B, Johnson NM A comparison between a combination of ipratropium bromide plus fenoterol in a single metered dose inhaler (Duovent) and salbutamol in asthma Postgrad Med J 1983 59(697):724 5 6227877
Foo AL, Sly PD Pulmonary function in a hospital population of asthmatic children J Asthma 1991 28(4):273 80 1890080
Foresi A, Morelli MC, Catena E Low-dose budesonide with the addition of an increased dose during exacerbations is effective in long-term asthma control. On behalf of the Italian Study Group Chest 2000 117(2):440 6 10669688
Forsch R Treating acute asthma in adults J Fam Pract 1996 43(4):339 40 8874362
Fost DA, Leung DY, Martin RJ, et al Inhibition of methylprednisolone elimination in the presence of clarithromycin therapy J Allergy Clin Immunol 1999 103(6):1031 5 10359882
Francis RS, McEnery G Disodium cromoglycate compared with beclomethasone dipropionate in juvenile asthma Clin Allergy 1984 14(6):537 40 6439430
Freeman W, Packe GE, Cayton RM The effect of sustained-release theophylline in nocturnal asthma Br J Clin Pract 1991 45(1):21 5 1931534
Furukawa CT, Shapiro GG, Bierman CW, et al A double-blind study comparing the effectiveness of cromolyn sodium and sustained-release theophylline in childhood asthma Pediatrics 1984 74(4):453 9 6435085
Furukawa CT Comparative trials including a beta 2 adrenergic agonist, a methylxanthine, and a mast cell stabilizer Ann Allergy 1988 60(5):472 6 2897179
Fyans PG, Chatterjee PC, Chatterjee SS Effects of adding nedocromil sodium (Tilade) to the routine therapy of patients with bronchial asthma Clin Exp Allergy 1989 19(5):521 8 2551469
Gagnon L, Boulet LP, Brown J, et al Influence of inhaled corticosteroids and dietary intake on bone density and metabolism in patients with moderate to severe asthma J Am Diet Assoc 1997 97(12):1401 6 9404337
Gajanan SG Inhaled corticosteroids in childhood bronchial asthma Natl Med J India 1993 6(2):76 7 8477214
Galant SP, Lawrence M, Meltzer EO, et al Fluticasone propionate compared with theophylline for mild-to-moderate asthma Ann Allergy Asthma Immunol 1996 77(2):112 8 8760776
Galant SP, van Bavel J, Finn A, et al Diskus and diskhaler: efficacy and safety of fluticasone propionate via two dry powder inhalers in subjects with mild-to-moderate persistent asthma Ann Allergy Asthma Immunol 1999 82(3):273 80 10094218
Gallefoss F, Bakke PS How does patient education and self-management among asthmatics and patients with chronic obstructive pulmonary disease affect medication? Am Respir Crit Care Med 1999 161(2 part 2):S137 S141
Garbe E, LeLorier J, Boivin JF, et al Inhaled and nasal glucocorticoids and the risks of ocular hypertension or open-angle glaucoma JAMA 1997 277(9):722 7 9042844
Garbe E, Suissa S, LeLorier J Association of inhaled corticosteroid use with cataract extraction in elderly patients JAMA 1998 280(6):539 43 9707144
Garcia-Marcos L, Schuster A New perspectives for asthma treatment: anti-leukotriene drugs Pediatr Allergy Immunol 1999 10(2):77 88 10478608
Garrett J, Fenwick JM, Taylor G, et al Peak expiratory flow meters (PEFMs)--who uses them and how and does education affect the pattern of utilisation? Aust N Z J Med 1994 24(5):521 9 7848156
Garrett J, Williams S, Wong C, et al Treatment of acute asthmatic exacerbations with an increased dose of inhaled steroid Arch Dis Child 1998 79(1):12 7 9771245
Gebert N, Hummelink R, Konning J, et al Efficacy of a self-management program for childhood asthma--a prospective controlled study Patient Educ Couns 1998 35(3):213 20 9887853
Geller-Bernstein C, Sneh N The management of bronchial asthma in children under the age of 3 1/2 years using Intal (sodium cromoglycate) administered by Spinhaler Clin Allergy 1980 10(Suppl):503 8
Gershman NH, Wong HH, Liu JT, et al Low- and high-dose fluticasone propionate in asthma; effects during and after treatment Eur Respir J 2000 15(1):11 8 10678614
Ghosh CS, Ravindran P, Joshi M, et al Reductions in hospital use from self management training for chronic asthmatics Soc Sci Med 1998 46(8):1087 93 9579760
Gibson PG, Coughlan J, Wilson AJ, et al Limited (information only) patient education programs for adults with asthma Cochrane Database Syst Rev 2000a(2):
Gibson PG, Coughlan J, Wilson AJ, et al Self-management education and regular practitioner review for adults with asthma Cochrane Database Syst Rev 2000b(2):
Gibson PG, Shah S, Mamoon HA. Peer-led asthma education for adolescents: Impact evaluation. J Adolesc Health. 1998;22:66-72. [pmid: 9436069].
Gibson PG, Wlodarczyk J, Hensley MJ, et al Using quality-control analysis of peak expiratory flow recordings to guide therapy for asthma Ann Intern Med 1995 123(7):488 92 7661491
Gillies J, Barry D, Crane J, et al A community trial of a written self management plan for children with asthma Asthma Foundation of NZ Children's Action. N Z Med J 1996 109(1015):30 3
Glass G. Summarizing effect sizes. In: New Directions for Methodology of Social and Behavioral Science: Quantitative Assessment of Research Domains, Jossey-Bass, San Francisco, 1980.
FDA approves Advair™ Diskus®: the first and only medication that simultaneously treats both underlying components of asthma [press release]. Research Triangle Park (NC). 2000 Aug 15. [pmcid: 284246].
Serevent® (salmeterol xinafoate) inhalation aerosol prescribing information. Research Triangle Park, NC. 2000 July.
Gluckman TJ, Corbridge T Management of respiratory failure in patients with asthma Curr Opin Pulm Med 2000 6(1):79 85 10608430
Goldstein DE, Konig P Effect of inhaled beclomethasone dipropionate on hypothalamic-pituitary-adrenal axis function in children with asthma Pediatrics 1983 72(1):60 4 6866593
Gonzalez JP, Brogden RN Nedocromil sodium. A preliminary review of its pharmacodynamic and pharmacokinetic properties, and therapeutic efficacy in the treatment of reversible obstructive airways disease Drugs 1987 34(5):560 77 2826101
Gonzalez Perez-Yarza E, Mintegui J, Garmendia A, et al [The excretion of free cortisol in the urine in healthy children and in asthmatics treated with long-term inhaled glucocorticoids] An Esp Pediatr 1996 Jun 44(6):531 6 (Spanish with English abstract) 8796962
Gorski P, PaLczynski C [Clinical evaluation of budesonide forte action in patients with atopic bronchial asthma] Pol Tyg Lek 1993 48(7-8):190 2 (Polish with English abstract) 8415265
Graber MA Cromolyn use in children with asthma J Fam Pract Feb 1998 46(2):113 4
Graham VA, Milton AF, Knowles GK, et al Routine antibiotics in hospital management of acute asthma Lancet 1982 1(8269):418 20 6121090
Greco DB, Negreiros EB, Chaieb JA, et al. A multicentre double-blind group comparative trial of two dose levels of nedocromil sodium and placebo in the management of perennial extrinsic asthma. Eur J Respir Dis Suppl. 1986;147:323-6. [pmid: 3021499].
Greening AP, Ind PW, Northfield M, et al Added salmeterol versus higher-dose corticosteroid in asthma patients with symptoms on existing inhaled corticosteroid. Allen & Hanburys Limited UK Study Group Lancet 1994 344(8917):219 24 7913155
Gregson RK, Rao R, Murrills AJ, et al Effect of inhaled corticosteroids on bone mineral density in childhood asthma: comparison of fluticasone propionate with beclomethasone dipropionate Osteoporos Int 1998 8(5):418 22 9850348
Greif J, Fink G, Smorzik Y, et al Nedocromil sodium and placebo in the treatment of bronchial asthma. A multicenter, double-blind, parallel-group comparison Chest 1989 96(3):583 8 2548815
Greineder DK, Loane KC, Parks P. A randomized controlled trial of a pediatric asthma outreach program. J Allergy Clin Immunol. 1999;103:436-40. [pmid: 10069877].
Griffiths C, Feder G, Wedzicha J, et al Feasibility of spirometry and reversibility testing for the identification of patients with chronic obstructive pulmonary disease on asthma registers in general practice Respir Med 1999 93(12):903 8 10653053
Groggins RC, Milner AD, Stokes GM Bronchodilator effects of clemastine, ipratropium, bromide, and salbutamol in preschool children with asthma Arch Dis Child 1981 56(5):342 4 6455096
Grossman J Multicenter comparison of once-daily Uniphyl tablets administered in the morning or evening with baseline twice-daily theophylline therapy in patients with nocturnal asthma Am J Med 1988 85(1B):11 3 3041821
Grossman J, Faiferman I, Dubb JW, et al Results of the first U. S. double-blind, placebo-controlled, multicenter clinical study in asthma with pranlukast, a novel leukotriene receptor antagonist J Asthma 1997 34(4):321 8 9250256
Grossman J, Smith LJ, Wilson AM, et al Long-term safety and efficacy of zafirlukast in the treatment of asthma: interim results of an open-label extension trial Ann Allergy Asthma Immunol 1999 82(4):361 9 10227334
Grutters JC, Brinkman L, Aslander MM, et al Asthma therapy modulates priming-associated blood eosinophil responsiveness in allergic asthmatics Eur Respir J 1999 14(4):915 22 10573242
Guarnaccia S, Pasquali M, Acerbis F, et al [Clinico-functional evaluation of flunisolide + salbutamol combination (VAL 679/A) vs salbutamol in pediatric patients] Minerva Pediatr 1990 42(6):237 42 (Italian, with English abstract) 2250630
Part II. Acute asthma. Working Group of the South African Pulmonology Society S Afr Med J 1994 84(6):332 8 7740379
Haahtela T, Jarvinen M, Kava T, et al Comparison of a beta 2-agonist, terbutaline, with an inhaled corticosteroid, budesonide, in newly detected asthma N Engl J Med 1991 325(6):388 92 2062329
Haahtela T, Jarvinen M, Kava T, et al Effects of reducing or discontinuing inhaled budesonide in patients with mild asthma N Engl J Med 1994 331(11):700 5 8058076
Halterman JS, Aligne CA, Auinger P, et al Inadequate therapy for asthma among children in the United States Pediatrics 2000 105(1 Pt 3):272 6 10617735
Hamedani P, Hafiz S, Ali J, et al Respiratory symptoms due to Branhamella catarrhalis and other Neisseria species infections -- response to erythromycin therapy Clin Ther 1989 11(5):633 9 2509070
Hamrick M, Chambliss ML Combined oral and inhaled steroids for acute asthma J Fam Pract 1999 48(9):657 8 10498061
Hancox RJ, Cowan JO, Flannery EM, et al Randomised trial of an inhaled beta 2 agonist, inhaled corticosteroidand their combination in the treatment of asthma Thorax 1999 54(6):482 7 10335000
Harrison LI, Colice GL, Donnell D, et al Adrenal effects and pharmacokinetics of CFC-free beclomethasone dipropionate: a 14-day dose-response study J Pharm Pharmacol 1999 51(3):263 9 10344626
Hart L, Lim S, Adcock I, et al Effects of inhaled corticosteroid therapy on expression and DNA-binding activity of nuclear factor kappa B in asthma Am J Respir Crit Care Med 2000 161(1):224 31 10619824
Hasegawa T, Ishihara K, Matsumoto H, et al [Treatment modalities and hypothalamo-pituitary-adrenal (HPA) axis suppression in Japanese patients with asthma] Nihon Kyobu Shikkan Gakkai Zasshi 1994 32(8):757 62 (Japanese, with English abstract) 7807754
Hatoum HT, Schumock GT, Kendzierski DL Meta-analysis of controlled trials of drug therapy in mild chronic asthma: the role of inhaled corticosteroids Ann Pharmacother 1994 28(11):1285 89 7849344
Haughney J The role of leukotriene receptor antagonists (LTRAs) in the management of asthma Scott Med J 1999 44(2):37 8 10370978
Heard AR, Richards IJ, Alpers JH, et al Randomised controlled trial of general practice based asthma clinics Med J Aust 1999 171(2):68 71 10474578
Hedges L. Distribution theory for Glass's estimator of effect size and related estimators. J Educat Stat. 1981;6:107-128.
Hedges LV, Olkin I, eds. Statistical methods for meta-analysis. Orlando: Academic Press. 1985. [pmcid: 397982].
Hekking PR, Maesen F, Greefhorst A, et al Long-term efficacy of formoterol compared to salbutamol Lung 1990 168(Suppl):76 82 1974686
Henriksen JM, Dahl R Effects of inhaled budesonide alone and in combination with low-dose terbutaline in children with exercise-induced asthma Am Rev Respir Dis 1983 128(6):993 7 6359989
Henriksen JM, Wenzel A Effect of an intranasally administered corticosteroid (budesonide) on nasal obstruction, mouth breathing, and asthma Am Rev Respir Dis 1984 130(6):1014 8 6507997
Henry RL, Hiller EJ, Milner AD, et al Nebulised ipratropium bromide and sodium cromoglycate in the first two years of life Arch Dis Child 1984 59(1):54 7 6230059
Hermansson BA, Jenkins RJ A 4-week comparison of salmeterol and terbutaline in adult asthma Allergy 1995 50(7):551 8 8588686
Hetzel MR, Clarke JH, Gillam SJ, et al Is sodium cromoglycate effective in nocturnal asthma? Thorax 1985 40(10):793 4 3933139
Hilton S, Sibbald B, Anderson HR, et al Controlled evaluation of the effects of patient education on asthma morbidity in general practice Lancet 1986 1(8471):26 9 2867269
Hoekstra MO, Grol MH, Bouman K, et al Fluticasone propionate in children with moderate asthma Am J Respir Crit Care Med 1996 154(4 Pt 1):1039 44 8887604
Hoekstra MO, Grol MH, Hovenga H, et al Eosinophil and mast cell parameters in children with stable moderate asthma Pediatr Allergy Immunol 1998 9(3):143 9 9814729
Holgate ST. Clinical evaluation of nedocromil sodium in asthma. Eur J Respir Dis Suppl. 1986;147:149-59. [pmid: 3021489].
Holgate ST The efficacy and therapeutic position of nedocromil sodium Respir Med 1996 90(7):391 4 8796230
Hollman GA, Allen DB Overt glucocorticoid excess due to inhaled corticosteroid therapy Pediatrics 1988 81(3):452 5 3344190
Holzheimer L, Mohay H, Masters IB Educating young children about asthma: comparing the effectiveness of a developmentally appropriate asthma education video tape and picture book Child Care Health Dev 1998 24(1):85 99 9468782
Hood PP, Cotter TP, Costello JF, et al Effect of intravenous corticosteroid on ex vivo leukotriene generation by blood leucocytes of normal and asthmatic patients Thorax 1999 54(12):1075 82 10567626
Hoogsteden HC, Verhoeven GT, Lambrecht BN, et al Airway inflammation in asthma and chronic obstructive pulmonary disease with special emphasis on the antigen-presenting dendritic cell: influence of treatment with fluticasone propionate Clin Exp Allergy 1999 29(Suppl 2):116 24
Hooi LN, Yew MO Asthma control in patients attending an asthma clinic Med J Malaysia 1996 51(2):215 21
Hopp RJ, Degan JA, Phelan J, et al Cross-sectional study of bone density in asthmatic children Pediatr Pulmonol 1995 20(3):189 92 8545172
Horn CR, Clark TJ, Cochrane GM Can the morbidity of asthma be reduced by high dose inhaled therapy? A prospective study Respir Med 1990 84(1):61 6 2371424
Horn CR, Clark TJ, Cochrane GM Inhaled therapy reduces morning dips in asthma Lancet 1984 1(8387):1143 5 6144875
Hoshino M, Nakamura Y, Shin Z, et al Effects of ketotifen on symptoms and on bronchial mucosa in patients with atopic asthma Allergy 1997 52(8):814 20 9284980
Hoshino M, Takahashi M, Takai Y, et al Inhaled corticosteroids decrease subepithelial collagen deposition by modulation of the balance between matrix metalloproteinase-9 and tissue inhibitor of metalloproteinase-1 expression in asthma J Allergy Clin Immunol 1999 104(2 Pt 1):356 63 10452757
Hoskins G, Neville RG, Smith B, et al Do self-management plans reduce morbidity in patients with asthma? Br J Gen Pract 1996 46(404):169 71 8731624 1239578
Hudgel DW, Langston L Jr, Selner JC, et al Viral and bacterial infections in adults with chronic asthma Am Rev Respir Dis 1979 120(2):393 7 475158
Hughes DA, Woodcock A, Walley T Review of therapeutically equivalent alternatives to short acting beta(2) adrenoceptor agonists delivered via chlorofluorocarbon-containing inhalers Thorax 1999 54(12):1087 92 10567628
Hyland ME, Coward G, Upchurch F, et al Asthma specific quality of life scale in a study of salmeterol hydroxynaphthoate Br J Gen Pract 1991 41(346):214 5 1678957 1371662
Hyland ME, Crocker GR Validation of an asthma quality of life diary in a clinical trial Thorax 1995 50(7):724 30 7570405
Hyland ME, Kenyon CA, Jacobs PA Sensitivity of quality of life domains and constructs to longitudinal change in a clinical trial comparing salmeterol with placebo in asthmatics Qual Life Res 1994 3(2):121 6 7913852
Ignacio-Garcia JM, Gonzalez-Santos P Asthma self-management education program by home monitoring of peak expiratory flow Am J Respir Crit Care Med 1995 151(2 Pt 1):353 9 7842191
Iikura Y, Hashimoto K, Akasawa A, et al Serum theophylline concentration levels and preventative effects on exercise-induced asthma Clin Exp Allergy 1996 26(Suppl 2):38 41 8963876
Indinnimeo L, Midulla F, Hindi-Alexander M, et al Controlled studies of childhood asthma self-management in Italy using the "open airways" and "living with asthma" programs: a preliminary report Health Educ Q 1987 14(3):291 308 3654236
Grampian Asthma Study of Integrated Care (GRASSIC) BMJ 1994 308(6928):559 64 8148678
Ip M, Lam K, Yam L, et al Decreased bone mineral density in premenopausal asthma patients receiving long-term inhaled steroids Chest 1994 105(6):1722 7 8205866
Ip M, Lam K, Yam L, et al Decreased bone mineral density in premenopausal asthma patients receiving long-term inhaled steroids Chest 1994 105(6):1722 7 8205866
Janson S Action plans in asthma management. Why, when, and how? West J Med 1996 165(3):149 53 8909173 1303728
Janson S Value of home peak flow monitoring for asthma control West J Med 1995 163(4):370 1 7483598 1303137
Jarvis B, Faulds D Inhaled fluticasone propionate: a review of its therapeutic efficacy at dosages < or = 500 microg/day in adults and adolescents with mild to moderate asthma Drugs 1999 57(5):769 803 10353302
Jenkins CR Long-acting beta 2-agonists: the new symptom controllers for asthma Med J Aust 6 1999 171(5):255 8
Joad JP, Ahrens RC, Lindgren SD, et al Relative efficacy of maintenance therapy with theophylline, inhaled albuterol, and the combination for chronic asthma J Allergy Clin Immunol 1987 79(1):78 85 3805550
Johansson G, Price MJ, Sondhi S Cost-effectiveness analysis of salmeterol/fluticasone propionate 50/100mug vs fluticasone propionate 100mug in adults and adolescents with asthma III: Results Pharmacoeconomics 1999 16(Suppl 2):15 21
Johnston SL, Pattemore PK, Sanderson G, et al The relationship between upper respiratory infections and hospital admissions for asthma: a time-trend analysis Am J Respir Crit Care Med 1996 Sep 154(3 Pt 1):654 60 8810601
Jonasson G, Carlsen KH, Blomqvist P Clinical efficacy of low-dose inhaled budesonide once or twice daily in children with mild asthma not previously treated with steroids Eur Respir J 1998 12(5):1099 104 9864004
Jonasson G, Carlsen KH, Sodal A, et al Patient compliance in a clinical trial with inhaled budesonide in children with mild asthma Eur Respir J 1999 14(1):150 4 10489843
Jones AH, Langdon CG, Lee PS, et al Pulmicort Turbohaler once daily as initial prophylactic therapy for asthma Respir Med 1994 88(4):293 9 8036292
Jones KP, Mullee MA, Middleton M, et al Peak flow based asthma self-management: a randomised controlled study in general practice. British Thoracic Society Research Committee Thorax 1995 50(8):851 7 7570436
Jones PW Quality of life, symptoms and pulmonary function in asthma: long-term treatment with nedocromil sodium examined in a controlled multicentre trial. Nedocromil Sodium Quality of Life Study Group Eur Respir J 1994 7(1):55 62 8143833
Juni P, Witschi A, Bloch R, et al The hazards of scoring the quality of clinical trials for meta-analysis JAMA 1999 282(11):1054 60 10493204
Juniper EF, Johnston PR, Borkhoff CM, et al Quality of life in asthma clinical trials: comparison of salmeterol and salbutamol Am J Respir Crit Care Med 1995 151(1):66 70 7812574
Juniper EF, Kline PA, Vanzieleghem MA, et al Effect of long-term treatment with an inhaled corticosteroid (budesonide) on airway hyperresponsiveness and clinical asthma in nonsteroid-dependent asthmatics Am Rev Respir Dis 1990 142(4):832 6 2221590
Juniper EF, Svensson K, O'Byrne PM, et al Asthma quality of life during 1 year of treatment with budesonide with or without formoterol Eur Respir J 1999 14(5):1038 43 10596687
Juniper EF Quality of life questionnaires: does statistically significant = clinically important? J Allergy Clin Immunol 1998 102(1):16 7 9679842
Kakhnovskii IM, Marinin VF, Arkhipova SV, et al [Complex assessment of inhacort effectiveness in bronchial asthma] Ter Arkh 1998 70(9):73 6 (Russian, with English abstract)
Kalra S, Swystun VA, Bhagat R, et al Inhaled corticosteroids do not prevent the development of tolerance to the bronchoprotective effect of salmeterol Chest 1996 109(4):953 6 8635376
Kannisto S, Korppi M, Remes K, et al Adrenal suppression, evaluated by a low dose adrenocorticotropin test, and growth in asthmatic children treated with inhaled steroids J Clin Endocrinol Metab 2000 85(2):652 7 10690871
Kanzow G, Nowak D, Magnussen H Short term effect of methotrexate in severe steroid-dependent asthma Lung 1995 173(4):223 31 7564481
Katz RM, Rachelefsky GS, Siegel SC, et al Twice-daily beclomethasone dipropionate in the treatment of childhood asthma J Asthma 1986 23(1):1 7 2875059
Kauppinen R, Sintonen H, Vilkka V, et al Long-term (3-year) economic evaluation of intensive patient education for self-management during the first year in new asthmatics Respir Med 1999 93(4):283 9 10464894
Kavuru M, Melamed J, Gross G, et al Salmeterol and fluticasone propionate combined in a new powder inhalation device for the treatment of asthma: a randomized, double-blind, placebo-controlled trial J Allergy Clin Immunol 2000 105(6 Pt 1):1108 16 10856143
Keenan JM, Bielory L, Flamion PC, et al Nedocromil in the outpatient management of asthma Arch Fam Med 1995 4(10):835 42 discussion7551130
Kelloway JS, Wyatt RA, Adlis SA Comparison of patients' compliance with prescribed oral and inhaled asthma medications Arch Intern Med 1994 Jun 27 154(12):1349 52
Kelloway JS, Wyatt R, DeMarco J, et al Effect of salmeterol on patients' adherence to their prescribed refills for inhaled corticosteroids Ann Allergy Asthma Immunol 2000 84(3):324 8 10752917
Kelly HW Comparison of inhaled corticosteroids Ann Pharmacother 1998 32(2):220 32 9496409
Kelsen SG, Church NL, Gillman SA, et al Salmeterol added to inhaled corticosteroid therapy is superior to doubling the dose of inhaled corticosteroids: a randomized clinical trial J Asthma 1999 36(8):703 15 10609625
Kelso TM, Abou-Shala N, Heilker GM, et al Comprehensive long-term management program for asthma: effect on outcomes in adult African-Americans Am J Med Sci 1996 311(6):272 80 8659554
Kelso TM, Self TH, Rumbak MJ, et al Educational and long-term therapeutic intervention in the ED: effect on outcomes in adult indigent minority asthmatics Am J Emerg Med 1995 13(6):632 7 7575800
Kemp J, Wanderer AA, Ramsdell J, et al Rapid onset of control with budesonide Turbuhaler in patients with mild-to-moderate asthma Ann Allergy Asthma Immunol 1999 82(5):463 71 10353578
Kemp JP Study designs and challenges in clinical studies conducted in infants and children with asthma J Allergy Clin Immunol 1999 104(4 Pt 2):184 90 10518845
Kemp JP, Cook DA, Incaudo GA, et al Salmeterol improves quality of life in patients with asthma requiring inhaled corticosteroids. Salmeterol Quality of Life Study Group J Allergy Clin Immunol 1998 101(2 Pt 1):188 95 9500751
Kemp JP, DeGraff AC Jr, Pearlman DS, et al A 1-year study of salmeterol powder on pulmonary function and hyperresponsiveness to methacholine J Allergy Clin Immunol 1999 104(6):1189 97 10589000
Kemp JP, Minkwitz MC, Bonuccelli CM, et al Therapeutic effect of zafirlukast as monotherapy in steroid-naive patients with severe persistent asthma Chest 1999 115(2):336 42 10027429
Kemp JP, Skoner DP, Szefler SJ, et al Once-daily budesonide inhalation suspension for the treatment of persistent asthma in infants and young children Ann Allergy Asthma Immunol 1999 83(3):231 9 10507269
Kerstjens HA, Postma DS, van Doormaal JJ, et al Effects of short-term and long-term treatment with inhaled corticosteroids on bone metabolism in patients with airways obstruction. Dutch CNSLD Study Group Thorax 1994 49(7):652 6 8066559
Kesten S, Chapman KR, Broder I, et al A three-month comparison of twice daily inhaled formoterol versus four times daily inhaled albuterol in the management of stable asthma Am Rev Respir Dis 1991 144(3 Pt 1):622 5 1892303
Kinberg KA, Hopp RJ, Biven RE, et al Bone mineral density in normal and asthmatic children J Allergy Clin Immunol 1994 94(3 Pt 1):490 7 8083454
Kips JC, O'Connor BJ, Inman MD, et al A long-term study of the antiinflammatory effect of low-dose budesonide plus formoterol versus high-dose budesonide in asthma Am J Respir Crit Care Med 2000 161(3 Pt 1):996 1001 10712354
Kivity S, Fireman E, Greif J, et al Effect of budesonide on bronchial hyperresponsiveness and pulmonary function in patients with mild to moderate asthma Ann Allergy 1994 72(4):333 6 8154631
Klein GL, Ziering RW Diagnosis and treatment of allergic rhinitis and asthma in infancy and childhood Compr Ther 1984 10(3):26 30
Knoell DL, Pierson JF, Marsh CB, et al Measurement of outcomes in adults receiving pharmaceutical care in a comprehensive asthma outpatient clinic Pharmacotherapy 1998 18(6):1365 74 9855341
Kokubu F, Suzuki H, Sano Y, et al [Tele-medicine system for high-risk asthmatic patients] Arerugi 1999 48(7):700 12 (Japanese, with English abstract) 10481354
Konig P, Hillman L, Cervantes C, et al Bone metabolism in children with asthma treated with inhaled beclomethasone dipropionate J Pediatr 1993 122(2):219 26 8429434
Konig P. Evidence for benefits of early intervention with non-steroidal drugs in asthma. Pediatr Pulmonol Suppl. 1997;15:34-9. [pmid: 9316100].
Korhonen K, Korppi M, Remes ST, et al Lung function in school-aged asthmatic children with inhaled cromoglycate, nedocromil and corticosteroid therapy Eur Respir J 1999 13(1):82 6 10836328
Korosec M, Novak RD, Myers E, et al Salmeterol does not compromise the bronchodilator response to albuterol during acute episodes of asthma Am J Med 1999 107(3):209 13 10492312
Kos-Kudla B, Pluskiewicz W Quantitative ultrasound of the heel and serum and urinary cortisol values in assessment of long-term corticotherapy side effects in female bronchial asthma patients Ultrasound Med Biol 1997 23(9):1325 30 9428131
Kotses H, Bernstein IL, Bernstein DI, et al A self-management program for adult asthma. Part I: Development and evaluation J Allergy Clin Immunol 1995 95(2):529 40 7852669
Kotses H, Stout C, McConnaughy K, et al Evaluation of individualized asthma self-management programs J Asthma 1996 33(2):113 8 8609098
Kraemer R, Modelska K, Aebischer CC, et al. Comparison of different inhalation schedules to control childhood asthma. Agents Actions Suppl. 1993;40:211-21. [pmid: 8480551].
Krahn M Issues in the cost-effectiveness of asthma education Chest 1994 106(4 Suppl):264S 269S 7924554
Krawiec ME, Wenzel SE Inhaled nonsteroidal anti-inflammatory medications in the treatment of asthma Respir Care Clin N Am 1999 5(4):555 74 10565881
Kreisman H, Cohen C, Ghezzo H, et al Combined therapy with ipratropium and theophylline in asthma Ann Allergy 1984 52(2):90 3 6230034
Kropfelder L A case management approach to pediatric asthma Pediatr Nurs 1996 22(4):291 5 8852107
Kubly LS, McClellan MS Effects of self-care instruction on asthmatic children Issues Compr Pediatr Nurs 1984 7(2-3):121 30 6565002
Kudo K, Hojo M, Kabe J [Inhaled beclomethasone in long-term management of asthma: optimal dose and optimal duration of treatment] Nihon Kyobu Shikkan Gakkai Zasshi 1995 33(9):956 65 (Japanese, with English abstract) 8538091
Kurzawa R, Barlinski J [Better control of asthma symptoms with salmeterol] Pol Merkuriusz Lek 1997 2(11):336 9 (Polish, with English abstract) 9377685
Lagerlov P, Veninga CC, Muskova M, et al Asthma management in five European countries: doctors' knowledge, attitudes and prescribing behaviour Eur Respir J 2000 15(1):25 9 10678616
Lahdensuo A, Haahtela T, Herrala J, et al Randomised comparison of guided self management and traditional treatment of asthma over one year BMJ 1996 312(7033):748 52 8605463
Lai CK, Chan CH, Ho SS, et al Inhaled salmeterol and albuterol in asthmatic patients receiving high-dose inhaled corticosteroids Chest 1995 108(1):36 40 7606988
Lal S, Malhotra S, Gribben D, et al Nedocromil sodium: a new drug for the management of bronchial asthma Thorax 1984 39(11):809 12 6150563
Langley SJ, Masterson CM, Batty EP, et al Bronchodilator response to salbutamol after chronic dosing with salmeterol or placebo Eur Respir J 1998 11(5):1081 5 9648959
Langton Hewer S, Hobbs J, French D, et al Pilgrim's progress: the effect of salmeterol in older children with chronic severe asthma Respir Med 1995 89(6):435 40 7644775
Lau EM, Li M, Woo J, et al Bone mineral density and body composition in patients with airflow obstruction -- the role of inhaled steroid therapy, disease and lifestyle Clin Exp Allergy 1998 28(9):1066 71 9761009
Laursen LC, Eriksson G, Weeke B Enprofylline and theophylline slow-eroding tablets in the treatment of asthma: a comparison Respiration 1986 50(1):57 61
Laursen LC, Taudorf E, Gnosspelius Y, et al Long-term oral therapy of asthma with terbutaline and theophylline, alone and combined Eur J Respir Dis 1985 66(2):82 90 2578971
Laviolette M, Malmstrom K, Lu S, et al Montelukast added to inhaled beclomethasone in treatment of asthma. Montelukast/Beclomethasone Additivity Group Am J Respir Crit Care Med 1999 160(6):1862 8 10588598
Lawrence G Asthma self-management programs can reduce the need for hospital-based asthma care Respir Care 1995 40(1):39 43 10142885
LeBaron S, Zeltzer LK, Ratner P, et al A controlled study of education for improving compliance with cromolyn sodium (Intal): the importance of physician-patient communication Ann Allergy 1985 55(6):811 8 3935013
Leblanc P, Knight A, Kreisman H, et al A placebo-controlled, crossover comparison of salmeterol and salbutamol in patients with asthma Am J Respir Crit Care Med 1996 154(2 Pt 1):324 8 8756801
Leech SH, Rolston BS, Izu AE Episodic asthma as a bronchial provocation test Ann Allergy 1980 45(5):288 93 7001961
Lefcoe NM, Toogood JH, Blennerhassett G, et al The addition of an aerosol anticholinergic to an oral beta agonist plus theophylline in asthma and bronchitis. A double-blind single dose study Chest 1982 82(3):300 5 6213382
Legorreta AP, Leung KM, Berkbigler D, et al Outcomes of a population-based asthma management program: quality of life, absenteeism, and utilization Ann Allergy Asthma Immunol 2000 85(1):28 34 10923601
Lenney W, Pedersen S, Boner AL, et al Efficacy and safety of salmeterol in childhood asthma Eur J Pediatr 1995 154(12):983 90 8801107
Leru P, Rascu A, Otelea M, et al Study of fluticasone propionate efficacy in the treatment of patients with bronchial asthma not controlled by other inhaled corticosteroids Rom J Intern Med 1998 36(1-2):105 11 10660975
Levenstein JH Quality of life, symptoms and pulmonary function in asthma. A year-long multicentre double-blind trial of nedocromil sodium versus placebo Fam Pract 1991 8(4):402 3 1666057
Lewis E Setting up a school asthma clinic Prof Nurse 1999 14(12):825 7 10603891
Li JT, Ford LB, Chervinsky P, et al Fluticasone propionate powder and lack of clinically significant effects on hypothalamic-pituitary-adrenal axis and bone mineral density over 2 years in adults with mild asthma J Allergy Clin Immunol 1999 103(6):1062 8 10359887
Li JT, Goldstein MF, Gross GN, et al Effects of fluticasone propionate, triamcinolone acetonide, prednisone, and placebo on the hypothalamic-pituitary-adrenal axis J Allergy Clin Immunol 1999 103(4):622 9 10200011
Li X, Ward C, Thien F, et al An antiinflammatory effect of salmeterol, a long-acting beta(2) agonist, assessed in airway biopsies and bronchoalveolar lavage in asthma Am J Respir Crit Care Med 1999 160(5 Pt 1):1493 9 10556111
Lieu TA, Quesenberry CP Jr, Capra AM, et al Outpatient management practices associated with reduced risk of pediatric asthma hospitalization and emergency department visits Pediatrics 1997 100(3 Pt 1):334 41 9282702
Liljas B, Lahdensuo A. Is asthma self-management cost-effective?. Patient Educ Counsel. 1997;32:S97-S104.
Lim TK Asthma management: evidence based studies and their implications for cost-efficacy Asian Pac J Allergy Immunol 1999 17(3):1947 51
Limaye SR, Pillai S, Tina LU Relationship of steroid dose to degree of posterior subcapsular cataracts in nephrotic syndrome Ann Ophthalmol 1988 20(6):225 7 3408090
Lindberg M, Ahlner J, Moller M, et al Asthma nurse practice -- a resource-effective approach in asthma management Respir Med 1999 93(8):584 8 10542993
Lipworth BJ, Aziz I Bronchodilator response to albuterol after regular formoterol and effects of acute corticosteroid administration Chest 2000 117(1):156 62 10631214
Lipworth BJ Systemic adverse effects of inhaled corticosteroid therapy: A systematic review and meta-analysis Arch Intern Med 1999 159(9):941 55 10326936
Lock SH, Kay AB, Barnes NC Double-blind, placebo-controlled study of cyclosporin A as a corticosteroid-sparing agent in corticosteroid-dependent asthma Am J Respir Crit Care Med 1996 153(2):509 14 8564089
Lockey RF, DuBuske LM, Friedman B, et al Nocturnal asthma: effect of salmeterol on quality of life and clinical outcomes Chest 1999 115(3):666 73 10084473
Lofdahl CG, Reiss TF, Leff JA, et al Randomised, placebo controlled trial of effect of a leukotriene receptor antagonist, montelukast, on tapering inhaled corticosteroids in asthmatic patients BMJ 1999 319(7202):87 90 28156 10398629
Lonnerholm G, Foucard T, Lindstrom B Combined treatment with sustained-release theophylline and beta2-adrenoceptor-stimulating agents in chronic childhood asthma Br Med J (Clin Res Ed) 1981 282(6269):1029 31
Luengo M, del Rio L, Pons F, et al Bone mineral density in asthmatic patients treated with inhaled corticosteroids: a case-control study Eur Respir J 1997 10(9):2110 3 9311512
Lundback B, Pieters WR, Johansson G, et al Cost-effectiveness analyses of salmeterol/fluticasone propionate combination product and fluticasone propionate in patients with asthma I: Introduction and overview Pharmacoeconomics 1999 16(Suppl 2):1 8
Lundback B, Rawlinson DW, Palmer JB Twelve month comparison of salmeterol and salbutamol as dry powder formulations in asthmatic patients. European Study Group Thorax 1993 48(2):148 53 8493629
Macarthur C, Calpin C, Parkin PC, et al Factors associated with pediatric asthma readmissions J Allergy Clin Immunol 1996 98(5 Pt 1):992 3 8939164
MacKenzie C Effects of inhaled corticosteroids on growth J Allergy Clin Immunol 1998 101(4 Pt 2):S451 5 9563371
MacKenzie CA, Tsanakas J, Tabachnik E, et al An open study to assess the long-term safety of fluticasone propionate in asthmatic children. International Study Group Br J Clin Pract 1994 48(1):15 8 8179974
MacKenzie CA, Weinberg EG, Tabachnik E, et al A placebo controlled trial of fluticasone propionate in asthmatic children Eur J Pediatr 1993 152(10):856 60 8223792
Madge P, McColl J, Paton J Impact of a nurse-led home management training programme in children admitted to hospital with acute asthma: a randomised controlled study Thorax 1997 52(3):223 8 9093336
Maha P, Okamoto LJ, Schaberg A, et al Impact of fluticasone propionate powder on health-related quality of life in patients with moderate asthma J Asthma 1997 34(3):227 34 9168850
Maha P, Pearlman D, Okamoto L The effect of fluticasone propionate on functional status and sleep in children with asthma and on the quality of life of their parents J Allergy Clin Immunol 1998 102(1):19 23 9679843
Majima T, Katoh H, Yoshida N, et al [Effects of high doses of beclomethasone dipropionate in bronchial asthma] Arerugi 1993 42(4):534 40 (Japanese, with English abstract) 8323451
Maljanian R, Wolf S, Goethe J, et al An inner-city asthma disease management initiative: Results of an outcomes evaluation Dis Manage Health Outcomes 1999 5(5):285 93
Malmstrom K, Rodriguez-Gomez G, Guerra J, et al Oral montelukast, inhaled beclomethasone, and placebo for chronic asthma. A randomized, controlled trial. Montelukast/Beclomethasone Study Group Ann Intern Med 1999 130(6):487 95 10075616
Malmstrom K, Sorva R, Silvasti M Application and efficacy of the multi-dose powder inhaler, Easyhaler, in children with asthma Pediatr Allergy Immunol 1999 10(1):66 70 10410920
Malo JL, Cartier A, Ghezzo H, et al Skin bruising, adrenal function and markers of bone metabolism in asthmatics using inhaled beclomethasone and fluticasone Eur Respir J 1999 13(5):993 8 10414395
Malo JL, L'Archeveque J, Trudeau C, et al Should we monitor peak expiratory flow rates or record symptoms with a simple diary in the management of asthma? J Allergy Clin Immunol 1993 91(3):702 9 8454792
Manicatide MA, Nicolaescu VV, Stroescu V, et al Dexamethasone-isonicotinate aerosol in the long-term treatment of steroid-dependent asthmatic children Med Interne 1980 18(2):203 10 7394460
Markham A, Faulds D Montelukast Drugs 1998a 56(2):251 6 9711449
Markham A, Faulds D Theophylline: a review of its potential steroid sparing effects in asthma Drugs 1998b 56(6):1081 91 9878995
Martin TG, Elenbaas RM, Pingleton SH Failure of peak expiratory flow rate to predict hospital admission in acute asthma Ann Emerg Med 1982 11(9):466 70 7114591
Maslennikova GYA, Morosova ME, Salman NV, et al Asthma education programme in Russia: educating patients Patient Educ Couns 1998 33(2):113 27 9732652
Mayo PH, Richman J, Harris HW Results of a program to reduce admissions for adult asthma Ann Intern Med 1990 112(11):864 71 2344111
McFadden ER, Casale TB, Edwards TB, et al Administration of budesonide once daily by means of turbuhaler to subjects with stable asthma J Allergy Clin Immunol 1999 104(1):46 52 10400838
McIntosh K, Ellis EF, Hoffman LS, et al The association of viral and bacterial respiratory infections with exacerbations of wheezing in young asthmatic children J Pediatr 1973 Apr 82(4):578 90 4349062
McIvor RA, Pizzichini E, Turner MO, et al Potential masking effects of salmeterol on airway inflammation in asthma Am J Respir Crit Care Med 1998 158(3):924 30 9731027
McNabb WL, Wilson-Pessano SR, Jacobs AM Critical self-management competencies for children with asthma J Pediatr Psychol 1986 11(1):103 17 3958864
McPeek B, Gilbert JP, Mosteller F The clinician's responsibility for helping to improve the treatment of tomorrow's patients N Engl J Med 1980 302(11):630 1 6986022
Medici TC, Grebski E, Hacki M, et al Effect of one year treatment with inhaled fluticasone propionate or beclomethasone dipropionate on bone density and bone metabolism: arandomised parallel group study in adult asthmatic subjects Thorax 2000 55(5):375 82 10770818
Meeran K, Hattersley A, Burrin J, et al Oral and inhaled corticosteroids reduce bone formation as shown by plasma osteocalcin levels Am J Respir Crit Care Med 1995 151(2 Pt 1):333 6 7842187
Mellon M Efficacy of budesonide inhalation suspension in infants and young children with persistent asthma. Budesonide Inhalation Suspension Study Group J Allergy Clin Immunol 1999 104(4 Pt 2):191 9 10518846
Meltzer EO, Kemp JP, Orgel HA, et al Flunisolide aerosol for treatment of severe, chronic asthma in steroid-independent children Pediatrics 1982 69(3):340 5 7063290
Meltzer EO, Orgel HA, Ellis EF, et al Long-term comparison of three combinations of albuterol, theophylline, and beclomethasone in children with chronic asthma J Allergy Clin Immunol 1992 90(1):2 11 1629506
"Dear Healthcare Professional" letter on Singulair® and Churg-Strauss syndrome. December 1998. West Point, PA.
Singulair® (montelukast sodium) tablets and chewable tablets prescribing information. Whitehouse Station, NJ. 2000 March. [pmcid: 384376].
Merkus PJ, van Essen-Zandvliet EE, Duiverman EJ, et al Long-term effect of inhaled corticosteroids on growth rate in adolescents with asthma Pediatrics 1993 91(6):1121 6 8502513
Mesters I, Meertens R, Kok G, et al Effectiveness of a multidisciplinary education protocol in children with asthma (0-4 years) in primary health care J Asthma 1994 31(5):347 59 7928930
Mikhail JR, Daly S Is twice daily prophylaxis with salbutamol and beclomethasone dipropionate effective in the management of asthma? Pharmatherapeutica 1986 4(10):648 54 3602016
Miles JF, Tunnicliffe W, Cayton RM, et al Potential effects of correction of inaccuracies of the mini-Wright peak expiratory flow meter on the use of an asthma self-management plan Thorax 1996 51(4):403 6 8733493
Minoguchi K, Kohno Y, Oda N, et al Effect of theophylline withdrawal on airway inflammation in asthma Clin Exp Allergy 1998 28(Suppl 3):57 63
Misson J, Clark W, Kendall MJ Therapeutic advances: leukotriene antagonists for the treatment of asthma J Clin Pharm Ther 1999 24(1):17 22 10319903
Mitchell EA, Bland JM, Thompson JM Risk factors for readmission to hospital for asthma in childhood Thorax 1994 49(1):33 6 8153938
Mitchell P, Cumming RG, Mackey DA Inhaled corticosteroids, family history, and risk of glaucoma Ophthalmology 1999 106(12):2301 6 10599661
Moher D, Pham B, Jones A, et al Does quality of reports of randomized controlled trials affect estimates of intervention efficacy reported in meta-analyses? Lancet 1998 352(9128):609 13 9746022
Morlion B, Verbandt Y, Paiva M, et al A telemanagement system for home follow-up of respiratory patients IEEE Eng Med Biol Mag 1999 18(4):71 9 10429904
Muhlhauser I, Richter B, Kraut D, et al Evaluation of a structured treatment and teaching programme on asthma J Intern Med 1991 230(2):157 164 1865168
Mulrow CD, Oxman AD, editors. Cochrane Collaboration Handbook. Available in the Cochrane Library [database on disk and CD-ROM]. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997.
Murphy S, Kelly HW Cromolyn sodium: a review of mechanisms and clinical use in asthma Drug Intell Clin Pharm 1987 21(1 Pt 1):22 35 3102198
Murray JJ, Church NL, Anderson WH, et al Concurrent use of salmeterol with inhaled corticosteroids is more effective than inhaled corticosteroid dose increases Allergy Asthma Proc 1999 20(3):173 80 10389550
Nassif E, Weinberger M, Sherman B, et al Extrapulmonary effects of maintenance corticosteroid therapy with alternate-day prednisone and inhaled beclomethasone in children with chronic asthma J Allergy Clin Immunol 1987 80(4):518 29 3668116
Nassif EG, Weinberger M, Thompson R, et al The value of maintenance theophylline in steroid-dependent asthma N Engl J Med 1981 304(2):71 5 7003383
Nathan RA, Bernstein IL, Bronsky EA, et al Comparison of the bronchodilator effects of nebulized bitolterol mesylate and isoproterenol hydrochloride in steroid-dependent asthma J Allergy Clin Immunol 1987 79(5):822 9 3571773
Nathan RA, Bernstein JA, Bielory L, et al Zafirlukast improves asthma symptoms and quality of life in patients with moderate reversible airflow obstruction J Allergy Clin Immunol 1998 102(6 Pt 1):935 42 9847434
Nathan RA, Minkwitz MC, Bonuccelli CM Two first-line therapies in the treatment of mild asthma: use of peak flow variability as a predictor of effectiveness Ann Allergy Asthma Immunol 1999 82(5):497 503 10353583
Nathan RA, Pinnas JL, Schwartz HJ, et al A six-month, placebo-controlled comparison of the safety and efficacy of salmeterol or beclomethasone for persistent asthma Ann Allergy Asthma Immunol 1999 82(6):521 9 10400478
Nathan RA, Seltzer JM, Kemp JP, et al Safety of salmeterol in the maintenance treatment of asthma Ann Allergy Asthma Immunol 1995 75(3):243 8 7552926
Expert panel report: guidelines for the diagnosis and management of asthma. Bethesda MD: National Institutes of Health; 1992. NIH Publication No 92-3091.
Expert panel report 2: guidelines for the diagnosis and management of asthma. Bethesda MD: National Institutes of Health; 1997. NIH Publication No. 97-4051.
Nayak AS, Banov C, Corren J et al Once-daily mometasone furoate dry powder inhaler in the treatment of patients with persistent asthma Ann Allergy Asthma Immunol 2000 84(4):417 24 10795650
Nelson HS Beta-adrenergic bronchodilators N Engl J Med 1995 333(8):499 506 7623883
Nelson H, Kemp JP, Bieler S, et al Comparative efficacy and safety of albuterol sulfate Spiros inhaler and albuterol metered-dose inhaler in asthma Chest 1999 115(2):329 35 10027428
Nelson HS, Busse WW, deBoisblanc BP, et al Fluticasone propionate powder: oral corticosteroid-sparing effect and improved lung function and quality of life in patients with severe chronic asthma J Allergy Clin Immunol 1999 103(2 Pt 1):267 75 9949318
Neri M, Migliori GB, Spanevello A, et al Economic analysis of two structured treatment and teaching programs on asthma Allergy 1996 51(5):313 9 8836335
Newhouse M, Knight A, Wang S, et al Comparison of efficacy and safety between flunisolide/AeroChamber and budesonide/turbuhaler in patients with moderate asthma. AER-MD-04 Study Group Ann Allergy Asthma Immunol 2000 84(3):313 9 10752915
Nguyen BP, Wilson SR, German DF Patients' perceptions compared with objective ratings of asthma severity Ann Allergy Asthma Immunol 1996 77(3):209 15 8814046
Nicholson KG, Kent J, Ireland DC Respiratory viruses and exacerbations of asthma in adults BMJ 1993 Oct 16 307(6910):982 6
Nicolaizik WH, Marchant JL, Preece MA, et al Endocrine and lung function in asthmatic children on inhaled corticosteroids Am J Respir Crit Care Med 1994 150(3):624 8 8087329
Nielsen LP, Pedersen B, Faurschou P, et al Salmeterol reduces the need for inhaled corticosteroid in steroid-dependent asthmatics Respir Med 1999 93(12):863 8 10653047
Ninan TK, Reid IW, Carter PE, et al Effects of high doses of inhaled corticosteroids on adrenal function in children with severe persistent asthma Thorax 1993 48(6):599 602 8346487
Ninan TK, Russell G Asthma, inhaled corticosteroid treatment, and growth Arch Dis Child 1992 67(6):703 5 1626989
Niu CK, Huang SC, Huang CB Effect of short-course budesonide on the bone turnover of asthmatic children Pediatr Pulmonol 1998 26(4):290 2 9811081
Nizankowska E, Soja J, Pinis G, et al Treatment of steroid-dependent bronchial asthma with cyclosporin Eur Respir J 1995 8(7):1091 9 7589392
Noonan M, Chervinsky P, Busse WW, et al Fluticasone propionate reduces oral prednisone use while it improves asthma control and quality of life Am J Respir Crit Care Med 1995 152(5 Pt 1):1467 73 7582278
Noonan M, Chervinsky P, Busse WW, et al Fluticasone propionate reduces oral prednisone use while it improves asthma control Am J Ther 1996 3(7):497 505 11862281
Norjavaara E, Gerhardsson De Verdier M, Lindmark B Reduced height in swedish men with asthma at the age of conscription for military service J Pediatrics 2000 137(1):25 9
Nowacka K, Lorenc RS Bone mineral density in asthmatic children Int Rev Allergol Clin Immunol 1998 4(1):21 2, 24
Nuhoglu Y, Dai A, Barlan IB, et al Efficacy of aminophylline in the treatment of acute asthma exacerbation in children Ann Allergy Asthma Immunol 1998 80(5):395 8 9609609
O'Byrne PM Effects of inhaled formoterol and budesonide in reducing asthma exacerbations Eur Respir Rev 1998 8(55):221 4
Odhiambo JA, Nganga LW, Gikonyo BM Efficacy and safety of inhaled Salmeterol (Serevent) as maintenance therapy for asthma in Nairobi East Afr Med J 1994 71(2):88 92 7925051
O'Donnell D, Cotter P, Kennedy N, et al An open steady-state pharmacokinetic study to compare Pro-Vent and Phyllocontin in asthmatic patients Br J Clin Pract 1986 40(8):318 22 3741751
Ogawa C, Sano Y [Long-term effects of inhaled beta 2-agonists on bronchial hyperresponsiveness in asthmatics] Nippon Rinsho 1996 54(11):3081 6 (Japanese, with English abstract) 8950959
Ogirala RG, Sturm TM, Aldrich TK, et al Single, high-dose intramuscular triamcinolone acetonide versus weekly oral methotrexate in life-threatening asthma: a double-blind study Am J Respir Crit Care Med 1995 152(5 Pt 1):1461 6 7582277
O'Leary PC, McIntyre E, Feddema P, et al Effect of asthma treatment on urinary growth hormone excretion in children Pediatr Pulmonol 1996 21(6):361 6 8927462
Olivieri D, Chetta A, Del Donno M, et al Effect of short-term treatment with low-dose inhaled fluticasone propionate on airway inflammation and remodeling in mild asthma: a placebo-controlled study Am J Respir Crit Care Med 1997 155(6):1864 71 9196087
Orefice U, Struzzo P, Dorigo R, et al Long-term treatment with sodium cromoglycate, nedocromil sodium and beclomethasone dipropionate reduces bronchial hyperresponsiveness in asthmatic subjects Respiration 1992 59(2):97 101 1320287
Osman LM, Abdalla MI, Beattie JA, et al Reducing hospital admission through computer supported education for asthma patients. Grampian Asthma Study of Integrated Care (GRASSIC) BMJ 1994 308(6928):568 71 8093148
Osterman K, Carlholm M, Ekelund J, et al Effect of 1 year daily treatment with 400 microg budesonide (Pulmicort Turbuhaler) in newly diagnosed asthmatics Eur Respir J 1997 10(10):2210 5 9387942
Overbeek SE, Kerstjens HA, Bogaard JM, et al Is delayed introduction of inhaled corticosteroids harmful in patients with obstructive airways disease (asthma and COPD)? The Dutch CNSLD Study Group. The Dutch Chronic Nonspecific Lung Disease Study Groups Chest 1996 110(1):35 41 8681660
Overbeek SE, Rijnbeek PR, Vons C, et al Effects of fluticasone propionate on methacholine dose-response curves in nonsmoking atopic asthmatics Eur Respir J 1996 9(11):2256 62 8947069
Paananen M, Karakorpi T, Kreus KE. Withdrawal of inhaled corticosteroid under cover of nedocromil sodium. Eur J Respir Dis Suppl. 1986;147:330-5. [pmid: 3021500].
Paggiaro PL, Giannini D, Bacci E, et al Clinical effects of salmeterol: A new long-acting beta 2-agonist Eur Respir Rev 1993 3(14):391 5
Paggiaro PL, Giannini D, Di Franco A, et al Comparison of inhaled salmeterol and individually dose-titrated slow-release theophylline in patients with reversible airway obstruction. European Study Group Eur Respir J 1996 9(8):1689 95 8866596
Palmer JB, Stuart AM, Shepherd GL, et al Inhaled salmeterol in the treatment of patients with moderate to severe reversible obstructive airways disease -- a 3-month comparison of the efficacy and safety of twice-daily salmeterol (100 micrograms) with salmeterol (50 micrograms) Respir Med 1992 86(5):409 17 1361068
Palmqvis M, Price MJ, Sondhi S Cost-effectiveness analysis of salmeterol/fluticasone propionate 50/250mug vs fluticasone propionate 250mug in adults and adolescents with asthma IV: Results Pharmacoeconomics 1999 16(Suppl 2):23 8
Partridge MR Asthma: guided self-management Br Med J 1994 308(6928):547 8 8148674
Pauwels RA, Lofdahl CG, Postma DS, et al Effect of inhaled formoterol and budesonide on exacerbations of asthma. Formoterol and Corticosteroids Establishing Therapy (FACET) International Study Group N Engl J Med 1997 337(20):1405 11 9358137
Pauwels RA, Yernault JC, Demedts MG, et al Safety and efficacy of fluticasone and beclomethasone in moderate to severe asthma. Belgian Multicenter Study Group Am J Respir Crit Care Med 1998 157(3 Pt 1):827 32 9517598
Thoracic Society of Australia and New Zealand Med J Aust 1996 164(12):727 30 8668080
Pearlman DS, Liddle R Controlling asthma symptoms: Salmeterol compared with salbutamol in large-scale multicentre studies Eur Respir Rev 1994 4(21):301 5
Pearlman DS, Noonan MJ, Tashkin DP, et al Comparative efficacy and safety of twice daily fluticasone propionate powder versus placebo in the treatment of moderate asthma Ann Allergy Asthma Immunol 1997 78(4):356 62 9109702
Pearlman DS, Stricker W, Weinstein S, et al Inhaled salmeterol and fluticasone: a study comparing monotherapy and combination therapy in asthma Ann Allergy Asthma Immunol 1999 82(3):257 65 10094216
Pearlman DS Long-acting beta 2-agonist salmeterol compared with albuterol in maintenance asthma therapy Ann Allergy Asthma Immunol 1995 75(2):180 4 7648385
Peden DB, Berger WE, Noonan MJ, et al Inhaled fluticasone propionate delivered by means of two different multidose powder inhalers is effective and safe in a large pediatric population with persistent asthma J Allergy Clin Immunol 1998 102(1):32 8 9679845
Pedersen S Treatment of nocturnal asthma in children with a single dose of sustained-release theophylline taken after supper Clin Allergy 1985 15(1):79 85 3884180
Pennings HJ, Borm PJ, Evelo CT, et al Changes in levels of catalase and glutathione in erythrocytes of patients with stable asthma, treated with beclomethasone dipropionate Eur Respir J 1999 13(6):1260 6 10445599
Persaud DI, Barnett SE, Weller SC, et al An asthma self-management program for children, including instruction in peak flow monitoring by school nurses J Asthma 1996 33(1):37 43 8621369
Persson G, Baas A, Knight A, et al One month treatment with the once daily oral beta 2-agonist bambuterol in asthmatic patients Eur Respir J 1995 8(1):34 9 7744191
Petersen W, Karup-Pedersen F, Friis B, et al Sodium cromoglycate as a replacement for inhaled corticosteroids in mild-to-moderate childhood asthma Allergy 1996 51(12):870 5 9020413
Phillip M, Aviram M, Leiberman E, et al Integrated plasma cortisol concentration in children with asthma receiving long-term inhaled corticosteroids Pediatr Pulmonol 1992 12(2):84 9 1315017
Pluskiewicz W, Rogala E [Secondary osteoporosis in patients with steroid-dependent asthma] Przegl Lek 1997 54(1):21 4 (Polish, with English abstract) 9190629
Pocock SJ, Elbourne DR Randomized trials or observational tribulations? N Engl J Med 2000 342(25):1907 9 10861329
Podell RN National guidelines for the management of asthma in adults Am Fam Physician 1992 46(4):1189 96 1357947
Ponticiello A, Vatrella A, Parrella R, et al Inhaled beclomethasone dipropionate (BDP) prevents seasonal changes in atopic asthmatics Monaldi Arch Chest Dis 1997 52(2):112 7 9203805
Pover GM, Greger G, Kaspar P Comparison of the effects of sequential or simultaneous administration of salbutamol and beclomethasone dipropionate Respiration 1986 50(2):83 7
Prahl P, Jensen T, Bjerregaard-Andersen H Adrenocortical function in children on high-dose steroid aerosol therapy. Results of serum cortisol, ACTH stimulation test and 24 hour urinary free cortical excretion Allergy 1987 42(7):541 4 3688377
Premaratne UN, Sterne JA, Marks GB, et al Clustered randomised trial of an intervention to improve the management of asthma: Greenwich asthma study BMJ 1999 318(7193):1251 5 27864 10231256
Price D Tolerability of montelukast Drugs 2000 59(Suppl 1):35 42 10741881
Price JF, Russell G, Hindmarsh PC, et al Growth during one year of treatment with fluticasone propionate or sodium cromoglycate in children with asthma Pediatr Pulmonol 1997 24(3):178 86 9330414
Price JF, Weller PH Comparison of fluticasone propionate and sodium cromoglycate for the treatment of childhood asthma (an open parallel group study) Respir Med 1995 89(5):363 8 7638372
Priftis K, Everard ML, Milner AD Unexpected side-effects of inhaled steroids: a case report Eur J Pediatr 1991 150(6):448 9 1904030
Priftis K, Milner AD, Conway E, et al Adrenal function in asthma Arch Dis Child 1990 65(8):838 40 2400219
Quezada A, Mallol J, Moreno J, et al Effect of different inhaled bronchodilators on recovery from methacholine-induced bronchoconstriction in asthmatic children Pediatr Pulmonol 1999 28(2):125 9 10423312
Qureshi F, Pestian J, Davis P, et al Effect of nebulized ipratropium on the hospitalization rates of children with asthma N Engl J Med 1998 339(15):1030 5 9761804
Rachelefsky G, Rohr A, Katz R, et al Sustained-release theophylline preparations in asthmatic children. A short-term comparison of two products and the relationship of serum theophylline levels and pulmonary function changes Am J Dis Child 1986 140(4):336 40 3513540
Rachelefsky GS, Wo J, Adelson J, et al Behavior abnormalities and poor school performance due to oral theophylline use Pediatrics 1986 78(6):1133 8 3786037
Rakos RF, Grodek MV, Mack KK The impact of a self-administered behavioral intervention program on pediatric asthma J Psychosom Res 1985 29(1):101 8 3920390
Ramage L, Cree IA, Dhillon DP Comparison of salmeterol with placebo in mild asthma: effect on peripheral blood phagocyte function and cytokine levels Int Arch Allergy Immunol 1994 105(2):181 4 7920018
Ramsdell JW, Fish L, Graft D, et al A controlled trial of twice daily triamcinolone oral inhaler in patients with mild-to-moderate asthma Ann Allergy Asthma Immunol 1998 80(5):385 90 9609607
Ratima MM, Fox C, Fox B, et al Long-term benefits for Maori of an asthma self-management program in a Maori community which takes a partnership approach Australia NZ J Pub Health 1999 23(6):601 5
Rebuck AS, Gent M, Chapman KR Anticholinergic and sympathomimetic combination therapy of asthma J Allergy Clin Immunol 1983 71(3):317 23 6219156
Rebuck AS, Kesten S, Boulet LP, et al A 3-month evaluation of the efficacy of nedocromil sodium in asthma: a randomized, double-blind, placebo-controlled trial of nedocromil sodium conducted by a Canadian multicenter study group J Allergy Clin Immunol 1990 85(3):612 7 2155958
Redline S, Wright EC, Kattan M, et al Short-term compliance with peak flow monitoring: results from a study of inner city children with asthma Pediatr Pulmonol 1996 21(4):203 10 9121848
Reed CE The natural history of asthma in adults: the problem of irreversibility J Allergy Clin Immunol 1999 103(4):539 47 10199998
Reed CE, Offord KP, Nelson HS, et al Aerosol beclomethasone dipropionate spray compared with theophylline as primary treatment for chronic mild-to-moderate asthma. The American Academy of Allergy, Asthma and Immunology Beclomethasone Dipropionate-Theophylline Study Group J Allergy Clin Immunol 1998 101(1 Pt 1):14 23 9449495
Reijonen TM, Korppi M One-year follow-up of young children hospitalized for wheezing: the influence of early anti-inflammatory therapy and risk factors for subsequent wheezing and asthma Pediatr Pulmonol 1998 26(2):113 9 9727762
Reinert P, Narcy P, Paliwoda A, et al [Evaluation of tixocortol pivalate-neomycin combination versus ++a placebo excipient in acute rhinopharyngitis in children] Ann Pediatr (Paris) 1991 38(7):503 8 (French, with English abstract) 358317 1952710
Reinus JF, Persky S, Burkiewicz JS, et al Severe liver injury after treatment with the leukotriene receptor antagonist zafirlukast Ann Intern Med 2000 133(12):964 968 11119397
Reiss TF, Altman LC, Chervinsky P, et al Effects of montelukast (MK-0476), a new potent cysteinyl leukotriene (LTD4) receptor antagonist, in patients with chronic asthma J Allergy Clin Immunol 1996 98(3):528 34 8828530
Reiss TF, Chervinsky P, Dockhorn RJ, et al Montelukast, a once-daily leukotriene receptor antagonist, in the treatment of chronic asthma: a multicenter, randomized, double-blind trial. Montelukast Clinical Research Study Group Arch Intern Med 1998 158(11):1213 20 9625400
Reiss TF, Sorkness CA, Stricker W, et al Effects of montelukast (MK-0476); a potent cysteinyl leukotriene receptor antagonist, on bronchodilation in asthmatic subjects treated with and without inhaled corticosteroids Thorax 1997 52(1):45 8 9039239
Ribeiro LB Budesonide: safety and efficacy aspects of its long-term use in children Pediatr Allergy Immunol 1993 4(2):73 8 8353649
Richardson CR Leukotriene receptor antagonists versus inhaled steroids in asthma J Fam Pract 1999 48(7):495 6 10428241
Ringdal N, Lundback B, Alton M, et al Comparable effects of inhaled fluticasone propionate and budesonide onthe hpa-axis in adult asthmatic patients Respir Med 2000 94(5):482 9 10868712
Rivington RN, Boulet LP, Cote J, et al Efficacy of Uniphyl, salbutamol, and their combination in asthmatic patients on high-dose inhaled steroids Am J Respir Crit Care Med 1995 151(2 Pt 1):325 32 7842186
Roberts JR, Desai HI, Gillespie CA, et al Sustained-release terbutaline vs sustained-release theophylline in young patients with asthma Am J Dis Child 1986 140(7):650 4 3717101
Rodbard C, Read M Involving patients in care Community Nurse 1996 2(2):
Rodrigo G, Rodrigo C, Burschtin O A meta-analysis of the effects of ipratropium bromide in adults with acute asthma Am J Med 1999 107(4):363 70 10527039
Rodrigo G, Rodrigo C Inhaled flunisolide for acute severe asthma Am J Respir Crit Care Med 1998 157(3 Pt 1):698 703 9517578
Rodrigo G, Rodrigo C Corticosteroids in the emergency department therapy of acute adult asthma: an evidence-based evaluation Chest 1999 116(2):285 95 10453853
Ronchetti R, Indinnimeo L, Bonci E, et al Asthma self-management programmes in a population of Italian children: a multicentric study. Italian Study Group on Asthma Self-Management Programmes Eur Respir J 1997 10(6):1248 53 9192924
Rosenthal R Combining results of independent studies Psych Bull 1978 85(1):185 93
Rosenthal R. "Parametric measures of effect size,". In The Handbook of Research Synthesis, Russell Sage Foundation, New York, 1994.
Rosenthal R. Meta-Analytic Procedures for Social Research, Beverly Hills: Sage Publications, 1984.
Rosenthal RR, Busse WW, Kemp JP, et al Effect of long-term salmeterol therapy compared with as-needed albuterol use on airway hyperresponsiveness Chest 1999 116(3):595 602 10492259
Ross RN, Morris M, Sakowitz SR, et al Cost-effectiveness of including cromolyn sodium in the treatment program for asthma: a retrospective, record-based study Clin Ther 1988 10(2):188 203 3152585
Rubin AE, Alroy G, Spitzer S The treatment of asthma in adults using sodium cromoglycate pressurized aerosol: a double-blind controlled trial Curr Med Res Opin 1983 8(8):553 8 6418441
Rubinfeld AR, Pain MC Perception of asthma Lancet 1976 1(7965):882 4 58147
Ruffin R, Alpers JH, Kroemer DK, et al. A 4-week Australian multicentre study of nedocromil sodium in asthmatic patients. Eur J Respir Dis Suppl. 1986;147:336-9. [pmid: 3021501].
Ruffin RE, Pierce RJ. Peak flow monitoring - which asthmatics, when, and how?. Aust N Z J Med. 1994;24:519-520. [pmid: 7848155].
Ruhle KH, Dorow P, Schmitz-Schumann H Effects of a combined treatment theophylline and tulobuterol on nocturnal chronic asthma Lung 1990 168(Suppl):192 3 1974676
Russell G, Williams DA, Weller P, et al Salmeterol xinafoate in children on high dose inhaled steroids Ann Allergy Asthma Immunol 1995 75(5):423 8 7583864
Russell G Fluticasone propionate in children Respir Med 1994 88(Suppl A):25 9 7972989
Rutten-van Molken MP, Van Doorslaer EK, Jansen MC, et al Costs and effects of inhaled corticosteroids and bronchodilators in asthma and chronic obstructive pulmonary disease Am J Respir Crit Care Med 1995 151(4):975 82 7697275
Sachs AP, Koeter GH, Groenier KH, et al Changes in symptoms, peak expiratory flow, and sputum flora during treatment with antibiotics of exacerbations in patients with chronic obstructive pulmonary disease in general practice Thorax 1995 50(7):758 63 7570411
Sakai H, Shimoda T, Matsuo N, et al Comparison of three treatment regimens of inhaled sodium cromoglycate in the management of adult patients with severe, steroid-dependent asthma Ann Allergy Asthma Immunol 1998 80(6):494 8 9647273
Scarfone RJ, Loiselle JM, Wiley JF 2nd, et al Nebulized dexamethasone versus oral prednisone in the emergency treatment of asthmatic children Ann Emerg Med 1995 26(4):480 6 7574132
Schuh S, Johnson DW, Callahan S, et al Efficacy of frequent nebulized ipratropium bromide added to frequent high-dose albuterol therapy in severe childhood asthma J Pediatr 1995 126(4):639 45 7699549
Schulz KF, Chalmers I, Hayes RJ, et al Empirical evidence of bias: dimensions of methodological quality associated with estimates of treatment effects in controlled trials JAMA 1995 273(5):408 12 7823387
Schwartz HJ, Petty T, Dube LM, et al A randomized controlled trial comparing zileuton with theophylline in moderate asthma. The Zileuton Study Group Arch Intern Med 1998 158(2):141 8 9448552
Scott MB, Skoner DP Short-term and long-term safety of budesonide inhalation suspension in infants and young children with persistent asthma J Allergy Clin Immunol 1999 104(4 Pt 2):200 9 10518847
Sears MR, Taylor DR, Print CG, et al Increased inhaled bronchodilator vs increased inhaled corticosteroid in the control of moderate asthma Chest 1992 102(6):1709 15 1446477
Selby C, Engleman HM, Fitzpatrick MF, et al Inhaled salmeterol or oral theophylline in nocturnal asthma? Am J Respir Crit Care Med 1997 155(1):104 8 9001297
Selcow JE, Mendelson LM, Rosen JP Clinical benefits of cromolyn sodium aerosol (MDI) in the treatment of asthma in children Ann Allergy 1989 62(3):195 9 2493756
Selroos O, Pietinalho A, Lofroos AB, et al Effect of early vs late intervention with inhaled corticosteroids in asthma Chest 1995 108(5):1228 34 7587421
Senderovitz T, Vestbo J, Frandsen J, et al Steroid reversibility test followed by inhaled budesonide or placebo in outpatients with stable chronic obstructive pulmonary disease. The Danish Society of Respiratory Medicine Respir Med 1999 93(10):715 8 10581660
Senderovitz T, Vestbo J, Frandsen J, et al Steroid reversibility test followed by inhaled budesonide or placebo in outpatients with stable chronic obstructive pulmonary disease. The Danish Society of Respiratory Medicine Respir Med 1999 93(10):715 8 10581660
Senn S The AB/BA crossover: past, present and future? Stat Methods Med Res 1994 3(4):303 24 7889225
Shapiro G, Bronsky EA, LaForce CF, et al Dose-related efficacy of budesonide administered via a dry powder inhaler in the treatment of children with moderate to severe persistent asthma J Pediatr 1998 132(6):976 82 9627589
Shapiro G, Lumry W, Wolfe J, et al Combined salmeterol 50 microg and fluticasone propionate 250 microg in the diskus device for the treatment of asthma Am J Respir Crit Care Med 2000 161(2 Pt 1):527 34 10673196
Shapiro G, Mendelson L, Kraemer MJ, et al Efficacy and safety of budesonide inhalation suspension (Pulmicort Respules) in young children with inhaled steroid-dependent, persistent asthma J Allergy Clin Immunol 1998 102(5):789 96 9819296
Shapiro GG, Eggleston PA, Pierson WE, et al Double blind study of the effectiveness of a broad spectrum antibiotic in status asthmaticus Pediatrics 1974 53(6):867 72 4598933
Shapiro GG, Sharpe M, DeRouen TA, et al Cromolyn versus triamcinolone acetonide for youngsters with moderate asthma J Allergy Clin Immunol 1991 88(5):742 8 1955633
Sharek PJ, Bergman DA The effect of inhaled steroids on the linear growth of children with asthma: a meta-analysis Pediatrics 2000 106(1):
Sheffer AL, LaForce C, Chervinsky P, et al Fluticasone propionate aerosol: efficacy in patients with mild to moderate asthma. Fluticasone Propionate Asthma Study Group J Fam Pract 1996 42(4):369 75 8627205
Sheikh S, Goldsmith LJ, Howell L, et al Comparison of the efficacy of inhaled fluticasone propionate, 880 microg/day, with flunisolide, 1500 microg/day, in moderate-to-severe persistent asthma Ann Allergy Asthma Immunol 1999 83(4):300 4 10541421
Shen X, Niu SF, Cai YY [A clinical trial of treating asthma of moderate severity with beclomethasone dipropionate aerosol] Chung Hua Nei Ko Tsa Chih 1991 30(9):536 8, 593 (Chinese with English abstract) 1806334
Sherman J, Hutson A, Baumstein S, et al Telephoning the patient's pharmacy to assess adherence with asthma medications by measuring refill rate for prescriptions J Pediatr 2000 136(4):532 6 10753254
Shim C, Williams MH Jr Cough and wheezing from beclomethasone aerosol Chest 1987 91(2):207 9 3802930
Shrewsbury S, Pyke S, Britton M Meta-analysis of increased dose of inhaled steroid or addition of salmeterol in symptomatic asthma (MIASMA) BMJ 2000 May 20 320(7246):1368 73 27379
Siersted HC, Mostgaard G, Hyldebrandt N, et al Interrelationships between diagnosed asthma, asthma-like symptoms, and abnormal airway behaviour in adolescence: the Odense Schoolchild Study Thorax 1996 51(5):503 509 8711678
Silverstein MD, Yunginger JW, Reed CE, et al. Attained adult height after childhood asthma: effect of glucocorticoid therapy. J Allergy Clin Immunol. 1997;99:466-474. [pmid: 9111490].
Simons FE A comparison of beclomethasone, salmeterol, and placebo in children with asthma. Canadian Beclomethasone Dipropionate-Salmeterol Xinafoate Study Group N Engl J Med 1997 337(23):1659 65 9385125
Simons FE, Persaud MP, Gillespie CA, et al Absence of posterior subcapsular cataracts in young patients treated with inhaled glucocorticoids Lancet 1993 342(8874):776 8 8103877
Singhi S, Banerjee S, Nanjundaswamy H Inhaled budesonide in acute asthma J Paediatr Child Health 1999 35(5):483 7 10571764
Sivananthan N, Kana D, Winson MD, et al A study comparing Pro-Vent and phyllocontin in stable asthmatics Br J Clin Pract 1988 42(12):498 500 3076785
Skoner DP, Boltansky H, Kobayashi RH, et al Extended-release albuterol in the treatment of 6- to 12-year-old asthmatic children Ann Allergy Asthma Immunol 1996 76(5):462 8 8630721
Skoner DP, Szefler SJ, Welch M, et al Longitudinal growth in infants and young children treated with budesonide inhalation suspension for persistent asthma J Allergy Clinical Immunol 2000 105(2 Pt 1):259 68 10669845
Slovik DM, Neer RM, Ohman JL, et al Parathyroid hormone and 25-hydroxyvitamin D levels in glucocorticoid-treated patients Clin Endocrinol (Oxf) 1980 12(3):243 8 298219 7389155
Sly PD Peak expiratory flow monitoring in pediatric asthma: is there a role? J Asthma 1996 33(5):277 87 8827935
Sly PD, Cahill P, Willet K, et al Accuracy of mini peak flow meters in indicating changes in lung function in children with asthma BMJ 1994 308(6928):572 4 8148680
Smith MJ, Hodson ME High-dose beclomethasone inhaler in the treatment of asthma Lancet 1983 1(8319):265 9 6130294
Smith NA, Seale JP, Ley P, et al Better medication compliance is associated with improved control of childhood asthma Monaldi Arch Chest Dis 1994 49(6):470 4 7711695
Sorva R, Turpeinen M, Juntunen-Backman K, et al Effects of inhaled budesonide on serum markers of bone metabolism in children with asthma J Allergy Clin Immunol 1992 90(5):808 15 1430706
Spector SL, Nicodemus CF, Corren J, et al Comparison of the bronchodilatory effects of cetirizine, albuterol, and both together versus placebo in patients with mild-to-moderate asthma J Allergy Clin Immunol 1995 96(2):174 81 7636054
Spector SL Management of asthma with zafirlukast. Clinical experience and tolerability profile Drugs 1996 52(Suppl 6):36 46 8941502
Spedini C, Lombardi C Long-term treatment with oral nifedipine plus theophylline in the management of chronic bronchial asthma Eur J Clin Pharmacol 1986 31(1):105 6 3780818
Stalenheim G, Wegener T, Grettve L, et al Efficacy and tolerance of a 12-week treatment with inhaled formoterol in patients with reversible obstructive lung disease Respiration 1994 61(6):305 9 7824809
Steffensen I, Faurschou P, Riska H, et al Inhaled formoterol dry powder in the treatment of patients with reversible obstructive airway disease. A 3-month, placebo-controlled comparison of the efficacy and safety of formoterol and salbutamol, followed by a 12-month trial with formoterol Allergy 1995 50(8):657 63 7503401
Steffensen IE, Faurschou P [Formoterol as inhalation powder in the treatment of patients with reversible obstructive lung diseases. A 3-month placebo-controlled comparison of the effects of formoterol and salbutamol, followed by a 12-month period with formoterol alone] Ugeskr Laeger 1996 158(49):7092 6 8999618
Stokes GM, Milner AD, Hodges IG, et al Nebulised ipratropium bromide in wheezy infants and young children Eur J Respir Dis Suppl 1983 128(Pt 2):494 8 6225670
Storr J, Lenney CA, Lenney W Nebulised beclomethasone dipropionate in preschool asthma Arch Dis Child 1986 61(3):270 3 3516078
Strunk RC, Fukuhara JT, LaBrecque JF, et al Outcome of long-term hospitalization for asthma in children J Allergy Clin Immunol 1989 83(1):17 25 2913136
Sudre P, Jacquemet S, Uldry C, et al. Objectives, methods and content of patient education programmes for adults with asthma: systematic review of studies published between 1979 and 1998. Thorax. 1999;54:681-687. [pmid: 10413719].
Suissa S, Dennis R, Ernst P, et al Effectiveness of the leukotriene receptor antagonist zafirlukast for mild-to-moderate asthma. A randomized, double-blind, placebo-controlled trial Ann Intern Med 1997 126(3):177 83 9027267
Svedmyr J, Nyberg E, Asbrink-Nilsson E, et al Intermittent treatment with inhaled steroids for deterioration of asthma due to upper respiratory tract infections Acta Paediatr 1995 84(8):884 8 7488811
Svedmyr J, Nyberg E, Thunqvist P, et al Prophylactic intermittent treatment with inhaled corticosteroids of asthma exacerbations due to airway infections in toddlers Acta Paediatr 1999 88(1):42 7 10090546
Svedmyr N, Lofdahl CG The use of beta 2-adrenoceptor agonists in the treatment of bronchial asthma Pharmacol Toxicol 1996 78(1):3 11 8685084
Svendsen UG, Frolund L, Madsen F, et al A comparison of the effects of nedocromil sodium and beclomethasone dipropionate on pulmonary function, symptoms, and bronchial responsiveness in patients with asthma J Allergy Clin Immunol 1989 84(2):224 31 2547858
Sykes RS, Cocchetto DM Antiasthma drugs: key issues in clinical trial methodology J Asthma 1992 29(2):79 90 1639738
Szefler S, Oliver S, Bender B, et al Design and implementation of a patient education center for the childhood asthma management program: Prepared for the Annals of Allergy, Asthma, and Immunology by the Childhood Asthma Management Program Research Group Ann Allergy Asthma Immunol 1998 81(6):571 81 9892029
Szefler SJ, Boushey HA, Pearlman DS, et al Time to onset of effect of fluticasone propionate in patients with asthma J Allergy Clin Immunol 1999 103(5 Pt 1):780 8 10329810
Szefler SJ, Nelson HS Alternative agents for anti-inflammatory treatment of asthma J Allergy Clin Immunol 1998 102(4 Pt 2):S23 35 9798721
Szefler SJ Meeting needs of infants and young children with asthma: new developments in nebulized corticosteroid therapy. Introduction J Allergy Clin Immunol 1999 104(4 Pt 2):159 61 10518841
Taggart AJ, Astbury C, Dixon JS, et al Prednisolone pharmacokinetics in patients with rheumatoid arthritis, polymyalgia rheumatica and asthma Clin Rheumatol 1986 5(3):327 31 3780140
Taggart VS, Zuckerman AE, Lucas S, et al Adapting a self-management education program for asthma for use in an outpatient clinic Ann Allergy 1987 58(3):173 8 3826770
Taggart VS, Zuckerman AE, Sly RM, et al You Can Control Asthma: evaluation of an asthma education program for hospitalized inner-city children Patient Educ Couns 1991 17(1):35 47 1997997
Taitel MS, Kotses H, Bernstein IL, et al A self-management program for adult asthma. Part II: Cost-benefit analysis J Allergy Clin Immunol 1995 95(3):672 6 7897149
Tal D, Gil-Spielberg R, Antonovsky H, et al Teaching families to cope with childhood asthma Fam Syst Med 1990 8(2):135 44
Tamaoki J, Kondo M, Sakai N, et al Leukotriene antagonist prevents exacerbation of asthma during reduction of high-dose inhaled corticosteroid. The Tokyo Joshi-Idai Asthma Research Group Am J Respir Crit Care Med 1997 155(4):1235 40 9105060
Tan WC, Koh TH, Hay CS, et al The effect of inhaled budesonide on the diurnal variation in airway mechanics, airway responsiveness and serum neutrophil chemotactic activity in Asian patients with predominant nocturnal asthma Respirology 1998 3(1):13 20 9657654
Tashkin DP, Nathan RA, Howland WC, et al An evaluation of zafirlukast in the treatment of asthma with exploratory subset analyses J Allergy Clin Immunol 1999 103(2 Pt 1):246 54 9949315
Taylor AV, Laoprasert N, Zimmerman D, et al Adrenal suppression secondary to inhaled fluticasone propionate Ann Allergy Asthma Immunol 1999 83(1):68 70 10437819
Taylor DA, Jensen MW, Kanabar V, et al A dose-dependent effect of the novel inhaled corticosteroid ciclesonide on airway responsiveness to adenosine-5'-monophosphate in asthmatic patients Am J Respir Crit Care Med 1999 160(1):237 43 10390406
Taylor DR, Sears MR, Herbison GP, et al Regular inhaled beta agonist in asthma: effects on exacerbations and lung function Thorax 1993 48(2):134 8 8493626
Tehan N, Sloane BC, Walsh-Robart N, et al Impact of asthma self-management education on the health behavior of young adults. A pilot study of the Dartmouth College "Breathe Free" program J Adolesc Health Care 1989 10(6):513 9 2606751
The Childhood Asthma Management Program (CAMP): design, rationale, and methods Childhood Asthma Management Program Research Group Control Clin Trials 1999 20(1):91 120 10027502
Thom D Antibiotic treatment of asthma J Fam Pract 1996 42(3):307 8 8636688
Tinkelman D Theophylline therapy for children with asthma Eur Respir Rev 1996 6(34):79 83
QVAR (beclomethasone dipropionate HFA) inhalation aerosol receives FDA approval for asthma [press release]. St. Paul (MN); 2000 Sept 15.
Tinkelman DG, Moss BA, Bukantz SC, et al A multicenter trial of the prophylactic effect of ketotifen, theophylline, and placebo in atopic asthma J Allergy Clin Immunol 1985 76(3):487 97 3897345
Tinkelman DG, Reed CE, Nelson HS, et al Aerosol beclomethasone dipropionate compared with theophylline as primary treatment of chronic, mild to moderately severe asthma in children Pediatrics 1993 92(1):64 77 8516087
Tirimanna PR, Den Otter JJ, Van Schayck CP, et al Evaluation of the suitability of weekly peak expiratory flow rate measurements in monitoring annual decline in lung function among patients with asthma and chronic bronchitis Br J Gen Pract 1996 46(402):15 8 8745846 1239505
Toelle BG, Peat JK, Salome CM, et al Evaluation of a community-based asthma management program in a population sample of schoolchildren Med J Aust 7 1993 158(11):742 6
Tomac N, Tuncer A, Saraclar Y, et al Efficacy of salmeterol in the treatment of childhood asthma Acta Paediatr Jpn 1996 38(5):489 94 8942009
Tomita K, Hashimoto K, Matsumoto S, et al [Pranlukast allows reduction of inhaled steroid dose without deterioration in lung function in adult asthmatics] Arerugi 1999 Apr 48(4):459 65 (Japanese, with English abstract) 10355150
Tomson Y, Hasselstrom J, Tomson G, et al Asthma education for Swedish primary care physicians -- a study on the effects of "academic detailing" on practice and patient knowledge Eur J Clin Pharmacol 1997 53(3-4):191 6 9476030
Toogood JH, Jennings B, Crepea SB, et al Efficacy of safety of concurrent use of intranasal flunisolide and oral beclomethasone aerosols in treatment of asthmatics with rhinitis Clin Allergy 1982 12(1):95 105 7067071
Toogood JH, Jennings B, Lefcoe NM A clinical trial of combined cromolyn/beclomethasone treatment for chronic asthma J Allergy Clin Immunol 1981 67(4):317 24 6782146
Tormey VJ, Faul J, Leonard C, et al A comparison of regular with intermittent bronchodilators in asthma patients on inhaled steroids Ir J Med Sci 1997 166(4):249 52 9394077
Tripathi RC, Kipp MA, Tripathi BJ, et al Ocular toxicity of prednisone in pediatric patients with inflammatory bowel disease Lens Eye Toxic Res 1992 9(3-4):469 82 1301798
Turner MO, Johnston PR, Pizzichini E, et al Anti-inflammatory effects of salmeterol compared with beclomethasone in eosinophilic mild exacerbations of asthma: a randomized, placebo controlled trial Can Respir J 1998 5(4):261 8 9753527
Turner MO, Taylor D, Bennett R, et al A randomized trial comparing peak expiratory flow and symptom self-management plans for patients with asthma attending a primary care clinic Am J Respir Crit Care Med 1998 157(2):540 6 9476870
Turpeinen M, Sorva R Inhaled beclomethasone dipropionate and growth in children with mild asthma Am J Respir Crit Care Med 1996 153(5):
Orally Inhaled/Intranasal Corticosteroids and Growth in Children: Transcripts of a joint meeting of Pulmonary Allergy Drugs Advisory Committee and the Endocrinologic and Metabolic Drugs Advisory Committee. Bethesda, MD, July 30 and 31, 1998. Available online at http://www.fda.gov/ohrms/dockets/ac/98/transcpt/3430t1.pdf (July 30, 1998 transcript) and http://www.fda.gov/ohrms/dockets/ac/98/transcpt/3430t2.pdf (July 31, 1998 transcript). Last accessed: December 4, 2000.
Ukena D, Harnest U, Sakalauskas R, et al Comparison of addition of theophylline to inhaled steroid with doubling of the dose of inhaled steroid in asthma Eur Respir J 1997 10(12):2754 60 9493656
Ulrik CS Outcome of asthma: longitudinal changes in lung function Eur Respir J 1999 13(4):904 18 10362061
van Bever HP, Desager KN, Lijssens N, et al. Does treatment of asthmatic children with inhaled corticosteroids affect their adult height?. Pediatric Pulmonol. 1999;27:369-375.
van der Molen T, Kerstjens HA Starting inhaled corticosteroids in asthma: when, how high, and how long Eur Resp J 2000 15(1):3 4
van der Molen T, Postma DS, Turner MO, et al Effects of the long acting beta agonist formoterol on asthma control in asthmatic patients using inhaled corticosteroids. The Netherlands and Canadian Formoterol Study Investigators Thorax 1997 52(6):535 9 9227720
van der Palen J, Klein JJ, Zielhuis GA, et al The role of self-treatment guidelines in self-management education for adult asthmatics Respir Med 1998 92(4):668 75 9659535
van Essen-Zandvliet EE, Hughes MD, Waalkens HJ, et al Effects of 22 months of treatment with inhaled corticosteroids and/or beta-2-agonists on lung function, airway responsiveness, and symptoms in children with asthma. The Dutch Chronic Non-specific Lung Disease Study Group Am Rev Respir Dis 1992 146(3):547 54 1355640
van Essen-Zandvliet EE, Hughes MD, Waalkens HJ, et al Remission of childhood asthma after long-term treatment with an inhaled corticosteroid (budesonide): can it be achieved? Dutch CNSLD Study Group Eur Respir J 1994 7(1):63 8 7908268
van Essen-Zandvliet EE Long-term intervention in childhood asthma: the Dutch study results. Dutch Chronic Nonspecific Lung Disease Study Group Monaldi Arch Chest Dis 1995 50(3):201 7 7663491
van Grunsven PM, Dompeling E, van Schayck CP, et al Treatment of mild asthma with inhaled corticosteroids: is discontinuation of therapy possible? Fam Med 1996 28(1):46 51 8720227
van Keimpema AR, Ariaansz M, Raaijmakers JA, et al Treatment of nocturnal asthma by addition of oral slow-release albuterol to standard treatment in stable asthma patients J Asthma 1996 33(2):119 24 8609099
van Noord JA, Schreurs AJ, Mol SJ, et al Addition of salmeterol versus doubling the dose of fluticasone propionate in patients with mild to moderate asthma Thorax 1999 54(3):207 12 10325895
van Schayck CP, Dompeling E, Rutten MP, et al The influence of an inhaled steroid on quality of life in patients with asthma or COPD Chest 1995 107(5):1199 205 7750306
van Schayck CP, Dompeling E, van Herwaarden CL, et al Bronchodilator treatment in moderate asthma or chronic bronchitis: continuous or on demand? A randomised controlled study BMJ 1991 303(6815):1426 31 1837744 1671690
van Schayck CP, Dompeling E, van Herwaarden CL, et al Continuous and on demand use of bronchodilators in patients with non-steroid dependent asthma and chronic bronchitis: four-year follow-up randomized controlled study Br J Gen Pract 1995 45(394):239 44 7619569 1239228
Vanto T, Koivikko A, Thuresson SO Efficacy and pharmacokinetics of slow release theophylline in preschool children with intermittent episodes of asthma Acta Paediatr Scand 1989 78(6):961 2 2690568
Vaughan LM, Milavetz G, Weinberger MM, et al Oral bioavailability of slow-release theophylline from unencapsulated beads in preschool children with chronic asthma Ther Drug Monit 1988 10(4):395 400 3059587
Vazquez MI, Buceta JM Effectiveness of self-management programmes and relaxation training in the treatment of bronchial asthma: relationships with trait anxiety and emotional attack triggers J Psychosom Res 1993 37(1):71 81 8421262
Vazquez MI, Fontan-Bueso J, Buceta JM Self-perception of asthmatic children and modification through self-management programmes Psychol Rep Dec 1992 71(3 Pt 1):903 13
Verberne AA, Frost C, Duiverman EJ, et al Addition of salmeterol versus doubling the dose of beclomethasone in children with asthma. The Dutch Asthma Study Group Am J Respir Crit Care Med 1998 158(1):213 9 9655732
Verberne AA, Frost C, Roorda RJ, et al One year treatment with salmeterol compared with beclomethasone in children with asthma. The Dutch Paediatric Asthma Study Group Am J Respir Crit Care Med 1997 156(3 Pt 1):688 95 9309980
Verberne AA, Hop WC, Creyghton FB, et al Airway responsiveness after a single dose of salmeterol and during four months of treatment in children with asthma J Allergy Clin Immunol 1996 97(4):938 46 8655889
Vermetten FA, Boermans AJ, Luiten WD, et al Comparison of salmeterol with beclomethasone in adult patients with mild persistent asthma who are already on low-dose inhaled steroids J Asthma 1999 36(1):97 106 10077139
Villaran C, O'Neill SJ, Helbling A, et al Montelukast versus salmeterol in patients with asthma and exercise-induced bronchoconstriction. Montelukast/Salmeterol Exercise Study Group J Allergy Clin Immunol 1999 104(3 Pt 1):547 53 10482826
von Berg A, de Blic J, la Rosa M, et al A comparison of regular salmeterol vs 'as required' salbutamol therapy in asthmatic children Respir Med 1998 92(2):292 9 9616529
Waalkens HJ, van Essen-Zandvliet EE, Gerritsen J, et al The effect of an inhaled corticosteroid (budesonide) on exercise-induced asthma in children. Dutch CNSLD Study Group [see comments] Eur Respir J 1993 6(5):652 6 8519374
Waalkens HJ, Van Essen-Zandvliet EE, Hughes MD, et al Cessation of long-term treatment with inhaled corticosteroid (budesonide) in children with asthma results in deterioration. The Dutch CNSLD Study Group Am Rev Respir Dis 1993 148(5):1252 7 8239161
Wallaert B, Brun P, Ostinelli J, et al A comparison of two long-acting beta-agonists, oral bambuterol and inhaled salmeterol, in the treatment of moderate to severe asthmatic patients with nocturnal symptoms. The French Bambuterol Study Group Respir Med 1999 93(1):33 8 10464846
Warner JO, Gotz M, Landau LI, et al Management of asthma: a consensus statement Arch Dis Child 1989 64(7):1065 79 2698121
Wasserman SI, Gross GN, Schoenwetter WF, et al A 12-week dose-ranging study of fluticasone propionate powder in the treatment of asthma J Asthma 1996 33(4):265 74 8707781
Webb MS, Henry RL, Milner AD Oral corticosteroids for wheezing attacks under 18 months Arch Dis Child 1986 61(1):15 9 3513715
Webb MS, Milner AD, Hiller EJ, et al Nebulised beclomethasone dipropionate suspension Arch Dis Child 1986 61(11):1108 10 3539031
Wechsler ME, Drazen JM Zafirlukast and Churg-Strauss syndrome Chest 1999 116(1):266 7
Wechsler ME, Finn D, Gunawardena D, et al Churg-Strauss syndrome in patients receiving montelukast as treatment for asthma Chest 2000 117(3):708 13 10712995
Wechsler ME, Pauwels R, Drazen JM Leukotriene modifiers and Churg-Strauss syndrome: adverse effect or response to corticosteroid withdrawal? Drug Saf 1999 21(4):241 51 10514017
Weersink EJ, Douma RR, Postma DS, et al Fluticasone propionate, salmeterol xinafoate, and their combination in the treatment of nocturnal asthma Am J Respir Crit Care Med 1997 155(4):1241 6 9105061
Weinberger M, Hendeles L Theophylline in asthma N Engl J Med 1996 334(21):1380 8 8614425
Weinstein S, Chervinsky P, Pollard SJ, et al A one-week dose-ranging study of inhaled salmeterol in children with asthma J Asthma 1997 34(1):43 52 9033439
Weller FR, Weller HH, Kallenberg CG, et al Sensitivity to hydrocortisone is a relevant factor in the immunoendocrine relationship. I. The cell-mediated immune response in relation to blood levels and in vitro immunosuppressive effects of hydrocortisone in patients with asthma and healthy control subjects J Allergy Clin Immunol 1986 78(3 Pt 1):423 30 3760402
Wells A, Drennan C, Holst P, et al Comparison of nedocromil sodium at two dosage frequencies with placebo in the management of chronic asthma Respir Med 1992 86(4):311 6 1333087
Wendel PJ, Ramin SM, Barnett-Hamm C, et al Asthma treatment in pregnancy: a randomized controlled study Am J Obstet Gynecol 1996 175(1):150 4 8694041
Wenzel A, Henriksen J, Melsen B Nasal respiratory resistance and head posture: effect of intranasal corticosteroid (Budesonide) in children with asthma and perennial rhinitis Am J Orthod 1983 84(5):422 6 6579843
Wenzel SE, Kamada AK Zileuton: the first 5-lipoxygenase inhibitor for the treatment of asthma Ann Pharmacother 1996 30(7-8):858 64 8826571
Wenzel SE Antileukotriene drugs in the management of asthma JAMA 1998 280(24):2068 9 9875862
Wenzel SE Leukotriene receptor antagonists and related compounds Can Respir J 1999 6(2):189 93 10322101
Wesseldine LJ, McCarthy P, Silverman M Structured discharge procedure for children admitted to hospital with acute asthma: A randomised controlled trial of nursing practice Arch Dis Child 1999 80(2):110 4 10325723
Westbroek J, Saarelainen S, Laher M, et al Oral steroid-sparing effect of two doses of nebulized fluticasone propionate and placebo in patients with severe chronic asthma Respir Med 1999 93(10):689 99 10581657
Wettengel R, Laurikainen K, Silvasti M, et al Therapeutic equivalence and acceptability of two multidose powder inhalers in the treatment of asthma Respiration 2000 67(1):77 82 10705267
Weytjens K, Malo JL, Cartier A, et al Comparison of peak expiratory flows and FEV1 in assessing immediate asthmatic reactions due to occupational agents Allergy 1999 54(6):621 5 10435478
Wheatley D Clenbuterol ("Spiropent"): a long-acting bronchodilator Curr Med Res Opin 1982 8(2):113 9 7049586
White MV, Cruz-Rivera M, Walton-Bowen K The efficacy and safety of budesonide inhalation suspension: a nebulizable corticosteroid for persistent asthma in infants and young children Fam Med 1999 31(5):337 45 10407712
Whitehead J Sequential designs for equivalence studies Stat Med 1996 15(24):2703 15 8981681
Whitman N, West D, Brough FK, et al A study of a Self-Care Rehabilitation Program in pediatric asthma Health Educ Q 1985 12(4):333 42 4077545
Wiegand L, Mende CN, Zaidel G, et al Salmeterol vs theophylline: sleep and efficacy outcomes in patients with nocturnal asthma Chest 1999 115(6):1525 32 10378544
Wigal JK, Stout C, Brandon M, et al The Knowledge, Attitude, and Self-Efficacy Asthma Questionnaire Chest 1993 104(4):1144 8 8404182
Wilding P, Clark M, Coon JT, et al Effect of long-term treatment with salmeterol on asthma control: a double blind, randomised crossover study BMJ 1997 314(7092):1441 6 9167559
Williams AJ, Stableforth D. The addition of nedocromil sodium to maintenance therapy in the management of patients with bronchial asthma. Eur J Respir Dis Suppl. 1986;147:340-3. [pmid: 3021502].
Williams C, Crossland L, Finnerty J, et al Case-control study of salmeterol and near-fatal attacks of asthma Thorax 1998 53(1):7 13 9577515
Williams HN Multi-centre clinical trial of nedocromil sodium in reversible obstructive airways disease in adults: a general practitioner collaborative study Curr Med Res Opin 1989 11(7):417 26 2550176
Wilson NM, Silverman M Treatment of acute, episodic asthma in preschool children using intermittent high dose inhaled steroids at home Arch Dis Child 1990 65(4):407 10 2189367
Wilson SR, Scamagas P, German DF, et al A controlled trial of two forms of self-management education for adults with asthma Am J Med 1993 94(6):564 76 8506881
Wolthers OD, Juul A, Hansen M, et al The insulin-like growth factor axis and collagen turnover in asthmatic children treated with inhaled budesonide Acta Paediatr 1995 84(4):393 7 7540898
Wolthers OD, Riis BJ, Pedersen S Bone turnover in asthmatic children treated with oral prednisolone or inhaled budesonide Pediatr Pulmonol 1993 16(6):341 6 8134155
Wong CS, Cooper S, Britton JR, et al Steroid sparing effect of nedocromil sodium in asthmatic patients on high doses of inhaled steroids Clin Exp Allergy 1993 23(5):370 6 8392897
Wongtim S, Mogmued S, Chareonlap P, et al Effect of inhaled corticosteroids on bronchial hyperresponsiveness in patients with mild asthma Asian Pac J Allergy Immunol 1995 13(2):81 5 8703248
Woolcock A, Lundback B, Ringdal N, et al Comparison of addition of salmeterol to inhaled steroids with doubling of the dose of inhaled steroids Am J Respir Crit Care Med 1996 153(5):1481 8 8630590
Woolcock AJ The combined use of inhaled salmeterol and inhaled corticosteroids Eur Respir Rev 1995 5(27):142 5
Wronska J, Chazan R, Mazurek J, et al [Treatment with salmeterol and quality of life in patients with asthma] Pneumonol Alergol Pol 1998 66(3-4):193 7 (Polish with English abstract) 9857664
Wynn SR Alternative approaches to asthma J Pediatr 1989 115(5 Pt 2):846 9 2530326
Yagupsky P, Shahak E, Tal A, et al Lipoprotein profile of children with asthma receiving long-term theophylline therapy: a preliminary study J Pediatr 1992 120(5):802 5 1578321
Yates DH, Sussman HS, Shaw MJ, et al Regular formoterol treatment in mild asthma. Effect on bronchial responsiveness during and after treatment Am J Respir Crit Care Med 1995 Oct 152(4 Pt 1):1170 4 7551366
Yiallouros PK, Milner AD, Conway E, et al Adrenal function and high dose inhaled corticosteroids for asthma Arch Dis Child 1997 76(5):405 10 9196354
Yildiz F, Kaur AC, Ilgazli A, et al Inhaled corticosteroids may reduce neutrophilic inflammation in patients with stable chronic obstructive pulmonary disease Respiration 2000 67(1):71 6 10705266
Yoon R, McKenzie DK, Bauman A, et al Controlled trial evaluation of an asthma education programme for adults Thorax 1993 48(11):1110 6 8296253
Yoshida S, Sakamoto H, Ishizaki Y, et al Efficacy of leukotriene receptor antagonist in bronchial hyperresponsiveness and hypersensitivity to analgesic in aspirin-intolerant asthma Clin Exp Allergy 2000 30(1):64 70 10606932
Youngchaiyud P, Permpikul C, Suthamsmai T, et al A double-blind comparison of inhaled budesonide, long-acting theophylline, and their combination in treatment of nocturnal asthma Allergy 1995 50(1):28 33 7741186
Zarkovic J, Gotz MH, Holgate ST, et al Effect of long-term regular salmeterol treatment in children with moderate asthma Clin Drug Invest 1998 15(3):169 75
Zehner WJ Jr, Scott JM, Iannolo PM, et al Terbutaline vs albuterol for out-of-hospital respiratory distress: randomized, double-blind trial Acad Emerg Med 1995 2(8):686 91 7584746
Zeiger RS, Schatz M, Sperling W, et al Efficacy of troleandomycin in outpatients with severe, corticosteroid-dependent asthma J Allergy Clin Immunol 1980 66(6):438 46 6968762
Accolate® (zafirlukast) tablets prescribing information. Wilmington, DE; 2000 June.
Zimmerman B, Gold M, Wherrett D, et al Adrenal suppression in two patients with asthma treated with low doses of the inhaled steroid fluticasone propionate J Allergy Clin Immunol 1998 101(3):425 6 9525464