# References

Zyflo® (zileuton) Filmtab® tablets prescribing information. North Chicago, IL; 1998 March.
Abuekteish F, Kirkpatrick JNP, Russell G Posterior subcapsular cataract and inhaled corticosteroid therapy Thorax 1995 Jun 50(6):674 6 7638813
Adkins JC, Brogden RN Zafirlukast: a review of its pharmacological properties and therapeutic potential in the management of asthma Drugs 1998 55(1):121 44 9463793
Adkins JC, McTavish D Salmeterol: a review of its pharmacological properties and clinical efficacy in the management of children with asthma Drugs 1997 52(2):331 354
Agertoft L, Larsen FE, Pedersen S Posterior subcapsular cataracts, bruises and hoarseness in children with asthma receiving long-term treatment with inhaled budesonide Eur Respir J 1998 Jul 12(1).
Agertoft L, Pedersen S Bone mineral density in children with asthma receiving long-term treatment with inhaled budesonide Am J Respir Crit Care Med 1998 Jan 157(1).
Agertoft L, Pedersen S Effect of long-term treatment with inhaled budesonide on adult height in children with asthma N Engl J Med 2000 Oct 12 343(15):1064 9
Agertoft L, Pedersen S Effects of long-term treatment with an inhaled corticosteroid on growth and pulmonary function in asthmatic children Respir Med 1994 May 88(5):373 81 8036306
Allen DB, Bronsky EA, LaForce CF, et al Growth in asthmatic children treated with fluticasone propionate. Fluticasone Propionate Asthma Study Group J Pediatr 1998 Mar 132(3 Pt 1):472 7 9544904
Allen DB, Mullen M, Mullen B A meta-analysis of the effect of oral and inhaled corticosteroids on growth J Allergy Clin Immunol 1994 Jun 93(6):967 76 8006318
American Thoracic Society Standardization of Spirometry, 1994 Update Am J Respir Crit Care Med 1995 Sep 152(3):1107 36 7663792
Anonymous Drugs for asthma Med Lett Drugs Ther 2000 Mar 6 42(1073):19 24
Aronson N, Seidenfeld J, Piper MA, et al. Use of Epoetin for Anemia in Oncology. In press.
Aronson N, Seidenfeld J, Samson DJ, et al. Relative Effectiveness and Cost-Effectiveness of Methods of Androgen Suppression in the Treatment of Advanced Prostate Cancer. Evidence Report/Technology Assessment No. 4. (Prepared by Blue Cross/Blue Shield Association Evidence-based Practice Center under Contract No. 290-97-0015. AHCPR Publication No. 99-E0012. Rockville, MD: Agency for Health Care Policy and Research. May 1999.).
AstraZeneca. "Dear Health Care Provider" letter on Accolate® and Churg-Strauss syndrome. 22 July 1997. Wilmington, DE.
Aubier M, Pieters WR, Schlosser NJ, et al Salmeterol/fluticasone propionate (50/500 microg) in combination in a Diskus inhaler (Seretide) is effective and safe in the treatment of steroid-dependent asthma Respir Med 1999 Dec 93(12):876 84 10653049
Ayres JG, Campbell LM A controlled assessment of an asthma self-management plan involving a budesonide dose regimen. OPTIONS Research Group Eur Respir J 1996 May 9(5):886 92 8793447
Bailey WC, Richards JM Jr, Brooks CM, et al A randomized trial to improve self-management practices of adults with asthma Arch Intern Med 1990 150(8):1664 8 2200380
Baker JW, Mellon M, Wald J, et al A multiple-dosing, placebo-controlled study of budesonide inhalation suspension given once or twice daily for treatment of persistent asthma in young children and infants Pediatrics 1999 103(2):414 21 9925834
Baraniuk J, Murray JJ, Nathan RA, et al Fluticasone alone or in combination with salmeterol vs triamcinolone in asthma Chest 1999 Sep 116(3):625 32 10492263
Barnes PJ Inhaled glucocorticoids for asthma N Engl J Med 1995 332(13):868 75 7870143
Bartow RA, Brogden RN Formoterol. An update of its pharmacological properties and therapeutic efficacy in the management of asthma Drugs 1998 55(2):303 22 9506248
Beasley R, D'Souza W, Te Karu H, et al Trial of an asthma action plan in the Maori community of the Wairarapa N Z Med J 1993 106(961):336 8 8341475
Begg C, Cho M, Eastwood S, et al Improving the quality of reporting of randomized trials: the CONSORT Statement JAMA 1996 Aug 28 276(8):637 9
Behrman RE, Kliegman RM, Jensen HB. Chapter 145: Asthma. In: Nelson Textbook of Pediatrics, 16th ed. Behrman RE, Kliegman RM, Jensen HB, eds. Philadelphia: W.B. Saunders. pp 664-679.
Benson K, Hartz AJ. A comparison of observational studies and randomized controlled trials. N Engl J Med. 2000;342:1878-86. [pmid: 10861324].
Berlin JA, Rennie D Measuring the quality of trials: the quality of the quality scales JAMA 1999 Sep 15 282(11):1083 5
Bernard-Bonnin AC, Stachenko S, Bonin D, et al. Self-management teaching programs and morbidity of pediatric asthma: A meta-analysis. J Allergy Clin Immunol. 1995;95:34-41. [pmid: 7822662].
Boulet LP, Cartier A, Milot J, et al Tolerance to the protective effects of salmeterol on methacholine-induced bronchoconstriction: influence of inhaled corticosteroids Eur Respir J 1998 May 11(5):1091 7 9648961
Bouros D, Bachlitzanakis N, Kottakis J, et al Formoterol and beclomethasone versus higher dose beclomethasone as maintenance therapy in adult asthma Eur Respir J 1999 Sep 14(3):627 32 10543286
Boyd G Salmeterol xinafoate in asthmatic patients under consideration for maintenance oral corticosteroid therapy. UK Study Group Eur Respir J 1995 Sep 8(9):1494 8 8575574
Brogden RN, Faulds D Salmeterol xinafoate A review of its pharmacological properties and therapeutic potential in reversible obstructive airways disease. Drugs 1991 42(5):895 912
Brogden RN, Sorkin EM Nedocromil sodium: an updated review of its pharmacological properties and therapeutic efficacy in asthma Drugs 1993 45(5):693 715 7686465
Cave A, Arlett P, Lee E. Inhaled and nasal corticosteroids: factors affecting the risks of systemic adverse effects. Pharmacol Ther. 1999;83:153-179. [pmid: 10576291].
Chalmers TC, Smith H Jr, Blackburn B, et al A method for assessing the quality of a randomized control trial Controlled Clin Trials 1981 May 2(1):31 49 7261638
Charlton I, Antoniou AG, Atkinson J, et al Asthma at the interface: bridging the gap between general practice and a district general hospital Arch Dis Child 1994 Apr 70(4):313 8 8185365
Charlton I, Charlton G, Broomfield J, et al Evaluation of peak flow and symptoms only self management plans for control of asthma in general practice BMJ 1990 Dec 15 301(6765):1355 9
Chee CBE. The utility of peak flow measurements in guiding asthma management - What is the evidence?. Singapore Med J. 1998;39:477-8.
The Childhood Asthma Management Program (CAMP): design, rationale, and methods. Control Clin Trials. 1999:91-120.
Long-term effects of budesonide or nedocromil in children with asthma N Engl J Med 2000a Oct 12 343(15):1054 63
Supplementary material: Long-term effects of budesonide or nedocromil in children with asthma. NAPS Document no. 05569. Obtained from National Auxiliary Publications Service, c/o Microfiche Publications, West Hempstead (NY); Printed 2000b Sept 8.
Choy DK, Tong M, Ko F, et al Evaluation of the efficacy of a hospital-based asthma education programme in patients of low socioeconomic status in Hong Kong Clin Exp Allergy 1999 29(1):84 90 10051706
Christian Virchow J, Prasse A, Naya I, et al Zafirlukast improves asthma control in patients receiving high-dose inhaled corticosteroids Am J Respir Crit Care Med 2000 Aug 162(2 Pt 1):578 85 10934090
Cluzel M, Bousquet J, Daures JP, et al Ambulatory long-term subcutaneous salbutamol infusion in chronic severe asthma J Allergy Clin Immunol 1990 Mar 85(3):599 606 2179366
Cohen J. Statistical Power Analysis for the Behavioral Sciences. New York: Academic Press. 1977:8-17. [pmcid: 333326].
Concato J, Shah N, Horwitz RI Randomized, controlled trials, observational studies, and the hierarchy of research designs N Engl J Med 2000 342(25):1887 92 10861325 1557642
Condemi JJ, Chervinsky P, Goldstein MF, et al Fluticasone propionate powder administered through Diskhaler versus triamcinolone acetonide aerosol administered through metered-dose inhaler in patients with persistent asthma J Allergy Clin Immunol 1997 Oct 100(4):467 74 9338539
Condemi JJ, Goldstein S, Kalberg C, et al The addition of salmeterol to fluticasone propionate versus increasing the dose of fluticasone propionate in patients with persistent asthma. Salmeterol Study Group Ann Allergy Asthma Immunol 1999 Apr 82(4):383 9 10227337
Connett GJ, Warde C, Wooler E, et al Use of budesonide in severe asthmatics aged 1-3 years Arch Dis Child 1993 Sep 69(3):351 5 8215545
Connolly CK, Murthy NK, Prescott RJ, et al Infection in exacerbations of asthma: views of different groups of practitioners Postgrad Med J 1991 Oct 67(792):892 6 1758798
Cote J, Cartier A, Robichaud P, et al Influence on asthma morbidity of asthma education programs based on self-management plans following treatment optimization Am J Respir Crit Care Med 1997 May 155(5):1509 14 9154850
Cowie RL, Revitt SG, Underwood MF, et al The effect of a peak flow-based action plan in the prevention of exacerbations of asthma Chest 1997 Dec 112(6):1534 8 9404750
Cumming RG, Mitchell P, Leeder SR Use of inhaled corticosteroids and the risk of cataracts N Engl J Med 1997 Jul 3 337(1):8 14
Cypcar D, Stark J, Lemanske RF Jr The impact of respiratory infections on asthma Pediatr Clin North Am 1992 Dec 39(6):1259 76 1437319
DerSimonian R, Laird N. Meta analysis in clinical trials. Controlled Clin Trials. 1986;7:177-188. [pmid: 3802833].
Devine EC. Meta-analysis of the effects of psychoeducational care in adults with asthma. Res Nursing Health. 1996;19:367-376.
Doull IJ, Freezer NJ, Holgate ST Growth of prepubertal children with mild asthma treated with inhaled beclomethasone dipropionate Am J Respir Crit Care Med 1995 Jun 151(6):1715 9 7767512
Drazen JM, Israel E, O'Byrne PM Treatment of asthma with drugs modifying the leukotriene pathway N Engl J Med 1999 340(3):197 206 9895400
Drummond N, Abdalla M, Beattie JAG, et al Effectiveness of routine self monitoring of peak flow in patients with asthma. Grampian Asthma Study of Integrated Care (GRASSIC) BMJ 1994 Feb 26 308(6928):564 7
Drummond N, Abdalla M, Buckingham JK, et al Integrated care for asthma: a clinical, social, and economic evaluation. Grampian Asthma Study of Integrated Care (GRASSIC) BMJ 1994 Feb 26 308(6928):559 64
D'Souza W, Burgess C, Ayson M, et al Trial of a "credit card" asthma self-management plan in a high-risk group of patients with asthma J Allergy Clin Immunol 1996 97(5):1085 92 8626986
D'Souza W, Crane J, Burgess C, et al Community-based asthma care: Trial of a 'credit card' asthma self-management plan Eur Respir J 1994 7(7):1260 5 7925904
D'Souza WJ, Te Karu H, Fox C, et al Long-term reduction in asthma morbidity following an asthma self-management programme Eur Respir J 1998 11(3):611 6 9596111
Eddy DM, Hasselblad V. FAST*PRO Software for Meta-analysis by the Confidence Profile Method. Orlando: Academic Press. 1992. [pmcid: 402151].
Emad A Effectiveness of adding alternate-day theophylline to the treatment regimen of patients with moderate-to-severe asthma Respir Care 1996 41(6):520 3
Evans DJ, Taylor DA, Zetterstrom O, et al A comparison of low-dose inhaled budesonide plus theophylline and high-dose inhaled budesonide for moderate asthma N Engl J Med 1997 337(20):1412 8 9358138
FitzGerald JM, Chapman KR, Della Cioppa G, et al Sustained bronchoprotection, bronchodilatation, and symptom control during regular formoterol use in asthma of moderate or greater severity. The Canadian FO/OD1 Study Group J Allergy Clin Immunol 1999 Mar 103(3 Pt 1):427 35 10069876
Gallefoss F, Bakke PS How does patient education and self-management among asthmatics and patients with chronic obstructive pulmonary disease affect medication? Am Respir Crit Care Med 1999 161(2 part 2):S137 S141
Garbe E, LeLorier J, Boivin JF, et al Inhaled and nasal glucocorticoids and the risks of ocular hypertension or open-angle glaucoma JAMA 1997 Mar 5 277(9):722 7
Garbe E, Suissa S, LeLorier J Association of inhaled corticosteroid use with cataract extraction in elderly patients JAMA 1998 Aug 12 280(6):539 43
Garcia-Marcos L, Schuster A New perspectives for asthma treatment: anti-leukotriene drugs Pediatr Allergy Immunol 1999 10(2):77 88 10478608
Garrett J, Fenwick JM, Taylor G, et al. Peak expiratory flow meters (PEFM's) - who uses them and does education affect the pattern of utilization?. Aust NZ J Med. 1994;24:21-529.
Ghosh CS, Ravindran P, Joshi M, et al Reductions in hospital use from self management training for chronic asthmatics Soc Sci Med 1998 46(8):1087 93 9579760
Gibson PG, Coughlan J, Wilson AJ, et al Limited (information only) patient education programs for adults with asthma Cochrane Database Syst Rev 2000a(2):
Gibson PG, Coughlan J, Wilson AJ, et al Self-management education and regular practitioner review for adults with asthma Cochrane Database Syst Rev 2000b(2):
Gillies J, Barry D, Crane J, et al A community trial of a written self management plan for children with asthma. Asthma Foundation of NZ Children's Action N Z Med J 1996 109(1015):30 3 8606811
Glass G. Summarizing effect sizes. In: New Directions for Methodology of Social and Behavioral Science: Quantitative Assessment of Research Domains, Jossey-Bass, San Francisco, 1980.
FDA approves Advair™ Diskus®: the first and only medication that simultaneously treats both underlying components of asthma [press release]. Research Triangle Park (NC). 2000 Aug 15. [pmcid: 284246].
Serevent® (salmeterol xinafoate) inhalation aerosol prescribing information. Research Triangle Park, NC. 2000 July.
Gonzalez Perez-Yarza E, Mintegui J, Garmendia A, et al [The excretion of free cortisol in the urine in healthy children and in asthmatics treated with long-term inhaled glucocorticoids] An Esp Pediatr 1996 Jun 44(6):531 6 8796962
Graham VA, Milton AF, Knowles GK, et al Routine antibiotics in hospital management of acute asthma Lancet 1982 1(8269):418 20 6121090
Greening AP, Ind PW, Northfield M, et al Added salmeterol versus higher-dose corticosteroid in asthma patients with symptoms on existing inhaled corticosteroid. Allen & Hanburys Limited UK Study Group Lancet 1994 Jul 23 344(8917):219 24
Grossman J Multicenter comparison of once-daily Uniphyl tablets administered in the morning or evening with baseline twice-daily theophylline therapy in patients with nocturnal asthma Am J Med 1988 Jul 29 85(1B):11 3 3041821
Grutters JC, Brinkman L, Aslander MM, et al Asthma therapy modulates priming-associated blood eosinophil responsiveness in allergic asthmatics Eur Respir J 1999 Oct 14(4):915 22 10573242
Haahtela T, Jarvinen M, Kava T, et al Effects of reducing or discontinuing inhaled budesonide in patients with mild asthma N Engl J Med 1994 Sep 15 331(11):700 5
Heard AR, Richards IJ, Alpers JH, et al Randomised controlled trial of general practice based asthma clinics Med J Aust 1999 171(2):68 71 10474578
Hedges L. Distribution Theory for Glass's Estimator of Effect Size and Related Estimators. J Educat Stat. 1981;6:107-128.
Hedges LV, Olkin I, eds. Statistical methods for meta-analysis. Orlando: Academic Press. 1985. [pmcid: 397982].
Hoekstra MO, Grol MH, Bouman K, et al Fluticasone propionate in children with moderate asthma Am J Respir Crit Care Med 1996 Oct 154(4 Pt 1):1039 44 8887604
Hoekstra MO, Grol MH, Hovenga H, et al Eosinophil and mast cell parameters in children with stable moderate asthma Pediatr Allergy Immunol 1998 9(3):143 9 9814729
Hollman GA, Allen DB Overt glucocorticoid excess due to inhaled corticosteroid therapy Pediatrics 1988 Mar 81(3):452 5 3344190
Hoskins G, Neville RG, Smith B, et al Do self-management plans reduce morbidity in patients with asthma? Br J Gen Pract 1996 46(404):169 71 8731624 1239578
Hudgel DW, Langston L Jr, Selner JC, et al Viral and bacterial infections in adults with chronic asthma Am Rev Respir Dis 1979 Aug 120(2):393 7 475158
Hyland ME, Crocker GR Validation of an asthma quality of life diary in a clinical trial Thorax 1995 Jul 50(7):724 30 7570405
Ignacio-Garcia JM, Gonzalez-Santos P Asthma self-management education program by home monitoring of peak expiratory flow Am J Respir Crit Care Med 1995 Feb 151(2 Pt 1):353 9 7842191
Ip M, Lam K, Yam L, et al Decreased bone mineral density in premenopausal asthma patients receiving long-term inhaled steroids Chest 1994 Jun 105(6):1722 7 8205866
Johnston SL, Pattemore PK, Sanderson G, et al The relationship between upper respiratory infections and hospital admissions for asthma: a time-trend analysis Am J Respir Crit Care Med 1996 Sep 154(3 Pt 1):654 60 8810601
Jonasson G, Carlsen KH, Blomqvist P, et al Clinical efficacy of low-dose inhaled budesonide once or twice daily in children with mild asthma not previously treated with steroids Eur Respir J 1998 Nov 12(5):1099 104 9864004
Jones KP, Mullee MA, Middleton M, et al Peak flow based asthma self-management: a randomised controlled study in general practice. British Thoracic Society Research Committee Thorax 1995 Aug 50(8):851 7 7570436
Juni P, Witschi A, Bloch R, et al The hazards of scoring the quality of clinical trials for meta-analysis JAMA 1999 282(11):1054 1060 10493204
Juniper EF, Svensson K, O'Byrne PM, et al Asthma quality of life during 1 year of treatment with budesonide with or without formoterol Eur Respir J 1999 Nov 14(5):1038 43 10596687
Kavuru M, Melamed J, Gross G, et al Salmeterol and fluticasone propionate combined in a new powder inhalation device for the treatment of asthma: a randomized, double-blind, placebo-controlled trial J Allergy Clin Immunol 2000 Jun 105(6 Pt 1):1108 16 10856143
Kelloway JS, Wyatt RA, Adlis SA Comparison of patients' compliance with prescribed oral and inhaled asthma medications Arch Intern Med 1994 Jun 27 154(12):1349 52
Kelly HW. Comparison of inhaled corticosteroids. Ann Pharmacother. 1998;32:220-32. [pmid: 9496409].
Kelsen SG, Church NL, Gillman SA, et al Salmeterol added to inhaled corticosteroid therapy is superior to doubling the dose of inhaled corticosteroids: a randomized clinical trial J Asthma 1999 Dec 36(8):703 15 10609625
Kemp JP, Cook DA, Incaudo GA, et al Salmeterol improves quality of life in patients with asthma requiring inhaled corticosteroids. Salmeterol Quality of Life Study Group J Allergy Clin Immunol 1998 Feb 101(2 Pt 1):188 95 9500751
Kemp JP, Skoner DP, Szefler SJ, et al Once-daily budesonide inhalation suspension for the treatment of persistent asthma in infants and young children Ann Allergy Asthma Immunol 1999 83(3):231 9 10507269
Kips JC, O'Connor BJ, Inman MD, et al A long-term study of the antiinflammatory effect of low-dose budesonide plus formoterol versus high-dose budesonide in asthma Am J Respir Crit Care Med 2000 Mar 161(3 Pt 1):996 1001 10712354
Kotses H, Bernstein IL, Bernstein DI, et al A self-management program for adult asthma. Part I: Development and evaluation J Allergy Clin Immunol 1995 95(2):529 40 7852669
Lagerlov P, Veninga CC, Muskova M, et al Asthma management in five European countries: doctors' knowledge, attitudes and prescribing behaviour Eur Respir J 2000 Jan 15(1):25 9 10678616
Lahdensuo A, Haahtela T, Herrala J, et al Randomised comparison of guided self management and traditional treatment of asthma over one year BMJ 1996 312(7033):748 52 8605463
Langley SJ, Masterson CM, Batty EP, et al Bronchodilator response to salbutamol after chronic dosing with salmeterol or placebo Eur Respir J 1998 May 11(5):1081 5 9648959
Laviolette M, Malmstrom K, Lu S, et al Montelukast added to inhaled beclomethasone in treatment of asthma. Montelukast/Beclomethasone Additivity Group Am J Respir Crit Care Med 1999 Dec 160(6):1862 8 10588598
Li X, Ward C, Thien F, et al An antiinflammatory effect of salmeterol, a long-acting beta(2) agonist, assessed in airway biopsies and bronchoalveolar lavage in asthma Am J Respir Crit Care Med 1999 Nov 160(5 Pt 1):1493 9 10556111
Lieu TA, Quesenberry CP Jr, Capra AM, et al Outpatient management practices associated with reduced risk of pediatric asthma hospitalization and emergency department visits Pediatrics 1997 100(3 Pt 1):334 41 9282702
Liljas B, Lahdensuo A. Is asthma self-management cost-effective?. Patient Educ Counsel. 1997;32:S97-S104.
Limaye SR, Pillai S, Tina LU Relationship of steroid dose to degree of posterior subcapsular cataracts in nephrotic syndrome Ann Ophthalmol 1988 Jun 20(6):225 7 3408090
Lindberg M, Ahlner J, Moller M, et al Asthma nurse practice -- a resource-effective approach in asthma management Respir Med 1999 93(8):584 8 10542993
Lipworth BJ Systemic adverse effects of inhaled corticosteroid therapy: A systematic review and meta-analysis Arch Intern Med 1999 159(9):941 55 10326936
Lofdahl CG, Reiss TF, Leff JA, et al Randomised, placebo controlled trial of effect of a leukotriene receptor antagonist, montelukast, on tapering inhaled corticosteroids in asthmatic patients BMJ 1999 Jul 10 319(7202):87 90 28156
Madge P, McColl J, Paton J Impact of a nurse-led home management training programme in children admitted to hospital with acute asthma: a randomised controlled study Thorax 1997 52(3):223 8 9093336
Maljanian R, Wolf S, Goethe J, et al An inner-city asthma disease management initiative: Results of an outcomes evaluation Dis Manage Health Outcomes 1999 5(5):285 93
Malo JL, L'Archeveque J, Trudeau C, et al Should we monitor peak expiratory flow rates or record symptoms with a simple diary in the management of asthma? J Allergy Clin Immunol 1993 91(3):702 9 8454792
Markham A, Faulds D Montelukast Drugs 1998a 56(2):251 6 9711449
Markham A, Faulds D Theophylline: a review of its potential steroid sparing effects in asthma Drugs 1998b 56(6):1081 91 9878995
Maslennikova GYA, Morosova ME, Salman NV, et al Asthma education programme in Russia: educating patients Patient Educ Couns 1998 33(2):113 27 9732652
McIntosh K, Ellis EF, Hoffman LS, et al The association of viral and bacterial respiratory infections with exacerbations of wheezing in young asthmatic children J Pediatr 1973 Apr 82(4):578 90 4349062
McIvor RA, Pizzichini E, Turner MO, et al Potential masking effects of salmeterol on airway inflammation in asthma Am J Respir Crit Care Med 1998 158(3):924 30 9731027
McPeek B, Gilbert JP, Mosteller F Sounding Boards. The clinician's responsibility for helping to improve the treatment of tomorrow's patients N Engl J Med 1980 13;302(11):630 1
Meltzer EO, Orgel HA, Ellis EF, et al Long-term comparison of three combinations of albuterol, theophylline, and beclomethasone in children with chronic asthma J Allergy Clin Immunol 1992 Jul 90(1):2 11 1629506
"Dear Healthcare Professional" letter on Singulair® and Churg-Strauss syndrome. December 1998. West Point, PA.
Singulair® (montelukast sodium) tablets and chewable tablets prescribing information. Whitehouse Station, NJ. 2000 March. [pmcid: 384376].
Minoguchi K, Kohno Y, Oda N, et al. Effect of theophylline withdrawal on airway inflammation in asthma. Clin Exp Allergy. 1998 Aug;28 Suppl 3:57-63.
Mitchell P, Cumming RG, Mackey DA Inhaled corticosteroids, family history, and risk of glaucoma Ophthalmology 1999 Dec 106(12):2301 6 10599661
Moher D, Pham B, Jones A, et al Does quality of reports of randomized controlled trials affect estimates of intervention efficacy reported in meta-analyses? Lancet 1998 Aug 22 352(9128):609 13
Muhlhauser I, Richter B, Kraut D, et al Evaluation of a structured treatment and teaching programme on asthma J Intern Med 1991 230(2):157 164 1865168
Mulrow CD, Oxman AD, editors. Cochrane Collaboration Handbook. Available in the Cochrane Library [database on disk and CD-ROM]. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997.
Murray JJ, Church NL, Anderson WH, et al Concurrent use of salmeterol with inhaled corticosteroids is more effective than inhaled corticosteroid dose increases Allergy Asthma Proc 1999 20(3):173 80 10389550
Nassif E, Weinberger M, Sherman B, et al Extrapulmonary effects of maintenance corticosteroid therapy with alternate-day prednisone and inhaled beclomethasone in children with chronic asthma J Allergy Clin Immunol 1987 Oct 80(4):518 29 3668116
Nassif EG, Weinberger M, Thompson R, et al The value of maintenance theophylline in steroid-dependent asthma N Engl J Med 1981 Jan 8 304(2):71 5
Expert panel report: guidelines for the diagnosis and management of asthma. Bethesda MD: National Institutes of Health; 1992. NIH Publication No 92-3091.
Expert panel report 2: guidelines for the diagnosis and management of asthma. Bethesda MD: National Institutes of Health; 1997 July. NIH Publication No. 97-4051.
Nelson HS Beta-adrenergic bronchodilators N Engl J Med 1995 Aug 24 333(8):499 506 7623883
Nicholson KG, Kent J, Ireland DC Respiratory viruses and exacerbations of asthma in adults BMJ 1993 Oct 16 307(6910):982 6
Nielsen LP, Pedersen B, Faurschou P, et al Salmeterol reduces the need for inhaled corticosteroid in steroid-dependent asthmatics Respir Med 1999 Dec 93(12):863 8 10653047
Osman LM, Abdalla MI, Beattie JA, et al Reducing hospital admission through computer supported education for asthma patients. Grampian Asthma Study of Integrated Care (GRASSIC) BMJ 1994 308(6928):568 71 8093148
Overbeek SE, Kerstjens HA, Bogaard JM, et al Is delayed introduction of inhaled corticosteroids harmful in patients with obstructive airways disease (asthma and COPD)? The Dutch CNSLD Study Group. The Dutch Chronic Nonspecific Lung Disease Study Groups Chest 1996 110(1):35 41 8681660
Partridge MR. Asthma: guided self-management should help adults. Br Med J. 1994;308:547-548. [pmid: 8148674].
Pauwels RA, Lofdahl CG, Postma DS, et al Effect of inhaled formoterol and budesonide on exacerbations of asthma. Formoterol and Corticosteroids Establishing Therapy (FACET) International Study Group N Engl J Med 1997 Nov 13 337(20):1405 11
Pauwels RA, Yernault JC, Demedts MG, et al Safety and efficacy of fluticasone and beclomethasone in moderate to severe asthma. Belgian Multicenter Study Group Am J Respir Crit Care Med 1998 157(3 Pt 1):827 32 9517598
Pearlman DS, Stricker W, Weinstein S, et al Inhaled salmeterol and fluticasone: a study comparing monotherapy and combination therapy in asthma Ann Allergy Asthma Immunol 1999 82(3):257 65 10094216
Pocock SJ, Elbourne DR Randomized trials or observational tribulations? N Engl J Med 2000 Jun 22 342(25):1907 9
Price JF, Russell G, Hindmarsh PC, et al Growth during one year of treatment with fluticasone propionate or sodium cromoglycate in children with asthma Pediatr Pulmonol 1997 24(3):178 86 9330414
Priftis K, Everard ML, Milner AD Unexpected side-effects of inhaled steroids: a case report Eur J Pediatr 1991 Apr 150(6):448 9 1904030
Priftis K, Milner AD, Conway E, et al Adrenal function in asthma Arch Dis Child 1990 Aug 65(8):838 40 2400219
Ramage L, Cree IA, Dhillon DP Comparison of salmeterol with placebo in mild asthma: effect on peripheral blood phagocyte function and cytokine levels Int Arch Allergy Immunol 1994 105(2):181 4 7920018
Redline S, Wright EC, Kattan M, et al Short-term compliance with peak flow monitoring: results from a study of inner city children with asthma Pediatr Pulmonol 1996 21(4):203 10 9121848
Reed CE The natural history of asthma in adults: the problem of irreversibility J Allergy Clin Immunol 1999 Apr 103(4):539 47 10199998
Reinus JF, Persky S, Burkiewicz JS, et al Severe liver injury after treatment with the leukotriene receptor antagonist zafirlukast Ann Intern Med 2000 133(12):964 968 11119397
Ribeiro LB Budesonide: safety and efficacy aspects of its long-term use in children Pediatr Allergy Immunol 1993 May 4(2):73 8 8353649
Rodrigo G, Rodrigo C Corticosteroids in the emergency department therapy of acute adult asthma: an evidence-based evaluation Chest 1999 116(2):285 95 10453853
Ronchetti R, Indinnimeo L, Bonci E, et al Asthma self-management programmes in a population of Italian children: a multicentric study. Italian Study Group on Asthma Self-Management Programmes Eur Respir J 1997 10(6):1248 53 9192924
Rosenthal R (1978) Combining results of independent studies Psych Bull 85(1),185 193
Rosenthal R. "Parametric measures of effect size,". In The Handbook of Research Synthesis, Russell Sage Foundation, New York, 1994.
Rosenthal R. Meta-Analytic Procedures for Social Research, Beverly Hills: Sage Publications, 1984.
Rubinfeld AR, Pain MC Perception of asthma Lancet 1976 Apr 24 1(7965):882 4
Ruffin RE, Pierce RJ. Peak flow monitoring - which asthmatics, when, and how?. Aust NZ J Med. 1994;24:519-520.
Russell G, Williams DA, Weller P, et al Salmeterol xinafoate in children on high dose inhaled steroids Ann Allergy Asthma Immunol 1995 Nov 75(5):423 8 7583864
Schulz KF, Chalmers I, Hayes RJ, et al Empirical evidence of bias: dimensions of methodological quality associated with estimates of treatment effects in controlled trials JAMA 1995 273(5):408 12 7823387
Scott MB, Skoner DP Short-term and long-term safety of budesonide inhalation suspension in infants and young children with persistent asthma J Allergy Clin Immunol 1999 Oct 104(4 Pt 2):200 9 10518847
Selroos O, Pietinalho A, Lofroos AB, et al Effect of early vs late intervention with inhaled corticosteroids in asthma Chest 1995 108(5):1228 34 7587421
Shapiro G, Lumry W, Wolfe J, et al Combined salmeterol 50 microg and fluticasone propionate 250 microg in the Diskus device for the treatment of asthma Am J Respir Crit Care Med 2000 Feb 161(2 Pt 1):527 34 10673196
Shapiro G, Mendelson L, Kraemer MJ, et al Efficacy and safety of budesonide inhalation suspension (Pulmicort Respules) in young children with inhaled steroid-dependent, persistent asthma J Allergy Clin Immunol 1998 102(5):789 96 9819296
Shapiro GG, Eggleston PA, Pierson WE, et al Double blind study of the effectiveness of a broad spectrum antibiotic in status asthmaticus Pediatrics 1974 53(6):867 72 4598933
Sharek PJ, Bergman DA The effect of inhaled steroids on the linear growth of children with asthma: a meta-analysis Pediatrics 2000 Jul 106(1):
Sherman J, Hutson A, Baumstein S, et al Telephoning the patient's pharmacy to assess adherence with asthma medications by measuring refill rate for prescriptions J Pediatr 2000 136(4):532 6 10753254
Shrewsbury S, Pyke S, Britton M Meta-analysis of increased dose of inhaled steroid or addition of salmeterol in symptomatic asthma (MIASMA) BMJ 2000 May 20 320(7246):1368 73 27379
Silverstein MD, Yunginger JW, Reed CE, et al. Attained adult height after childhood asthma: effect of glucocorticoid therapy. J Allergy Clin Immunol. 1997;99:466-474. [pmid: 9111490].
Simons FE A comparison of beclomethasone, salmeterol, and placebo in children with asthma. Canadian Beclomethasone Dipropionate-Salmeterol Xinafoate Study Group N Engl J Med 1997 Dec 4 337(23):1659 65 9385125
Simons FE, Persaud MP, Gillespie CA, et al Absence of posterior subcapsular cataracts in young patients treated with inhaled glucocorticoids Lancet 1993 342(8874):776 8 8103877
Smith NA, Seale JP, Ley P, et al Better medication compliance is associated with improved control of childhood asthma Monaldi Arch Chest Dis 1994 49(6):470 4 7711695
Storr J, Lenney CA, Lenney W Nebulised beclomethasone dipropionate in preschool asthma Arch Dis Child 1986 Mar 61(3):270 3 3516078
Sudre P, Jacquemet S, Uldry C, et al. Objectives, methods and content of patient education programmes for adults with asthma: systematic review of studies published between 1979 and 1998. Thorax. 1999;54:681-687. [pmid: 10413719].
Svedmyr N, Lofdahl CG The use of beta 2-adrenoceptor agonists in the treatment of bronchial asthma Pharmacol Toxicol 1996 78(1):3 11 8685084
Tamaoki J, Kondo M, Sakai N, et al Leukotriene antagonist prevents exacerbation of asthma during reduction of high-dose inhaled corticosteroid. The Tokyo Joshi-Idai Asthma Research Group Am J Respir Crit Care Med 1997 Apr 155(4):1235 40 9105060
Taylor AV, Laoprasert N, Zimmerman D, et al Adrenal suppression secondary to inhaled fluticasone propionate Ann Allergy Asthma Immunol 1999 Jul 83(1):68 70 10437819
Taylor DA, Jensen MW, Kanabar V, et al A dose-dependent effect of the novel inhaled corticosteroid ciclesonide on airway responsiveness to adenosine-5'-monophosphate in asthmatic patients Am J Respir Crit Care Med 1999 Jul 160(1):237 43 10390406
QVAR (beclomethasone dipropionate HFA) inhalation aerosol receives FDA approval for asthma [press release]. St. Paul (MN). 2000 Sept 15. [pmcid: 384376].
Tinkelman DG, Reed CE, Nelson HS, et al Aerosol beclomethasone dipropionate compared with theophylline as primary treatment of chronic, mild to moderately severe asthma in children Pediatrics 1993 Jul 92(1).
Tomita K, Hashimoto K, Matsumoto S, et al [Pranlukast allows reduction of inhaled steroid dose without deterioration in lung function in adult asthmatics] Arerugi 1999 Apr 48(4):459 65 10355150
Tripathi RC, Kipp MA, Tripathi BJ, et al Ocular toxicity of prednisone in pediatric patients with inflammatory bowel disease Lens Eye Toxic Res 1992 9(3-4):469 82 1301798
Turner MO, Taylor D, Bennett R, et al A randomized trial comparing peak expiratory flow and symptom self-management plans for patients with asthma attending a primary care clinic Am J Respir Crit Care Med 1998 Feb 157(2):540 6 9476870
Ukena D, Harnest U, Sakalauskas R, et al Comparison of addition of theophylline to inhaled steroid with doubling of the dose of inhaled steroid in asthma Eur Respir J 1997 Dec 10(12):2754 60 9493656
Ulrik CS Outcome of asthma: longitudinal changes in lung function Eur Respir J 1999 Apr 13(4):904 18 10362061
Orally Inhaled/Intranasal Corticosteroids and Growth in Children: Transcripts of a joint meeting of Pulmonary Allergy Drugs Advisory Committee and the Endocrinologic and Metabolic Drugs Advisory Committee. Bethesda, MD, July 30 and 31, 1998. Available online at http://www.fda.gov/ohrms/dockets/ac/98/transcpt/3430t1.pdf (July 30, 1998 transcript) and http://www.fda.gov/ohrms/dockets/ac/98/transcpt/3430t2.pdf (July 31, 1998 transcript). Last accessed: December 4, 2000.
Van Bever HP, Desager KN, Lijssens N, et al. Does treatment of asthmatic children with inhaled corticosteroids affect their adult height?. Pediatric Pulmonol. 1999;27:369-375.
van der Molen T, Postma DS, Turner MO, et al Effects of the long acting beta agonist formoterol on asthma control in asthmatic patients using inhaled corticosteroids. The Netherlands and Canadian Formoterol Study Investigators Thorax 1997 Jun 52(6):535 9 9227720
van Essen-Zandvliet EE, Hughes MD, Waalkens HJ, et al Effects of 22 months of treatment with inhaled corticosteroids and/or beta-2-agonists on lung function, airway responsiveness, and symptoms in children with asthma. The Dutch Chronic Non-specific Lung Disease Study Group Am Rev Respir Dis 1992 Sep 146(3):547 54 1355640
van Noord JA, Schreurs AJ, Mol SJ, et al Addition of salmeterol versus doubling the dose of fluticasone propionate in patients with mild to moderate asthma Thorax 1999 Mar 54(3):207 12 10325895
Verberne AA, Frost C, Duiverman EJ, et al Addition of salmeterol versus doubling the dose of beclomethasone in children with asthma. The Dutch Asthma Study Group Am J Respir Crit Care Med 1998 Jul 158(1):213 9 9655732
Verberne AA, Frost C, Roorda RJ, et al One year treatment with salmeterol compared with beclomethasone in children with asthma. The Dutch Paediatric Asthma Study Group Am J Respir Crit Care Med 1997 Sep 156(3 Pt 1):688 95 9309980
Vermetten FA, Boermans AJ, Luiten WD, et al Comparison of salmeterol with beclomethasone in adult patients with mild persistent asthma who are already on low-dose inhaled steroids J Asthma 1999 36(1):97 106 10077139
Villaran C, O'Neill SJ, Helbling A, et al Montelukast versus salmeterol in patients with asthma and exercise-induced bronchoconstriction. Montelukast/Salmeterol Exercise Study Group J Allergy Clin Immunol 1999 Sep 104(3 Pt 1):547 53 10482826
Wechsler ME, Drazen JM Zafirlukast and Churg-Strauss syndrome Chest 1999 116(1):266 7
Wechsler ME, Finn D, Gunawardena D, et al Churg-Strauss syndrome in patients receiving montelukast as treatment for asthma Chest 2000 117(3):708 13 10712995
Wechsler ME, Pauwels R, Drazen JM Leukotriene modifiers and Churg-Strauss syndrome: adverse effect or response to corticosteroid withdrawal? Drug Saf 1999 21(4):241 51 10514017
Weersink EJ, Douma RR, Postma DS, et al Fluticasone propionate, salmeterol xinafoate, and their combination in the treatment of nocturnal asthma Am J Respir Crit Care Med 1997 Apr 155(4):1241 6 9105061
Weinberger M, Hendeles L Theophylline in asthma New Engl J Med 1996 334(21):1380 8 8614425
Wesseldine LJ, McCarthy P, Silverman M Structured discharge procedure for children admitted to hospital with acute asthma: A randomised controlled trial of nursing practice Arch Dis Child 1999 80(2):110 4 10325723
White MV, Cruz-Rivera M, Walton-Bowen K The efficacy and safety of budesonide inhalation suspension: a nebulizable corticosteroid for persistent asthma in infants and young children Fam Med 1999 31(5):337 45 10407712
Wilding P, Clark M, Coon JT, et al Effect of long-term treatment with salmeterol on asthma control: a double blind, randomised crossover study BMJ 1997 May 17 314(7092):1441 6
Woolcock A, Lundback B, Ringdal N, et al Comparison of addition of salmeterol to inhaled steroids with doubling of the dose of inhaled steroids Am J Respir Crit Care Med 1996 May 153(5):1481 8 8630590
Yates DH, Sussman HS, Shaw MJ, et al Regular formoterol treatment in mild asthma. Effect on bronchial responsiveness during and after treatment Am J Respir Crit Care Med 1995 Oct 152(4 Pt 1):1170 4 7551366
Yoon R, McKenzie DK, Bauman A, et al Controlled trial evaluation of an asthma education programme for adults Thorax 1993 48(11):1110 6 8296253
Accolate® (zafirlukast) tablets prescribing information. Wilmington, DE. 2000 June. [pmcid: 384376].
Zimmerman B, Gold M, Wherrett D, et al Adrenal suppression in two patients with asthma treated with low doses of the inhaled steroid fluticasone propionate J Allergy Clin Immunol 1998 Mar 101(3):425 6 9525464