# Future Research Priorities

- The overriding priority is to develop a national research agenda for long-term studies to improve the effectiveness of asthma management. Short-term drug efficacy studies are overrepresented in the present literature. It is imperative to develop an evidence base that supports clinical decision-making on the intensity of treatment, optimization of medication regimens, and utility of disease management interventions for various asthma populations.

The dearth of long-term effectiveness studies compared to short-term drug efficacy studies is demonstrated by the evidence base available for this systematic review. Twenty-eight trials reporting on over 7,000 patients were identified to show the efficacy of adding long-term beta-2 agonists to ICS, when used over periods of 6 weeks to 1 year. In contrast, for the question of whether early initiation of long-term controller therapy prevents disease progression in patients with mild to moderate asthma, a mere four trials reporting on 475 patients over approximately 3 years were available when this project began. Moreover, these trials were not adequately designed to answer the question of interest, leaving virtually no evidence on which to base a clinical decision of profound concern.

As this systematic review was nearing completion, the results of the National Institutes of Health funded CAMP trial were published, offering the most robust evidence to date on whether chronic use of ICS prevents an irreversible long-term decline in lung function among mild-moderate asthmatics. However, several relevant dimensions of this question have yet to be addressed, including the proper timing for the initiation of ICS, the consequences for changes in lung function over a lifetime, and the effect of treatment in subpopulations of asthmatics that may have variable outcomes. There are well-known difficulties in conducting randomized controlled trials in large populations over the necessarily long time periods, primarily due to resource constraints. Careful consideration should be given to various epidemiological and intervention approaches so that studies that are both rigorous and feasible can be conducted. The Framingham studies of cardiovascular disease are an example that might serve as a model for such an undertaking.

Comparative studies of the relative effectiveness, cost-effectiveness, and patient utilities of alternative management strategies for various asthma populations are needed. A portfolio of study questions can be prioritized to support the systematic development of treatment algorithms for clinical indications that occur commonly and also for those that are less common, but difficult to manage. Studies to support clinical decision-making will differ from the approach that we found to be most common in the existing literature; in which two drugs were compared and group means reported for a heterogeneous population of asthmatics. Studies that compare alternative management strategies in specific asthma populations would have greater clinical relevance. The specific pharmacologic agent is only one component of a management strategy; which may also include questions of when to initiate, change, or combine agents and other questions related to dose intensity, frequency, and timing. Comparisons of the interchangeability and costs of various agents and combinations should be incorporated into this research agenda.

This systematic review has shown that there is little empirical evidence to support the effectiveness of the discrete components of disease management intervention we considered, i.e., the use of PFMs and written asthma management plans. Nor does the available evidence clearly show that these interventions are ineffective, especially if they are used in highly selected populations rather than the general asthma population. It would be preferable if careful culling and empirical study of the various components had preceded, rather than followed, widespread dissemination of these interventions. Until more rigorous evidence is available, the best data on the outcomes of disease management may be from evaluation research in health care settings that implement such programs. However, such data will be better suited to evaluating the overall effect of disease management interventions, rather than determining the contribution of specific components. National recommendations on methods for conducting evaluations, along with a venue for systematically reporting the findings of evaluations conducted in accordance with those methods, would have practical value.

- Pediatric studies should have high priority in a national research agenda for long-term studies to improve the effectiveness of asthma management.

Long-term studies in children are especially important. Childhood asthma and its treatment are common and likely increasing. Long term, epidemiologic evidence on the natural history and prognostic factors in childhood asthma would improve understanding of the relative benefits and risks of alternative management strategies. Specifically, a better understanding of the natural history and prognostic indicators in childhood asthma is a crucial foundation to determining the utility of early intervention with long-term controller medication, especially in very young children. Systematic pharmacologic studies on minimal effective dosages of individual agents and combinations in children would complement the long-term research agenda by providing data to avoid unnecessary exposure to adverse effects. To date, evidence on long-term adverse effects of ICS on growth addresses mainly vertical growth, and the potential for more subtle growth effects that are neurologic, organ, or endocrine system-related, and perhaps specific to certain developmental stages, appears to be largely unexplored. Evidence on the benefits and adverse effects of asthma treatment in populations of children who are undergoing concurrent treatment for other chronic conditions is relevant to the broader concerns of pediatric practice. In general, the setting of any chronic treatment initiated in childhood poses challenges in assessing the effects of cumulative exposure and interactions with other risk factors over the course of a lifetime.

- Future asthma trials should use common, internationally accepted definitions for defining asthma severity, other relevant population characteristics, and outcome measures. Distinct definitions for children and adults are likely to be necessary. Validation work is needed on classification schemes for severity. Because classifications of severity and prognosis may evolve with future research, panels of relevant data elements to be collected should also be standardized. The common definitions should include validated instruments for standard measurement of symptoms and of quality of life. Finally, compliance with recognized standards for reporting and statistical analyses should be common practice.

Compared to other fields studying common conditions, such as oncology and cardiology, asthma trials were found to be notably lacking in common definitions for patient entry characteristics, clinically relevant endpoints, and outcome measures. Such common definitions should be internationally accepted; for example, European trials often reported on mixed populations of patients with asthma and/or COPD without clearly distinguishing baseline characteristics or results. Where relevant trials existed for the key questions, the ability to compare and combine results was often hampered by the lack of consistent definitions for reporting patient characteristics and outcomes. In addition, benchmarks were lacking to interpret the clinical relevance of the most frequently reported outcome measurements.

The relationship between lung function measures and symptoms as indicators of asthma control is not well delineated. It was difficult to gauge the clinical significance of the reported magnitudes of change in symptom scores in studies where symptom frequencies were not also reported. Few studies prospectively defined the changes in measures of primary outcomes that would be considered clinically significant in assessing results. Validated QOL instruments were infrequently utilized.

In addition, there were common reporting deficiencies in clinical asthma trials. The recommendations of the CONSORT Statement should be more widely and completely adopted in the reporting of asthma trials. In addition, as evidenced by the detailed analysis in "Results and Conclusions Part 2: Effects of Delayed ICS on Progression and Reversibility," several widely cited and influential studies concluding that earlier intervention with ICS benefits long-term lung function suffered from serious deficiencies in methodology. It is not surprising that the more rigorous design and methods used in the CAMP trial did not confirm the conclusions of these studies.

- Research to support to the rational use of antibiotics should include explicit study questions and populations relevant to the treatment of patients with asthma.

This key question was narrowly defined to the use of antibiotics in the treatment of asthma exacerbations. It is plausible that many clinicians have a lower threshold for antibiotic use in patients with asthma, with the rationale that aggressive treatment of respiratory infection may have a positive impact on the severity of the asthma exacerbation. There were no trials relevant to the use of antibiotics to prevent exacerbations that were specifically secondary to bacterial infection. Empirical evidence is needed to improve the differential diagnosis of viral and bacterial infection in asthmatics, and to identify indications where antibiotic use results in clinically significant improvements in the course of infection. Studies of antibiotic use should include explicit study questions and populations relevant to the treatment of patients with asthma. Evidence is needed to determine indications where asthma patients can benefit from more aggressive antibiotic use and to identify indications where such practices lead to unnecessary use of antibiotics.