# Results and Conclusions Part 5. Asthma Management Plans

Key Question 5a. Compared to medical management alone, does the use of a written asthma action plan improve outcomes?

Key Question 5b. Compared to a written action plan based on symptoms, does use of a written action plan based on peak flow monitoring improve outcomes?

(Evidence also was sought to address the four additional questions below, but no studies that met the study selection criteria were found.

- What are the outcomes of a written action plan for daily use compared to a written action plan for exacerbation use only?
- What are the outcomes of peak flow monitoring without an action plan to medical management alone?
- What are the outcomes of chronic peak flow monitoring compared to exacerbation-only peak flow monitoring?
- What are the relative outcomes of alternative schedules of peak flow monitoring?)

## Overview

The objective of this chapter is to assess the independent effects of specific components commonly included in asthma self-management plans. However, there were considerable difficulties in analyzing the evidence, largely due to three general attributes of the available literature. The first is the complexity of the multimodal asthma management interventions that are applied in published clinical trials. Most studies did not permit isolation of the independent effects of a written action plan, or the effects of a peak-flow-based plan compared to a symptom plan. Second, the studies did not clearly identify the patient population expected to benefit from a written asthma plan, the primary outcomes of interest, or prospectively define the level of improvement that was considered clinically meaningful. As a consequence, the third feature of this literature is that it is almost completely composed of studies that were not powered to detect a difference in outcome between the treatment and control groups. Finally, in the two studies that did report statistically significant results, there is insufficient detail in reporting to judge whether the results represent a treatment effect or biases related to patient selection and withdrawal.

The initial selection criteria for this question were broad and resulted in a total of 36 studies meeting the criteria (Table 25). Review of these studies revealed many that were confounded by multiple asthma management interventions and thus did not isolate a comparison of interest to this review. For example, the in tervention group might receive optimization of medications, education, and counseling in addition to a PFM-based written action plan, while the control group received usual care. Particular caution was taken with studies that reviewed or adjusted medications in the treatment group, but not the control group, as this in itself is likely to improve control. Therefore, the study selection criteria were refined to identify those articles that made specific comparisons relevant to this analysis, randomly allocated patients to treatment group, and were not confounded by other components of asthma management that might affect outcomes. This second-level review resulted in a total of nine randomized controlled trials that met the selection criteria for this key question. (See Evidence Tables 5-1 through 5-9.)

Table 25. Table of included and excluded studies for results and conclusions, part 5

Author/Year | Design | Components | | Applicable to relevant comparison | Random allocation? | Met criteria for written action plan? | Intervention group free of contamination? | Include/exclude
Author/Year | Design | Control | Intervention | Applicable to relevant comparison | Random allocation? | Met criteria for written action plan? | Intervention group free of contamination? | Include/exclude
D'Souza, Burgess, Ayson et al. 1996 | Pre-post, retrospective Action plan vs. usual care | M.D. review | 1. M.D. review; 2. Education; 3. Support (transport, answer questions); 4. Credit card written action plan, using symptoms or PF | Yes | No | Yes | No | Exclude
Garret, Fenwick, Taylor et al. 1994 | RCT Asthma education in asthma clinic vs. usual followup | Usual care | 1. Education; 2. Action plan based on symptoms and/or PF readings | Yes | Yes | Yes | No | Exclude
Wesseldine, McCarthy, and Silverman 1999 | RCT Self mgt w/written action plan vs. usual care | Usual care | 1. Education (one 20-min session and written materials); 2. Written action plan based on symptoms and PF readings | Yes | Yes | Yes | No | Exclude
Beasley, D'Souza, Te Karu et al. 1993 | Pre-post Asthma action plan vs. usual care | Usual care | 1. Asthma clinics; 2. Review meds; 3. Letter to M.D.; 4. Action plan; 5. Support (transport, answer questions) | Yes | No | NR | No | Exclude
D'Souza, Crane, Burgess et al. 1994 | Pre-post Self-mgt vs. usual care | M.D. review | 1. M.D. review; 2. Education; 3. Support (transport, answer questions); 4. Credit card written action plan, using symptoms or PF | Yes | No | Yes | No | Exclude
D'Souza, Te Karu, Fox et al. 1998 | Followup of credit card program | M.D. review | 1. M.D. review; 2. Education; 3. Support (transport, answer questions); 4. Credit card written action plan, using symptoms or PF | Yes | No | Yes | No | Exclude
Choy, Tong, Ko et al. 1999 | Pre-post, prospective Self-mgt vs. usual care | Usual care | 1. Education (1 2-hr session); 2. Educational videos at clinic followup; 3. Credit card action plan based on PF and/or symptoms | Yes | No | Yes | No | Exclude
Maljanian, Wolf, Goethe et al. 1999 | Pre-post, prospective Self-management vs. Usual care | Usual care | 1. Education (6 sessions, ? total time); 2. Environmental control measures; 3. Action plan | Yes | No | NR | No | Exclude
Jones, Mullee, Middleton et al. 1995 | RCT PF self-mgt vs. M.D. mgt | M.D. review of symptom diary. Five study visits | 1. PFM self monitoring; 2. Written action plan based on PF; 3. M.D. review of symptom diary. Five study visits | Yes | Yes | NR | Yes | Include
Drummond, Abdalla, Buckingham et al. 1994 GRASSIC | RCT 2x2x2 Integrated vs. conventional care | Usual care | Integrated care - systematic management of chronic disease by specialists and general practitioners | No | Yes | Yes | No | Exclude
Drummond, Abdalla, Beattie et al. 1994 GRASSIC | RCT 2x2x2 Self-monitoring vs. conventional monitoring of PF | Usual oupt advice (no action plan; no PF). | 1. PF self-monitoring; 2. Action plan based on PFM | Yes | Yes | Yes | Yes | Include
Kotses, Bernstein, Bernstein et al. 1995 | RCT, crossover Self-mgt vs. waiting list control (2 vs. 6 mos baseline) | Usual care (delayed intervention) | 1. Symptom diary; 2. PF self monitoring; 3. Patient manual; 4. Education sessions (7 90-min sessions) | Yes | Yes | Yes | No | Exclude
Ignacio-Garcia and Gonzalez-Santos, 1995 | RCT Self-mgt w/PF vs. Dr. mgt w/symptoms and spirometry | 1. Dr. review + adjust meds; 2. PF self-monitoring | 1. Dr. review + adjust meds; 2. PF self-monitoring; 3. Written action plan based on PF readings; 4. Education (1 30-min session) | Yes | Yes | Yes | Yes | Include
Osman, Abdalla, Beattie et al. 1994 | RCT Computer enhanced education vs. usual education | 1. Usual care; 2. Usual asthma education; 3. M.D. review every 3 mos | 1. Enhanced asthma education (4 pt booklets); 2. M.D. review every 3 mos | No | Yes | Yes | No | Exclude
Gillies, Barrie, Crane et al. 1996 | Pre-post; prospective. Written action plan vs. Usual care | Usual care | Written action plan, using both symptoms and peak flow as appropriate | Yes | No | Yes | Yes | Exclude
Hoskins, Neville, Smith et al. 1996 | Randomized practitioners Action plan + usual care vs. usual care | Usual care | Written action plan based on symptoms and/or PF readings | Yes | No | Yes | Yes | Exclude
Madge, McColl, Paton et al. 1997 | RCT Self-mgt vs. usual care | Usual care | 1. Written action plan; 2. 1-3 education sessions with nurse; 3. F/U nurse appointment Telephone contact as needed | Yes | Yes | No | No | Exclude
Cote, Cartier, Robichaud et al. 1997 | RCT Optimization only vs. optimization + self mgt w/PF vs. optimization + self mgt w/symptoms | 1. Limited education | Group 1; 1. Enhanced education; 2. Written action plan based on PF readings; Group 2; 1. Enhanced education; 2. Written action plan based on symptoms | Yes | Yes | NR | No (Control vs. intervention) Yes (Group 1 vs. Group 2) | Include
Lindberg, Ahlner, Moller et al. 1999 | Pre-post Nurse education in self mgt vs. usual care | Usual care | 1. Nurse education (3 sessions, 90 min, 60 min, 60 min); 2. Symptom monitoring; 3. PF self-monitoring | Yes | No | Yes | No | Exclude
Heard, Richards, Alpers 1999 | RCT Unblinded Education + written plan vs. usual care | Usual care | 1. Education (3 3-hour asthma clinic per week); 2. PF self-monitoring; 3. written action plan based on PF readings; 4. Patient diary | Yes | Yes | Yes | No | Exclude
Ghosh, Ravindran, Joshi et al. 1998 | RCT Asthma self-mgt vs. usual care | Usual care | 1. Education (4 sessions 2- hours each); 2. PF self-monitoring; 3. Written action plan based on PF readings | Yes | Yes | NR | No | Exclude
Turner, Taylor, Bennett et al. 1998 | RCT Self mgt w/PF vs. Self mgt symptoms | No 'control' group | Group 1; 1. Education; 2. Written action plan based on PF readings; Group 2; 1. Education; 2. Written action plan based on symptoms | Yes | Yes | Yes | Yes | Include
Cowie, Revitt, Underwood et al. 1997 | RCT No action plan vs. action plan w/symptoms vs. action plan w/PF | Education | Group 1; 1. Education; 2. Written action plan based on PF readings; Group 2; 1. Education; 2. Written action plan based on symptoms | Yes | Yes | Yes | Yes | Include
Lieu, Quesenberry Jr, Capra et al. 1997 | Case control, Associational [not intervention] study | Controls - Patients without hospitalization or ER visit | Cases - Patients with a hospitalization or ER visit in past 24 months | No | No | Not able to determine | No | Exclude
Ronchetti, Indinnimeo, Bonci et al. 1997 | RCT Self-mgt education 1 vs. self mgt ed 2 vs. no self mgt | Usual care | 1. Education - two different education interventions (4-8 1-hour sessions); 2. Written action plan | Yes | Yes | NR | No | Exclude
Charlton, Antoniou, Atkinson et al. 1994 | RCT Self mgt w/PF vs. usual care + PF | 1. Nurse interview in hospital; 2. PF instructions and self-management; 3. Nurse visit every 3 mos | 1. Nurse extended interview in hospital; 2. PF instructions and self-management; 3. Diary card; 4. Instructions on meds; 5. Nurse visit every 3 mos | Yes | Yes | Yes | Yes | Include
Yoon, McKenzie, Bauman et al. 1993 | RCT Education vs. no education | 1. Usual care; 2. PF self-monitoring | 1. Education (1 session 2.5-3 hrs); 2. PF self-monitoring; 3. "Treatment plan" based on PF readings | Yes | Yes | NR | No | Exclude
Charlton, Charlton, Broomfield et al. 1990 | RCT PF Self mgt vs. symptoms only self-mgt | | Group 1 Written action plan based on PF Group 2 Written action plan based on symptoms | Yes | Yes | NR | Yes | Include
Bailey, Richards Jr, Brooks et al. 1990 | RCT Self mgt vs "usual care" | 1. Usual care; 2. Standard education | 1. Enhanced education; 2. One-to-one counseling session; 3. Asthma support group; 4. Telephone contact | Yes | Yes | No | No | Exclude
Gallefoss and Bakke 1999 | RCT Education vs. usual care | Usual care | 1. Education (2 2-hr sessions, written materials); 2. 1-2 individual sessions with nurse; 3. PF self-monitoring; 4. Written action plan based on PF readings | Yes | Yes | NR | No | Exclude
Mulhauser, Richter, Kraut et al. 1991 | Pre-post, prospective Self-mgt/education vs. usual care | Usual care | 1. Education (20 hrs of group instruction); 2. Written action plan based on symptoms | Yes | No | NR | No | Exclude
Maslennikova, Morosova, Salman et al. 1998 | RCT Self-mgt education 1 vs. self mgt ed 2 vs. no self mgt | Usual care | Education (4 sessions 1-1.25 hrs) - one of two programs based on literacy levels | Yes | Yes | NR | No | Exclude
Malo, L'Archeveque, Trudeau et al. 1993 | RCT, single-blind, crossover Symptom monitoring vs. PF monitoring | Symptom monitoring | PF self-monitoring | No | Yes | NR | Yes | Exclude
Smith, Seale, Ley et al. 1994 | Pre-post Written action vs. usual care | 1. Usual care; 2. PF self-monitoring | 1. Education (written materials); 2. Behavioral strategies for barriers to compliance; 3. Written action plan | Yes | No | NR | No | Exclude
Lahdensuo, Haahtela, Herrala et al. 1996 | RCT Self-mgt vs. usual care To detect exacerbations | Usual care | 1. Education; 2. Counseling; 3. Symptom recording; 4. PF self-monitoring; 5. Written action plan based on PF readings | Yes | Yes | No | No | Exclude
Ayres and Campbell 1996 | RCT, open Self mgt vs. Dr. mgt To adjust daily ICS dose | 1. PF self-monitoring; 2. Dr. management of ICS (4 study visits) | 1. PF self-monitoring; 2. Self-management of ICS dose based on PF readings | Yes | Yes | NR | Yes | Include

The nine randomized controlled trials enrolled a total of 1,501 patients. Tables 26-30 summarize the study characteristics and key findings for these studies. The largest of the nine trials was the Grampian Asthma Study of Integrated Care (GRASSIC, n=569), a community study conducted in the United Kingdom (Drummond, Abdalla, Beattie et al., 1994). The other eight studies were of similar size, with a range of 43-64 patients enrolled in each arm. Note that two trials (Cowie, Revitt, Underwood et al., 1997, Cote, Cartier, Robichaud et al., 1997) included three arms: medical management alone, PFM-based written action plan, and symptom-based written action plan group. This resulted in 11 comparisons among the nine studies. All studies used a parallel group design, with treatment duration ranging from 24 to 52 weeks.

Table 28. Change in lung function outcomes reported

Citation | Study Arm | # Enrolled # Evaluable | Overall Change FEV1 | Treatment Difference | p Value | Overall Change PEF | Treatment Difference | p Value
Usual care vs. PFM action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64/39 | −4.2% pred | | | −2.0% pred
Jones, Mullee, Middleton, et al., 1995 | PFM action plan | 63/33 | −3.9% pred | 0.2% pred | NS | −0.8% pred | 1.2% pred | NS
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284/260 | −2.7% pred | | | 3.4 L/min
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM action plan | 285/250 | −2.7% pred | 0 | NS | 5.5 L/min | 2.1 L/min | NS
Ayres, Campbell and Follows, 1995 | Usual care | 64/64 | 0.2 L | | | 28 L/min
Ayres, Campbell and Follows, 1995 | PFM action plan | 61/61 | 0.0 L | −0.2 L | NS | 10 L/min | 18 L/min | NS
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48/ | NR | | | NR
Cowie, Revitt, Underwood, et al., 1997 | PFM action plan | 46/ | NR | | | NR
Cote, Cartier, Robichaud et al., 1997 | Usual care | 54/ | NR | | | NR
Cote, Cartier, Robichaud et al., 1997 | PFM action plan | 50/ | NR | | | NR
Usual care + PFM use alone vs. usual care + PFM action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44/35 | 0.2% pred | | | 5 L/min
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM action plan | 50/35 | 11.4% pred | 11.2% pred | <0.004 | 31 L/min | 26 L/min | <0.003
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43/37 | NR | | | NR
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM action plan | 48/42 | NR | | | NR
PFM action plan vs. symptom action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom action plan | 48/48 | 7.4% pred | | | 40 L/min
Turner, Taylor, Bennett, et al., 1998 | PFM action plan | 44/44 | 4.9% pred | −2.5% pred | NS | 38 L/min | 2 L/min | NS
Charlton, Charlton, Broomfield, et al., 1990 | Symptom action plan | 64/ | NR | | | NR
Charlton, Charlton, Broomfield, et al., 1990 | PFM action plan | 51 | NR | | | NR
Cowie, Revitt, Underwood, et al., 1997 | Symptom action plan | 45/ | NR | | | NR
Cowie, Revitt, Underwood, et al., 1997 | PFM action plan | 46/ | NR | | | NR
Cote, Cartier, Robichaud et al., 1997 | Symptom action plan | 45/ | NR | | | NR
Cote, Cartier, Robichaud et al., 1997 | PFM action plan | 50/ | NR | | | NR

Table 29. Symptom and medication use outcomes reported

Citation | Study Arm | # Enrolled # Evaluable | Change in Symptom Score | Treatment Difference | p Value | Change in Symptom Frequency | Treatment Difference | p Value | Change in B-Agonist Use | Treatment Difference | p Value | Oral Steroid Use | p Value
Usual care vs. PFM action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64/39 | 4.95 ^a^ (0-3 scale) x (28 days)
Jones, Mullee, Middleton, et al., 1995 | PFM action plan | 63/33 | 2.85 ^a^ (0-3 scale) x (28 days) | 2.10 | NS
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284/260 | | | | 2.6 ^a^ nights/wk with symptoms | | | 9.0 (mean # prescribed/pt) | 1.1 (beta-2 agonist prescribed/pt) | NS | 1.4 courses/pt
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM action plan | 285/250 | | | NS ^a^ | 2.3 ^a^ nights/wk with symptoms | −0.3 nights/wk with symptoms | NS | 10.1 (mean # prescribed/pt) | | | 1.4 courses/pt | NS ^a^
Ayres, Campbell and Follows, 1995 | Usual care | 64/64 | −0.52 (0-3 scale) | −0.13 | NS | −3.9 nights/wk with symptoms
Ayres, Campbell and Follows, 1995 | PFM action plan | 61/61 | −0.39 (0-3 scale) | | | −3.9 nights/wk with symptoms | 0 nights/wk with symptoms | NS | | | | | NS ^a^
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48/ | | | | 4.9 ^a^ nights/wk with symptoms
Cowie, Revitt, Underwood, et al., 1997 | PFM action plan | 46/ | | | | 4.9 ^a^ nights/wk with symptoms | 0 nights/wk with symptoms | NS
Cote, Cartier, Robichaud et al., 1997 | Usual care | 54/ | | | | | | | | | | 0.5 courses/pt
Cote, Cartier, Robichaud et al., 1997 | PFM action plan | 50/ | | | | | | | | | | 0.7 courses/pt | NS
Usual care + PFM use alone vs. usual care + PFM action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44/35 | | | | 37.9 nights with symptoms | | | 1 dose/pt/6 mos | | | 1,350 mg total use/pt
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM action plan | 50/35 | | | | 16.5 nights with symptoms | −21.4 nights with symptoms | <0.001 ^a^ | −47 doses/pt/6 mos | −48 doses/pt/6 mos | NS | 927 mg total use/pt | NS
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43/37 | 0.22 ^a^ (0-3 scale) | 0.04 (0-3 scale) | NS | | | | 1.7 ^a^ puffs/day | −0.2 puffs/day | NS | 0 days/pt/yr | NS
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM action plan | 48/42 | 0.26 ^a^ (0-3 scale) | | | | | | 1.9 ^a^ puffs/day | | | 2.0 days/pt/yr
PFM action plan vs. symptom action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom action plan | 48/48 | −3.9 (0-24 scale) | | | | | | | | | 6 total pts treated
Turner, Taylor, Bennett, et al., 1998 | PFM action plan | 44/44 | −5.0 (0-24 scale) | −1.1 (0-24 scale) | NS | | | | | | | 3 total pts treated | NR
Charlton, Charlton, Broomfield, et al., 1990 | Symptom action plan | 64/ | | | | | | | | | | 12% % pts treated
Charlton, Charlton, Broomfield, et al., 1990 | PFM action plan | 51 | | | | | | | | | | 47% % pts treated | NS
Cowie, Revitt, Underwood, et al., 1997 | Symptom action plan | 45/ | | | | 3.6 ^a^ nights/wk with symptoms | −1.3 nights/wk with symptoms | NS
Cowie, Revitt, Underwood, et al., 1997 | PFM action plan | 46/ | | | | 4.9 ^a^ nights/wk with symptoms
Cote, Cartier, Robichaud et al., 1997 | Symptom action plan | 45/ | | | | | | | | | | 0.9 courses/pt
Cote, Cartier, Robichaud et al., 1997 | PFM action plan | 50/ | | | | | | | | | | 0.7 courses/pt | NS

a Represents final value. Information not provided to calculate change.

Table 30. Utilization outcomes reported

Citation | Study Arm | # Enrolled # Evaluable | Office Visit | p Value | ER Visit | p Value | Hospital Visit | p Value | Missed Days | p Value | Comments
Usual care vs. PFM action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64/39 | 24 (total pts with any visits) | | | | | | 21 (total pts with any missed days) | | Office visit="seen doctor or hospital doctor" and is the actual # of cases with this outcome
Jones, Mullee, Middleton, et al., 1995 | PFM action plan | 63/33 | 17 (total pts with any visit) | NR | | | | | 18 (total pts with any missed days) | NR | Office visit="seen doctor or hospital doctor" and is the actual # of cases with this outcome
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284/260 | 2.2 (Mean) | | | | 0.12 (Mean)
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM action plan | 285/250 | 2.6 (Mean) | NS | | | 0.13 (Mean) | NS
Ayres, Campbell and Follows, 1995 | Usual care | 64/64
Ayres, Campbell and Follows, 1995 | PFM action plan | 61/61
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48/ | | | 55 | | 6 | | | | ER visits=total 6 mos
Cowie, Revitt, Underwood, et al., 1997 | PFM action plan | 46/ | | | 5 | =0.002 | 2 | NS | | | ER visits=total 6 mos
Cote, Cartier, Robichaud et al., 1997 | Usual care | 54/ | | | 0.8 +/−1.5 | | 0.04 +/−0.3 | | 5.2 +/−12.5
Cote, Cartier, Robichaud et al., 1997 | PFM action plan | 50/ | | | 0.7 +/−1.4 | NS | 0.04 +/−0.3 | NS | 2.2 +/−12.7 | NS
Usual care + PFM use alone vs. usual care + PFM action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44/35 | 4.51 +/−4.0 | | 1.91 +/−2.8 | | 5 (Mean) | | 20 +/−28.9
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM action plan | 50/35 | 1.51 +/−1.1 | <0.001 | 0.65 +/−0.7 | <0.05 | 0 (Mean) | NS | 4.92 +/−6.6 | <0.008
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43/37 | 2 (Median) | | | | 1 (Median) | | 4.7 (Median)
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM action plan | 48/42 | 2.3 (Median) | NS | | | 5 (Median) | NS | 2.1 (Median) | NS
PFM action plan vs. symptom action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom action plan | 48/48 | 12 | | 2 | | 1 | | 8 | | Outcomes are number of pts. with an event. Excludes one pt who was an outlier who was off work for 120 days
Turner, Taylor, Bennett, et al., 1998 | PFM action plan | 44/44 | 17 | NS | 6 | NS | 0 | NS | 9 | NS | Outcomes are number of pts. with an event. Excludes one pt who was an outlier who was off work for 120 days
Charlton, Charlton, Broomfield, et al., 1990 | Symptom action plan | 64/ | 0.53
Charlton, Charlton, Broomfield, et al., 1990 | PFM action plan | 51 | 0. | NS
Cowie, Revitt, Underwood, et al., 1997 | Symptom action plan | 45/ | | | 45 | | 2 | | | | ER visits=total 6 mos
Cowie, Revitt, Underwood, et al., 1997 | PFM action plan | 46/ | | | 5 | =0.006 | 2 | NS | | | ER visits=total 6 mos
Cote, Cartier, Robichaud et al., 1997 | Symptom action plan | 45/ | | | 0.7 +/−1.3 | | 0.09 +/−0.3 | | 2.9 +/−12.7
Cote, Cartier, Robichaud et al., 1997 | PFM action plan | 50/ | | | 0.7 +/−1.4 | NS | 0.04 +/−0.3 | NS | 2.2 +/−12.7 | NS

The largest body of evidence, five trials enrolling 1,019 patients, compared a PFM-based written action plan to medical management without a written action plan. In two other trials (n=185), a PFM-based written action plan was compared to a control group that had PFMs but no written action plan (Ignacio-Garcia and Gonzalez-Santos, 1995; Charlton, Antoniou, Atkinson et al., 1994). In four trials (n=393), two types of written action plans, PFM-based and symptom-based, were compared (Turner, Taylor, Bennett et al., 1998; Charlton, Charlton, Broomfield et al., 1990; Cowie, Revitt, Underwood et al., 1997; Cote, Cartier, Robichaud et al., 1997).

The trials used a variety of patient selection criteria, including: symptom or medication-based criteria (six trials), utilization-based criteria (five trials); and lung function criteria (four trials).

The setting was specialty care in five studies, primary care in one study, mixed primary and specialty care in two studies, and unknown in one study. Five of the nine studies were multicenter, four were from a single institution.

None of the trials was conducted in the United States. Four were based in the United Kingdom, three in Canada, and one each in Australia and Spain. Four were supported by grants from the pharmaceutical industry, two by academic grants, two by private/hospital funding, and one trial did not specify the funding source.

### Patient Populations

Eight of the nine trials enrolled an adult population, with mean age ranging from 28.6-51.1 years. One trial (Charlton, Antoniou, Atkinson et al., 1994) was restricted to children with a mean age of approximately 6.5 years (range 3-16). The populations consisted primarily of patients with long-standing asthma. Of the eight trials in adults, six reported the mean duration of asthma, with a range of 8.9-17.9 years. In the trial on children, mean duration of asthma was 4.3 years. It is difficult to assess the level of asthma severity and control of the patients across these trials due to inconsistent reporting of baseline lung function values, symptom frequencies, and utilization.

In the five studies that reported baseline FEV1, the range was 65.34 to 87.1 percent predicted. Standard deviation is large in all these studies. Two studies reported the proportion of patients below 60 percent predicted and one of these also reported the proportion above 80 percent. The baseline means and SDs for FEV1 percent predicted (control and treatment arms, respectively) were as follows:

- Ignacio-Garcia and Gonzalez-Santos (1995) reported 65.3 (+/−16.6), and 69.03 (+/−24.0); Jones, Mulee, Middleton et al. (1995) reported 85.4 (+/−17.5) and 87.1 (+/−16.9).
- In the study by Turner, Taylor, Bennett et al. (1998), mean was 78.7 (+/−18.9) (>80 percent predicted= 50 percent,<60 percent predicted =12.5 percent) and 78.1 (+/−19.7) (>80 percent predicted= 55 percent,<60 percent predicted= 20.5 percent).
- The three-arm trial by Cowie, Revitt, Underwood et al. (1997) reported baseline FEV1 as 78 (+/−21.3) (<60 percent predicted=21 percent) in the control group, 79 (+/−18) (<60 percent predicted=18 percent) in the symptom-based plan group, and 82 (+/−20.5) (<60 percent predicted=20 percent) in the PFM-based group
- The GRASSIC trial (Drummond, Abdalla, Beattie et al., 1994) reported 78.1 percent (95 percent CI 74.8-81.4, calculated SD 26.7) in the control arm and 77.3 percent (95 percent CI 74.1-80.5, calculated SD 26.0) in the treatment arm.
- Cote, Cartier, Robichaud et al. (1997) restricted their population to primarily moderate to severe asthma and reported a mean baseline PEF percent predicted of approximately 95 percent.

Baseline symptom values were reported for only three of the study populations. Because of differences in units, these data were not helpful in comparing baseline severity across studies. Ayres, Campbell, and Follows (1996) reported baseline symptom scores of 1.8-1.9 (+/−0.6) on a 0-3 scale; Turner, Taylor, Bennett et al. (1998) reported a baseline symptom score of 8-9 on a scale of 0-24. Cowie, Revitt, Underwood et al. (1997) reported the number of nights per week with symptoms, which was 4.9 (+/−5.7) in the control group, 3.6 (+/−6.07) in the symptom-based plan group, and 4.9 (+/−7.11) in the PFM-based plan group. Ayres, Campbell, and Follows (1996) also reported number of nights per week with symptoms during the week before study entry, with an average of 5.2 for both groups.

Seven trials used utilization-based patient selection criteria. Studies varied in how the baseline utilization information for the period prior to study entry was collected. Three studies used a patient interview and consulted the medical record (Cote, Cartier, Robichaud et al., 1997; Ignacio-Garcia and Gonzalez-Santos, 1995; Turner, Taylor, Bennett et al., 1998). One study used patient interview only (Cowie, Revitt, Underwood et al., 1997), and one used records only (Charlton, Antoniou, Atkinson et al., 1994). The GRASSIC study (Drummond, Abdalla, Beattie et al., 1994) did not use baseline information in the analysis; utilization outcomes were collected for the study period only.

- Cowie, Revitt, Underwood et al. (1997) recruited patients who had received urgent treatment in the ER or clinic for asthma exacerbation in the past year. At baseline, mean urgent care visits per person in the past year were 3.5 (+/−3.4) in the control group, 2.6 (+/−4.53) in the symptom-based plan group and 3.3 (+/−7.56) in the PFM-based plan group. Mean hospital admissions per person were 0.48, 0.35, and 0.49, respectively (SD not available).
- Cote, Cartier, Robichaud et al. (1997) recruited patients from three tertiary care hospitals who had been admitted for asthma or treated in a pulmonary clinic during an 8-month period. Baseline ER visits per patient in the year prior to study participation were 2.4 (+/−2.9) in the control group, 1.9 (+/−2.7) in the symptom-based plan group, and 2.3 (+/−2.8) in the PFM-based plan group. Baseline hospitalizations were 0.21 (+/−0.44), 0.40 (+/−2.7), and 0.24 (+/−0.50) respectively.
- Charlton, Antoniou, Atkinson et al. (1994) enrolled children with either a hospital admission for asthma or who attended the hospital's outpatient department; 55 percent of all patients enrolled in the study had a hospital admission in the past 6 months.
- Charlton, Charlton, Broomfield et al. (1990) recruited patients from a single asthma clinic by sending letters to all patients on the repeat prescribing register and enrolling respondents. Patients selected for the Ayres, Campbell, and Follows (1996) study had one documented exacerbation in the prior 6 months that required contact with a physician or nurse.
- The Ignacio-Garcia and Gonzalez-Santos (1995) study enrolled patients from a hospital outpatient asthma clinic who had asthma of at least 2 years' duration. Baseline ER visits for the prior 6 months were 2.08 (+/−2.07) in the control group and 1.94 (+/−1.30) in the PFM-based plan group. Prior hospitalization was 0.11 per person in both groups (SD not available).
- GRASSIC (Drummond, Abdalla, Beattie et al., 1994) recruited patients attending outpatient chest clinics in a three-city region.

### Interventions

All studies used a written action plan that contained the following components: a written algorithm given to patients that identified specific clinical indicators that should trigger adjustments in medications; and specific instructions on how to adjust medications in response to such triggers. The medication regimen was classified as "optimized" if the patient's medications were reviewed and adjusted at entry or if the investigators sent a letter to the patient's physician recommending adjustments to medication. The medications were classified as "usual care" if patients continued their existing physician-prescribed regimen without adjustment or recommendation by the study investigators. Studies in which one arm (typically the treatment arm) received an optimized regimen and the comparison arm (typically the control) received usual care were excluded from this systematic review of evidence.

The written action plans were typically four-zone plans, although some studies used three-zone plans. Some four-zone action plans provided the patient with a prescription for oral corticosteroids and directed the patient to initiate treatment and then advise the treating physician; others instructed the patient to contact the treating physician in order to initiate oral corticosteroids. Three-zone plans did not give directions on the use of oral corticosteroids prior to seeking emergency medical care.

The clinical indicators for these action plans could be PFM reading thresholds (peak-flow meter-based action plan) or a predefined level of clinical symptoms (symptom-based action plan). Other components of self-management needed to be balanced across study groups within each study in order to meet the selection criteria. However, there were differences among studies in other self-management components, as displayed in Table 26 and described in the following sections for each of the three sets of comparisons included in this systematic review of evidence.

Table 26. Study characteristics and intervention components

Citation | Study Arm | # Enrolled # Evaluable | Medication | Intervention Components | | | | | | | | Treatment Duration (weeks)
Citation | Study Arm | # Enrolled # Evaluable | Medication | PFM Use (freq) | Action Plan | Education | Symptom Diary | Follow-up | Pt Counseling | Behavior Mod | Environ Mod | Treatment Duration (weeks)
Optimal medical management vs. optimal medical management + PFM action plan
Jones, Mullee, Middleton, et al., 1995 -- Randomized; parallel, controlled | Usual care | 64/39 | ICS, <1,000 mcg/day | | | | X | X | | | | 24
Jones, Mullee, Middleton, et al., 1995 -- Randomized; parallel, controlled | PFM action plan | 63/33 | ICS, <1,000 mcg/day | X 1x/day | X | | X | X | | | | 24
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) -- Randomized; parallel, controlled | Usual care | 284/260 | Not stated | | | | | X | | | | 52
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) -- Randomized; parallel, controlled | PFM action plan | 285/250 | Not stated | X (not specified) | X | | | X | | | | 52
Ayres, Campbell and Follows, 1995 - Randomized; parallel, controlled | Usual care | 64/64 | BUD, 490 mcg/day | | | | X | X | | | | 24
Ayres, Campbell and Follows, 1995 - Randomized; parallel, controlled | PFM action plan | 61/61 | BUD, 446 mcg/day | X 2x/day | X | | X | X | | | | 24
Cowie, Revitt, Underwood, et al., 1997 - Randomized; parallel, controlled | Usual care | 48/ | ICS, 1,066 mcg/day | | | X | | X | X | | | 24
Cowie, Revitt, Underwood, et al., 1997 - Randomized; parallel, controlled | PFM action plan | 46/ | ICS, 908 mcg/day | X (not specified) | X | X | | X | X | | | 24
Cote, Cartier, Robichaud et al., 1997 - Randomized; parallel, controlled | Usual care | 54/ | BDP, 1,370 mcg/day | | | X | | | | | | 52
Cote, Cartier, Robichaud et al., 1997 - Randomized; parallel, controlled | PFM action plan | 50/ | BDP, 1,380 mcg/day | X 2x/day | X | X | | | X | | | 52
Usual care + PFM use alone vs. usual care + PFM action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 - Randomized; parallel, controlled | Usual care + PFM use | 44/35 | BUD, oral beta-2 agonists, theophylline, prednisone | X 1x/day | | | X | X | | | | 28
Ignacio-Garcia and Gonzalez-Santos, 1995 - Randomized; parallel, controlled | Usual care + PFM action plan | 50/35 | BUD, oral beta-2 agonists, theophylline, prednisone | X 1x/day | X | X | X | X | | | | 28
Charlton, Antoniou, Atkinson, et al., 1994 - Randomized; parallel, controlled | Usual care + PFM use | 43/ | Not stated | X 2x/day | | X | X | X | | | | 52
Charlton, Antoniou, Atkinson, et al., 1994 - Randomized; parallel, controlled | Usual care + PFM action plan | 48/ | Not stated | X 2x/day | X | X | X | X | | | | 52
PFM action plan vs. symptom action plan
Turner, Taylor, Bennett, et al., 1998 - Randomized; parallel, controlled | Symptom action plan | 48/48 | ICS, ~460 mcg/day | | X | X | X | | X | X | X | 24
Turner, Taylor, Bennett, et al., 1998 - Randomized; parallel, controlled | PFM action plan | 44/44 | ICS, ~370 mcg/day | X (not specified) | X | X | X | | X | X | X | 24
Charlton, Charlton, Broomfield, et al., 1990 - Randomized; parallel, controlled | Symptom action plan | 64/ | Not stated | | X | X | | X | | | | 52
Charlton, Charlton, Broomfield, et al., 1990 - Randomized; parallel, controlled | PFM action plan | 51 | Not stated | X (not specified) | X | X | | X | X | | | 52
Cowie, Revitt, Underwood, et al., 1997 - Randomized; parallel, controlled | Symptom action plan | 45/ | ICS, 870 mcg/day | | X | X | | X | X | | | 24
Cowie, Revitt, Underwood, et al., 1997 - Randomized; parallel, controlled | PFM action plan | 46/ | ICS, 908 mcg/day | X (not specified) | X | X | | X | X | | | 24
Cote, Cartier, Robichaud et al., 1997 - Randomized; parallel, controlled | Symptom action plan | 45/ | BDP, 1,522 mcg/day | | X | X | X | | X | | | 52
Cote, Cartier, Robichaud et al., 1997 - Randomized; parallel, controlled | PFM action plan | 50/ | BDP, 1,380 mcg/day | X 2x/day | X | X | | | X | | | 52

X= outcome reported

#### Peak Flow Meter-Based Action Plan vs. Medical Management

The frequency of PFM use varied between once and twice per day. Other components of the treatment intervention varied across trials. Two of the five had education interventions in both groups, apart from instructions on PFM use and action plans. Four of the five trials had regularly scheduled followup in both groups, two included use of a symptom diary, and one included individual patient counseling.

#### Peak Flow Meter-Based Action Plan vs. Peak Flow Meter Use Without an Action Plan

In each of these two studies (Ignacio-Garcia and Gonzalez-Santos, 1995; Charlton, Antoniou, Atkinson et al., 1994), both groups performed peak flow self-monitoring, kept a symptom diary, and had regularly scheduled followup visits. Ignacio-Garcia and Gonzalez-Santos (1995) included a brief educational component in the action plan group that was not given to the control group. This brief educational session was 30 minutes in length, within the 1 hour or less threshold that was used as a selection criterion.

#### Peak Flow Meter-Based Action Plan vs. Symptom-Based Action Plan

In all four of these studies (Turner, Taylor, Bennett et al., 1998; Charlton, Charlton, Broomfield et al., 1990; Cowie, Revitt, Underwood et al., 1997; Cote, Cartier, Robichaud et al., 1997), one group was given a symptom-based action plan while a second group was given a peak-flow meter based action plan. Other components of the interventions varied between studies (Table 26). All four studies included an education component, and all four included some degree of patient counseling. Two studies included a symptom diary for both groups, and two studies included regularly scheduled followup visits. Behavioral modification and environmental modification was included in one of the four studies.

### Outcomes

As summarized in Table 27, the nine included trials reported the following outcomes and outcome measures:

- Eight of nine studies reported utilization outcomes in some manner. The utilization outcomes that were reported varied in type (office visits, ER visits, hospitalizations, missed days of work or school), units of reporting (number of patients with event, number of events/person, total number of events over study), and statistical presentation (mean, median). Five studies reported on office visits; four studies on reported ER visits; six studies reported on hospitalizations; and five studies reported on missed days of work or school.
- Medication use outcomes were reported in seven of the nine studies. Six of these seven studies reported oral corticosteroid usage, using a variety of reporting units (e.g., courses per patient, total number of milligrams, days used per patient per year, percent of patients treated). Two of the seven studies reported beta-2 agonist usage.
- Lung function outcomes were reported in five of the nine studies. Both FEV1 and PEF outcomes were reported in these five studies, although the units of reporting varied (e.g., percent predicted, absolute value in liters or L/min). Only one of the five studies reporting lung function outcomes included bronchial hyperresponsiveness.
- Four of nine studies reported on symptom outcomes. All four reported daytime symptom score outcomes, with variation in the type and range of symptom scores. Three of the four studies also included nighttime symptom scores. Symptom frequency measures and/or frequency of exacerbations were also reported in three of the four studies

Table 27. Outcomes reported

Citation | Study Arm | # Enrolled # Evaluable | Pop Age (years) | Outcomes Reported | | | | | | Comments
Citation | Study Arm | # Enrolled # Evaluable | Pop Age (years) | FEV1 | PEF | Sx | Meds | Exacerbation | Utilization | Comments
Optimal medical management vs. optimal medical management + PFM action plan
Jones, Mullee, Middleton, et al., 1995 | Usual care | 64/39 | 28.6 (Mean) +/−7 | X | X | X | | | X | Course of oral steroids given before randomization to optimize lung function
Jones, Mullee, Middleton, et al., 1995 | PFM action plan | 63/33 | 30.4 (Mean) +/−11.5 | X | X | X | | | X | Course of oral steroids given before randomization to optimize lung function
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | Usual care | 284/260 | 50.5 (Mean) (95% CI 48.4-52.6) | X | X | | X | X | X | Patient eligibility based on lung function and utilization
Drummond, Abdalla, Beattie, et al., 1994 (GRASSIC) | PFM action plan | 285/250 | 51.1 (Mean) (95% CI 49.2-53.0) | X | X | | X | X | X | Patient eligibility based on lung function and utilization
Ayres, Campbell and Follows, 1995 | Usual care | 64/64 | 47 (Mean) +/− 16.0 | X | X | X | | X | | Patient eligibility based on lung function, symptoms, utilization
Ayres, Campbell and Follows, 1995 | PFM action plan | 61/61 | 44 (Mean) +/−15.6 | X | X | X | | X | | Patient eligibility based on lung function, symptoms, utilization
Cowie, Revitt, Underwood, et al., 1997 | Usual care | 48/ | 36.4 (Mean) +/−12.76 | X | | | X | X | X | Subjects were recruited by contacting those who had been treated for an exacerbation of asthma in an ER or those attending a university asthma clinic with a history of having received urgent treatment for their asthma in the previous 12 months.
Cowie, Revitt, Underwood, et al., 1997 | PFM action plan | 46/ | 39.1 (Mean) +/−14.41 | X | | | X | X | X
Cote, Cartier, Robichaud et al., 1997 | Usual care | 54/ | 36 (Mean) +/−22.0 | | X | | X | | X | Patient eligibility based on lung function and symptoms
Cote, Cartier, Robichaud et al., 1997 | PFM action plan | 50/ | 37 (Mean) +/−14.1 | | X | | X | | X | Patient eligibility based on lung function and symptoms
Usual care + PFM use alone vs. usual care + PFM action plan
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM use | 44/35 | 43 (Mean) +/−16.1 | X | X | | X | | X | Patient eligibility based on utilization only
Ignacio-Garcia and Gonzalez-Santos, 1995 | Usual care + PFM action plan | 50/35 | 40.88 (Mean) +/−18.1 | X | X | | X | | X | Patient eligibility based on utilization only
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM use | 43/37 | 6.2 (Mean); Range: 3-16 | | | X | X | X | X | Patient eligibility based on utilization only Inclusion: pts who required admission for asthma or attended the Outpatient Dept.
Charlton, Antoniou, Atkinson, et al., 1994 | Usual care + PFM action plan | 48/42 | 6.8 (Mean); Range: 3-16 | | | X | X | X | X | Patient eligibility based on utilization only Inclusion: pts who required admission for asthma or attended the Outpatient Dept.
PFM action plan vs. symptom action plan
Turner, Taylor, Bennett, et al., 1998 | Symptom action plan | 48/48 | 34.1 (Mean) +/−9.4 | X | X | X | X | | X | Patient eligibility based on lung function and symptoms
Turner, Taylor, Bennett, et al., 1998 | PFM action plan | 44/44 | 34.1 (Mean) +/−10.5 | X | X | X | X | | X | Patient eligibility based on lung function and symptoms
Charlton, Charlton, Broomfield, et al., 1990 | Symptom action plan | 64/ | | | | | X | | X | Patient eligibility based on symptoms only; patients were not randomly selected for participation. Letters were sent to patients on the repeat prescribing register and invited to make an appointment with a nurse
Charlton, Charlton, Broomfield, et al., 1990 | PFM action plan | 51 | | | | | X | | X
Cowie, Revitt, Underwood, et al., 1997 | Symptom action plan | 45/ | 36.8 (Mean) +/−16.5 | X | | | X | X | X | Patient eligibility based on symptoms and utilization; subjects were recruited by contacting those who had been treated for an exacerbation of asthma in an ER or those attending a university asthma clinic with a history of having received urgent treatment for their asthma in the previous 12 months
Cowie, Revitt, Underwood, et al., 1997 | PFM action plan | 46/ | 39.1 (Mean) +/−14.41 | X | | | X | X | X
Cote, Cartier, Robichaud et al., 1997 | Symptom action plan | 45/ | 39 (Mean) +/−13.4 | | X | | X | | X | Patient eligibility based on lung function and symptoms;
Cote, Cartier, Robichaud et al., 1997 | PFM action plan | 50/ | 37 (Mean) +/−14.1 | | X | | X | | X | Patient eligibility based on lung function and symptoms;

"X" = outcome reported

Most studies did not clearly define the primary endpoints of interest. To do so requires a model of the expected impact of an asthma management plan and which outcomes are the goals of treatment. For example, if the goal of an asthma management plan is to control symptoms and prevent exacerbations, reporting change in lung function (e.g., FEV1) from baseline to final lung functions is less useful than measures that indicate the level of control achieved throughout the course of the study. The disease features that are the target of intervention may be too variable over time to be captured by single measures at study entry and endpoint. Comparisons of symptom frequency, beta-2 agonist use, exacerbations, or oral corticosteroid use over followup period compared to the run-in period provide more meaningful measures.

An important goal of asthma management is to prevent serious or potentially life-threatening events as indicated by ER visits or hospitalizations. However, these events occur infrequently in the overall population of asthmatics. In order to assess the impact of a written management plan on these outcomes, the study population selected should either be extremely large or have a high baseline frequency of events. Interpretation of data on courses of oral corticosteroid used or unscheduled physicians visits may be difficult in the absence of data on serious events. For example, an increase in oral corticosteroid use or unscheduled physician visits might be a favorable outcome if ER utilization and hospitalization decreases significantly as a result.

## Study Quality

Quality of study design and conduct was assessed as described in the "Methodology" chapter. The objective was to identify a group of higher quality trials for purposes of sensitivity analysis. The definition for higher quality studies includes general quality indicators that have been shown to minimize biases that could overestimate the magnitude of effect in randomized controlled trials, and disease-specific features that control for potential confounders of outcomes. To be defined as a higher quality study, we usually require three general quality indicators: (1) double blinding; (2) appropriate handling of exclusions and withdrawals as demonstrated by percentage of excluded patients below threshold or results analyzed by intent to treat; and (3) concealment of treatment allocation.

However, given the nature of the written asthma plan intervention, double-blinding would not be feasible and so was not required in our general quality criteria for this aspect of the analysis. Note, however, that since some of the outcomes of interest are self-reported, the infeasibility of blinding in this setting introduces the potential for bias in these measures. A summary of the study quality assessment of the nine trials included in this chapter is displayed in Table 31.

Table 31. Assessment of study quality

| General Quality Indicators | | | Asthma-Specific Quality Indicators
Citation | Blinding | Percentage of excluded subjects below specified threshold? (required) | Allocation concealed? (NS=not specified) | Accounted for excluded patients? | Power calculations? | Reversibility established? | Controlled for other medication use? | Reported compliance? | Addressed seasonality?
Jones, Mulee, Middleton et al., 1995 | (No) | No | (NS) | No | Yes | No | Yes | No | No
GRASSIC (Drummond, Abdalla, Beattie et al., 1994) | (No) | No | (NS) | No | Yes | Yes | No | No | No
Ayres, Campbell, and Follows, 1996 | (No) | No | (NS) | Yes | Yes ^a^ | No | Yes | No | No
Cowie, Revitt, Underwood et al., 1997 | (No) | NS | (NS) | NS | No | No | No | No | No
Cote, Cartier, Robichaud et al., 1997 | (No) | No | (NS) | Yes | No | Yes | No | Yes | No
Ignacio-Garcia and Gonzalez-Santos, 1995 | (No) | No | (NS) | No | No | No | No | No | No
Charlton, Antoniou, Atkinson et al., 1994 | (No) | No | (NS) | No | No | No | No | No | No
Turner, Taylor, Bennett et al., 1998 | (No) | No | (NS) | Yes | No | No | No | Yes | No
Charlton, Charlton, Broomfield et al., 1990 | (No) | NS | (NS) | NS | No | No | No | No | No

( ) Indicates generic quality indicators that were not required for this class of studies, due to the nature of the intervention.

a Power calculations reported, but number of enrolled patients failed to reach threshold for adequate power.

None of the included studies met either of the remaining two general quality indicators that were used to define higher quality studies. In all of the studies, the number of patients excluded from analysis exceeded the predefined threshold. Nor did any of the studies report whether the method of allocation to treatment arm was concealed.

With respect to the asthma-specific quality indicators, three studies reported prospective power calculations (Jones, Mulee, Middleton et al., 1995; Drummond, Abdalla, Beattie et al., 1994; Ayres, Campbell, and Follows, 1996), but the number of patients in the Ayres, Campbell, and Follows (1996) study failed to reach the threshold for adequate power. Each of these three studies also fulfilled one of the additional disease-specific features that control for potential confounders of outcomes.

GRASSIC (Drummond, Abdalla, Beattie et al., 1994) established reversibility and also met at least of one of our designated asthma-related quality indicators; Jones, Mulee, Middleton et al. (1995) and Ayres, Campbell, and Follows (1996) controlled for other medication use. Two additional studies reported on compliance (Cote, Cartier, Robichaud et al., 1997; Turner, Taylor, Bennett et al., 1998), and one study (Cote, Cartier, Robichaud et al., 1997) also established reversibility of lung obstruction. The remaining four studies did not did not report on any of our designated asthma-related indicators (Cowie, Revitt, Underwood et al., 1997; Ignacio-Garcia and Gonzalez-Santos, 1995; Charlton, Antoniou, Atkinson et al., 1994; Charlton, Charlton, Broomfield et al., 1990).

### Power Issues in Included Studies

In general, the included studies did not clearly identify the patient population expected to benefit from a written asthma plan or specify the primary outcomes of interest; nor was the level of improvement to be considered clinically meaningful prospectively defined. Only three of the nine studies reported power calculations. In two of the three studies, power was calculated based on effect size observed in an earlier study that lacked a contemporaneous control group, and this effect size was much larger than that ultimately observed in the setting of randomized controlled trials (Jones, Mulee, Middleton et al., 1995; Ayres, Campbell, and Follows, 1996). As a consequence, this literature is largely composed of studies that enrolled too few patients to have adequate power to detect a difference in outcome between the treatment and control groups. When the outcomes of interest are infrequent events such as hospitalization or ER visits, the study population must either be very large or else selected for a high baseline rate of utilization.

The GRASSIC trial (Drummond, Abdalla, Beattie et al., 1994; n=569) reported 80 percent power at the 5 percent significance level to detect a difference equivalent to 23 percent of the SD for each variable of interest. Based on the number of patients actually accrued (n=45 control, 39 treatment arm), the study by Jones, Mulee, Middleton et al. (1995) was estimated to have 80 percent power to detect at the 5 percent significance level the following differences between groups: 13 points for FEV1 percent predicted; 25 percent for patients with night awakenings; and 30 percent for patients taking days off school or work. Ayres, Campbell, and Follows (1996) calculated 52 patients per group to detect a 28 percent reduction in the number of sleep-disturbed nights; but the reduction actually observed was 3 percent.

Sample power calculations for utilization outcomes were performed based on information provided in the available studies. These are displayed and explained in Table 32. Although hospitalization is the least frequent outcome reported in these studies; it was the outcome for which the most data was available to perform the calculations, derived from baseline rates reported in four studies (Drummond, Abdalla, Beattie et al., 1994; Cote, Cartier, Robichaud et al., 1997; Cowie, Revitt, Underwood et al., 1997; and Ignacio-Garcia and Gonzalez-Santos, 1995) and SDs reported in two of these (Drummond, Abdalla, Beattie et al., 1994; Cote, Cartier, Robichaud et al., 1997). The unit of measurement is mean number or hospitalizations per year; and postintervention mean in the control arm was used to calculate the number needed per study arm, assuming a 25 percent, 50 percent, or 75 percent decrease from the control arm. In the absence of more specific data, these calculations also were used to roughly estimate required sample sizes for ER visits.

Table 32. Power calculations for hospitalizations per patient per year

Assumed control mean | Possible treatment mean | % decrease | N needed per study arm
0.10 | 0.075 | 25 | 3,077
0.10 | 0.05 | 50 | 770
0.10 | 0.025 | 75 | 342
0.20 | 0.015 | 25 | 770
0.20 | 0.10 | 50 | 193
0.20 | 0.05 | 75 | 86
0.30 | 0.225 | 25 | 342
0.30 | 0.15 | 50 | 86
0.30 | 0.075 | 75 | 38

Studies were identified that contained baseline rates on hospitalizations/patient/year, or information that allowed calculation of this parameter (Drummond, Abdalla, Beattie et al., 1994; Cote, Cartier, Robichaud et al., 1997; Cowie, Revitt, Underwood et al., 1997; Ignacio-Garcia and Gonzalez-Santos, 1995). Baseline rates of hospitalization varied in these studies from 0.04-0.29/patient/year. Standard deviations for this outcome were available only in two studies; Cote, Cartier, Robichaud et al. (1997) reported an SD of 0.30 for this variable, and an SD of 0.35 was calculated from the confidence intervals reported in GRASSIC (Drummond, Abdalla, Beattie et al., 1994). For the calculations, the more conservative 0.35 estimate for SD was used.

Number of patients per study arm were estimated for 80 percent power at the 5 percent significance level using control arm means of 0.10, 0.20, and 0.30 hospitalizations/patient/year. The expected reduction in this variable was tested along a spectrum from 25-75 percent.

By these calculations, a study with a sample size similar to GRASSIC (approximately 250 patients per treatment arm) would have power to detect a reduction of 50 percent or more in the hospitalization outcome given a control rate of 0.2 hospitalizations per patient per year or higher. In actuality, GRASSIC (Drummond, Abdalla, Beattie et al., 1994) found that the mean number of hospitalizations per patient per year was 0.12 in the control arm and 0.13 in the treatment arm, closer to the 0.10 calculated baseline rate. With this baseline rate, a sample size of over 700 patients per arm would be required to detect a 50 percent change in baseline rates, while over 3,000 patients per arm would be required to detect a difference of 25 percent.

The other eight studies in this evidence base were of smaller size, with a range of approximately 40-65 patients per study arm. It was estimated that, with 86 patients per study arm and an assumed 0.30 hospitalizations per patient per year baseline mean for the control arm, a 50 percent difference in outcome could be detected.

Apparent treatment effects may be biased by important baseline differences between treatment groups, or differences that result from withdrawals over the course of the study. Tests of statistical significance are frequently used to assess the importance of such differences. But given the small sample size of many of the included studies, there may be insufficient power to detect differences in baseline characteristics, just as there is insufficient power to detect differences in outcome. Thus, baseline differences that are not statistically significant when pre-intervention characteristics are compared may nonetheless be sufficient to bias results over the course of the study.

## Results

### Medical Management Alone Versus Use of a Written Asthma Action Plan

Seven trials compared medical management with and without a written action plan; all used a PFM-based plan. Five of the trials compared a PFM-based action plan with medical management alone. In two of the seven trials, the control group also used PFMs, but had no written action plan.

### Written Action Plan Using Peak Flow Meter Compared to Medical Management Only

Five trials (Jones, Mulee, Middleton et al., 1995; Drummond, Abdalla, Beattie et al., 1994, Ayres, Campbell, and Follows, 1996; Cowie, Revitt, Underwood et al., 1997; Cote, Cartier, Robichaud et al., 1997) compared use of a peak-flow meter based action plan in the treatment group and medical management alone in the control group. Altogether, 1,019 patients were enrolled. The largest of these trials was the GRASSIC study (n=569), a community study conducted in the United Kingdom (Drummond, Abdalla, Beattie et al., 1994).

#### Utilization Outcomes

Utilization outcomes were reported in some manner in all five studies. In all, nine comparisons of utilization measures were abstracted from these five studies (three hospitalizations, two office visits, two ER visits, two missed school/work). A statistically significant difference between groups was reported for only one of these nine comparisons, in favor of the PFM-action plan group.

Cowie, Revitt, Underwood et al., (1997) reported an 11-fold difference in total ER visits for the PFM-action plan group (p=0.002): 5 visits among 5 patients compared to 55 visits among 19 patients. Cowie, Revitt, Underwood et al., (1997) also reported fewer total hospitalizations among the PFM-action plan group (2 vs. 12), but this difference did not reach statistical significance. Cote, Cartier, Robichaud et al. (1997) reported no difference in the mean number of ER visits per patient (0.8 vs. 0.7, p=NS) or in the mean number of hospitalizations per patient (0.04 vs. 0.04, p=NS). The GRASSIC trial (Drummond, Abdalla, Beattie et al., 1994) was the third study reporting frequency of hospitalizations and found no difference in the mean number of hospitalizations per patient (0.12 vs. 0.13, p=NS).

Two studies reported on the number of office visits, with no significant differences found in either case. Jones, Mulee, Middleton et al. (1995) reported the number of patients with an unscheduled office visit (24 of 45 in usual care vs. 17 of 39 in PFM-based action plan group, p=NS). The GRASSIC study (Drummond, Abdalla, Beattie et al., 1994) reported the mean number of office visits for asthma/patient/year (2.2 in the usual care vs. 2.6 in the PFM-action plan group).

Missed days of work and/or school were reported in two studies. Jones, Mulee, Middleton et al. (1995) reported a median of 0 days of missed work/school for both groups. Cote, Cartier, Robichaud et al. (1997) reported a higher number of missed days in the usual care group as compared to the PFM-action plan group (5.2 vs. 2.2, p=NS), but the difference did not reach statistical significance.

#### Symptoms

Four of the five studies reported measures related to changes in the frequency or severity of symptoms. No findings were statistically significant, including those of the largest study, the GRASSIC trial (Drummond, Abdalla, Beattie et al., 1994).

Two studies reported symptom scores. Jones, Mulee, Middleton et al. (1995) reported daytime symptom scores that tended to be lower for the PFM-based group as compared to usual care (cough: 2.85 vs. 4.95; wheeze: 4.39 vs. 5.46; shortness of breath: 6.50 vs. 7.88; activity restriction: 0 vs. 0.17); while Ayres, Campbell, and Follows (1996) reported symptom scores that were very similar among the PFM-action plan and the usual care group (overall severity of asthma: 1.38 vs. 1.39; cough at rest: 0.87 vs. 0.69; cough with activity: 1.28 vs. 1.30; wheeze: 0.74 vs. 0.67; difficulty breathing: 0.85 vs. 0.96; sleep disturbance: 0.67 vs. 0.69). In both studies, none of the group comparisons in symptom scores reached statistical significance.

Symptom frequency measures were reported as days/month of restricted activity in one study (Drummond, Abdalla, Beattie et al., 1994), and as nights/week with symptoms in two studies (Drummond, Abdalla, Beattie et al., 1994; Ayres, Campbell, and Follows, 1996). None of the group comparisons of symptom frequency measures were statistically significant. Two studies compared the number of oral corticosteroid courses among groups (Drummond, Abdalla, Beattie et al., 1994; Cote, Cartier, Robichaud et al., 1997), with no group differences reported.

#### Lung Function

Three of the five studies reported lung function outcomes (Jones, Mulee, Middleton et al., 1995; Drummond, Abdalla, Beattie et al., 1994; Ayres, Campbell, and Follows, 1996), including both FEV1 and PEF data in all three cases. There were no statistically significant differences between groups for any of these comparisons. An unexpected observation is that a decline in FEV1 was observed in both arms of the trials by Jones, Mulee, Middleton et al. (1995) (−4.2 and −3.9 percent predicted) and GRASSIC (Drummond, Abdalla, Beattie et al., 1994) (both −2.7 percent predicted). In Jones, Mulee, Middleton et al. (1995), this decline followed a 2-week period of treatment with oral corticosteroids and may represent a falling off from optimal lung function. Ayres, Campbell, and Follows (1996) found an increase of 0.2 L in the control group and no change in the PFM-based plan group

#### Discussion

Of the five trials comparing a PFM-based action plan to no action plan, one found statistically significant results. Cowie, Revitt, Underwood et al. (1997) reported a reduction in total ER visits for the PFM-action plan group (5 vs. 55, p=0.002). However, this trial has significant limitations and is not adequate to demonstrate that a written action plan is superior to medical management alone. None of the five studies reported a significant difference in any other measures of utilization, symptoms, or lung function that were abstracted. This includes the largest of these trials, the GRASSIC study (Drummond, Abdalla, Beattie et al., 1994). But these studies are not adequately powered to demonstrate that there is no benefit from a written action plan.

Data presented in the Cowie, Revitt, Underwood et al. (1997) study suggest that the difference in ER visits is attributable to a subset of patients who were high frequency users. At baseline the mean number of visits/patient/year were 3.5 (+/−3.4) in the control group and 3.3 (+/−7.56) in the PFM-based action plan group. The high standard deviations indicate that both groups had patients with no emergency visits, and other patients who had a much higher than average number of visits. This pattern is more pronounced in the PFM-based plan group, where the SD was two times greater than the mean. At study end, ER visits per patient per year was 2.3 in the control group and 0.22 in the PFM-based plan group. The percent of patients who had any ER visits was 40 percent (n=19) in the control group and 11 percent (n=5) in the PFM-based plan group; with 5.7 and 2 visits per patient per year, respectively. However, it is not possible to determine the change in the number of patients who had ER visits, as the baseline number was not reported.

It is important to appreciate that the Cowie, Revitt, Underwood et al. (1997) study does not compare change from baseline among groups, or incorporate baseline values as covariates in the analysis. The results reported are strictly a postintervention comparison among groups; and the necessary data to perform a comparison of change among groups is not provided. Moreover, any comparison of pre- and postintervention values is subject to the limitation that all data were collected by patient self-report. Data collection was by mail questionnaire and telephone interview without verification from patient records. Baseline data are from recall of a 1-year period, and are, thus, less reliable than the study data, collected contemporaneously at 3-month intervals.

Nonetheless, based on qualitative examination of the reported data, the advantage Cowie, Revitt, Underwood et al. (1997) reported for the peak flow action plan group is unlikely to disappear if a comparison of change between groups were performed. However, the results might differ in two ways. First, the magnitude of difference between groups might be smaller than the present analysis suggests. Second, the effect might be limited to a small group of patients with very high frequency of ER use. Moreover, it is possible that the advantage observed in the peak flow action plan group is related to overrepresentation of patients with high use in that study group. This is suggested by the high mean and SD for emergency visits per patient per year at baseline, 3.3 (+/−7.56) vs. 3.5 (+/−3.40) in the no-action plan group. Finally, the use of data derived solely from patient recall without corroboration by medical records also decreases confidence in the results of this study.

### Written Action Plan Using Peak Flow Meter Versus Peak Flow Meter Only

Two trials enrolling a total of 185 patients addressed the independent effect of a written action plan, when added to peak flow self-monitoring (Ignacio-Garcia and Gonzalez-Santos, 1995; Charlton, Antoniou, Atkinson et al., 1994). The Charlton study (Charlton, Antoniou, Atkinson et al., 1994) was a population of children aged 16 years or younger, with mean age 6.2 years.

#### Utilization

Ignacio-Garcia and Gonzalez-Santos (1995) reported significantly better outcomes for the action plan group as compared to the no-action-plan group for the mean number of office visits (4.51 vs. 1.51, p<0.001), ER visits (1.91 vs. 0.65, p<0.05), and missed days of work (20 vs. 4.92, p<0.008). This study also reported fewer hospitalizations for the action plan group, but the difference did not reach statistical significance (5 vs. 0, p=NS).

Charlton, Antoniou, Atkinson et al. (1994) reported no significant differences between the action plan and no-action plan group on the median number of office visits (2 vs. 2.3, p=NS), hospitalizations (1 vs. 5, p=NS), and days of missed school (4.7 vs. 2.1, p=NS). Charlton, Antoniou, Atkinson et al. (1994) did not report on ER visits.

#### Symptoms

Ignacio-Garcia and Gonzalez-Santos (1995) reported significant differences in the number of nights with symptoms (16.45 vs. 37.94, p<0.001) and symptom score outcomes were reported only by Charlton, Antoniou, Atkinson et al. (1994), with no significant differences found between the action plan and no-action-plan groups for daytime (0.26 vs. 0.22, p=NS) or nighttime (0.15 vs. 0.25, p=NS) symptom scores. Charlton, Antoniou, Atkinson et al. (1994) did report a significant difference favoring the PFM-action plan group on the activity restriction score (0.13 vs. 0.06, p<0.05).

Both studies reported on use of beta-agonists and oral steroids, with neither study reporting significant group differences in these outcome measures. Oral corticosteroid use (927 vs. 1,350 total mg) and total number of beta-2 agonist inhalations (106 vs. 153) was lower in the PFM-based action plan group in Ignacio-Garcia and Gonzalez-Santos (1995). But Charlton, Antoniou, Atkinson et al. (1994) reported higher use in the PFM-based arm than the control arm for oral corticosteroids (2.0 vs, 0 days used/patient per year) and beta-2 agonists puffs per day (1.9 vs. 1.7 median).

#### Lung Function

Lung function outcomes were only reported by Ignacio-Garcia and Gonzalez-Santos (1995). There was significantly greater improvement in lung function outcomes for the action plan group as compared to the no-action-plan group on FEV1 percent predicted (69.03 → 80.45 percent vs. 65.34 → 65.48 percent, p<0.004), and on PEF (370 → 401 vs. 316 → 321, p<0.003).

#### Discussion

Two studies compared peak flow monitoring with and without a written action plan, with one reporting significant differences favoring the PFM action plan. Ignacio-Garcia and Gonzalez-Santos (1995) reported statistically significant differences favoring the written action plan group for office visits, ER visits, symptoms, and FEV1. The only significant difference reported by Charlton, Antoniou, Atkinson et al. (1994) was on one symptom subscale, with no other outcome measures showing significant differences between groups.

Although the results of Ignacio-Garcia and Gonzalez-Santos (1995) appear to strongly favor PFM monitoring, there are potential sources of bias that could lead to overestimation of the treatment effect. One concern is the high level of involvement of the study physicians in all phases of patient assessment and treatment. "One physician, who was aware of the group to which each patient had been assigned, was responsible for the assessment of all patients' conditions and modifications of treatment in the followup group" (Ignacio-Garcia and Gonzalez-Santos, 1995).

A second concern is the high rate (25 percent) of patients withdrawn after randomization to the study. Of 94 patients randomized, 9 patients in the control group and 15 in the experimental group completed the initial assessment but were dropped, leaving a study population of 35 patients per arm. Sixteen of these patients, 5 patients in the control group and 11 in the treatment group, were excluded at the time of 3-month assessment due to noncompliance with PEF monitoring, prescribed medications, or proper inhalation technique. If, for example, the treatment group was more intensively screened for noncompliant patients, the potential for treatment success could be improved. Results were not reported by intent to treat analysis and the possibility that selective withdrawal from the study arms introduced bias cannot be ruled out.

In addition, the patients remaining in the treatment group had slightly better baseline characteristics, although the differences were not statistically significant. In comparison, the control group was slightly older than the treatment group (42 vs. 40.9 years, respectively) with longer duration of asthma (13.4 vs. 10.4 years, respectively), lower baseline percent predicted FEV1 (65 percent vs. 69 percent, respectively), somewhat more smokers and chronic bronchitis (14 percent and 17 percent vs. 8 percent and 11 percent, respectively), but also more nonsmokers (63 percent vs. 54 percent, respectively).

Finally, Ignacio-Garcia and Gonzalez-Santos (1995) report improvement in lung function (FEV1 11.4 percent predicted) in the treatment group that is notably larger than observed in the other included studies, but there is no obvious explanation for this. Ignacio-Garcia and Gonzalez-Santos (1995) is the only study to find a significant between-group difference in final FEV1 or PEF. Turner, Taylor, Bennett et al. (1998) reported the next largest improvement in FEV1, 7.4 percent predicted in the symptom-based plan group. But decline in FEV1 was observed in the PFM-monitoring arms of the Jones, Mulee, Middleton et al. (1995) (−3.9 percent predicted) and GRASSIC (Drummond, Abdalla, Beattie et al., 1994) (−2.7 percent predicted) trials. Ayres, Campbell, and Follows (1996) found an increase of 0.2 L in the control group and no change in the PFM-plan group. Also of interest is that Ignacio-Garcia and Gonzalez-Santos (1995) reported that lung function measurements initially increased in both groups (approximately FEV1 5 percent predicted), then declined in the control group by the 3-month visit, while continuing to rise in the treatment group. However, Ignacio-Garcia and Gonzalez-Santos (1995) do not discuss possible explanations for the rise and subsequent decline to baseline in the control group. In addition, it is not possible to verify from the relevant table whether values from all patients in the study are reported at each time point.

In summary, despite the apparently strong findings in favor of the PFM action plan, confidence in the results of the Ignacio-Garcia and Gonzalez-Santos (1995) study is diminished by three concerns. The first is that the same physician, who was not blinded to treatment assignment, was responsible for educating, treating, and assessing the outcomes of the patients in this study. The second is the high number of patients excluded from analysis. The third is the exceptionally large improvement in FEV1 in the treatment arm compared to other studies, which is not adequately addressed in the discussion section of the paper.

#### Conclusion

The available evidence is insufficient to demonstrate that asthma outcomes are improved when a written asthma action plan is added to medical management. Two trials reported statistically significant and striking reductions in ER utilization with use of a PFM-based action plan. However, both trials have serious flaws that diminish our confidence in the results. Five additional trials, including a community study of 569 patients, found no significant differences. But these studies are not adequately powered to demonstrate that there is no benefit from a written action plan.

### Written Action Plan Based on Symptoms Versus A Written Action Plan Based on Peak Flow Monitoring

Four studies enrolling a total of 393 patients compared symptom-based written action plans to peak-flow meter-based action plans.

#### Utilization

Utilization measures were the most commonly reported outcomes among these studies. In total, eight comparisons of utilization measures were made among these four studies. Three studies reported on number of ER visits. Cowie, Revitt, Underwood et al. (1997) reported a striking reduction in total ER visits for the peak-flow meter group as compared to the symptom group (5 vs. 45, p<0.002); 5 visits among 5 patients compared to 45 visits among 14 patients. There was no significant difference in total ER visits reported by Turner, Taylor, Bennett et al. (1998) (6 vs. 2, p=NS) and no difference in number of ER visits/patient reported by Cote, Cartier, Robichaud et al. (1997) (0.7 vs. 0.7, p=NS).

In the two studies that reported baseline ER use in the 12 months preceding the trial (Cowie, Revitt, Underwood et al., 1997; Cote, Cartier, Robichaud et al., 1997), Cowie, Revitt, Underwood et al. (1997) reported a higher rate (3.1 per person vs. 2.2 per person). The baseline data in Cote, Cartier, Robichaud et al. (1997) might be more reliable as they were collected from a patient interview and medical records, while Cowie, Revitt, Underwood et al. (1997) used patient interview only.

All studies but Charlton, Charlton, Broomfield et al. (1990) reported on hospitalization; no significant differences were found. Compared to the symptom-based plan, hospitalizations in the PFM plan were 1 vs. 0 (Turner, Taylor, Bennett et al., 1998); 2 vs. 2 (Cowie, Revitt, Underwood et al., 1997); and 0.09 vs. 0.04 per patient (Cote, Cartier, Robichaud et al., 1997). Charlton and Turner, Taylor, Bennett et al. (1998) reported on office visits, and found no significant group differences in office visits: 0.53 vs. 0 and12. vs. 17.

#### Symptoms

Turner, Taylor, Bennett et al. (1998) reported on the use of beta-agonists and three studies reported the use of oral steroids (Turner, Taylor, Bennett et al., 1998; Charlton, Charlton, Broomfield et al., 1990; Cote, Cartier, Robichaud et al., 1997). No differences were statistically significant, and findings did not consistently favor one arm over the other. For oral corticosteroid use, the results for PFM-plan arm compared to symptom plan were: 6 vs. 3 patients treated (Turner, Taylor, Bennett et al., 1998); 12 vs. 47 percent treated (Charlton, Charlton, Broomfield et al., 1990); and 0.9 vs. 0.7 courses per patient (Cote, Cartier, Robichaud et al., 1997).

Symptom score outcomes were reported by one study (Turner, Taylor, Bennett et al., 1998) and symptom frequencies were reported by one study (Cowie, Revitt, Underwood et al., 1997), with no statistically significant group differences found in either case. Turner, Taylor, Bennett et al. (1998) reported 8 vs. 9 and Cote, Cartier, Robichaud et al. (1997) reported 2.9 vs. 2.2 missed work or school days, but neither finding was statistically significant.

#### Lung Function Measures

Lung function outcomes were reported by only one of the four studies (Turner, Taylor, Bennett et al., 1998), with no group differences found in percent predicted FEV1 or bronchial hyperresponsiveness. Turner, Taylor, Bennett et al. (1998) observed a slight decline in FEV1 in both the PFM and symptom plan groups between visit six and seven, which was the final visit (−4.5 vs. 2.3 percent predicted).

#### Discussion

Three of four trials found no significant difference in any outcome measure between a written action plan based on symptoms and a comparable written action plan based on peak flow monitoring. Two of these trials were three-arm studies that compared no written action plan to a symptom-based written action plan and to a peak-flow-monitor-based written action plan. Cote, Cartier, Robichaud et al. (1997) found no significant outcome differences among the three groups. However, Cowie, Revitt, Underwood et al. (1997) reported a statistically significant and striking difference in total ER visits for the peak-flow-meter-based action plan group as compared to the either the symptom-group-based action plan group or the no-action-plan group.

The limitations of the Cowie, Revitt, Underwood et al. (1997) study were discussed in detail in the main body of the report. Here we comment only on the comparison of the symptom-based and PFM action plan. The favorable results reported for the PFM-plan group may be attributable to improvement in a small number of patients who had very high ER utilization. At baseline the mean number of visits per patient per year were 2.6 (+/−4.53) in the symptom group and 3.3 (+/−7.56) in PFM-based action plan group. The large SDs indicate that both groups had patients with no emergency visits, and other patients who had a higher than average number of visits. For both groups, the SD was about 2 times greater than the mean; however the PFM-plan arm appears to include patients with an even higher frequency of ER use than does the symptom-plan arm.

In contrast to Cowie, Revitt, Underwood et al. (1997), Cote, Cartier, Robichaud et al. (1997) conducted a similar three-arm comparison in a more rigorous fashion. All patients, including those in the control arm, participated in a 2-6 week run-in period where medication use was optimized. Data were collected for all patients by questionnaire and review of medical charts. The study followup period was 1 year, as compared to 6 months in the Cowie, Revitt, Underwood et al. (1997) study. Cote, Cartier, Robichaud et al. (1997) compared change in asthma morbidity from baseline, while Cowie, Revitt, Underwood et al. (1997) only reported a postintervention comparison between groups.

Cote, Cartier, Robichaud et al. (1997) found no statistically significant difference among groups for change from baseline in hospitalizations (p=0.6), ER visits (p=0.5), oral corticosteroid use (p=0.2), or days lost from work or school (p=0.6). However, all three groups had a significant improvement in asthma morbidity compared to the year prior to study entry. Cote, Cartier, Robichaud et al. (1997) also analyzed changes in morbidity for patients (n=100) who had a hospital admission or ER visit in the prior year compared with other study patients (n=49). The patients with a history of hospitalization or emergency visit did not have a greater decrease in morbidity (p=0.5).

#### Conclusion

The available evidence does not permit conclusions as to whether the use of a written action plan based on peak flow monitoring improves outcomes compared to a written action plan based on symptoms.

## Comparison of These Results with Others

The results of this systematic review should be compared with two other analyses on this subject. The first is a systematic review performed by the Cochrane Collaboration (Gibson, Coughlan, Wilson et al., 2000b). The Cochrane review was largely drawn from the same evidence base that was used for this present evidence review, but was less restrictive in excluding multimodal interventions that could confound the comparison of a written action plan to no written action plan. The second is a case control study by Lieu and colleagues that assessed self-management practices associated with reduced risk of hospitalization or ER visit in pediatric asthma patients (Lieu, Quesenberry Jr, Capra et al., 1997). This present systematic evidence review was restricted to randomized controlled trials, which are the most rigorous design for assessing the effects of an intervention. In contrast, case control studies can only observe associations. But case control studies permit accrual of large numbers of subjects with lower costs and shorter time frames. Such studies can be helpful where large populations are necessary in order to observe infrequent events, as is the case with the asthma utilization outcomes addressed in this chapter.

### Cochrane Review

The Cochrane review compared self-management education programs to regular review of asthma care by a physician or nurse practitioner, and included a total of 24 trials with 30 self-management interventions. Among these 30 interventions, those that included a written action plan (n=17) were compared with those that did not include a written action plan (n=13). Overall, the pooled analysis showed reduced rates of hospitalization (OR=0.58, 95 percent CI 0.38-0.88) and ER visits (OR=0.71, 95 percent CI 0.57-0.90) with self-management education compared to written review. Programs with a written action plan were associated with a greater reduction in hospitalizations as compared to programs without a written action plan (OR=0.35, 95 percent CI 0.18-0.68) and a greater reduction in ER visits (OR=0.55, 95 percent CI 0.39-0.77).

The differences in the conclusions of this systematic review likely arise from the different study selection process. Study selection focused on trials that isolated the effect of a written action plan apart from other components of a self-management intervention, while the Cochrane review focused on self-management interventions versus regular review. As a result, the articles in this systematic review allow a clearer comparison of written action plans versus no written action plans in a smaller set of studies. For example, trials were excluded in which optimization of asthma medications was a component of the treatment intervention, but was not provided to the control group. The Cochrane review allowed studies that in the present evidence review were judged to include intervention components that might confound the independent effect of a written asthma plan. It is possible that the presence of a written action plan is a marker for a more intensive intervention in general, and that the beneficial effect found in the Cochrane review results from components other than the written action plan.

The Cochrane review also compared outcomes of a PFM-based action plan versus a symptom-based action plan. For this comparison, the Cochrane selection process was similar to the present evidence review, resulting in the same four articles used in this systematic review (Cote, Cartier, Robichaud et al., 1997; Cowie, Revitt, Underwood et al., 1997; Charlton, Turner, Taylor, Bennett et al., 1998). For three of these studies, the pooled odds ratio for the number of patients with ER visits result was not statistically significant (OR=0.87, 95 percent CI 0.49, 1.54). However, the finding of an odds ratio favoring a PFM-based action plan was driven solely by the Cowie, Revitt, Underwood et al. (1997) study, which, while significant, had a wide confidence interval (OR=0.30, 95 percent CI 0.11, 0.81). The Cochrane meta-analysis was based on total patients in the study with ER visits, rather than total number of ER visits. While this is a more conservative measure of the Cowie, Revitt, Underwood et al. (1997) results, it permits a more robust pooled analysis of the findings of the group of studies.

### Case Control Study

Lieu and colleagues (Lieu, Quesenberry Jr, Capra et al., 1997) conducted a case control study of children age 14 or under who were enrolled in the Kaiser Permanente regional health maintenance organization. Cases were 508 children who had been hospitalized or visited the ER for asthma treatment during the study period. Controls were 990 children with asthma who had not been hospitalized or visited the ER during the study period. Cases and controls were matched on age, gender, and number of asthma-related hospitalizations in the past 24 months. Data on asthma management practices was collected from chart review, telephone interviews with parents, and computerized databases, including pharmacy databases.

Multivariate regression analyses were conducted for patient characteristics and asthma management practices associated with hospitalization or ER visit. Cases with hospitalization were less likely than controls (44 percent vs. 51 percent) to have a written asthma management plan and to report washing bedding in hot water twice monthly (74 percent vs. 56 percent). The multivariate regression model examined numerous patient characteristics (e.g., asthma severity, race, income, parents' education) and potential predictors of ER visits. Potential predictors included asthma education, exposure to smoking, day care attendance, use of a PFM, treatment by an asthma specialist, as well as other asthma management practices. The strongest associations between not having a hospitalization or ER visit were: (1) having a written asthma management plan; (2) washing bedding twice monthly in hot water; and (3) starting or increasing medications at onset of cold or flu.

Having an asthma management plan was associated with reduced odds of hospitalization (OR=0.54, 95 percent CI 0.30, 0.99) and ER visit (OR=0.45, 95 percent CI 0.27, 0.76). Causal inferences cannot be made from this data. This case control study does not test the effectiveness of a written asthma management plan. For example, some parents may confuse hospital discharge instructions with an asthma management plan. Most importantly, it is plausible that having a written asthma management plan, or frequent washing of bedding, is actually a marker of high parental motivation to comply with medications and to control asthma triggers.

Thus, the Lieu study (Lieu, Quesenberry Jr, Capra et al., 1997) supplements the randomized controlled trials included in this systematic review with data from a much larger and targeted population of patients who have been hospitalized or visited the ER for asthma. However, while suggestive, the Lieu study cannot, by its design, demonstrate that written asthma management plans are an effective intervention for reducing severe asthma-related morbidity. If the Lieu finding is actually a marker for other asthma health-related behaviors, implementing a program to disseminate written asthma management plans will not in itself improve the outcomes of asthma treatment.

## Conclusions

A large body of literature on self-management interventions in asthma is available and was reviewed for this report. From this literature, randomized controlled trials were selected that contained specific comparisons relevant to this key question and that were largely free of contamination by interventions that were not directly relevant to the key questions. Many articles were excluded due to the presence of multimodal interventions in the treatment group, particularly intensive patient education or optimization of medications, which were likely to confound results.

Nine randomized controlled trials, enrolling a total of 1,501 patients, met the study selection criteria for this key question. Two of these trials included three arms; medical management alone, PFM-based written action plan, and symptom-based written action plan group. This resulted in 11 comparisons among the 9 studies. Seven trials (n=1,079) compared medical management with and without a written action plan; all used a PFM-based plan. The two types of written action plan, PFM-based and symptom-based, were compared in four trials (n=393).

Of the nine trials reviewed above, seven reported no significant differences in any measure of utilization, symptoms, or lung function. This includes the largest (n=569) of these trials, the GRASSIC trial (Drummond, Abdalla, Beattie et al., 1994). However, as a group, the included trials are underpowered to detect differences in utilization outcomes such as hospitalization and ER visits, which are events that occur infrequently. Two trials reported statistically significant and striking reductions in ER utilization with use of a PFM-based action plan. However, both trials have serious flaws that diminish confidence in the results.

The available evidence does not demonstrate that written asthma action plans improve outcomes. Nor does this evidence refute the hypothesis that use of a written asthma plan is beneficial. If there is benefit in a written asthma action plan, it is most likely to be found in a population with severe or poorly controlled asthma leading to high utilization of in-hospital and ER treatment. Both trials reporting benefit used a peak-flow meter action plan, but neither provides a rigorous comparison with a symptom-based plan.