# Results and Conclusions Part 4. Effect of Antibiotics on Acute Asthma Exacerbations

Key Question 4a. Does routinely adding antibiotics to standard care improve the outcomes of treatment for acute exacerbation of asthma?

Key Question 4b. Does the addition of antibiotics to standard care in the following populations improve the outcomes of treatment for an acute exacerbation of asthma?

- patients without signs and symptoms of a bacterial infection
- patients with signs and symptoms of a bacterial infection
- patients with signs/symptoms of sinusitis

## Overview

Two trials, including a total of 121 admissions, met the study selection criteria for this key question. These were relatively older studies; the more recent one was published in 1982 (Graham, Milton, Knowles et al., 1982) and the earlier one in 1974 (Shapiro, Eggleston, Pierson et al., 1974). Both trials studied patients hospitalized for an exacerbation of asthma, and used a randomized, double-blinded, placebo-controlled, parallel-group design. The unit of analysis in each study was admissions to the hospital. Graham, Milton, Knowles et al. (1982) studied 60 adults and adolescents, who experienced a total of 71 admissions, and used amoxicillin as the antibiotic treatment. Shapiro, Eggleston, Pierson et al. (1974) included 50 admissions in children with no clinical evidence of bacterial infection and used hetacillin, an analogue of ampicillin. (See Evidence Tables 4-1 through 4-5.)

The trial by Shapiro, Eggleston, Pierson et al. (1974) is notable because patients with clinical evidence of a bacterial infection or recent use of antibiotics were excluded, so those patients selected for this trial had a low likelihood of bacterial infection. Thus, the trial by Shapiro, Eggleston, Pierson et al. (1974) addresses whether antibiotic treatment improves outcomes among children without signs and symptoms of a bacterial infection who are hospitalized for an asthma exacerbation. In contrast, Graham, Milton, Knowles et al. (1982) excluded patients with evidence of pneumonia on chest X-ray, but otherwise did not exclude patients with clinical evidence of bacterial infection. Thus, Graham, Milton, Knowles et al., (1982) addresses the routine use of antibiotics in a population of adults and adolescents hospitalized for asthma exacerbation.

The antibiotics used in these studies do not have activity against atypical organisms, such as Mycoplasma or Chlamydia. Thus, the available studies do not address whether antibiotics in current use that have activity against atypical organisms may improve outcomes. Moreover, Shapiro, Eggleston, Pierson et al. (1974) reported only results at 24 hours, a length of time that may not be sufficient to judge the effect of antibiotics.

The trial by Graham, Milton, Knowles et al. (1982) was conducted in the United Kingdom and was funded by a government grant. The Shapiro, Eggleston, Pierson et al. (1974) trial was conducted in the United States and was funded by both a government and a pharmaceutical industry grant. Both were single institution studies.

### Patient Populations

The Graham, Milton, Knowles et al. (1982) study population was largely adults, with a mean age of approximately 39 years (range: 13-82 years). Shapiro, Eggleston, Pierson et al. (1974) included only children 18 years or younger, with a mean age of approximately 8.5 years (range: 1.3-18 years).

On admission to the hospital, both studies recorded baseline lung function measurements and baseline symptom scores. These measures were indicative of severe disease, as would be expected during an acute asthma exacerbation. The mean FEV1 was very low in both studies, in the range of 20-28 percent predicted. Graham, Milton, Knowles et al. (1982) required that patients have an FEV1 level below 1.5 liters and/or a peak flow reading below 150 liters/minute on admission. In the Shapiro, Eggleston, Pierson et al. (1974) trial, patients were eligible based on severe bronchospasm and lack of response to epinephrine, regardless of baseline lung function values. Each study used a different 12-point scale for symptom scores. For Graham, Milton, Knowles et al. (1982), the baseline symptom score was 11 on a 6-12-point scale while for Shapiro, Eggleston, Pierson et al. (1974), it was 7.1 on a 0-12-point scale.

The populations in these studies consisted primarily of patients without signs and symptoms of bacterial illness. In the trial by Shapiro, Eggleston, Pierson et al. (1974), patients with signs and symptoms of bacterial disease were excluded. In Graham, Milton, Knowles et al. (1982), all patients were treated and cultures were taken to assess the presence of bacterial disease. Only a very small number of admissions (n=4 of 71) had documented bacterial disease.

### Interventions

In both trials, all patients received high dose oral or intravenous corticosteroids, and regularly scheduled beta-2 agonist treatment. Graham, Milton, Knowles et al. (1982) included chest physiotherapy for all patients, while Shapiro, Eggleston, Pierson et al. (1974) treated all patients with intravenous aminophylline followed by oral theophylline.

In the Graham, Milton, Knowles et al. (1982) trial, antibiotic treatment was amoxicillin 500 mg, three times daily. Shapiro, Eggleston, Pierson et al. (1974) started antibiotic treatment with intravenous hetacillin 100 mg/kg every 24 hours for a minimum of 24 hours, followed by hetacillin 225 mg, four times per day for 6 days.

### Outcomes

Both studies reported only on short-term outcomes of treatment for acute asthma exacerbations as followup for each patient was only for the duration of hospitalization. Length of hospitalization ranged from 3-25 days in the Graham, Milton, Knowles et al. (1982) study and was a mean of less than 3 days in the Shapiro, Eggleston, Pierson et al. (1974) study. Outcomes reported included FEV1, PEF, symptom scores, and hospital length of stay.

### Study Quality

Quality of study design and conduct was assessed as described in the "Methodology" chapter. The objective was to identify a group of higher quality trials for purposes of sensitivity analysis. Our definition for higher quality studies required double-blinded randomized controlled trials that met additional criteria for percent of patients excluded from analysis, handling of exclusions, and concealment of allocation. Neither the Graham, Milton, Knowles et al. (1982) nor the Shapiro, Eggleston, Pierson et al. (1974) trial met the criteria for defining higher quality studies (Table 24).

Table 24. Assessment of study quality

| General Quality Indicators | | | Asthma-Specific Quality Indicators
Citation | Blinding (required) | Percentage of excluded subjects below specified threshold? (required) | Allocation concealed? (NS=not specified) | Power calculations? | Accounted for excluded patients? | Reversibility established? | Controlled for other medication use? | Addressed compliance? | Addressed seasonality?
Shapiro, Eggleston, Pierson et al., 1974 | Yes | No | NS | No | Yes | No | Yes | NA | NA
Graham, Milton, Knowles et al., 1982 | Yes | Yes | NS | No | Yes | Yes | Yes | NA | NA

Graham, Milton, Knowles et al. (1982) met most of the study quality criteria, including double blinding, number and handling of exclusions, establishing reversibility and controlling for other medication use. They did not specify the adequacy of allocation concealment, a common situation in studies published at this point in time. They also did not report power calculations. Shapiro, Eggleston, Pierson et al. (1974) was double-blinded, but had a number of withdrawals greater than our threshold. They did account for excluded patients and controlled for other medication use but did not establish reversibility. In both cases, addressing compliance and seasonality were not applicable to these short-term, hospital studies.

## Results

Pre and post-treatment FEV1 values were reported in both studies; Graham, Milton, Knowles et al. (1982) also reported pre- and post-treatment PEF outcomes. There were no significant differences in FEV1 percent predicted reported by Shapiro, Eggleston, Pierson et al. (1974) between the placebo and experimental groups after 24 hours of treatment (49 percent vs. 61 percent, p=NS). Graham, Milton, Knowles et al. (1982) reported better FEV1 percent predicted and PEF outcomes at the time of discharge for the placebo group as compared to the antibiotic group. These results reached statistical significance when withdrawals were excluded: FEV1 percent predicted 65.6 percent vs. 52.3 percent (p=0.04), and PEF 72.8 percent vs. 59.0 percent, (p=0.05). They were not statistically significant when withdrawals were included in the analysis (data not given). There were two withdrawals from the placebo arm because progress was considered inadequate. Thus, this statistically significant finding may reflect that the sickest patients were excluded from analysis in the placebo arm, but not from the antibiotic arm.

There were no significant group differences for either study in pre- and post-treatment symptom scores. Furthermore, there were no group differences in hospital length of stay reported for either study. The criteria used to establish readiness for discharge were not described in either study.

## Conclusions

The available evidence consists of two randomized, placebo-controlled trials enrolling a total of 121 admissions to the hospital for an acute asthma exacerbation (Graham, Milton, Knowles et al., 1982; Shapiro, Eggleston, Pierson et al., 1974). Both studies were relatively old, having been published in 1982 and 1974, respectively. They may have been underpowered to detect treatment differences. Shapiro, Eggleston, Pierson et al. (1974) evaluated lung function and symptom outcomes only at 24 hours after admission, a length of time that may be insufficient to evaluate the benefit of antibiotics. In addition, the antibiotics used in these studies do not have activity against atypical organisms, such as Mycoplasma or Chlamydia. It is not known whether antibiotics in current use that have activity against atypical organisms may improve outcomes.

The available evidence suggests there is no benefit to using antibiotic treatment routinely or for patients where suspicion of bacterial infection is low. Neither study found a statistically significant benefit for antibiotics on the outcomes of lung function at time of discharge, hospital length of stay, or symptom scores. There were no studies that addressed the question of greatest relevance to contemporary clinical practice, which is whether adding antibiotics, when signs and symptoms suggest the possibility of bacterial infection but do not clearly indicate its presence, improves the outcomes of treatment for acute exacerbation of asthma.