# Results and Conclusions Part 3. Addition of Other Long-Term Controller Medications to ICS

Key Question 3. In patients with moderate asthma who are receiving ICS, does adding another long-term control agent improve outcomes? Three settings are of interest:

a. Addition of long-term controller in order to improve asthma control attained with a fixed dose of ICS;
b. Addition of long-term controller in order to maintain or improve asthma control while titrating ICS to the lowest effective dose.
c. Addition of long-term controller as an alternative to increasing ICS dose in order to improve asthma control.

## Overview

This chapter reviews the evidence on the addition of other long-term control medications to ICS. In patients who are being treated with ICS, adding another long-term control medication might be considered in order to improve asthma control; or as a corticosteroid-sparing measure to reduce or avoid increasing the dosage of ICS. Agents of interest are long-acting inhaled beta-2 agonists, theophylline, leukotriene antagonists, and cromolyn/nedocromil. However, there were no studies of the use of cromolyn/nedocromil added to ICS that met the study selection criteria for this systematic review.

The evidence on the addition of each of these long-term controller agents to ICS is grouped into three categories. The first category of studies compares the agent added to a fixed dose of ICS with the same dose of ICS alone. These studies most closely address clinical settings where addition of another long-term controller may achieve better symptom control than that attained with ICS alone. The second category of studies addresses patients who are adequately controlled, but who may benefit from reducing the dose of ICS by titrating to the lowest effective dose after administering an additional agent. The last category of studies compares the addition of an agent to a low-to-moderate ICS dose with an increased dose of ICS. These studies are relevant to the patient population that is receiving submaximal doses of ICS, where a higher dose of ICS is being considered to improve control.

Overall, 42 studies met the inclusion criteria for these questions. However, three of these articles were deemed to be duplicate reports of studies reported in other articles (Juniper, Svensson, O'Byrne et al., 1999; Hyland and Crocker, 1995; Kips, O'Connor, Inman et al., 2000). If additional relevant outcomes were contained in these duplicate reports, they were added to the data from the original report with citation to the supplementary article. This left a total of 39 unique studies enrolling a total of 9,020 patients. Tables 15-18 summarize the study characteristics and key findings for these studies. Three of these studies (Pauwels, Lofdahl, Postma et al., 1997; Pearlman, Stricker, Weinstein et al., 1999; Verberne, Frost, Duiverman et al., 1998) reported comparisons that were relevant to two questions: the addition of a long-acting beta-2 agonist to a fixed dose of ICS and the addition of a long-acting beta-2 agonist compared with an increased dose of ICS. Two of these three studies evaluated the addition of a long-acting beta-2 agonist to two different fixed doses of ICS. The third (Verberne, Frost, Duiverman et al., 1998) evaluated the addition of a long-acting beta-2 agonist to low-dose ICS compared to low-dose and high-dose ICS alone. Finally, one study (Woolcock, Lundback, Ringdal et al., 1996) compared two doses of a long-acting beta-2 agonist to increased dose ICS. This resulted in a total of 39 unique studies reporting on 45 comparisons relevant to this review. (See Evidence Tables 3-1 through 3-11.)

Table 17. Symptoms and medication outcomes

Citation | Study Arm | # Enrolled/ # Evaluable | Change in Symptom Score | Treatment Difference | p Value | Change in Symptom-Free Days ^a^ | Treatment Difference | p Value | Overall Change Puffs per Day | | Treatment Difference | p Value | Oral Steroid Use | p Value
ADDITION OF LONG-ACTING BETA AGONISTS
- Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | FP + placebo | 165 | | | | 28% ^b^
Aubier, Pieters, Schlosser, et al., 1999 | FP + salmeterol | 167 | | | | 38% ^b^ | 10% | NS
Boulet, Cartier, Milot, et al., 1998 | BDP + placebo | 16/15
Boulet, Cartier, Milot, et al., 1998 | BDP + salmeterol | 16/15
Boyd, 1995 | BDP + placebo | 64/52 | −0.12 (scale 0-4) | | | 13 | | | −2.50
Boyd, 1995 | BDP + salmeterol | 55/48 | −0.20 (scale 0-4) | −0.08 | NS | 22 | 9% | NS | −5.00 | | −2.50 | =0.002
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS + placebo | 91/72 | −0.17 (scale 0-4) | | | | | | −0.53 | | | | 6 events
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS + formoterol + placebo | 89/72 | −0.62 (scale 0-4) | −0.45 | <0.0500 | | | | −1.16 | | −0.63 | <0.0500 | 3 events | NR
Kavuru, Melamed, Gross, et al., 2000 | FP | 90/85 | −0.2 (scale, 0 5) | | | 7.2% | | | −0.4 +/− 1.9
Kavuru, Melamed, Gross, et al., 2000 | FP + salmeterol | 92/87 | −0.7 (scale, 0-5) | −0.5 | <0.025 | 22.6% | 15.4% | <0.025 | −1.9 +/− 2.4 | | −1.5 | <0.025
Kemp, Cook, Incaudo, et al., 1998 | ICS + placebo | 254 | −0.30 (scale 0-3) | | | 18% | | | −1.06
Kemp, Cook, Incaudo, et al., 1998 | ICS + salmeterol | 252 | −0.55 (scale 0-3) | −0.25 | <0.001 | 38% | 20% | <0.001 | −2.73 | | −1.67 | <0.001
Langley, Masterson, Batty, et al., 1998 | ICS + placebo | 24/23 | 0.50 (scale ?) | | | 9.6%
Langley, Masterson, Batty, et al., 1998 | ICS + salmeterol | 25/24 | −1.00 (scale ?) | −1.50 | =0.0040 | 39.1% | 29.5% | =0.002
Li, Ward, Thien, et al., 1999 | BDP or BUD + placebo | 16/16 | −0.15 (scale 0-4) | | | | | | −0.20
Li, Ward, Thien, et al., 1999 | BDP or BUD; + salmeterol | 13/13 | −1.00 (scale 0-4) | −0.85 | <0.05 | | | | −1.10 | | −0.90 | <0.05
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg + placebo | 213/? | 0.07 (scale 0-3) | | | 41.7% episode-free days ^b^ | | | 0.91 ^b^
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200 mcg + formoterol | 210/? | −0.06 (scale 0-3) | −0.13 | <0.001 | 51.1% episode-free days ^b^ | 9.4% | =0.001 | 0.57 ^b^ | | −0.34 | <0.001
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg + placebo | 214/? | 0.04 (scale 0-3) | | | 45.7% episode-free days ^b^ | | | 0.82 ^b^
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg + formoterol | 215/? | −0.19 (scale 0-3) | −0.23 | <0.001 | 54.8% episode-free days ^b^ | 9.1% | =0.001 | 0.44 ^b^ | | −0.38 | <0.001
Pearlman, Stricker, Weinstein, et al., 1999 | FP 176 mcg | 23/23 | −0.10 (scale 0-3) | | | 5.0 | | | −1.1
Pearlman, Stricker, Weinstein, et al., 1999 | FP 176 + salmeterol | 25/25 | −0.80 (scale 0-3) | −0.70 | <0.05 | 34.0 | 29.0% | <0.05 | −1.5 | | −0.40 | NS
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 mcg | 23/23 | −0.30 (scale 0-3) | | | 12.0 | | | −1.4 | | | NS
Pearlman, Stricker, Weinstein, et al., 1999 | FP 440 + salmeterol | 21/21 | −0.40 (scale 0-3) | −0.10 | | 24.0 | 12.0% | <0.05 | −1.4 | | 0.0 | NS
Russell, Williams, Weller, et al., 1995 | BDP or equiv + placebo | 107/89 | | | | 18.0 | | | −0.3
Russell, Williams, Weller, et al., 1995 | BDP + salmeterol | 99/78 | | | | 45.0 | 27.0% | =0.0080 | −0.8 | | −.5 | =0.032
Shapiro, Lumry, Wolfe, et al., 2000 | FP | 84/81 | −0.40 (scale 0-5) | | | 15.4 | | | −0.9
Shapiro, Lumry, Wolfe, et al., 2000 | FP; salmeterol | 84/66 | −0.8 (scale 0-5) | −0.40 | =0.01 | 33.8 | 18.4% | <0.004 | −2.3 | | −1.4 | =0.002
van der Molen, Postma, Turner, et al., 1997 | ICS + placebo | 114/113 | −0.64 (scale 0-21) | | | | | | −0.4 | | | | 32 pts/55 courses
van der Molen, Postma, Turner, et al., 1997 | ICS + formoterol | 125/125 | −1.28 (scale 0-21) | −0.64 | =0.039 | | | | −1.5 | | −1.10 | <0.001 | 33 pts/58 courses
Verberne, Frost, Duiverman, et al., 1998 | BDP | 57 | | | | | | | 0.15 ^c^ (median) | | | | 13 courses/10 patients
Verberne, Frost, Duiverman, et al., 1998 | BDP + salmeterol | 60 | | | | | | | 0.19 ^c^ (median) | | 0.04 | NS | 13 courses/10 patients
- Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS + placebo | 17/13 | −2,500 mcg/day (−87%) | | | −1.10 (scale 0-6) | | | | | | 0.20
McIvor, Pizzichini, Turner, et al., 1998 | ICS + salmeterol | 17/13 | −2,115 mcg/day (−69%) | −385 mcg/day (18%) | =0.04 | −1.40 (scale 0-6) | −0.30 | NS | | | | −0.90 | −1.10 | NS
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP + placebo | 19/19 | −253 mcg/day (−19.8%) | | | 0 (0-5 scale)
Nielsen, Pedersen, Faurschou, et al., 1999 | BDP + salmeterol | 15/15 | +42 mcg/day (+3.6%) | −295 mcg/day (23.4%) | <0.01 | −1 (0-5 scale) | −1 | <0.001
Wilding, Clark, Coon, et al., 1997 | ICS + placebo | 100/84 | −140 mcg/day (20.0%) | | | | | | 8.0%
Wilding, Clark, Coon, et al., 1997 | ICS + salmeterol | 100/87 | −47 (6.5%) | −93mcg/day (13.5%) | <0.001 | | | | 26.0% | 18.0% | <0.001
- Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | FP + placebo | 223/223 | −0.46 (scale 0-4) | | | 22.6% | | | −2.4
Baraniuk, Murray, Nathan, et al., 1999 | FP + salmeterol | 231/231 | −0.44 (scale 0-4) | 0.02 | NS | 29.2% | 6.6% | NS | −2.9 | | −0.50 | <0.001
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP | 65/58 | −0.50 (scale 0-4) | | | | | | −0.40 | | | | 5.2% of patients
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP + formoterol | 69/64 | −0.80 (scale 0-4) | −0.30 | <0.05 | | | | −0.70 | | −0.30 | <0.05 | 12.5% of patients | NS
Condemi, Goldstein, Kalberg, et al., 1999 | FP + placebo | 216 | −0.26 (scale 0-4) | | | 17.5% | | | −1.55
Condemi, Goldstein, Kalberg, et al., 1999 | FP + salmeterol | 221 | −0.43 (scale 0-4) | −0.17 | <0.001 | 30.0% | 12.5% | <0.014 | −2.51 | | −0.96 | <0.001
Greening, Ind, Northfield, et al., 1994 | BDP + placebo | 206/206 | −0.43 (scale ?) | | | −26.0 (% days/wk with sx) | | | −0.90
Greening, Ind, Northfield, et al., 1994 | BDP + salmeterol | 220/220 | −0.55 (scale ?) | −0.12 | NS | −31.0 (% days/wk with sx) | 5.00% | NS | −0.90 | | 0.00 | NS
Kelsen, Church, Gillman, et al., 1999 | BDP | 244/240 | | | | 17.0% | | | −0.44 (puffs/night)
Kelsen, Church, Gillman, et al., 1999 | BDP + salmeterol | 239/236 | | | | 33.55 | 16.5% | < 0.05 | −0.52 (puffs/night) | | −0.08 | <0.05
Murray, Church, Anderson, et al., 1999 | BDP | 254/253 | −0.25 (scale 0-4) | | | 12.05 | | | −0.95
Murray, Church, Anderson, et al., 1999 | BDP + salmeterol | 260/259 | −0.60 (scale 0-4) | −0.35 | <0.05 | 32.5% | 20.5% | <0.001 | −2.25 | | −1.30 | <0.05
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD + placebo | 214/? | 0.04 (scale 0-3) | | | 45.7% episode-free days ^b^ | | | 0.82 ^b^
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD formoterol 12mcg | 210/? | −0.06 (scale 0-3) | 0.10 | NR | 51.1% episode-free days ^b^ | 5.4% episode-free days | NR | 0.57 ^b^ | | −0.25 | NR
Pearlman, Stricker, Weinstein, et al., 1999 | FP | 23/23 | −0.30 (scale 0-3) | | | 12.0% | | | −1.4
Pearlman, Stricker, Weinstein, et al., 1999 | salmeterol + FP | 25/25 | −0.80 (scale 0-3) | −0.50 | NS | 34.0% | 22.0% | <0.05 | −1.5 | | −0.1 | NS
van Noord, Schreurs, Mol, et al., 1999 | FP | 135 | | | | −2.0 (days/wk with sx) | | | | | | | 11% of patients
van Noord, Schreurs, Mol, et al., 1999 | FP + salmeterol | 139 | | | | −2.5 (days/wk with sx) | 0.5 (days/wk with sx) | =0.04 | | | | | 12% of patients | 1% of patients
Verberne, Frost, Duiverman, et al., 1998 | BDP | 60/54 | | | | | | | 0. 33 ^c^ (median) | | | | 8 courses/7 patients
Verberne, Frost, Duiverman, et al., 1998 | BDP + salmeterol | 60/55 | | | | | | | 0.19 ^c^ (median) | | −0.14 | NS | 13 courses/10 patients
Vermetten, Boermans, Luiten, et al., 1999 | BDP | 120 | | | | −16 (days/wk with sx) | | | −0.23
Vermetten, Boermans, Luiten, et al., 1999 | BDP + salmeterol | 113 | | | | −19 (days/wk with sx) | 0.03 (days/wk with sx) | NS | −0.40 | | −0.17 | <0.05
Woolcock, Lundback, Ringdal, et al., 1996 | BDP | 251 | | | | 42.0% | | | | | | | 39 patients
Woolcock, Lundback, Ringdal, et al., 1996 | BDP + salmeterol | 243 | | | | 85.0% | 43.0% | <0.0010 | | | | | 35 patients | −4
Woolcock, Lundback, Ringdal, et al., 1996 | BDP + salmeterol | 244 | | | | 84.0% | 42.0% | <0.0010 | | | | | 30 patients | −9
ADDITION OF THEOPHYLLINE
- Studies Using a Fixed ICS Dose in all study arms
Emad, 1996 | BDP + placebo | 40/40
Emad, 1996 | BDP + theo | 40/40
Meltzer, Orgel, Ellis, et al., 1992 | albuterol + BDP + placebo | 37/33 | 0.22 (scale 0-3) | | | | | | | | | | 6 patients
Meltzer, Orgel, Ellis, et al., 1992 | albuterol + BDP + theo | 35/29 | 0.13 (scale 0-3) | −0.09 | NS | | | | | | | | 5 patients
Minoguchi, Kohno, Oda, et al., 1998 | BDP + theo | 19/18 | 2.92
Minoguchi, Kohno, Oda, et al., 1998 | BDP + theo | 19/17 | 0.45 | −2.47 | <0.05
Nassif, Weinber-ger, Thompson, et al., 1981 | BDP + placebo | 22/18 | | | | 50% ^b^ | | | 0.9 ^c^ | | | | 9 patients
Nassif, Weinber-ger, Thompson, et al., 1981 | BDP + theo | 22/18 | | | | 71% ^b^ | 21% | <0.01 | 0.4 ^c^ | | −0.5 | <0.01 | 2 patients
- Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | BUD + placebo | 31/31 | −0.10 | | | | | | −0.80
Evans, Taylor, Zetterstrom et al., 1997 | BUD + theo | 31/31 | −0.15 | −0.05 | 0.26 | | | | −0.75 | | 0.05 | 0.57
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP + placebo | 90/64 | −1.00 (scale 0-4) | | | | | | 0.3 (median)
Ukena, Harnest, Sakalauskas, et al., 1997 | BDP + theo | 100/69 | −0.95 (scale 0-4) | 0.05 | NS | | | | 0.5 (median) | | 0.2 | NS
ADDITION OF LEUKOTRIENE RECEPTOR ANTAGONISTS
- Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | BDP + placebo | 200/193 | −0.02 (scale 0-6)
Laviolette, Malmstrom, Lu, et al., 1999 | BDP + montelukast | 193/193 | −0.13 (scale 0-6) | −0.11 | =0.041
Tamaoki, Kondo, Sakai, et al., 1997 | BDP + theo + placebo | 40/37 | | | | 6.30 (episodes/wk) | | | 21.64 (puffs/wk)
Tamaoki, Kondo, Sakai, et al., 1997 | BDP + theo + pranlukast | 43/42 | | | | −0.20 (episodes/wk) | −6.50 | =0.033 | 6.29 (puffs/wk) | | −15.35 | =0.026
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP | 17/17 | 0.20
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP + pranlukast | 24/24 | −0.40 | −0.60
Christian Virchow, Prasse, Naya et al., 2000 | ICS + placebo | 188/188 | −0.3 +/− 1.4 (scale, 0-3) | | | 3.48 sx-free days/mo. | | | −0.2 ± 4.1
Christian Virchow, Prasse, Naya et al., 2000 | ICS + zafirlukast | 180/180 | −0.6 +/− 1.3 (scale, 0-3) | −0.3 | <0.001 | 6.19 sx-free days/mo. | 2.71 | NS | −1.3 ± 4.0 | | −1.1 | =0.007
- Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | ICS + placebo | 113/113 | 0.12 (scale 0-6) | | | | | | 0.36
Lofdahl, Reiss, Leff, et al., 1999 | ICS + montelukast | 113/112 | 0.07 (scale 0-6) | −0.05 | NS | | | | 0.29 | | −0.07 | NS

a Change in symptom free days unless noted

b Outcome is an absolute value, data for change not given

c Not stated if outcome is a change or absolute value

Table 16. Change in lung function outcomes reported

Citation | Study Arm | # Enrolled/# Evaluable | Overall Change FEV1 | Treatment Difference | p Value | Overall Change PEF | Treatment Difference | p Value | Overall Change PC20 | Treatment Difference | p Value
ADDITION OF LONG-ACTING BETA AGONISTS
- Studies Using a Fixed ICS Dose in All Study Arms
Aubier, Pieters, Schlosser, et al., 1999 | FP/placebo | 165 | 0.17 +/− 0.3 L | | | 15 +/− 39.8 L/min
Aubier, Pieters, Schlosser, et al., 1999 | FP/salmeterol | 167 | 0.25 +/− 0.6 L | 0.08 L | NS | 35 +/− 40.1 L/min | 20.0 L/min | <0.001
Boulet, Cartier, Milot, et al., 1998 | BDP + placebo | 16/15 | −2.30% pred | | | | | | .10 mg/mL methacholine
Boulet, Cartier, Milot, et al., 1998 | BDP + salmeterol | 16/15 | 0.30% pred | 2.60% pred | | | | | .40 mg/mL methacholine | 0.30 mg/mL | NS
Boyd, 1995 | BDP + placebo | 64/52 | 0.14L | | | 32L/min
Boyd, 1995 | BDP + salmeterol | 55/48 | 0.21L | 0.07 L | NS | 52 L/min | 20.0 L/min | =0.006
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS + placebo | 91/72 | 0.01L | | | 8.0 L/min | | | 0.92 mg/mL methacholine
FitzGerald, Chapman, Della Cioppa, et al., 1999 | ICS + formoterol + placebo | 89/72 | 0.13L | 0.12 L | NS ^b^ | 31.0 L/min | 23.0 L/min | <0.05 ^a^ | 4.18 mg/mL methacholine | 3.26 mg/mL | <0.001 ^a^
Grutters, Brinkman, Aslander, et al., 1999 | BDP | 15/15 | 9.00% pred
Grutters, Brinkman, Aslander, et al., 1999 | BDP salmeterol | 12/12 | 15.00% pred | 6.00%pred | NS ^b^
Kavuru, Melamed, Gross, et al., 2000 | FP | 90/85 | 0.28 +/− 0.5 L | | | 17.3 +/− 41.7 L/min
Kavuru, Melamed, Gross, et al., 2000 | FP + salmeterol | 92/87 | 0.51 +/− 0.5 L | 0.23 L | <0.001 | 52.5 +/− 50.8 L/min | 35.2 L/min | <0.025
Kemp, Cook, Incaudo, et al., 1998 | ICS; placebo | 254 | 0.15L | | | 14 L/min
Kemp, Cook, Incaudo, et al., 1998 | ICS; salmeterol | 252 | 0.42L | 0.27 L | <0.001 | 47 L/min | 33.0 L/min | <0.001
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; placebo | 24/23 | 0.65L | | | −9.00 L/min
Langley, Masterson, Batty, et al., 1998 | ICS; ipratropium bromide; salmeterol | 25/24 | 0.72L | 0.07L | NS | 27.00 L/min | 36.0 L/min | =0.0001
Li, Ward, Thien, et al., 1999 | BDP or BUD Placebo | 16/16 | 1.00% pred | | | 5.00 L/min
Li, Ward, Thien, et al., 1999 | BDP or BUD; Salmeterol | 13/13 | 2.00% pred | 1.00% pred | NS | 35.0 L/min | 30.0 L/min | <0.05
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200mcg + placebo | 213/? | 2.2% pred | | | −11 L/min
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 200mcg + formoterol | 210/? | 8.3% pred | 6.1% pred | | 17 L/min | 28 L/min
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800mcg + placebo | 214/? | 5.6% pred | | | 2 L/min
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD 800 mcg + formoterol | 215? | 10.4% pred | 4.8% pred | NR | 26 L/min | 24 L/min | NR
Pearlman, Stricker, Weinstein, et al., 1999 | FP 88mcg | 23/23 | 0.27L | | | 10.0 L/min
Pearlman, Stricker, Weinstein, et al., 1999 | FP 88 + salmet | 25/25 | 0.59L | 0.32 L | <0.05 | 57.0 L/min | 47.0 L/min | <0.05
Pearlman, Stricker, Weinstein, et al., 1999 | FP 220mcg | 23/23 | 0.30L | | | 25.0 L/min
Pearlman, Stricker, Weinstein, et al., 1999 | FP 220 + salmet | 21/21 | 0.73L | 0.43 L | <0.05 | 32.0 L/min | 7.0 L/min
Russell, Williams, Weller, et al., 1995 | BDP + placebo | 107/89 | | | | 4.90% pred
Russell, Williams, Weller, et al., 1995 | BDP + salmeterol | 99/78 | | | | 8.20% pred | 3.30% pred | =0.0170
Shapiro, Lumry, Wolfe, et al., 2000 | FP | 84/66 | 0.25 L | | | 3.30% pred
Shapiro, Lumry, Wolfe, et al., 2000 | FP; salmeterol | 84/81 | 0.48 L | 0.23 L | <0.001 | 11.80% pred | 8.50% pred | NS
van der Molen, Postma, Turner, et al., 1997 | ICS; placebo | 114/113 | 0.09L | | | −2.10 L/min
van der Molen, Postma, Turner, et al., 1997 | ICS; formoterol | 125/125 | 0.22L | 0.13L | NS ^b^ | 25.90 L/min | 28.0 L/min | <0.001 ^a^
Verberne, Frost, Duiverman, et al., 1998 | BDP | 57 | 2.00% pred | | | 27.30 L/min | | | 8.00 DD
Verberne, Frost, Duiverman, et al., 1998 | BDP; salmeterol | 60 | −0.10% pred | −2.10% pred | NS ^b^ | 41.80 L/min | 14.50 L/min | NS ^a^ | 11.50 DD | 3.50 DD | NS
Weersink, Douma, Postma, et al., 1997 | FP | 17/16 | 13.6% pred
Weersink, Douma, Postma, et al., 1997 | FP + salmeterol | 16/14 | 9.9% pred | −3.70% pred | NS ^b^
- Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | ICS placebo | 17/13 | −8.30%pred | | | 10.0 L/min | | | 0.0mg/mL meth
McIvor, Pizzichini, Turner, et al., 1998 | ICS + salmeterol | 17/13 | 0.40% pred | 8.70% pred | NS | 32.0 L/min | 22.0 L/min | NS ^a^ | −.1mg/mL meth | −0.10mg/mL | NS ^a^
Nielsen, Pedersen, Faurschou, et al, 1999 | BDP placebo | 19/19 | −0.04L | | | 3.70 L/min
Nielsen, Pedersen, Faurschou, et al, 1999 | BDP salmeterol | 15/15 | 0.16L | 0.20L | NS ^b^ | 17.40 L/min | 13.70 L/min | NS
Wilding, Clark, Coon, et al., 1997 | ICS; placebo | 100/84 | 0.00L | | | 16.00 L/min
Wilding, Clark, Coon, et al., 1997 | ICS; salmeterol | 100/87 | 0.13L | 0.13L | <0.001 | 36.00 L/min | 20.00 L/min | <0.001 ^a^
- Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | FP; placebo | 223/223 | 14.0% pred | | | 9.00% pred
Baraniuk, Murray, Nathan, et al., 1999 | FP; salmeterol | 231/231 | 16.70% pred | 2.70% pred | 0.018 | 11.00% pred | 2.00% pred | <0.033
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP | 65/58 | 0.20L | | | 18.60 L/min
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | BDP; formoterol | 69/64 | 0.28L | 0.08L | NS ^b^ | 34.60 L/min | 16.00 L/min | =0.002
Condemi, Goldstein, Kalberg, et al., 1999 | fp; placebo | 216 | 0.33L | | | 31.30 L/min
Condemi, Goldstein, Kalberg, et al., 1999 | FP;salmeterol | 221 | 0.43L | 0.10L | 0.0130 | 52.30 L/min | 21.00 L/min | <0.01
Greening, Ind, Northfield, et al., 1994 | BDP; placebo | 206/206 | | | | 7.00 L/min
Greening, Ind, Northfield, et al., 1994 | BDP; salmeterol | 220/220 | | | | 27.50 L/min | 20.50 L/min | <0.01
Kelsen, Church, Gillman, et al., 1999 | BDP | 244/240 | 0.25L | | | 20.0 L/min
Kelsen, Church, Gillman, et al., 1999 | BDP; salmeterol | 239/236 | 0.34L | 0.09L | NS | 46.0 L/min | 26.0 L/min | <0.001
Murray, Church, Anderson, et al., 1999 | BDP | 254/253 | 0.23L | | | 31.0 L/min
Murray, Church, Anderson, et al., 1999 | BDP; salmeterol | 260/259 | 0.38L | 0.15L | <0.05 | 49.4 L/min | 18.40 L/min | <0.05
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD; placebo | 214/? | 5.6% pred | | | 2 L/min
Pauwels, Lofdahl, Postma, et. al., 1997 | BUD; formoterol | 210/? | 8.3% pred | 2.7% pred | NR | 17 L/min | 15 L/min | NR
Pearlman, Stricker, Weinstein, et al., 1999 | FP | 23/23 | 0.30L | | | 25.0 L/min
Pearlman, Stricker, Weinstein, et al., 1999 | FP; salmeterol | 25/25 | 0.59L | 0.29L | <0.05 | 57.0 L/min | 32.0 L/min | <0.05
van Noord, Schreurs, Mol, et al., 1999 | FP | 135 | 0.09L | | | 19.0 L/min
van Noord, Schreurs, Mol, et al., 1999 | FP; salmeterol | 139 | 0.09L | 0.0L | NS ^b^ | 19.0 L/min | 0.0 L/min | NS ^a^
Verberne, Frost, Duiverman, et al., 1998 | BDP | 60/54 | 3.50% pred | | | 41.10 L/min | | | 17.00 DD
Verberne, Frost, Duiverman, et al., 1998 | BDP; salmeterol | 60/55 | −0.10% pred | −3.60% pred | NS ^b^ | 41.80 L/min | 0.70 L/min | NS ^a^ | 11.50 DD | −5.50 DD | NS
Vermetten, Boermans, Luiten, et al., 1999 | BDP | 120/ | | | | 6.30% pred
Vermetten, Boermans, Luiten, et al., 1999 | BDP; salmeterol | 113/? | | | | 7.00% pred | 0.70% pred | NS*
Woolcock, Lundback, Ringdal, et al., 1996 | BDP | 251 | 3.2% pred | | | 3.0% pred
Woolcock, Lundback, Ringdal, et al., 1996 | BDP; salmeterol | 243 | 7.2% pred | 4.00% pred | <0.05 | 10.0% pred | 7.00% pred | <0.001
Woolcock, Lundback, Ringdal, et al., 1996 | BDP; salmeterol | 244 | 7.2% pred | 4.00% pred | <0.05 ^c^ | 10.0% pred | 7.00% pred | <0.001 ^c^
ADDITION OF THEOPHYLLINE
- Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 | BDP; placebo | 40/40 | 0.17L | | | 12.60 L/min
Emad, 1996 | BDP; theophylline | 40/40 | 0.51L | 0.34L | 0.0010 | 71.40 L/min | 58.0 L/min | =0.010 ^a^
Meltzer, Orgel, Ellis, et al., 1992 | albuterol; BDP; placebo | 37/33 | 22.0% pred | | | 25.0% pred
Meltzer, Orgel, Ellis, et al., 1992 | albuterol; BDP; theophylline | 35/29 | 28.0% pred | 6.00% pred | NS ^b^ | 38.0% pred | 13.0% pred | NS
Minoguchi, Kohno, Oda, et al., 1998 | BDP; theophylline | 19/18 | −0.14 | | | −35.50 L/min
Minoguchi, Kohno, Oda, et al., 1998 | BDP; theophylline | 19/17 | −0.05 | 0.09 | NR | 4.40 L/min | 39.90 L/min | NR
Nassif, Weinberger, Thompson, et al., 1981 | BDP; placebo | 22/18
Nassif, Weinberger, Thompson, et al., 1981 | BDP; theophylline | 22/18
- Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | BUD; placebo | 31/31 | 0.11 L | | | 25.0 L/min
Evans, Taylor, Zetterstrom et al., 1997 | BUD; theophylline | 31/31 | 0.21 L | 0.10 L | 0.03 | 23.0 L/min | −2 L/min | 0.16
Ukena, Harnest, Saka-lauskas, et al., 1997 | BDP; placebo | 90/64 | 0.19L | | | 22.0 L/min
Ukena, Harnest, Saka-lauskas, et al., 1997 | BDP; theophylline | 100/69 | 0.26L | 0.07L | NS ^d^ | 33.0 L/min | 11.0 L/min | NS
ADDITION OF LEUKOTRIENE RECEPTOR ANTAGONISTS
- Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | BDP; placebo | 200/193 | 0.72% pred | | | 2.65 L/min
Laviolette, Malmstrom, Lu, et al., 1999 | BDP; montelukast | 193/193 | 5.08% pred | 4.36% pred | <0.001 | 10.41 L/min | 7.76 L/min | =0.0041
Tamaoki, Kondo, Sakai, et al., 1997 | BDP; theophylline placebo | 40/37 | −0.33L | | | −46.0 L/min
Tamaoki, Kondo, Sakai, et al., 1997 | BDP; theophylline; pranlukast | 43/42 | 0.08L | 0.41L | 0.0070 | 5.00 L/min | 51.00 L/min | <0.0010
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP | 17/17 | | | | 7.70% pred
Tomita, Hashimoto, Matsumoto, et al., 1999 | BDP + pranlukast | 24/24 | | | NS | 9.70% pred | 2.00% pred | <0.05 ^a^
Christian Virchow, Prasse, Naya et al., 2000 | ICS + placebo | 188/188 | 0.09 +/− 0.41 L | | | 1.5 +/− 52.1 L/min
Christian Virchow, Prasse, Naya et al., 2000 | ICS + zafirlukast | 180/180 | 0.19 +/− 0.54 L | 0.10 L | 0.014 | 18.7 +/− 48.3 L/min | 17.2 L/min | <0.001
- Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | ICS + placebo | 113/113 | 5.40% pred
Lofdahl, Reiss, Leff, et al., 1999 | ICS + montelukast | 113/112 | 2.70% pred | −2.70% pred | NS

a Study was 28 wks. but outcome measures were at 12 wks.

b Significance level based on the absolute values at baseline vs. study endpoint.

c Compared to group 1

d Geometric mean and 95% CI calculated for test/reference ration of baseline-adjusted medians, and equivalence concluded if the lower limit of the CI was above 0.90.

Table 18. Change in quality of life outcomes

Citation | QOL Instrument | Treatment Arm | # Eval Pts | Scale(s) | Result | Treatment Difference | p Value | Comments
ADDITION OF LONG-ACTING BETA AGONISTS
Studies Using a Fixed ICS Dose in All Study Arms
Kemp, Cook, Incaudo, et al., 1998 | AQLQ | corticosteroid, inhaled; placebo | | Global Activity limitation Asthma symptoms Emotional function Environmental exposure | 0.61 0.54 0.71 0.65 0.47 | | | Results reported as change from baseline
Kemp, Cook, Incaudo, et al., 1998 | AQLQ | corticosteroid, inhaled; salmeterol 42 mcg | | Global Activity limitation Asthma symptoms Emotional function Environmental exposure | 1.08 0.91 1.28 1.17 0.84 | 0.53 0.37 0.57 0.52 0.37 | <0.016 <0.016 <0.016 <0.016 <0.016 | Results reported as change from baseline
Pauwels, Lofdahl, Postma, et. Al., 1997 (QOL data reported by Juniper, Svensson, O'Byrne, et al., 1999) | AQLQ | budesonide 100 mcg; placebo | | Overall change AQLQ Change activity Change symptoms Change emotional Environmental, change | 0 0.02 0.03 0.05 0.05 | | | Run-in period there was improvement in QoL in all domains & overall score; improvements were stat. sig (p<.0001) with a change in mean score of ~.50. Scores in all groups were maintained at same level, no evidence of deterioration; 356 pts completed 12 months
Pauwels, Lofdahl, Postma, et. Al., 1997 (QOL data reported by Juniper, Svensson, O'Byrne, et al., 1999) | AQLQ | budesonide 100 mcg; formoterol 12 mcg | | Overall change AQLQ Change activity Change symptoms Change emotional Environmental, change | 0.06 0 0 −0.06 −0.25 | 0.06 −0.02 −0.03 −0.11 −0.30 | NS | Following randomization, only the BUD800+formoterol group showed further improvement in AQLQ scores. The mean improvement of 0.2 was less than the minimal important difference of 0.5. In all 4 groups, the QoL achieved 1 month after randomization sustained
Pauwels, Lofdahl, Postma, et. Al., 1997 (QOL data reported by Juniper, Svensson, O'Byrne, et al., 1999) | AQLQ | budesonide 400 mcg; placebo | | Overall change AQLQ Change activity Change symptoms Change emotional Environmental, change | 0.1 −0.1 0 0 −0.2 | | NS
Pauwels, Lofdahl, Postma, et. Al., 1997 (QOL data reported by Juniper, Svensson, O'Byrne, et al., 1999) | AQLQ | budesonide 400 mcg; formoterol 12 mcg | | Overall change AQLQ Change activity Change symptoms Change emotional Environmental, change | 0.21 −0.3 −0.1 −0.3 −0.3 | 0.11 −0.20 −0.10 −0.30 −0.10 | 0.028 | Correlations between change in AQLQ scores and change in clinical measures over randomization period were only weak to moderate. 356 out of 466 completed study. Don't give n by study group for outcomes
Greening, Ind, Northfield, et al., 1994 (QOL reported by Hyland and Crocker, 1995) | Living with Asthma Questionnaire | beclomethasone dipropionate 500 mcg; placebo | 160 | Questionnaire Functional limitation Distress Diary Problem incidence Problem severity | 0.85 0.5 0.35 0.90 | | | Functional limitation baseline 0.94; Distress baseline 0.61; Problem incidence baseline 0.50; Problem severity baseline 1.00
Greening, Ind, Northfield, et al., 1994 (QOL reported by Hyland and Crocker, 1995) | Living with Asthma Questionnaire | beclomethasone dipropionate 200 mcg; salmeterol 50 mcg | 175 | Questionnaire Functional limitation Distress Diary Problem incidence Problem severity | 0.85 0.56 0.42 0.80 | 0.00 0.06 0.07 0.10 | NS NS 0.02 0.03 | Functional limitation baseline 0.95; Distress baseline 0.63; Problem incidence baseline 0.67; Problem severity baseline 1.25
Vermetten, Boermans, Luiten, et al., 1999 | Hyland Quality of Life Questionnaire | beclomethasone dipropionate 400 mcg; | | A cold does not hurt me very much I can run as fast as other people my age I can climb a hill as fast as other people my age I can go out at night to a bar without problems Apart from exacerbations I am not troubled by asthma That I cannot do sports frustrates me | NR NR NR NR NR NR | | | Within group improvement for items 1-5; "A smoky restaurant can spoil a dinner completely" p sig within group; "I never worry about the possibility that my asthma problems may worsen by going on holiday" p sig within group
Vermetten, Boermans, Luiten, et al., 1999 | Hyland Quality of Life Questionnaire | beclomethasone dipropionate 200 mcg; salmeterol 50 mcg | | A cold does not hurt me very much I can run as fast as other people my age I can climb a hill as fast as other people my age I can go out at night to a bar without problems Apart from exacerbations I am not troubled by asthma That I cannot do sports frustrates me | NR NR NR NR NR NR | | NS NS NS NS NS NS | Within group improvement for items 1-6; "A smoky restaurant can spoil a dinner completely" p NS within or between group; "I never worry about the possibility that my asthma problems may worsen by going on holiday" p NS within or between groups

Overall, 34 of 45 comparisons evaluated the addition of a long-acting beta-2 agonist to ICS six used added theophylline, and five added leukotriene antagonists. The number of studies (and number of patients enrolled) for each agent class within each of the three comparison categories is shown in Table 19.

Table 19. Numbers of studies (and number of patients enrolled) for each agent class within each of the three comparison categories

| Long-Acting Beta-2 Agonists | Theophylline | Leukotriene Antagonists
Addition to fixed-dose ICS | 18 comparisons (n=3,163) | 4 comparisons (n=234) | 4 comparisons (n=885)
Titrated dose ICS after addition of drug | 3 comparisons (n=268) | 0 comparisons | 1 comparison (n=226)
Low-mod dose ICS + additional agent vs. high dose ICS | 13 comparisons (n=4,285) | 2 comparisons (n=252) | 0 comparisons

The available evidence largely reports on adult populations; 35 of the studies enrolled subjects with a mean age in the range of 27 to 49 years. There is little evidence on children treated with a long-term controller agent added to ICS. Four studies enrolled children with a mean age of approximately 10 to 11 years. Two of the pediatric studies addressed the addition of long-acting beta-2 agonists to ICS; and reported on a total of 383 evaluable patients of whom 167 were treated with long-acting beta-2 agonist (Russell, Williams, Weller et al., 1995; Verberne, Frost, Duiverman et al., 1998). Addition of theophylline was also addressed in two studies of children, which reported on a total of 98 evaluable patients, 47 of whom were treated with theophylline (Meltzer, Orgel, Ellis et al., 1992; Nassif, Weinberger, Thompson et al., 1981).

All of the studies were randomized studies with the exception of one (Emad, 1996) in which patients were sequentially assigned to treatment groups. The vast majority of the studies (34 of 37) employed a parallel group treatment design; three studies (Boulet, Cartier, Milot et al., 1998; McIvor, Pizzichini, Turner et al., 1998; Wilding, Clark, Coon et al., 1997) employed a crossover design. Ten studies had a duration of 24 weeks or greater and an additional study had a duration of 21 weeks. With the exception of two ICS dose-reduction studies that continued until the minimum effective ICS dose was reached for each patient, all other studies were 12 weeks or less in duration.

Table 15 summarizes the outcomes of the 43 comparisons included in this key question. Lung function outcomes were the most consistently reported measures; with 38 comparisons reporting on forced expiratory volume in 1 second (FEV1) and 39 reporting on PEF. Symptom-based outcomes were reported by the majority of studies; with 25 reporting symptom score measures, 24 reporting symptom frequency measures, and 16 reporting exacerbation outcomes. Symptom score instruments varied in the parameters addressed and the interval scales used, making comparison across studies difficult. Medication use outcomes were also commonly reported; 26 studies reported on short-acting beta-2 agonist use, usually as puffs/day, and 10 studies reported on oral corticosteroid use. Four studies reported quality of life outcomes. Two studies used the Asthma Quality of Life Questionnaire (AQLQ; Juniper, Svensson, O'Byrne et al., 1999; Cook, Incaudo et al., 1998), one used the Hyland Quality of Life Questionnaire (Vermetten, Boermans, Luiten et al., 1999), and one used the Living with Asthma Questionnaire (Hyland and Crocker, 1995).

Table 15. Study characteristics and outcomes reported

Citation/Study Design | Eligibility | Estimated Disease Severity | Study Duration (weeks) | Study Arm | # Enrolled # Evaluable | Baseline FEV1 | Age ± SD (or range) | Lung Function Outcomes | | | Sx / Med Use | QOL
Citation/Study Design | Eligibility | Estimated Disease Severity | Study Duration (weeks) | Study Arm | # Enrolled # Evaluable | Baseline FEV1 | Age ± SD (or range) | FEV1 | PEF | PC20 | Sx / Med Use | QOL
ADDITION OF LONG-ACTING BETA-2 AGONISTS
- Studies Using a Fixed ICS Dose in all study arms
Aubier, Pieters, Schlosser, et al., 1999 -randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 50% pred; FEV1 maximum 100% pred; PEF (a.m. (home)) minimum 51% of normal; Symptom score >2 on at least 4 of 7 consecutive days | Mod-severe | 28 | FP/placebo | 165 | 2.33 ± 0.8 L | 50 12-76 | X | XX
Aubier, Pieters, Schlosser, et al., 1999 -randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 50% pred; FEV1 maximum 100% pred; PEF (a.m. (home)) minimum 51% of normal; Symptom score >2 on at least 4 of 7 consecutive days | Mod-severe | 28 | FP/salmeterol | 167 | 2.44 ± 0.8 L | 46 12-78
Boulet, Cartier, Milot, et al., 1998 -- randomized; crossover, (placebo); double-blinded | FEV1 (Predose) minimum 61% pred; FEV1 (Predose) maximum 100% pred; methacholine PC20 maximum 7.9 | Mild-moderate | 4 | BDP/placebo | 16/15 | 77.3 ± 11.2% pred | 45.3 ± 17.2 | X | | XX
Boulet, Cartier, Milot, et al., 1998 -- randomized; crossover, (placebo); double-blinded | FEV1 (Predose) minimum 61% pred; FEV1 (Predose) maximum 100% pred; methacholine PC20 maximum 7.9 | Mild-moderate | 4 | BDP/salmeterol | 16/15 | 76.7 ± 10.0% pred | 45.3 ± 17.2
Boyd, 1995- randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 40% pred; Use of >1500 mcg/day ICS, under consideration for oral steroids; At least 2 of: nighttime sx score >1, daytime sx score >2, >8 puffs/day, PEF variability >15% on at least 3 of 7 days | Severe | 12 | BDP/placebo | 64/52 | 1.87 ± 0.74 L | 47 18-73 | X | XX | | X
Boyd, 1995- randomized; parallel, controlled (placebo); double-blinded | | Severe | 12 | BDP/salmeterol | 55/48 | 1.78 ± 0.71 L | 47 18-79
FitzGerald, Chapman, Della Cioppa, et al., 1999 -randomized; parallel, controlled (placebo); double-blinded | FEV1 min 50%; methacholine PC20 maximum 8; patients on ICS, 400-1200 mcg/day and short-acting beta-agonists for at least one month. Use of rescue med at least 5 of last 7 days; no more than 2 night awakenings/wk | Mild-severe | 24 | ICS/placebo | 91/72 | 2.67 ± 0.74 L | 36 ± 12 | X | X | XX | X
FitzGerald, Chapman, Della Cioppa, et al., 1999 -randomized; parallel, controlled (placebo); double-blinded | | Mild-severe | 24 | ICS/formoterol + placebo | 89/72 | 2.79 ± 0.79 L | 36 ± 13
Grutters, Brinkman, Aslander, et al., 1999 randomized; parallel, controlled; double-blinded | FEV1 (Predose) minimum 61% pred; FEV1 (Predose) maximum 100% pred; Histamine PC20 maximum 3.9 | Moderate | 8 | BDP | 15/15 | 86 ± 15.5% pred | 26 ± 19.4 | X
Grutters, Brinkman, Aslander, et al., 1999 randomized; parallel, controlled; double-blinded | FEV1 (Predose) minimum 61% pred; FEV1 (Predose) maximum 100% pred; Histamine PC20 maximum 3.9 | Moderate | 8 | BDP/salmeterol | 12/12 | 79 ± 17.3% pred | 27 ± 20.8
Kavuru, Melamed, Gross, et al., 2000 randomized; parallel, controlled; double-blinded | FEV1 minimum 40% of predicted, maximum 85% of predicted; Not more than 3 night awakenings in previous week | Mod-severe | 12 | FP | 90/85 | 2.11 ± 0.7 L | 39 12-67 | XX | X | | X
Kavuru, Melamed, Gross, et al., 2000 randomized; parallel, controlled; double-blinded | FEV1 minimum 40% of predicted, maximum 85% of predicted; Not more than 3 night awakenings in previous week | Mod-severe | 12 | FP/salmeterol | 92/87 | 2.17 ± 0.6 L | 38 12-70
Kemp, Cook, Incaudo, et al., 1998 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 40% pred; FEV1 maximum 80% pred; Average symptom score of at least 1 during run-in period; Using a fixed dose of ICS | Mod-severe | 12 | ICS/Placebo | 254 | 2.17 ± 0.6 L | 41.6 ± 15.9 | X | X | | X^a^ | X
Kemp, Cook, Incaudo, et al., 1998 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 40% pred; FEV1 maximum 80% pred; Average symptom score of at least 1 during run-in period; Using a fixed dose of ICS | Mod-severe | 12 | ICS/salmeterol | 252 | 2.16 ± 0.6 L | 42 ± 15.9
Langley, Masterson, Batty, et al., 1998 randomized; parallel, controlled; double-blinded | FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 90% pred; Ipratropium (<240 mcg/day) use on >4 of 7 days prior to randomization OK | Mild-moderate; | 4 | ICS/placebo | 24/23 | 2.4 ± 0.64 L | 37.5 20-69 | XX | X | | X
Langley, Masterson, Batty, et al., 1998 randomized; parallel, controlled; double-blinded | FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 90% pred; Ipratropium (<240 mcg/day) use on >4 of 7 days prior to randomization OK | Mild-moderate; | 4 | ICS/salmeterol | 25/24 | 2.29 ± 0.54 L | 49 19-68
Li, Ward, Thien, et al., 1999 randomized; parallel controlled (placebo); double-blinded | FEV1 (a.m. predose) minimum 60% pred; FEV1 (a.m. predose) maximum 100% pred; PEF variability minimum 16%; Symptom score of >2, or use of rescue medication, on at least 7 of 14 days | Moderate | 12 | BDP/BUD + placebo | 16/16 | 82 ± 12.0% pred | 33 22-68 | X | X | | X
Li, Ward, Thien, et al., 1999 randomized; parallel controlled (placebo); double-blinded | FEV1 (a.m. predose) minimum 60% pred; FEV1 (a.m. predose) maximum 100% pred; PEF variability minimum 16%; Symptom score of >2, or use of rescue medication, on at least 7 of 14 days | Moderate | 12 | BDP/BUD+ salmeterol | 13/13 | 85 ± 14.4% pred | 38 20-70
Pauwels, Lofdahl, Postma, et. al., 1997 randomized; parallel, controlled (placebo); double-blinded (Juniper, Svensson, O'Byrne, et al., 1999 for QOL data) | FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 100% pred | Mild-severe | 52 | BUD/placebo | 213/? | 75.8 ± 17.5% pred | 42 | X | X | | X | X
Pauwels, Lofdahl, Postma, et. al., 1997 randomized; parallel, controlled (placebo); double-blinded (Juniper, Svensson, O'Byrne, et al., 1999 for QOL data) | FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 100% pred | Mild-severe | 52 | BUD/formoterol | 210/? | 75.7 ± 17.4% pred | 41
Pauwels, Lofdahl, Postma, et. al., 1997 randomized; parallel, controlled (placebo); double-blinded (Juniper, Svensson, O'Byrne, et al., 1999 for QOL data) | FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 100% pred | Mild-severe | 52 | BUD/placebo | 214/? | 75.4 ± 16.1% pred | 44
Pauwels, Lofdahl, Postma, et. al., 1997 randomized; parallel, controlled (placebo); double-blinded (Juniper, Svensson, O'Byrne, et al., 1999 for QOL data) | FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 100% pred | Mild-severe | 52 | BUD/formoterol | 215/? | 76.3 ± 16.1% pred | 42
Pearlman, Stricker, Weinstein, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. predose) minimum 50% pred; FEV1 (a.m. predose) maximum 80% pred | Moderate | 4 | FP 88mcg | 23/23 | 2.91 ± 0.6 L | 27 13-50 | X | X | | X
Pearlman, Stricker, Weinstein, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. predose) minimum 50% pred; FEV1 (a.m. predose) maximum 80% pred | Moderate | 4 | salmeterol/FP | 25/25 | 2.31 ± 0.6 L | 33 4-60
Pearlman, Stricker, Weinstein, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. predose) minimum 50% pred; FEV1 (a.m. predose) maximum 80% pred | Moderate | 4 | FP | 23/23 | 2.52 ± 0.7 L | 32 14-61
Pearlman, Stricker, Weinstein, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. predose) minimum 50% pred; FEV1 (a.m. predose) maximum 80% pred | Moderate | 4 | salmeterol/FP | 21/21 | 2.62 ± 0.5 L | 26 13-52
Russell, Williams, Weller, et al., 1995 randomized; parallel, controlled (placebo); double-blinded | PEF (a.m. (home)) maximum 90% pred; PEF variability minimum 15%; Symptoms on at least 7 of prior 14 days | Moderate-severe | 12 | BDP/placebo | 107/89 | | 10.3 ± 2.7 | | X | | X
Russell, Williams, Weller, et al., 1995 randomized; parallel, controlled (placebo); double-blinded | PEF (a.m. (home)) maximum 90% pred; PEF variability minimum 15%; Symptoms on at least 7 of prior 14 days | Moderate-severe | 12 | BDP/salmeterol | 99/78 | | 10.2 ± 2.7
Shapiro, Lumry, Wolfe, et al., 2000 randomized; parallel, controlled; double-blinded | FEV1min 40% of predicted, max 85% of predicted; No more than 3 night awakenings in prior 2 weeks, no more than 3 of last 14 days with 12 or more puffs rescue medication | Moderate-severe | 12 | FP | 84/66 | 2.12 ± 0.54 L | 40 12-67 | XX | X | | X
Shapiro, Lumry, Wolfe, et al., 2000 randomized; parallel, controlled; double-blinded | FEV1min 40% of predicted, max 85% of predicted; No more than 3 night awakenings in prior 2 weeks, no more than 3 of last 14 days with 12 or more puffs rescue medication | Moderate-severe | 12 | FP/salmeterol | 84/81 | 2.23 ± 0.63 L | 38 12-69
van der Molen, Postma, Turner, et al., 1997 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m.) minimum 40% pred: At least 5 puffs/week of rescue medication; Regular use of ICS | Mild-severe | 24 | ICS/placebo | 114/113 | 2.16 ± 0.8 L | 45.4±14 | X | X | | XX
van der Molen, Postma, Turner, et al., 1997 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m.) minimum 40% pred: At least 5 puffs/week of rescue medication; Regular use of ICS | Mild-severe | 24 | ICS/formoterol | 125/125 | 2.29 ± 0.7 L | 40.5 ± 13.7
Verberne, Frost, Duiverman, et al., 1998 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 55% pred; FEV1 maximum 90% pred; PC20 of <150 mcg methacholine; No exacerbations or URI for at least 1 month prior to study | Mild-moderate; | 54 | BDP | 57 | 102.2 ± 12% pred | 11.1 ± 2.7 | X | X | X | X
Verberne, Frost, Duiverman, et al., 1998 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 55% pred; FEV1 maximum 90% pred; PC20 of <150 mcg methacholine; No exacerbations or URI for at least 1 month prior to study | Mild-moderate; | 54 | BDP/salmeterol | 60 | 103.5 ± 13.1% pred | 10.8 ± 2.5
Weersink, Douma, Postma, et al., 1997 randomized; parallel, controlled (placebo); double-blinded | PEF variability minimum 15%; Methacholine PC20 maximum 9.6; Patients had a history of episodic dyspnea or wheezing consistent with asthma | Mild-severe | 6 | FP | 17/16 | 88.4 ± 19.5% pred | 28 ± 6.2 | X | | X
Weersink, Douma, Postma, et al., 1997 randomized; parallel, controlled (placebo); double-blinded | PEF variability minimum 15%; Methacholine PC20 maximum 9.6; Patients had a history of episodic dyspnea or wheezing consistent with asthma | Mild-severe | 6 | FP/salmeterol | 16/14 | 83.1 ± 14.4% pred
- Studies that titrated ICS dose after addition of long-acting beta-2 agonists
McIvor, Pizzichini, Turner, et al., 1998 randomized; crossover, randomized sequence (placebo); double-blinded | Methacholine PC20 maximum 8; < 4 puff/day rescue beta-agonist. No exacerbations of asthma in last 4 wks | Mild-severe | until mild exacerbation or total ICS withdrawal | ICS/placebo | 17/13 | 77.4 ± 17.2% pred | 43.6 ±10.7 | X | X | X | XX | X
McIvor, Pizzichini, Turner, et al., 1998 randomized; crossover, randomized sequence (placebo); double-blinded | Methacholine PC20 maximum 8; < 4 puff/day rescue beta-agonist. No exacerbations of asthma in last 4 wks | Mild-severe | until mild exacerbation or total ICS withdrawal | ICS/salmeterol | 17/13 | 75.2 ± 16.3% pred | 43.6 ±10.7
Nielsen, Pedersen, Faurschou, et al., 1999 rando-mized; parallel, con-trolled (placebo); double-blinded | FEV1 (Predose) min 61% pred; max 100% pred; PEF (a.m. (home)) minimum 61% pred; PEF variability minimum 0%; Total symptom score < 2 on all days of run-in | Mild-moderate | until minimal acceptable ICS dose | BDP/placebo | 19/19 | 86.7% pred 2.98 (Mean) L | 43 | X | X | | XX
Nielsen, Pedersen, Faurschou, et al., 1999 rando-mized; parallel, con-trolled (placebo); double-blinded | FEV1 (Predose) min 61% pred; max 100% pred; PEF (a.m. (home)) minimum 61% pred; PEF variability minimum 0%; Total symptom score < 2 on all days of run-in | Mild-moderate | until minimal acceptable ICS dose | BDP/salmeterol | 15/15 | 86.1% pred 2.80 (Mean) L | 45
Wilding, Clark, Coon, et al., 1997 randomized; crossover, randomized sequence (placebo); double-blinded | FEV1 (Predose) minimum 50% pred; Patients receiving >400 mcg/day of BDP or BUD, titered during run-in to >200 mcg/day. No exacerbations or URI's in previous 6 wks | Mild-severe | 24 | ICS/placebo | 100/84 | 2.71 ± 0.79 L | 39±10 | X | X | X | XX
Wilding, Clark, Coon, et al., 1997 randomized; crossover, randomized sequence (placebo); double-blinded | FEV1 (Predose) minimum 50% pred; Patients receiving >400 mcg/day of BDP or BUD, titered during run-in to >200 mcg/day. No exacerbations or URI's in previous 6 wks | Mild-severe | 24 | ICS/salmeterol | 100/87 | 2.71 ± 0.79 L | 39±10
- Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Baraniuk, Murray, Nathan, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. Predose) minimum 40% pred; FEV1 (a.m. Predose) maximum 85% pred | Mod-severe | 12 | FP/placebo | 223/223 | 63.1 ± 12.2% pred | 40(mean) 12-74 | XX | X | | X
Baraniuk, Murray, Nathan, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. Predose) minimum 40% pred; FEV1 (a.m. Predose) maximum 85% pred | Mod-severe | 12 | FP/salmeterol | 231/231 | 63.1 ± 11.9% pred | 41(mean) 12-79
Bouros, Bachlitzanakis, Kottakis, et al., 1999 randomized; parallel, controlled | FEV1 (Predose) min 40% pred; max 85% pred; Daytime and nighttime symptom score of 2 or greater on at least 4 of 7 days prior to randomization | Mod-severe | 12 | BDP | 65/58 | 2.15 ± 0.75 L | 43±14.9 | X | XX | | X
Bouros, Bachlitzanakis, Kottakis, et al., 1999 randomized; parallel, controlled | FEV1 (Predose) min 40% pred; max 85% pred; Daytime and nighttime symptom score of 2 or greater on at least 4 of 7 days prior to randomization | Mod-severe | | BDP/formoterol | 69/64 | 2.27 ± 0.79 L | 43±14.9
Condemi, Goldstein, Kalberg, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. Predose) minimum 40% pred; maximum 85% pred; PEF variability minimum 20%; At least 3 days in prior wk with symptoms | Mod-severe | 24 | FP/placebo | 216 | 2.14 ± 0.6 L | 36.8±13.2 | X | X | | X
Condemi, Goldstein, Kalberg, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. Predose) minimum 40% pred; maximum 85% pred; PEF variability minimum 20%; At least 3 days in prior wk with symptoms | Mod-severe | 24 | FP/salmeterol | 221 | 2.12 ± 0.6 L | 39.6±13.4
Greening, Ind, Northfield, et al., 1994 randomized; parallel, controlled (placebo); double-blinded (Hyland and Crocker, 1995 for QOL data) | FEV1 minimum 50% pred; PEF variability minimum 15%; Days/wk with symptoms minimum 4 | Mod-severe | 21 | BDP/placebo | 206/206 | | 47±15 | | XX | | X | X
Greening, Ind, Northfield, et al., 1994 randomized; parallel, controlled (placebo); double-blinded (Hyland and Crocker, 1995 for QOL data) | FEV1 minimum 50% pred; PEF variability minimum 15%; Days/wk with symptoms minimum 4 | Mod-severe | 21 | BDP/salmeterol | 220/220 | | 48±15
Kelsen, Church, Gillman, et al., 1999 randomized; parallel, controlled; double-blinded | FEV1 (a.m. Predose) minimum 45% pred; FEV1 (a.m. Predose) maximum 80% pred | Mod-severe | 24 | BDP | 244/240 | 64.14 ± 10.2% pred | 42±12.5 | X | X | | X
Kelsen, Church, Gillman, et al., 1999 randomized; parallel, controlled; double-blinded | FEV1 (a.m. Predose) minimum 45% pred; FEV1 (a.m. Predose) maximum 80% pred | Mod-severe | 24 | BDP/salmeterol | 239/236 | 64.93 ± 10.2% pred | 42.4±13.9
Murray, Church, Anderson, et al., 1999 randomized; parallel, controlled; double-blinded | FEV1 (a.m. Predose) minimum 45% pred; maximum 80% pred; >3 nights with awakenings, >3 days with sx or with albuterol use during 7 days prior to randomization | Mod-severe | 24 | BDP | 254/253 | 2.31 L | 41.9 ±14.3 | X | X | | X
Murray, Church, Anderson, et al., 1999 randomized; parallel, controlled; double-blinded | FEV1 (a.m. Predose) minimum 45% pred; maximum 80% pred; >3 nights with awakenings, >3 days with sx or with albuterol use during 7 days prior to randomization | Mod-severe | 24 | BDP/salmeterol | 260/259 | 2.3 L | 42.8±12.9
Pauwels, Lofdahl, Postma, et. al., 1997 randomized; parallel, controlled (placebo); double-blinded (Kips, O'Connor, Inman, et al 2000 for QOL data) | FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 100% pred | Mild-severe | 52 | BUD/placebo | 214/? | 75.4 ± 16.1% pred | 44 | X | X | | X | X
Pauwels, Lofdahl, Postma, et. al., 1997 randomized; parallel, controlled (placebo); double-blinded (Kips, O'Connor, Inman, et al 2000 for QOL data) | FEV1 (Predose) minimum 50% pred; FEV1 (Predose) maximum 100% pred | Mild-severe | 52 | BUD/formoterol | 210/? | 75.7 ± 17.4% pred | 41
Pearlman, Stricker, Weinstein, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. predose) minimum 50% pred; FEV1 (a.m. predose) maximum 80% pred | Moderate | 4 | FP | 23/23 | 2.52 ± 0.7 L | 32 14-61 | X | X | | X
Pearlman, Stricker, Weinstein, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. predose) minimum 50% pred; FEV1 (a.m. predose) maximum 80% pred | Moderate | 4 | salmeterol + FP | 25/25 | 2.31 ± 0.6 L | 33 14-60
van Noord, Schreurs, Mol, et al., 1999 randomized; parallel, controlled; double-blinded | FEV1 (a.m. predose) minimum 50% pred; maximum 100% pred; PEF variability minimum 15%; Total daytime plus nighttime symptoms score of >1 or use of beta-agonist on >2 occasions in 4 days | Mild-severe | 12 | FP | 135 | 2.39 ± 0.75 L | 47±14 | X | X | | X
van Noord, Schreurs, Mol, et al., 1999 randomized; parallel, controlled; double-blinded | FEV1 (a.m. predose) minimum 50% pred; maximum 100% pred; PEF variability minimum 15%; Total daytime plus nighttime symptoms score of >1 or use of beta-agonist on >2 occasions in 4 days | Mild-severe | 12 | FP/salmeterol | 139 | 2.38 ± 0.75 L | 46±15
Verberne, Frost, Duiverman, et al., 1998 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 55% pred; FEV1 maximum 90% pred; PC20 of <150 mcg methacholine; No exacerbations or URI for at least 1 month prior to study | Mild-moderate | 54 | BDP | 60/54 | 102.3 ± 11.4% pred | 11.4± 2.9 | X | X | X | X
Verberne, Frost, Duiverman, et al., 1998 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 55% pred; FEV1 maximum 90% pred; PC20 of <150 mcg methacholine; No exacerbations or URI for at least 1 month prior to study | Mild-moderate | 54 | BDP/salmeterol | 60/55 | 103.5 ± 13.1% pred | 10.8± 2.5
Vermetten, Boermans, Luiten, et al., 1999 randomized; parallel, controlled; double-blinded | PEF (Not specified (clinic)) minimum 60% pred; patients on ICS at least 6 weeks and needed beta-agonist rescue medication | Mild-moderate | 12 | BDP | 120 | | 42±14 | | X | | X | X
Vermetten, Boermans, Luiten, et al., 1999 randomized; parallel, controlled; double-blinded | PEF (Not specified (clinic)) minimum 60% pred; patients on ICS at least 6 weeks and needed beta-agonist rescue medication | Mild-moderate | 12 | BDP/salmeterol | 113 | | 42±14
Woolcock, Lundback, Ringdal, et al., 1996 randomized; parallel, controlled; double-blinded | FEV1 minimum 50% pred; PEF (Mean a.m., p.m.) minimum 50% pred; Either daytime plus nighttime symptom score >2, PEF variability >15%, or >4 puffs/day on 4 of 7 days prior to randomization | Mod-severe | 26 | BDP | 251 | 75% pred | 42 17-72 | X | X | X | X
Woolcock, Lundback, Ringdal, et al., 1996 randomized; parallel, controlled; double-blinded | FEV1 minimum 50% pred; PEF (Mean a.m., p.m.) minimum 50% pred; Either daytime plus nighttime symptom score >2, PEF variability >15%, or >4 puffs/day on 4 of 7 days prior to randomization | Mod-severe | 26 | BDP/salmeterol | 243 | 72% pred | 44 18-79
Woolcock, Lundback, Ringdal, et al., 1996 randomized; parallel, controlled; double-blinded | FEV1 minimum 50% pred; PEF (Mean a.m., p.m.) minimum 50% pred; Either daytime plus nighttime symptom score >2, PEF variability >15%, or >4 puffs/day on 4 of 7 days prior to randomization | Mod-severe | 26 | BDP/salmeterol | 244 | 71% pred | 46 19-75
ADDITION OF THEOPHYLLINE
- Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 parallel, controlled (placebo) | Objective evidence of airways obstruction during episodes of wheezing or dyspnea, and objective evidence of improved airflow when symptom-free | Moderate-severe; | 24 | BDP/placebo | 40/40 | 1.32 ± 0.19 L | 34.47 ±5.26 | X | X
Emad, 1996 parallel, controlled (placebo) | Objective evidence of airways obstruction during episodes of wheezing or dyspnea, and objective evidence of improved airflow when symptom-free | Moderate-severe; | 24 | BDP/theo | 40/40 | 1.31 ± 0.19 L | 34.52 ± 5.52
Meltzer, Orgel, Ellis, et al., 1992 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. Predose) maximum 75% pred | Moderate-severe; | 12 | albuterol/BDP + placebo | 37/33 | 71 ± 18.2% pred | 10 6-16 | X | X | | X
Meltzer, Orgel, Ellis, et al., 1992 randomized; parallel, controlled (placebo); double-blinded | FEV1 (a.m. Predose) maximum 75% pred | Moderate-severe; | 12 | albuterol/BDP + theo | 35/29 | 70 ± 20.1% pred | 10.1 6-16
Minoguchi, Kohno, Oda, et al., 1998 randomized; parallel, controlled | PEF minimum 80% pred; PEF variability maximum 20%; All patients already treated with ICS and theophylline | Not specified; | 6 | BDP/theo | 19/18 | 2.36 ± 0.6 L | 45.9 26-65 | X | X | | X
Minoguchi, Kohno, Oda, et al., 1998 randomized; parallel, controlled | PEF minimum 80% pred; PEF variability maximum 20%; All patients already treated with ICS and theophylline | Not specified; | 6 | BDP/theo | 19/17 | 2.3 ± 0.6 L | 44.7 19-65
Nassif, Weinberger, Thompson, et al., 1981 randomized; crossover, randomized sequence (placebo); double-blinded | Steroid-dependent children with asthma, with a history of frequent hospitalizations and emergency room visits | Not specified; | 4 | BDP/placebo | 22/18 | | 13.6 7-19
Nassif, Weinberger, Thompson, et al., 1981 randomized; crossover, randomized sequence (placebo); double-blinded | Steroid-dependent children with asthma, with a history of frequent hospitalizations and emergency room visits | Not specified; | 4 | BDP/theo | 22/18 | | 13.6 7-19
- Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | FEV1 minimum 50% pred; FEV1 maximum 85% pred; Nights/week with symptoms minimum 3: Puffs/day minimum 4; Symptom score >2 on >3 days during week prior to randomization | | 12 | BUD/placebo | 31/31 | 2.50 ± 0.78 L | 39.5 18-66 | X | XX | | X
Evans, Taylor, Zetterstrom et al., 1997 | FEV1 minimum 50% pred; FEV1 maximum 85% pred; Nights/week with symptoms minimum 3: Puffs/day minimum 4; Symptom score >2 on >3 days during week prior to randomization | | 12 | BUD/theo | 31/31 | 2.48 ± 1.0 L | 38.1 ± 18-67
Ukena, Harnest, Sakalauskas, et al., 1997 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 50% pred; maximum 85% pred; Nights/week with symptoms minimum 3: Puffs/day minimum 4; Symptom score >2 on >3 days during week prior to randomization | Mild-moderate; | 6 | BDP/placebo | 90/64 | 2.4 ± 0.75 L | 49 18-70 | X | XX | | X
Ukena, Harnest, Sakalauskas, et al., 1997 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 50% pred; maximum 85% pred; Nights/week with symptoms minimum 3: Puffs/day minimum 4; Symptom score >2 on >3 days during week prior to randomization | Mild-moderate; | 6 | BDP/theo | 100/69 | 2.3 ± 0.62 L | 48 20-70
ADDITION OF LEUKOTRIENE RECEPTOR ANTAGONISTS
- Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | (Predose) minimum 50% pred; FEV1 (Predose) maximum 85% pred; minimum 64: Puffs/day minimum 1 | Mild-Severe; | | BDP/placebo | 200/193 | 71 ± 12% pred (a.m.) | 39 15-78 | XX | X | | XX
Laviolette, Malmstrom, Lu, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | (Predose) minimum 50% pred; FEV1 (Predose) maximum 85% pred; minimum 64: Puffs/day minimum 1 | Mild-Severe; | | BDP/montelukast | 193/193 | 72 ± 12% pred (a.m.) | 40 15-76
Tamaoki, Kondo, Sakai, et al., 1997 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 70% pred; PEF (a.m. (home)) minimum 70% pred; Days/wk with symptoms maximum 0.71; Patients already on >1500 mcg ICS and well-controlled >6 weeks | Not specified; | 6 | BDP + theo + placebo | 40/37 | 81.6 ± 14.5% pred | 47 ± 19 | X | X | | X
Tamaoki, Kondo, Sakai, et al., 1997 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 70% pred; PEF (a.m. (home)) minimum 70% pred; Days/wk with symptoms maximum 0.71; Patients already on >1500 mcg ICS and well-controlled >6 weeks | Not specified; | 6 | BDP + theo + pranlukast | 43/42 | 79.1 ± 17.0% pred | 49 ± 19.7
Tomita, Hashimoto, Matsumoto, et al., 1999 randomized; parallel, controlled | Patient eligibility based on Lung function and symptoms | Mild-moderate | 8 | BDP | 17/17 | | 42.2 ± 16.9 | | X | | X
Tomita, Hashimoto, Matsumoto, et al., 1999 randomized; parallel, controlled | Patient eligibility based on Lung function and symptoms | Mild-moderate | 8 | BDP/pranlukast | 24/24 | | 56.7 ± 18
Christian Virchow, Prasse, Naya et al., 2000 randomized; parallel, controlled (placebo); double-blinded | Patient eligibility based on lung function and symptoms; FEV1 minimum 50% pred; FEV1 maximum 75% pred; symptom score > 10/wk (scale, 0-3/d) at end of 2 week baseline period | Mild-severe | 6 | ICS/placebo | 188/188 | 2.01 ± 0.59 L | 49.2 ± 12.9 | X | XX | | X
Christian Virchow, Prasse, Naya et al., 2000 randomized; parallel, controlled (placebo); double-blinded | Patient eligibility based on lung function and symptoms; FEV1 minimum 50% pred; FEV1 maximum 75% pred; symptom score > 10/wk (scale, 0-3/d) at end of 2 week baseline period | Mild-severe | 6 | ICS/zafirlukast | 180/180 | 2.08 ± 0.61 L | 47.4 ± 12.6
- Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 70% pred | Not specified; | 12 | ICS/placebo | 113/113 | 82.3 ± 12.9% pred | 41 16-68 | X | | | XX
Lofdahl, Reiss, Leff, et al., 1999 randomized; parallel, controlled (placebo); double-blinded | FEV1 minimum 70% pred | Not specified; | 12 | ICS/montelukast | 113/112 | 84.8 ± 11.1% pred | 40 17-70

"X"= outcome reported; "XX"= primary outcome reported

a Primary outcome measure was Asthma Quality of Life Questionnaire Global Score.

b Primary outcome was proportion of eosinophils.

Of the 39 studies included in this review of evidence, 13 were conducted in North America; 13 were conducted in a single European nation; and 8 were multinational. Of five studies not based in North America or Europe, three were conducted in Japan, one in Australia, and one in Iran. The vast majority of the studies reported pharmaceutical industry funding, but only two studies reported any governmental funding sources (Nassif, Weinberger, Thompson et al., 1981; Tamaoki, Kondo, Sakai et al., 1997).

## Study Quality

Quality of study design and conduct was assessed as described in the "Methodology" chapter. The objective was to identify a group of higher quality trials for purposes of sensitivity analysis. The definition for higher quality studies is applicable only to randomized controlled trials and excluded nonrandomized controlled trials and single arm studies. It includes general quality indicators that have been shown to be associated with a bias in magnitude of effect, and asthma-specific study features that control for potential confounders of outcomes.

To be defined as a higher quality study, a randomized controlled trial needed to meet three general quality indicators: (1) double blinding; (2) appropriate handling of exclusions and withdrawals as demonstrated by percentage of excluded patients less than a defined threshold or results analyzed by intent to treat analysis (see "Methodology, Criteria to Define Higher Quality Trials for the Sensitivity Analysis," for details); and (3) concealment of treatment allocation.

In addition, the presence of six features specific to the setting of asthma was assessed. The first was prospectively specified power calculations for primary outcomes. The second criterion was whether the study accounted for the reasons that patients withdrew from the study, particularly regarding the number of patients that were withdrawn due to lack of efficacy. Next, the presence of specific study features designed to control for potential confounders of outcome was assessed. These were: (1) whether reversibility of lung obstruction was established at study entry; (2) whether use of asthma medications other than the study medication was controlled for; (3) whether measures of patient compliance were reported; (4) and whether the influence of seasonal differences on outcomes was addressed.

For the purpose of sensitivity analysis, studies were grouped in three categories. The first was studies meeting all three generic criteria for higher quality. However, for each of the analyses there were insufficient studies for pooling, as a minimum of three studies was required to combine results. Therefore the generic criteria were relaxed to drop the requirement for allocation concealment and created two additional study quality categories for purposes of sensitivity analysis. These were: 2) meets the generic criteria except allocation concealment and meets at least four of the six asthma-specific criteria; and 3) meets the generic criteria except allocation concealment. The third category was least restrictive, and in some cases excluded few of the total studies available for pooling.

Of the 16 trials that added a long-acting beta-2 agonist to a fixed ICS dose, three studies met all three general quality criteria (Table 20: Boyd, 1995; Shapiro, Lumry, Wolfe et al., 2000; Verberne, Frost, Duiverman et al., 1998). These studies were double-blinded and had adequate allocation concealment. Boyd (1995) and Shapiro, Lumry, Wolfe et al. (2000) were 12-week studies in which the percentage of exclusions exceeded the predefined thresholds, but analysis was done on an intent-to-treat basis. Verberne, Frost, Duiverman et al. (1998) was a 1-year study in children in which the percentage of exclusions was below the thresholds; this study also met at least four of the six asthma-specific criteria.

Table 20. Assessment of study quality

A. Addition of long-acting beta-2 agonists: Studies Using a Fixed ICS Dose in All Study Arms
| General Quality Indicators | | | | Asthma-Specific Quality Measures
Citation | Blinding | % of excluded subjects below specified threshold? | Intent to treat analysis? | Allocation concealed? | Power calculations? | Accounted for excluded patients? | Reversibility established? | Controlled for other medication use? | Reported compliance? | Addressed seasonality?
Aubier, Pieters, Schlosser, et al., 1999 | Yes | No | Yes | NS | No | Yes | No | No | Yes | No
Boulet, Cartier, Milot, et al., 1998 | Yes | Yes | No | NS | Yes | No | No | Yes | No | No
Boyd, 1995 | Yes | No | Yes | Yes | Yes | Yes | Yes | No | No | No
FitzGerald, Chapman, Della Cioppa, et al., 1999 | Yes | No | No | NS | No | No | Yes | No | No | No
Grutters, Brinkman, Aslander, et al., 1999 | Yes | Yes | No | NS | No | No | Yes | NS | No | No
Kavuru, Melamed, Gross, et al., 2000 | Yes | No | Yes | NS | Yes | Yes | Yes | Yes | Yes | No
Kemp, Cook, Incaudo, et al., 1998 | Yes | No | No | NS | Yes | Yes | Yes | NS | No | No
Langley, Masterson, Batty, et al., 1998 | Yes | Yes | Yes | NS | Yes | No | Yes | Yes | No | No
Li, Ward, Thien, et al., 1999 | Yes | Yes | No | NS | No | No | No | NS | No | No
Pauwels, Lofdahl, Postma, et al., 1997 | Yes | No | Yes | NS | No | No | Yes | NS | No | No
Pearlman, Stricker, Weinstein, et al., 1999 | Yes | Yes | Yes | NS | No | Yes | Yes | Yes | No | No
Russell, Williams, Weller, et al., 1995 | Yes | No | Yes | NS | Yes | Yes | No | No | No | No
Shapiro, Lumry, Wolfe, et al., 2000 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No
van der Molen, Postma, Turner, et al., 1997 | Yes | No | Yes | NS | Yes | Yes | Yes | Yes | No | No
Verberne, Frost, Duiverman, et al., 1998 | Yes | Yes | No | Yes | Yes | Yes | Yes | NS | Yes | No
Weersink, Douma, Postma, et al., 1997 | Yes | No | No | NS | No | Yes | No | Yes | No | No
B. Addition of long-acting beta-2 agonists: Studies that Titrated ICS Dose After Addition of Long-Acting Beta-2 Agonists
McIvor, Pizzichini, Turner, et al., 1998 | Yes | No | No | NS | Yes | Yes | Yes | No | No | No
Nielsen, Pedersen, Faurschou, et al, 1999 | Yes | Yes | No | NS | No | No | No | No | No | No
Wilding, Clark, Coon, et al., 1997 | Yes | No | No | NS | No | No | Yes | No | Yes | No
C. Addition of long-acting beta-2 agonists: Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose Plus Added Medication
Baraniuk, Murray, Nathan, et al., 1999 | Yes | Yes | Yes | NS | Yes | Yes | Yes | No | No | No
Bouros, Bachlitzanakis, Kottakis, et al., 1999 | No | Yes | No | NS | Yes | Yes | Yes | Yes | No | No
Condemi, Goldstein, Kalberg, et al., 1999 | Yes | No | Yes | NS | Yes | Yes | Yes | Yes | No | No
Greening, Ind, Northfield, et al., 1994 | Yes | No | Yes | NS | Yes | Yes | Yes | No | Yes | No
Kelsen, Church, Gillman, et al., 1999 | Yes | No | Yes | NS | Yes | Yes | Yes | Yes | No | No
Murray, Church, Anderson, et al., 1999 | Yes | No | Yes | NS | Yes | Yes | Yes | Yes | Yes | No
Pauwels, Lofdahl, Postma, et al., 1997 | Yes | No | Yes | NS | No | No | Yes | NS | No | No
Pearlman, Stricker, Weinstein, et al., 1999 | Yes | Yes | Yes | NS | No | Yes | Yes | Yes | No | No
van Noord, Schreurs, Mol, et al., 1999 | Yes | Yes | No | Yes | No | Yes | Yes | No | No | No
Verberne, Frost, Duiverman, et al., 1998 | Yes | Yes | No | Yes | Yes | Yes | Yes | NS | Yes | No
Vermetten, Boermans, Luiten, et al., 1999 | Yes | No | No | NS | No | No | Yes | Yes | No | No
Woolcock, Lundback, Ringdal, et al., 1996 | Yes | No | Yes | NS | Yes | Yes | Yes | No | No | No
D. Addition of theophylline
Studies Using a Fixed ICS Dose in All Study Arms
Emad, 1996 | No | Yes | No | No | No | NA | No | NS | No | No
Meltzer, Orgel, Ellis, et al., 1992 | Yes | No | No | NS | No | Yes | Yes | Yes | Yes | No
Minoguchi, Kohno, Oda, et al., 1998 | NS | No | No | NS | No | No | No | NS | No | No
Nassif, Weinberger, Thompson, et al., 1981 | Yes | Yes | No | Yes | No | Yes | No | No | Yes | No
Studies Using an Increased ICS Dose Alone vs. a Lower ICS Dose + Added Medication
Evans, Taylor, Zetterstrom et al., 1997 | Yes | Yes | No | NS | Yes | No | Yes | Yes | Yes | No
Ukena, Harnest, Saka-lauskas, et al., 1997 | Yes | No | No | NS | Yes | Yes | No | Yes | Yes | Yes ^a^
E. Addition of Leukotriene Receptor Antagonists
Studies Using a Fixed ICS Dose in All Study Arms
Laviolette, Malmstrom, Lu, et al., 1999 | Yes | No | No | NS | Yes | Yes | Yes | Yes | Yes | No
Tamaoki, Kondo, Sakai, et al., 1997 | Yes | Yes | No | NS | No | Yes | No | No | No | No
Tomita, Hashimoto, Matsumoto, et al., 1999 | No | Yes | No | No | No | NA | No | | No | No
Christian Virchow, Prasse, Naya et al., 2000 | Yes | Yes | Yes | NS | No | Yes | Yes | Yes | Yes | No
Studies that Titrated ICS Dose After Addition of Leukotriene Antagonist
Lofdahl, Reiss, Leff, et al., 1999 | Yes | No | Yes | NS | Yes | Yes | Yes | NS | No | Yes ^a^

Dark shading - Met strict criteria for high quality study

Dark shading - met all specific criteria (except seasonality)

Light shading - Met modified criteria for high quality

Light shading - Met most specific criteria, (> 4)

a Continuous enrollment over a short (<3 months) fixed period of time

When allocation concealment was not required as a criterion for high quality, all of the studies except three (FitzGerald, Chapman, Della Cioppa et al., 1999; Kemp, Cook, Incaudo et al., 1998; Weersink, Douma, Postma et al., 1997) met the remaining two generic criteria. Three of these studies also met at least four of the asthma-specific criteria (Kavuru, Melamed, Gross et al., 2000; Shapiro, Lumry, Wolfe et al., 2000; van der Molen, Postma, Turner et al., 1997). Overall, the majority of studies established reversibility (11 of 16), accounted for excluded patients (10 of 16), and reported power calculations (9 of 16). Seven of the studies controlled for other medication use; four reported the extent of patient compliance; none addressed seasonality.

Of the three studies that added long-acting beta-2 agonists and titrated ICS to minimum effective dose, none met all three generic quality indicators. One of the three (Nielsen, Pedersen, Faurschou et al., 1999) met the two generic indicators besides allocation concealment. None of the three studies met at least four of the asthma-specific indicators.

Of the 12 trials that compared addition of a long-acting beta-2 agonist to an increased ICS dose, two studies met all three general quality criteria (van Noord, Schreurs, Mol et al., 1999; Verberne, Frost, Duiverman et al., 1998). Both of these studies were double blinded and had adequate allocation concealment. van Noord, Schreurs, Mol et al. (1999) was a 12-week study in which the percentage of exclusions was below the predefined thresholds. Verberne, Frost, Duiverman et al. (1998) was a year-long study in children in which the percentage of exclusions was also below the thresholds; this study also met at least four of the six asthma-specific criteria.

When allocation concealment was not required as a criterion for high quality, all of the studies except two (Bouros, Bachlitzanakis, Kottakis et al., 1999; Vermetten, Boermans, Luiten et al., 1999) met the remaining two generic criteria. Five of these studies also met more than four of the asthma-specific criteria (Bouros, Bachlitzanakis, Kottakis et al., 1999; Condemi, Goldstein, Kalberg et al., 1999; Greening, Ind, Northfield et al., 1994; Kelsen, Church, Gillman et al., 1999; Murray, Church, Anderson et al., 1999; Verberne, Frost, Duiverman et al., 1998). Overall, the majority of studies established reversibility (11 of 12), accounted for excluded patients (10 of 12), and reported power calculations (7 of 12). Five controlled for other medication use; only three reported compliance and none addressed seasonality.

Of the six trials evaluating the addition of theophylline, none met all three generic indicators of quality. Two of the six trials (Nassif, Weinberger, Thompson et al., 1981; Evans, Taylor, Zetterstrom et al., 1997) met all of the generic indicators besides allocation concealment. Evans, Taylor, Zetterstrom et al. (1997) also met four of the six asthma-specific quality indicators while Nassif, Weinberger, Thompson et al. (1981) did not. Only two of the six trials reported power calculations; three accounted for excluded patients; two established reversibility; three controlled for other medication use; four reported compliance; and one addressed seasonality.

Of the five trials evaluating the addition of leukotriene antagonists, none met all three generic indicators of quality. Three of the five (Tamaoki, Kondo, Sakai et al., 1997; Lofdahl, Reiss, Leff et al., 1999; Christian Virchow, Prasse, Naya et al., 2000) met all of the generic indicators besides allocation concealment; Christian Virchow, Prasse, Naya et al., (2000) also met at least four of six asthma-specific quality indicators while the other two did not. Only two of the five trials reported power calculations; four accounted for excluded patients; three established reversibility; two controlled for other medication use; two reported compliance; and one addressed seasonality.

## Results. Addition of Long-Acting Beta-2 Agonists to ICS

### Trials Comparing Addition of Long-Acting Beta-2 Agonists to Fixed-Dose ICS vs. Fixed-Dose ICS Only

Sixteen studies, enrolling a total of 3,163 patients, compared addition of a long-acting beta-2 agonist to fixed-dose ICS vs. the same dose of ICS without addition of long-acting beta agonist. Study size ranged from 27-852 patients. The two largest studies enrolled about 200 (Pauwels, Lofdahl, Postma et al., 1997) and 250 (Kemp, Cook, Incaudo et al., 1998) patients per study arm. Two additional studies (van der Molen, Postma, Turner et al., 1997; Russell, Williams, Weller et al., 1995) enrolled approximately 100 patients per study arm, with the remaining studies enrolling fewer patients.

These studies were largely short-term, with 11 of the 16 being 12 weeks' duration or less. Two studies (Pauwels, Lofdahl, Postma et al., 1997; Verberne, Frost, Duiverman et al., 1998) were approximately 1 year in duration, while three other studies (Aubier, Pieters, Schlosser et al., 1999; FitzGerald, Chapman, Della Cioppa et al., 1999; van der Molen, Postma, Turner et al., 1997) were approximately 6 months in duration. Of note, the trial by Pauwels, Lofdahl, Postma et al. (1997) was both the largest in terms of number of patients and had the longest duration of followup.

Fourteen trials enrolled an adult population. Of the two pediatric trials, Verberne, Frost, Duiverman et al. (1998) enrolled children between the ages of 6 and 16 years old, with a mean age of approximately 11 years old. Russell, Williams, Weller et al. (1995) enrolled patients between the ages of 4 and 16 years, with a mean age of 10.3 years. In the remaining studies of adults, the mean age ranged from 26-50 years of age.

Study eligibility was most commonly based on lung function measures, with all of the trials basing eligibility partly or completely on lung function parameters. Thirteen studies specified a minimum FEV1 percent predicted, ranging from 40-61 percent. One study specified only a maximum FEV1, which was 90 percent predicted (Russell, Williams, Weller et al., 1995); and the two remaining studies (FitzGerald, Chapman, Della Cioppa et al., 1999; Weersink, Douma, Postma et al., 1997) specified eligibility based on bronchial hyperresponsiveness (methacholine PC20 maximum of 8 and 9.6, respectively). Seven studies had additional eligibility criteria based on symptoms and five studies included eligibility criteria based on medication use. These studies generally selected patients who were not adequately controlled on their current regimen; however, the level of symptoms or medication used to define inadequate control varied, with each study setting different thresholds.

Asthma severity for these study populations was estimated using the 1997 NHLBI classification scheme (National Heart, Lung, and Blood Institute, 1997). In most cases, severity was estimated by baseline FEV1 percent predicted; when reported, baseline measure of symptom frequency was used together with FEV1. With one exception (Boyd, 1995), all studies included patients with moderate asthma, but most studies were not confined to a population with moderate severity. The population in Boyd (1995) was judged to be severe based on the frequency of symptoms, particularly at night.

Three studies were confined to patients with moderate severity (Grutters, Brinkman, Aslander et al., 1999; Li, Ward, Thien et al., 1999; Pearlman, Stricker, Weinstein et al., 1999); three included patients in the mild-moderate range (Boulet, Cartier, Milot et al., 1998; Langley, Masterson, Batty et al., 1998; Verberne, Frost, Duiverman et al., 1998); in five studies the range was moderate-severe (Aubier, Pieters, Schlosser et al., 1999; Kavuru, Melamed, Gross et al., 2000; Kemp, Cook, Incaudo et al., 1998; Russell, Williams, Weller et al., 1995; Shapiro, Lumry, Wolfe et al., 2000); and five studies included the range from mild to severe (FitzGerald, Chapman, Della Cioppa et al., 1999; Pauwels, Lofdahl, Postma et al., 1997; van der Molen, Postma, Turner et al., 1997; Weersink, Douma, Postma et al., 1997).

Applying the NHLBI'S ICS dose classification scheme (National Heart, Lung, and Blood Institute, 1997), the baseline ICS dose was low in four (Kavuru, Melamed, Gross et al., 2000; Li, Ward, Thien et al., 1999; Pauwels, Lofdahl, Postma et al., 1997; Pearlman, Stricker, Weinstein et al., 1999), low-medium in one (Kemp, Cook, Incaudo et al., 1998), low-high in four (Boulet, Cartier, Milot et al., 1998; FitzGerald, Chapman, Della Cioppa et al., 1999; Langley, Masterson, Batty et al., 1998; van der Molen, Postma, Turner et al., 1997), medium in five (Grutters, Brinkman, Aslander et al., 1999; Pearlman, Stricker, Weinstein et al., 1999; Shapiro, Lumry, Wolfe et al., 2000; Verberne, Frost, Duiverman et al., 1998; Weersink, Douma, Postma et al., 1997), medium-high in one study of children (Russell, Williams, Weller et al., 1995), and high in three (Aubier, Pieters, Schlosser et al., 1999; Boyd, 1995; Pauwels, Lofdahl, Postma et al., 1997) of the 18 comparisons reported in this group of studies (See Evidence Table 3-3, "Population Characteristics," for details on ICS dose).

#### Lung Function Outcomes

FEV1 outcomes were reported for 15 of the 16 trials. The direction of results favored the long-acting beta-2 agonists group in 12 of 15 trials; results were statistically significant in four of these trials (Kavuru, Melamed, Gross et al., 2000; Kemp, Cook, Incaudo et al., 1998; Pearlman, Stricker, Weinstein et al., 1999; Shapiro, Lumry, Wolfe et al., 2000). Three trials (Boyd, 1995, Verberne, Frost, Duiverman et al., 1998; Weersink, Douma, Postma et al., 1997), reported results favoring ICS alone, but no differences were significant. Seven studies reported FEV1 outcomes as percent predicted; the treatment effect (i.e., difference in change from baseline between the long-acting beta-2 agonist group and the ICS alone group) ranged from −3.7 to 6.0 percent predicted. Eight studies reported FEV1 outcomes in liters, with treatment effect ranging from −0.1 to 0.43 liters.

Thirteen studies reported morning PEF outcomes, measured by the patient on a daily basis in nearly all cases. The results favored long-acting beta-2 agonists in all studies, and were statistically significant in 10. The treatment effect ranged from 7 to 47 L/min in the 11 studies that reported PEF in this unit of measure. In the two studies that reported PEF as percent predicted, the difference was 3.3 percent (Russell, Williams, Weller et al., 1995) and 8.5 percent (Shapiro, Lumry, Wolfe et al., 2000). Only three studies reported on PC20 outcomes; one found a significant difference (3.26mg/mL methacholine) favoring the long-acting beta-2 agonist group (FitzGerald, Chapman, Della Cioppa et al., 1999).

#### Meta-Analysis of Lung Function Outcomes

Combined analyses of FEV1 outcomes and of PEF outcomes were performed using the random-effects, empirical Bayes model. Studies were combined on the basis of calculated effect size (see "Methodology" chapter for details on meta-analysis and discussion of effect size), so that studies reporting in either liters or percent predicted (for FEV1) and L/min or percent predicted (for PEF) could be pooled. Combination was limited to adult studies that reported sufficient data to calculate effect size; studies of children were omitted to avoid heterogeneity in the patient population. Results of all meta-analyses are summarized in Tables 21-23 and Figures 1-6; details can be found in Meta-Analysis Tables 3-12 through 3-21.

Table 21. Meta-analysis: Lung function outcomes for studies comparing the addition of long-acting beta-2 agonists to a fixed ICS dose

Meta-Analysis | Effect Size Estimate | 95% CI | Test for Homogeneity p Value | Treatment Effect Estimate | 95% CI
FEV1: Combined studies (N=14) | 0.334 | 0.241, 0.428 | 0.10 | 0.17 L 3.71% pred | 0.12, 0.22 2.67, 4.75
FEV1: Sensitivity analysis by quality: studies that that meet all generic quality criteria except allocation concealment and meet most (>4) of asthma-specific criteria (N=3) | 0.319 | 0.139, 0.499 | 0.14 | 0.17 L 3.43% pred | 0.07, 0.26 1.54, 5.54
FEV1: Sensitivity analysis by quality: studies that meet all generic quality criteria except allocation concealment (N=11) | 0.368 | 0.257, 0.478 | 0.20 | 0.19 L 4.08% pred | 0.13, 0.25 2.85, 5.30
PEF: Combined studies (N=9) | 0.581 | 0.417, 0.745 | 0.0034 | 24.68 L/min 7.26% pred | 17.70, 31.65 5.21, 9.31
PEF: Sensitivity analysis by quality: studies that that meet all generic quality criteria except allocation concealment and meet most (>4) of asthma-specific criteria (N=4) | 0.643 | 0.460, 0.826 | 0.17 | 27.33 L/min 8.04% pred | 19.55, 35.10 5.75, 10.32
PEF: Sensitivity analysis by quality: studies that meet all generic quality criteria except allocation concealment (N=8) | 0.630 | 0.478, 0.781 | 0.06 | 26.77 L/min 7.88% pred | 20.32, 33.19 5.98, 9.76

Figure 1. Meta-analysis: FEV1 individual and combined effect size outcomes for studies comparing the addition of long-acting beta-2 agonists to a fixed ICS dose

Figure 6. Meta-analysis: Medication use outcomes for studies comparing a lower ICS Dose + long-acting beta-2 agonists vs. an increased ICS dose

For the category of the addition of long-acting beta-2 agonist to a fixed ICS dose, two studies were omitted from both meta-analyses because they were restricted to children (Russell, Williams, Weller et al., 1995; Verberne, Frost, Duiverman et al., 1998). Four additional studies were omitted from the PEF meta-analysis due to insufficient data (Boulet, Cartier, Milot et al., 1998; FitzGerald, Chapman, Della Cioppa et al., 1999; Grutters, Brinkman, Aslander et al., 1999; Pauwels, Lofdahl, Postma et al., 1997).

For FEV1, 14 unique studies were combined that reported 16 comparisons (Pearlman, Stricker, Weinstein et al., [1999] and Pauwels, Lofdahl, Postma et al., [1997] were four-arm studies, each represented as two two-arm studies). A total of 2,781 patients were included in this analysis. The effect size for all included studies was 0.334 (95 percent CI, 0.241-0.428). A chi-square test for homogeneity was not significant, indicating that within the limits of this test, the studies appear to be relatively homogeneous. The result indicates a positive and significant combined treatment effect for the addition of a long-acting beta-2 agonist to ICS compared to ICS alone (Figure 1). By estimating an average SD for change from baseline in either L or percent predicted (see "Meta-Analysis Technical Supplement" at the end of the "Methodology" chapter for details), this effect size converts to an estimated treatment effect for FEV1 of 0.17 L, or 3.71 percent predicted. In other words, the study arm that received ICS plus long-acting beta-2 agonist improved by 0.17 L, or 3.71 percent predicted, more on average than did the study arm that received only ICS.

Sensitivity analysis by study quality did not greatly alter effect size. Estimated treatment effect is 0.17 L and 3.43 percent predicted in the more restrictive sensitivity analysis and 0.19 L and 4.08 percent predicted in the less restrictive sensitivity analysis; compared to 0.17 L, or 3.71 percent predicted when all studies are combined.

For PEF, nine studies were combined (n=1,678) that reported 10 comparisons (Pearlman, Stricker, Weinstein et al., [1999] was a four-arm study represented as two two-arm studies) (Figure 2). These 9 studies are a subset of the 14 combined in the meta-analysis of FEV1. The effect size for all included studies was 0.581 (95 percent CI, 0.417-0.745). Again, the result favors addition of the long-acting beta-2 agonist and is significant. Estimated treatment effects are 24.68 L/min or 7.26 percent predicted.

Figure 2. Meta-analysis: PEF individual and combined effect size outcomes for studies comparing the addition of long-acting beta-2 agonists to a fixed ICS dose

A chi-square test for homogeneity was significant (p=0.0034), suggesting heterogeneity among studies. Several reasons may contribute to this, including PEF variability and sample size. PEF is an inherently more variable outcome than FEV1. This is, in part, because PEF is measured and reported by the patient and is subject to the level of instruction and compliance achieved in each study setting. The fact that the studies combined for FEV1, which include all studies combined for PEF, appear homogeneous by the same test, lends further support to PEF measurement being a strong source of variation. In addition, the larger sample size of 5 of the 11 studies could reduce within-study variation and increase the significance of the test for homogeneity. Thus, the meta-analysis for PEF estimates only the average effect across the various populations included in this study, and cannot distinguish differences among these heterogeneous populations. Nevertheless, individual study results indicate predominantly significant effect sizes in favor of the addition of long-acting beta-2 agonist.

Sensitivity analysis by study quality did not greatly alter the summary effect size. For the four studies (n=672) that met all generic study quality criteria except allocation concealment and met at least four of the asthma-specific criteria, the combined effect size was 0.643. For the eight studies (n=1,172) that met the less restrictive study quality criteria, the combined effect size was 0.630.

Studies were also stratified into two levels for each of four potentially confounding variables: baseline ICS dose, treatment duration, mean patient age, and mean baseline FEV1 as a surrogate for baseline disease severity (Meta-Analysis Tables 3-18 and 3-19). FEV1 effect size was greater for the 4 (n= 672) studies administering a low ICS dose compared to 12 (n= 2,089) studies with patients receiving higher doses; the difference in effect sizes was 0.22 (95 percent CI, 0.03-0.40). This confidence interval approaches, but does not cross zero, indicating a difference that is barely statistically significant. This result suggests that when baseline ICS dose is low, the magnitude of improvement in lung function achieved by the addition of a long-acting beta-2 agonist may be larger. However, this result should be interpreted with caution due to the lack of control for other potential confounders. Moreover, the only trials that directly compared the addition of long-acting beta-2 agonist to a low and a higher dose of ICS found no difference in treatment effect (Pauwels, Lofdahl, Postma et al., 1997; Pearlman, Stricker, Weinstein et al., 1999).

Combined studies with higher mean baseline FEV1 had a greater FEV1 effect size than those with a lower baseline FEV1, but this difference was not statistically significant. FEV1 results stratified by age and treatment duration varied little and not significantly.

Stratified analysis was not considered useful for PEF effect sizes, as the group of studies of low-dose baseline ICS studies available for combination was merely a subset of three of the four low-dose ICS studies that were used for analysis of FEV1, and did not include the largest study (Pauwels, Lofdahl, Postma et al., 1997).

#### Symptom and Medication Use Outcomes

The most common symptom or medication use outcome reported was supplemental beta-2 agonist use. Eleven studies reported on the outcome, generally in units of puffs/day. The direction of results of 10 studies favored long-acting beta-2 agonists, and in 9, the differences were statistically significant. In these 10 studies, the long-acting beta-2 agonists groups used from 0.3 to 2.5 fewer puffs/day than the ICS-alone groups. The baseline supplemental beta-2 agonist use ranged from about 2 to 5 puffs/day in most studies; Boyd (1995) was an exception, enrolling patients with severe asthma and a baseline use of approximately 10 to 11 puffs/day. In the Verberne, Frost, Duiverman et al. (1998) pediatric study, the long-acting beta-2 agonists group used a median of 0.04 more puffs/day than the ICS-alone group (baseline use not reported), but the difference was not significant.

Ten studies reported daytime symptom score outcomes, but the method of reporting was not standardized. Scores were generally reported on a 3, 4 or 5-point scale. The direction of results favored long-acting beta-2 agonists in all 10 studies, 9 of which reported a statistically significant difference. The range of treatment effect was from 0.08 (0-4 scale) to 0.85 (0-4 scale). Langley, Masterson, Batty et al. (1998) reported a treatment difference in symptom scores of 1.5, but the symptom scale was not described. Only 4 of 10 studies (Boyd, 1995; FitzGerald, Chapman, Della Cioppa et al., 1999; Kemp, Cook, Incaudo et al., 1998; Pauwels, Lofdahl, Postma et al., 1997) reported nighttime symptom scores; all results were significant and in favor of the addition of long-acting beta-2 agonists.

Nine studies reported on symptom-free days, episode-free days, or provided information that could be used to calculate these values. The direction of results in all studies favored long-acting beta-2 agonists; and in six of nine studies, the difference was statistically significant. The net improvement in symptom-free days ranged from 9 percent to 29.5 percent, or a gain of about 3 to 10 symptom-free days per month. Oral corticosteroid use was reported in only three studies. The number of patients receiving oral corticosteroids was similar and no tests of statistical significance were reported. Only five studies reported on acute exacerbation frequency; two studies reported significant differences between treatment arms, two reported no significant difference, and one reported no test of significance. Measures of exacerbation frequency varied, making it difficult to compare results across studies.

Quality of life data were reported in two studies (Kemp, Cook, Incaudo et al., 1998; Juniper, Svensson, O'Byrne et al., 1999). Juniper, Svensson, O'Byrne et al. (1999) reported quality of life data for a subset of patients in the Pauwels, Lofdahl, Postma et al. (1997) trial. Both of these studies used the AQLQ as their measurement instrument. The AQLQ is a validated asthma-specific quality of life measure that reports scores for global quality of life (QOL) as well as subscales for activity limitation, asthma symptoms, emotional function, and environmental exposure. Kemp, Cook, Incaudo et al. (1998) reported that all the scales on the AQLQ improved significantly more in the long-acting beta-2 agonist group. The range of improvement for the beta-2 agonist group ranged from 0.84-1.28 for the salmeterol group, compared with 0.47-0.71 for the ICS-alone group. The authors of this study used a definition of 0.5 units as a small clinically significant change, and a 1.0 unit improvement as a moderate clinically significant change. Juniper, Svensson, O'Byrne et al. (1999) reported improvements in AQLQ for the run-in period of approximately 0.5-0.6 units for all four treatment groups. During the treatment period, a further improvement of 0.21 units was reported for the high-dose ICS plus long-acting beta-2 agonists, but not for the other three groups.

#### Meta-Analysis of Supplemental Beta-2 Agonist Use

Six studies (n=1,142) reported sufficient data for combined analysis on the outcome of puffs/day of beta-2 agonists (seven comparisons, with Pearlman, Stricker, Weinstein et al. [1999], reporting two comparisons). Results were combined as the difference of mean changes from baseline (treatment effect). Overall, the treatment effect was −1.18 puffs/day (95 percent CI, −1.56 to −0.84), which was significant and favored the addition of long-acting beta-2 agonists (Table 22, Figure 3). Both studies that met all generic criteria for higher quality indicated a significant treatment effect, but were not combined. For the three studies (n=515) that met all generic study quality criteria except allocation concealment and at least four asthma-specific criteria, the treatment effect was −1.34 puffs/day. For the five studies (n=636) that met all generic study quality criteria except allocation concealment, the combined treatment effect was −1.00 puffs/day. Thus, studies that reported parameters indicating higher quality did not show markedly lesser treatment effects.

Table 22. Meta-analysis: Medication use outcomes for studies comparing the addition of long-acting beta-2 agonists to a fixed ICS dose

Meta-Analysis | Treatment Effect Estimate | 95% CI | Test for Homogeneity p Value
Puffs/day: Combined Studies (N=6) | − 1.18 | − 1.56, − 0.80 | 0.018
Puffs/day: Sensitivity analysis by quality: studies that that meet all generic quality criteria except allocation concealment and meet most (>4) of asthma-specific criteria (N=3) | − 1.34 | − 1.87, − 0.84 | 0.20
Puffs/day: Sensitivity analysis by quality: studies that meet all generic quality criteria except allocation concealment (N=5) | − 1.00 | − 1.34, − 0.66 | 0.14

Figure 3. Meta-analysis: Medication use outcomes for studies comparing the addition of long-acting beta-2 agonists to a fixed ICS dose

Meta-analysis of medication use outcomes is limited by several factors. First, only a limited number of the included studies reported data in sufficient detail for combination. Second, most studies include patients with disease severity ranging from moderate to severe, with baseline puffs/day in the range of 2-5. An exception is Boyd (1995), which enrolled only patients with severe disease with correspondingly higher baseline puffs/day. This may contribute to study heterogeneity. Finally, endpoint results may have a non-normal distribution for this variable that is skewed toward zero; analyzing change rather than endpoint values alleviates this problem as much as possible. Thus, the results suggest a statistically significant reduction in the use of short-acting beta-2 agonists when long-acting beta-2 agonists are added to ICS use; however, the estimated magnitude of effect may not be reliable.

Combined analysis on the symptom score outcomes, the percent of symptom-free days, oral corticosteroid use, acute exacerbation frequency, and quality of life data was not deemed appropriate. These outcomes had extensive missing data for combined analysis, including lack of reporting of measures of variance, statistical tests used, and exact p-values, and/or variation across studies in units of measure. Symptom score outcomes were further limited by differences in the scales used.

#### Summary

The evidence on the effects of adding a long-acting beta-2 agonist to a fixed dose of ICS is relatively robust, with 14 randomized clinical trials enrolling over 2,800 adult patients. However, pediatric studies were limited to two trials that reported on 323 evaluable patients, only 167 of whom were treated with long-acting beta-2 agonist. The studies generally reported on short-term outcomes observed over 12 weeks or less. Several studies reported longer-term outcomes, up to 1 year, but no studies reported outcomes longer than 1 year.

The results of these studies consistently favor the addition of long-acting beta-2 agonists to ICS compared to ICS alone. In almost all cases, endpoint FEV1 and morning, patient-measured PEF show greater improvements in the combined medication group compared with ICS alone. Most studies also reported reductions in supplemental beta-2 agonist use. Symptom score outcomes and symptom frequency outcomes also favored the beta-2 agonist group in most studies in which they were reported.

Combined analyses found a statistically significant effect of beta-2 agonists on the outcomes of FEV1 (n=2,781), PEF (n=1,678), and puffs/day of supplemental beta-2 agonists (n=1,142). The estimated treatment effect for FEV1 was 0.17 L (95 percent CI, 0.12-0.22), or 3.71 percent predicted (95 percent CI, 2.67-4.75). For PEF, the estimated treatment effect was 24.68 L/min (95 percent CI, 17.70-31.65), or 7.26 percent predicted (95 percent CI, 5.21-9.31). The estimation for supplemental beta-2 agonist use was 1.18 fewer puffs/day (95 percent CI, −1.56 to −0.84). Sensitivity analysis by study quality did not greatly alter effect size.

The magnitude of improvement in lung function outcomes is difficult to put into clinical perspective, given the lack of benchmarks for clinically meaningful changes in these outcome measures. Symptom score outcomes, which were not combined due to the variety of scales, present a similar difficulty. For supplemental beta-2 agonist use, the results suggest on average approximately one less puff/day, or 15 fewer "treatments" (two puffs) with rescue medication per month. However, given the small number of studies available for meta-analysis and the non-normal distribution for this parameter, the estimate may not be accurate; nonetheless, the effect is likely to be statistically significant. For symptom frequency outcomes, which were not combined due to lack of sufficient data, gains in symptom-free days in the range of 3-10 per month were reported.

### Trials Comparing Titration of ICS to Lowest Effective Dose With and Without Addition of Long-Acting Beta-2 Agonists

Three trials, enrolling a total of 151 patients, had as the primary outcome reduction in the dose of ICS after starting treatment with long-acting beta-2 agonists (McIvor, Pizzichini, Turner et al., 1998; Nielsen, Pedersen, Faurschou et al., 1999; Wilding, Clark, Coon et al., 1997). Two of the studies were randomized crossover trials (McIvor, Pizzichini, Turner et al., 1998; Wilding, Clark, Coon et al., 1997), and the third was a randomized parallel group trial (Nielsen, Pedersen, Faurschou et al., 1999). All were placebo controlled.

The largest trial (Wilding, Clark, Coon et al., 1997) was a crossover trial that enrolled 100 patients, with each treatment period lasting 6 months. The other two trials (McIvor, Pizzichini, Turner et al., 1998; Nielsen, Pedersen, Faurschou et al., 1999) enrolled 17 and 34 patients respectively and had a variable treatment period. McIvor, Pizzichini, Turner et al. (1998) treated until patients experienced an exacerbation of asthma or had completely withdrawn ICS. Nielsen, Pedersen, Faurschou et al. (1999) treated patients until they reached a pre-defined "minimal acceptable dose" of ICS. Due to the small size of two of the three studies, it was judged inappropriate to perform combined analysis of outcomes.

All three trials enrolled an adult population with a mean age ranging from 39 to 45 years. Eligibility criteria included lung function, symptoms, and medication use parameters. The presence of stable asthma was established in all three studies by a maximum threshold for symptoms, medication use, and prior exacerbations. Severity of asthma was estimated to range from mild to severe in two of the studies (McIvor, Pizzichini, Turner et al., 1998; Wilding, Clark, Coon et al., 1997), and to be in the mild-to-moderate range in the third (Nielsen, Pedersen, Faurschou et al., 1999). Baseline ICS dose was high in two studies (McIvor, Pizzichini, Turner et al., 1998; Nielsen, Pedersen, Faurschou et al., 1999) and low in a third (Wilding, Clark, Coon et al., 1997).

#### Reduction of ICS Dosage

All three studies demonstrated that ICS could be reduced significantly more in the long-acting beta-2 agonists group as compared to placebo. McIvor, Pizzichini, Turner et al. (1998) reduced the dose of ICS by 87 percent in the long-acting beta-2 agonists group, as compared to 69 percent in the placebo group (p=0.04). The median ICS dose at the end of the study period was 277 (+/−661) mcg/day for long-acting beta-2 agonists treatment compared with 612 (+/−795) mcg/day for placebo (p=0.01). Nielsen, Pedersen, Faurschou et al. (1999) reduced the ICS dose by a mean of 253 mcg (19.8 percent) in the long-acting beta-2 agonists group compared with an increase of 42 mcg (−3.6 percent) in the placebo group (p<0.01). Twelve patients in the long-acting beta-2 agonists group were able to decrease their ICS dose by at least 50 percent compared with two patients in the placebo group (p=0.001).

Wilding, Clark, Coon et al. (1997) reported that the mean daily ICS dose was lower in the long-acting beta-2 agonists group compared with placebo (561 mcg vs. 674 mcg), representing 17 percent less total ICS usage (95 percent CI 12-22 percent, p<0.001). The percent reduction in ICS dose was approximately 20 percent in the long-acting beta-2 agonist group compared with 6.5 percent in the placebo group (p<0.001). Since the starting ICS dose was already low for the Wilding, Clark, Coon et al. (1997) study, it is not surprising that the percent dose reduction after the addition of long-acting beta-2 agonist was less than in the other two studies.

#### Lung Function Outcomes

These studies suggest that the reduction in ICS dose with long-acting beta-2 agonists is achieved without diminishing lung function outcomes. The direction of FEV1 and morning, patient-measured PEF outcomes favored the long-acting beta-2 agonists group in all studies, but only the results of the Wilding, Clark, Coon et al. (1997) study were statistically significant. Nielsen, Pedersen, Faurschou et al. (1999) and Wilding, Clark, Coon et al. (1997) reported treatment differences of FEV1 0.2 (p=NS) and 0.13 (p<0.001) liters respectively. McIvor, Pizzichini, Turner et al. (1998) reported a nonsignificant difference of 8.7 percent predicted FEV1. For PEF, the treatment differences ranged from 13.7 to 22 liters/min.

#### Symptom and Medication Use Outcomes

ICS dose reduction was achieved without increase in symptoms, and there is limited evidence suggesting improvement. Wilding, Clark, Coon et al. (1997) reported an 18 percent (p<0.001) greater improvement in number of symptom-free days for the long-acting beta-2 agonist group. McIvor, Pizzichini, Turner et al. (1998) and Nielsen, Pedersen, Faurschou et al. (1999) reported daytime symptom score outcomes. McIvor, Pizzichini, Turner et al. (1998) reported a 0.30 units greater reduction for the long-acting beta-2 agonists group on a 6-point scale, which was not statistically significant. Nielsen, Pedersen, Faurschou et al. (1999) reported an improvement of 1.0 unit on a 0-5 scale for the long-acting beta-2 agonists group as compared to no change for the placebo group (p<0.001). McIvor, Pizzichini, Turner et al. (1998) reported that the long-acting beta-2 agonists group had a reduction of 1.1 puffs/day as compared to placebo, but the difference was not statistically significant.

#### Summary

Three studies enrolling a total of 151 patients evaluated reducing the dose of ICS after the addition of long-acting beta-2 agonists as their primary outcome. Two studies were small, short-term trials, and the third enrolled 100 patients treated for 6 months. None of the three trials met the criteria for higher quality studies. All three trials demonstrated statistically significant reductions in ICS dosage for the long-acting beta-2 agonist group. The magnitude of treatment difference was 13.5 percent, 18 percent, and 23.4 percent greater reduction in ICS as compared to placebo. The evidence suggests that the reduction in dose is achieved without diminishment of lung function or increase in symptoms; and there is limited evidence that suggests improvement in symptoms.

### Trials Comparing Addition of Long-Acting Beta-2 Agonists to ICS vs. Increased ICS Dose

Twelve studies, enrolling a total of 4,285 patients, compared a maintenance ICS dose plus long-acting beta-2 agonist to an increased ICS dose. These studies ranged from 48 to 738 total patients enrolled. The larger studies enrolled approximately 200-250 patients per study arm (Baraniuk, Murray, Nathan et al., 1999; Condemi, Goldstein, Kalberg et al., 1999; Greening, Ind, Northfield et al., 1994; Kelsen, Church, Gillman et al., 1999; Murray, Church, Anderson et al., 1999; Pauwels, Lofdahl, Postma et al., 1997; Woolcock, Lundback, Ringdal et al., 1996). The remaining studies (Bouros, Bachlitzanakis, Kottakis et al., 1999; Pearlman, Stricker, Weinstein et al., 1999; van Noord, Schreurs, Mol et al., 1999; Verberne, Frost, Duiverman et al., 1998; Vermetten, Boermans, Luiten et al., 1999) enrolled between 23 and 139 patients per treatment arm.

These trials were largely short-term, with most having a duration of 6 months or less. Two studies (Pauwels, Lofdahl, Postma et al., 1997; Verberne, Frost, Duiverman et al., 1998) were approximately 1 year in duration and five studies (Condemi, Goldstein, Kalberg et al., 1999; Greening, Ind, Northfield et al., 1994; Kelsen, Church, Gillman et al., 1999; Murray, Church, Anderson et al., 1999; Woolcock, Lundback, Ringdal et al., 1996) were approximately 6 months in duration. The remaining five trials (Baraniuk, Murray, Nathan et al., 1999; Bouros, Bachlitzanakis, Kottakis et al., 1999; Pearlman, Stricker, Weinstein et al., 1999; van Noord, Schreurs, Mol et al., 1999; Vermetten, Boermans, Luiten et al., 1999) were 12 weeks' duration or less.

All trials except Verberne, Frost, Duiverman et al. (1998) enrolled an adult population. Verberne, Frost, Duiverman et al. (1998) enrolled children between the ages of 6 and 16 years, with a mean age of approximately 11 years. In studies of adults, the mean age ranged from 32-48 years. Eligibility was most commonly based on lung function measures, with all of the trials basing eligibility partly or completely on lung function parameters. All of the studies specified a minimum FEV1, ranging from 40-60 percent predicted. Nine studies also specified a maximum FEV1, ranging from 80 to 100 percent predicted. Eight studies had additional eligibility criteria based on symptoms or medication use. These studies selected patients who were not adequately controlled on their current regimen. However, each study set different thresholds for level of symptoms or medication used to define inadequate control.

Asthma severity was estimated using the 1997 NHLBI classification scheme (National Heart, Lung, and Blood Institute, 1997). Estimation of severity was generally based on baseline FEV1 percent predicted, together with a baseline measure of symptom frequency when reported. All of the studies included, but were not confined to, patients with moderate asthma. Seven studies included patients in the moderate to severe category (Baraniuk, Murray, Nathan et al., 1999; Bouros, Bachlitzanakis, Kottakis et al., 1999; Condemi, Goldstein, Kalberg et al., 1999; Greening, Ind, Northfield et al., 1994; Kelsen, Church, Gillman et al., 1999; Murray, Church, Anderson et al., 1999; Woolcock, Lundback, Ringdal et al., 1996); in two studies, severity was estimated to be in the mild-moderate range (Verberne, Frost, Duiverman et al., 1998; Vermetten, Boermans, Luiten et al., 1999); two studies ranged from mild-severe (Pauwels, Lofdahl, Postma et al., 1997; van Noord, Schreurs, Mol et al., 1999); in the final study severity was estimated to be confined to the moderate range (Pearlman, Stricker, Weinstein et al., 1999).

Baseline ICS doses, using NHLBI criteria (National Heart, Lung, and Blood Institute, 1997), were categorized as low for nine studies; van Noord, Schreurs, Mol et al. (1999) included a majority of patients receiving a medium baseline ICS dose, the Verberne, Frost, Duiverman et al. (1998) study of children administered a medium baseline ICS dose, and patients in the Woolcock, Lundback, Ringdal et al. (1996) study were initially receiving high ICS doses.

#### Lung Function Outcomes

FEV1 outcomes were reported for 10 of the 12 trials. The direction of results favored the long-acting beta-2 agonists group in 8 of 10 studies, with 5 reporting statistically significant differences. The only trial that favored higher dose ICS was a pediatric study by Verberne, Frost, Duiverman et al. (1998); the treatment difference was 3.6 percent predicted, but was not statistically significant. Another trial (van Noord, Schreurs, Mol et al., 1999) reported identical changes in FEV1 for both treatment groups. In the eight remaining studies, FEV1 outcomes were reported as percent predicted in three, with a treatment difference ranging from 2.7 to 4.0 percent predicted. Five studies reported FEV1 outcomes in liters, with a treatment difference ranging from 0.08 to 0.29 L in favor of the long-acting beta-2 agonist group.

PEF outcomes (all patient-measured; most reported as morning) were reported in all 12 studies. The direction of results favored long-acting beta-2 agonists in 10 of 12 studies, and were statistically significant in 8. In one study (Vermetten, Boermans, Luiten et al., 1999), there was a nonsignificant difference of 1.0 percent predicted in favor of the higher ICS group. In another study (van Noord, Schreurs, Mol et al., 1999), the change in PEF was identical between groups. In the 10 remaining studies, PEF was reported in L/min in 8, with a treatment difference ranging from 0.7 to 32 L/min. The final two studies reported PEF in percent predicted, with treatment differences of 2.0 and 7.0 percent predicted. Only one study (Verberne, Frost, Duiverman et al., 1998) reported on PC20 outcomes, and the difference between groups was not significant.

#### Meta-Analysis of Lung Function Outcomes

Combined analyses of FEV1 outcomes and of PEF outcomes were performed. Results are presented in Table 23 and Figures 4-6; details are available in Meta-Analysis Tables 3-12 through 3-21. Studies omitted from the meta-analysis were those that did not report sufficient data to calculate effect size (Woolcock, Lundback, Ringdal et al., 1996), and also the Verberne, Frost, Duiverman et al. (1998) study, which exclusively enrolled a pediatric population.

Table 23. Meta-analysis: Lung function outcomes for studies comparing a lower ICS dose plus long-acting beta-2 agonists vs. an increased ICS dose

Meta-Analysis | Effect Size Estimate | 95% CI | Test for Homogeneity p Value | Treatment Effect Estimate | 95% CI
FEV1: Combined studies (N=8) | 0.209 | 0.133, 0.285 | 0.93 | 0.11 L 2.32% pred | 0.07, 0.15 1.48-3.16
FEV1: Sensitivity analysis by quality: studies that that meet all generic quality criteria except allocation concealment and meet most (>4) of asthma-specific criteria (N=4) | 0.203 | 0.107, 0.299 | 0.94 | 0.11 L 2.25% pred | 0.06, 0.16 1.19, 3.32
FEV1: Sensitivity analysis by quality: studies that meet all generic quality criteria except allocation concealment (N=7) | 0.212 | 0.134, 0.290 | 0.88 | 0.11 L 2.35% pred | 0.07, 0.15 1.49, 3.22
PEF: Combined studies (N=10) | 0.310 | 0.192, 0.429 | 0.0002 | 11.6 L/min 3.4% pred | 5.2-18.0 1.5-5.3
PEF: Sensitivity analysis by quality: studies that that meet all generic quality criteria except allocation concealment and meet most (>4) of asthma-specific criteria (N=4) | 0.300 | 0.030, 0.569 | 0.000007 | 12.75 L/min 3.75% pred | 1.28, 24.18 0.38, 7.11
PEF: Sensitivity analysis by quality: studies that meet all generic quality criteria except allocation concealment (N=7) | 0.296 | 0.143, 0.449 | 0.00005 | 12.58 L/min 3.7% pred | 6.08, 19.08 1.79, 5.61

Figure 5. Meta-analysis: PEF individual and combined effect size outcomes for studies comparing a lower ICS dose + long-acting beta-2 agonists vs. an increased ICS dose

Figure 4. Meta-analysis: FEV1 individual and combined effect size outcomes for studies comparing a lower ICS dose + long-acting beta-2 agonists vs. an increased ICS dose

For FEV1, the effect size for all eight included studies (n=2,754) combined was 0.209 (95 percent CI, 0.133-0.285), indicating a positive and significant treatment effect for the addition of a long-acting beta-2 agonist (Figure 4). A chi square test for homogeneity was not significant. Using an average standard deviation for change from baseline in either liters or percent predicted, this effect size converts to an estimated treatment effect of 0.11 L. Expressed as percent predicted, the estimated treatment effect was 2.32 percent.

Sensitivity analysis by study quality did not greatly alter effect size. For the four studies (n=1,706) that met all generic study quality criteria except allocation concealment and also met at least four asthma-specific criteria, the combined effect size was 0.203. For the seven studies (n=2,632) that met the less restrictive study quality criteria, the combined effect size was 0.212.

The PEF effect size for all 10 included studies (n=3,042) combined was 0.310 (95 percent CI, 0.192, 0.429). This group of studies includes seven of the eight studies combined above for FEV1. Again, the effect favors addition of the long-acting beta-2 agonist and is significant. Estimated treatment effects are 11.6 L/min or 3.4 percent predicted. A chi-square test for homogeneity was highly significant, suggesting heterogeneity among studies.

The effect size for one study (van Noord, Schreurs, Mol et al., 1999) was slightly negative; this was only one of two analyzed studies for which a majority of patients were on medium or high baseline ICS doses. The effect size for the other study (Woolcock, Lundback, Ringdal et al., 1996) was 0.298. Recalculation of the combined effect size without the van Noord, Schreurs, Mol et al. (1999) and Woolcock, Lundback, Ringdal et al. (1996) results did not appreciably change the estimate (0.366 vs. 0.310), and the p-value for homogeneity remained highly significant.

Several reasons may contribute to PEF heterogeneity including PEF variability and sample size. As noted previously, PEF is an inherently more variable outcome than FEV1. In addition, the majority of studies had large sample sizes, which may reduce within-study variation and increase the significance of the test for homogeneity Thus, the meta-analysis for PEF estimates only the average effect across the various populations included in this study, and cannot distinguish differences among these heterogeneous populations. Nevertheless, both combined and individual study results indicate predominantly significant effect sizes in favor of the addition of long-acting beta-2 agonist.

Sensitivity analysis by study quality did not greatly alter the summary effect size. For those studies that met all generic study quality criteria except allocation concealment and met at least four of asthma-specific criteria (four studies, n=1,283), the combined effect size was 0.300. For those studies (n=2,687) that met the less-restrictive study quality criteria (eight studies), the combined effect size was 0.296.

Stratified analysis by dose was not performed as almost all studies used low dose baseline ICS. Studies were stratified into two levels for each of three potentially confounding variables: treatment duration, mean patient age, and mean baseline FEV1 as a surrogate for baseline disease severity. No significant effects were found. These analyses would only detect large effects, and likely miss lesser influences of confounding variables. Details of these analyses are presented in Meta-Analysis Tables 3-20 and 3-21.

These results are consistent with a previous meta-analysis of studies sponsored by GlaxoWellcome, all of which compared an increased dose of ICS to a lower dose plus salmeterol (Shrewsbury, Pyke, and Britton, 2000). For FEV1, the treatment effect estimate of 0.11 L is very similar to the Shrewsbury, Pyke, and Britton (2000) estimate of 0.10 L at 3 months of treatment, and 0.08 L at 6 months. However, their PEF treatment effect estimates of approximately 22 to 28 L/min are much higher than the estimate obtained in the current analysis; 11.6 L/min overall and 15.1 L/min when limited to studies of patients treated for more than 21 weeks.

Seven of the 9 studies included in the Shrewsbury meta-analysis (Shrewsbury, Pyke, and Britton, 2000) were also among the 11 studies included in the current evidence report's meta-analysis for either FEV1, PEF, or both. While the data included in the current meta-analysis overlaps substantially, it differs in four respects from that in the Shrewsbury and coworkers meta-analysis (Shrewsbury, Pyke, and Britton, 2000). First, the current meta-analysis includes four additional studies; two studies were sponsored by Glaxo Wellcome (Baraniuk, Murray, Nathan et al., 1999; Pearlman, Stricker, Weinstein et al., 1999) and two were sponsored by other pharmaceutical companies (Bouros, Bachlitzanakis, Kottakis et al., 1999; Pauwels, Lofdahl, Postma et al., 1997). Second, for all studies, only published summary data were available for abstraction and these were not consistent in the outcome units of measure reported, thus requiring combination on the basis of calculated effect size. Shrewsbury, Pyke, and Britton (2000) had access to patient data and could combine results directly. Third, the current meta-analysis was restricted to studies that were published as full articles, and excluded two studies published only as abstracts that were included by Shrewsbury, Pyke, and Britton (2000). Finally, because the Shrewsbury and coworker (2000) analysis used patient datasets, data from 3- and 6-month time points could be compared; while the current analysis used only published data taken at study endpoint, which varied in duration.

#### Symptom and Medication Use Outcomes

The most common symptom or medication use outcome reported was supplemental beta-2 agonist use. Ten studies reported this outcome, generally in units of puffs/day (Kelsen, Church, Gillman et al., 1999 reported only puffs/night, p<0.05 in favor of combination therapy). The direction of results favored long-acting beta-2 agonist in nine comparisons, and six were statistically significant. In the tenth study, there was an identical change in beta-2 agonist use between groups (Greening, Ind, Northfield et al., 1994). For the nine studies favoring long-acting beta-2 agonists, the treatment difference ranged from 0.08 to 1.3 fewer puffs/day or approximately 1-20 fewer 'treatments' (two puffs) per month. Baseline use where reported (seven studies) was in the range of approximately one to five puffs/day.

Seven studies reported daytime symptom score outcomes, but the method of reporting was not standardized. Scores were generally reported on a 3- or 4-point scale; in some cases the scale was not reported. The direction of results favored long-acting beta-2 agonists in five of the seven studies, three of which reported a statistically significant difference. Two studies reported nonsignificant differences in favor of higher dose ICS, with differences of 0.02 (0-4 scale) and 0.10 (0-3 scale). The range of treatment effect in the four studies favoring long-acting beta-2 agonists was from 0.12 (scale not reported) to 0.50 (0-3 scale). Only two studies reported nighttime symptom score outcomes (Bouros, Bachlitzanakis, Kottakis et al., 1999; Pauwels, Lofdahl, Postma et al., 1997); only Bouros, Bachlitzanakis, Kottakis et al. (1999) reported a significant difference, which was in favor of ICS plus beta-2 agonist.

Ten studies reported on symptom-free days, episode-free days, or provided information that could be used to calculate these values. In all of these comparisons, the direction of results favored long-acting beta-2 agonists; and in seven, the difference was statistically significant. The net improvement in symptom-free days ranged from 5-22 percent, translating to between approximately two and seven additional symptom-free days gained per month. One study of poorly controlled patients (0 percent symptom-free days at baseline) found a 43 percent net improvement or a gain of approximately 13 additional symptom-free days per month (Woolcock, Lundback, Ringdal et al., 1996).

Oral corticosteroid use was less frequently reported as an outcome in these studies, with five studies reporting this measure. There were no statistically significant differences in oral corticosteroid use. Seven studies reported acute exacerbation outcomes; five reported non-significant differences and two reported no tests of significance. Exacerbation measures differed, making it difficult to compare results across studies.

Two studies reported on QOL data (Hyland and Crocker, 1995; Vermetten, Boermans, Luiten et al., 1999). Hyland and Crocker (1995) reported QOL data on the same population contained in Greening, Ind, Northfield et al. (1994). These two studies used different QOL instruments, with Hyland and Crocker (1995) using the Living with Asthma Questionnaire while Vermetten, Boermans, Luiten et al. (1999) used the Hyland Quality of Life Questionnaire. Hyland and Crocker (1995) also used a QOL diary in which patients recorded daily QOL information. Hyland and Crocker (1995) did not find any treatment differences between groups on the Living with Asthma Questionnaire, but did find a significant benefit for the long-acting beta-2 agonist group on the diary measures. Vermetten, Boermans, Luiten et al. (1999) reported that there were no differences on summary QOL measures between groups.

#### Meta-Analysis of Supplemental Beta-2 Agonist Use

Three studies (n=725) reported sufficient data for combined analysis of puffs/day of beta-2 agonists. Results were combined as the difference of mean changes from baseline (treatment effect). Overall, the treatment effect was −0.19 puffs/day (95 percent CI, −0.31 to −0.06) or approximately three fewer treatments per month, a small but significant reduction in favor of the addition of long-acting beta-2 agonists. There were insufficient studies for a sensitivity analysis by study quality.

Meta-analysis of medication use outcomes is limited by the small number of studies that reported data in sufficient detail for combination. In view of this, the small estimated treatment effect may not be clinically significant.

Combined analysis on the symptom score outcomes, the percent of symptom-free days, oral corticosteroid use, and quality of life data was not deemed appropriate. All of these outcomes had extensive missing data for combined analysis, including lack of reporting of measures of variance, statistical tests used, and exact p-values. Symptom score outcomes were further limited by differences in the scales used.

#### Summary

The evidence on the comparison of adding a long-acting beta-2 agonist to ICS vs. increasing the dose of ICS is relatively robust, with 11 randomized controlled trials enrolling over 4,000 total adult patients. However, there is only one pediatric study, reporting on 120 evaluable patients. The studies generally report on short-term outcomes, with several studies reporting longer term outcomes, up to 6 months or 1 year.

These studies consistently show greater improvement in outcomes for the addition of long-acting beta-2 agonists compared with increasing the ICS dose. In almost all cases, FEV1 and PEF show statistically significant improvements in the combined medication group compared with higher dose ICS. Most studies also reported supplemental beta-2 agonist use, and this outcome also consistently favored the addition of long-acting beta-2 agonist. Symptom scores and symptom frequency also favored this group in most studies that reported these outcome measures.

Combined analyses demonstrated a positive and statistically significant effect of addition of long-acting beta-2 agonists on FEV1 (n=2,754) and PEF (n=3,042). The estimated treatment effect for FEV1 was 0.11 L (95 percent CI, 0.07-0.15), or 2.32 percent predicted (95 percent CI, 1.48-3.16). For PEF, the estimated treatment effect was 11.6 L/min (95 percent CI, 5.2-18.0), or 3.4 percent predicted (95 percent CI, 1.5-5.3). The combined (n=725) estimate of treatment effect for puffs/day of beta-2 agonists was significant but small at 0.19 fewer puffs/day (95 percent CI, −0.06 to −0.31) associated with long-acting beta-2 agonist use. However, this estimate was limited by a small number of available studies.

The magnitude of improvement in lung function and symptom score outcomes is difficult to put into clinical perspective, given the lack of benchmarks for clinically meaningful changes in these outcome measures. For supplemental beta-2 agonist use, the combined estimate of the treatment difference appears to be small, an improvement of 0.19 fewer puffs/day in a group of studies for which baseline use was approximately 1-5 puffs/day. This indicates on average approximately three fewer "treatments" (two puffs) with rescue medication per month. For the individual studies favoring long-acting beta-2 agonists, the treatment difference ranged from 0.08 to 1.3 fewer puffs/day or approximately 1-20 fewer treatments per month. For the symptom frequency outcomes, which were not combined due to lack of sufficient data, the treatment difference suggests a gain in symptom-free days in the range of 2-7 per month with one outlier study suggesting a gain of 13 symptom-free days per month in a poorly controlled population.

### Adverse Events Associated With Addition of Long-Term Beta-2 Agonists to ICS

The evaluation of adverse events for this review topic was not a primary question; therefore, an exhaustive literature search and analysis was not performed. However, short-term adverse events data were abstracted from studies included for review as described in the "Methodology" chapter and are summarized in Evidence Table 3-11. These data will be discussed in aggregate for all studies examining the addition of long-term beta-2 agonists to continued ICS, regardless of the ICS dose.

Reporting of adverse events varied considerably among studies. The selection of adverse events was different, and total patients experiencing any adverse event, or total patients experiencing treatment- or drug-related adverse events were often not reported. However, in general, there were few obvious differences between study arms within studies, and these did not consistently indicate either an increase or a decrease in adverse events when long-acting beta-2 agonists were added.

Nineteen of 29 studies reported total number of patients who dropped out of the study due to adverse events other than disease progression or acute exacerbation. Only 2 of 19 showed significant differences for this parameter. Baraniuk, Murray, Nathan et al. (1999) reported more dropouts due to adverse events in the salmeterol study arm than in the ICS-only study arm (fixed ICS dose); this difference was barely significant at p=0.05. Condemi, Goldstein, Kalberg et al. (1999) reported the opposite finding, more dropouts due to adverse events in the ICS-only study arm (increased ICS dose; p=0.03).

Out of seven studies reporting the total number of patients experiencing any adverse event, only one showed a significant difference. The Verberne, Frost, Duiverman et al. (1998) study, which enrolled only children, showed a significant difference between the increased ICS arm and the salmeterol plus ICS arm, with more patients in the salmeterol arm experiencing any adverse event; however, the difference between the fixed-dose ICS arm and the salmeterol arm was not significant, although in the same direction. Five studies reported the number of patients experiencing treatment- or drug-related adverse events; none of these showed significant differences between study arms.

Numbers of patients reporting specific adverse events were examined qualitatively. Although there are several instances where various adverse events appear to differ between study arms (e.g., headaches in Russell, Williams, Weller et al., 1995; upper respiratory and/or sinus infections in Condemi, Goldstein, Kalberg et al., 1999; gastrointestinal distress in Verberne, Frost, Duiverman et al., 1998), no category of adverse events is consistently affected, nor are there consistently more or fewer patients consistently affected in the ICS-only vs. the ICS plus long-acting beta-2 agonist arm.

Given the results described and the limited data, there is no obvious indication that patients administered long-acting beta-2 agonists in addition to continuing ICS vs. fixed, titrated, or increased ICS only experience significant differences in adverse events.

## Results. Addition of Theophylline to ICS

### Trials Comparing Addition of Theophylline to Fixed-Dose ICS vs. Fixed-Dose ICS Only

Four studies evaluating a total of 213 patients compared ICS plus theophylline to the same dose of ICS. Three of the four studies were randomized parallel group design, one study (Nassif, Weinberger, Thompson et al., 1981) was a crossover trial with randomized sequence of treatment. The duration of the parallel group studies was between 6 and 24 weeks, and the crossover trial used periods of 1 month for the length of each treatment period. Prior theophylline treatment was very common among these studies. In the studies by Nassif, Weinberger, Thompson et al. (1981) and Meltzer, Orgel, Ellis et al. (1992), 100 percent and 85 percent of the subjects had been taking regular theophylline. The study of Minoguchi, Kohno, Oda et al. (1998) was designed explicitly as a theophylline withdrawal study, as the initial part of the study consisted of all patients being treated with ICS and theophylline before half of the participants were randomized to having theophylline withdrawn.

None of the studies met all three generic quality criteria. The trials by Nassif, Weinberger, Thompson et al. (1981) and Evans, Taylor, Zetterstrom et al. (1997) met two of three general quality indicators; and none of the five studies met at least four of the asthma-specific quality indicators. However, there were no obvious differences in results when comparing studies that met quality criteria with studies that did not. Because of the limited number of studies, and the lack of studies meeting the definition for high quality, sensitivity analysis by study quality was not attempted.

All the studies have statistical problems that inhibit confident interpretation of the results. Three studies included additional treatment groups not relevant to this key question, and are somewhat problematic in the statistical interpretation of their results because many of the statistical tests calculated significance levels and confidence levels which included the other treatment arms. For example, the Nassif, Weinberger, Thompson et al. study (1981) included a group of patients receiving alternate-day oral prednisone. Many p-values of the principal results were calculated combining the ICS and oral prednisone groups, comparing theophylline and placebo treatment periods. Emad (1996) included an additional group that was not receiving a placebo medication, and calculated all p-values based on a three-group analysis of variance (ANOVA). However, inspection of those results reveals little difference between the groups not receiving a placebo and receiving a placebo, making it plausible to attribute statistical significance to the comparison between theophylline and the two control groups. Meltzer, Orgel, Ellis et al. (1992) included a group treated with albuterol and theophylline. It appears that some of the p-values calculated were overall comparisons between the three groups, making interpretation of the relevant two-group comparison problematic. Although the study by Minoguchi, Kohno, Oda et al. (1998) directly compares only the two relevant comparison groups of interest, it appears that there were no between-group statistical tests performed, only pre-post statistical tests within a group.

#### Lung Function Outcomes

All four studies reported FEV1 and PEF outcomes. Three of four studies reported morning, patient-measured PEF; Emad (1996) reported results measured in the clinic. All studies report results suggesting improved FEV1 and PEF with combined theophylline plus ICS, but the statistical interpretation of the results is somewhat complicated by various factors within each study. As reported above, Emad's study (1996) reports p-values based on a one-way ANOVA of three groups, but it appears that all of the significance can be attributed to the theophylline-plus-ICS group versus the two control groups. Thus, this study can be interpreted as showing both statistically significant improved FEV1 and PEF on combined theophylline plus ICS (treatment difference 0.34 L for FEV1, 58.0 L/min for PEF).

The study by Minoguchi, Kohno, Oda et al. (1998) does not report between-group p-values, only pre-post within-group p-values. However, the study did report a significant within-group decrease in both FEV1 (− 0.14 L) and PEF (− 35.5 L/min) for the group that had theophylline withdrawn. In the group that remained on theophylline, there was a small, nonsignificant decline in FEV1 (− 0.05 L) and a small, nonsignificant increase in PEF (+4.4 L/min).

The study by Nassif, Weinberger, Thompson et al. (1981) reported a 3 percent difference in predicted FEV1 and a 5 percent difference in predicted daily peak flow measurements when the patients were on combined theophylline and ICS compared with when they were on ICS alone in this randomized crossover trial. However, the statistical significance was based on a comparison of a larger number of patients which included 10 out of the 28 total which were on oral corticosteroid rather than ICS. However, the effect sizes appear to be similar between the ICS and oral corticosteroid groups.

Finally, the study by Meltzer, Orgel, Ellis et al. (1992) reported a difference of 6.0 percent predicted FEV1 and 13 percent predicted PEF, which favored the combined theophylline plus ICS group, but was not statistically significant.

#### Symptom and Medication Use Outcomes

Three of the four studies in this group examined symptom outcomes. In the study by Minoguchi, Kohno, Oda et al. (1998), daily symptoms were assessed on a 22-point scale that summed up wheezing, cough, and nighttime symptoms. The data were not appropriately analyzed with between-group statistics. However, asthma symptoms increased in the group in which theophylline was withdrawn (from 1.27 to 4.19, p<0.05), whereas symptom changes in the group maintained on theophylline were small and not significant (from 1.11 to 1.56).

In the study by Nassif, Weinberger, Thompson et al. (1981), symptoms were evaluated on the basis of percent of days free of symptoms. There was a significant difference in the percentage of days free of symptoms between the theophylline periods and placebo periods of the study (71 percent theophylline vs. 50 percent placebo, p<0.01).

In the study by Meltzer, Orgel, Ellis et al. (1992), separate symptom scores were calculated for all treatment groups for wheeze, shortness of breath, cough, activity tolerated, and nocturnal symptoms. Statistical comparisons were performed on the absolute value of these separate scores, rather than change from baseline. Separate p-values are not reported, but the text states that no comparisons between ICS plus theophylline and ICS alone were statistically significant.

Two of the studies reported medication use outcomes. In the study by Nassif, Weinberger, Thompson et al. (1981), inhalation treatments with metaproterenol were more common during the placebo periods than during the theophylline periods (0.9 uses per day vs. 0.4 uses per day, p<0.01). In the study by Meltzer, Orgel, Ellis et al. (1992), additional beta-2 agonist was required by 43 percent of patients taking ICS alone and 34 percent of those on ICS and theophylline (p-value not reported for two-group comparison). However, if a chi-square test is applied to these proportions, the difference is not statistically significant.

#### Adverse Effects

Only a few studies formally compared adverse events between treatment regimens. Emad (1996) reports "minimal" tremor in two patients taking theophylline. Nassif, Weinberger, Thompson et al. (1981) only report in text "infrequent, mild, and transient" symptoms when patients switched from placebo to theophylline. Meltzer, Orgel, Ellis et al. (1992) reports a long list of 16 adverse events that occurred between treatment groups, but with no formal statistical comparisons. However, there appear to be no notable differences in numbers of adverse events.

#### Summary

The studies are generally mixed in their results, but the qualitative direction of most of the study results is that the combination of theophylline and ICS produces improved lung function and symptoms. The study by Nassif, Weinberger, Thompson et al. (1981) shows improved lung function and symptoms, while the study by Meltzer, Orgel, Ellis et al. (1992) showed no difference in either of these types of outcomes. The study by Emad (1996) only reports lung function outcomes, and the study by Minoguchi, Kohno, Oda et al. (1998) is difficult to interpret because of lack of between-group statistical comparisons. Adverse event reporting was incomplete in all the studies, but there appear to be no differences.

### Trials Comparing Addition of Theophylline to ICS vs. Increased ICS Dose

Two studies enrolling a total of 195 patients (Ukena, Harnest, Sakalauskas et al., 1997; Evans, Taylor, Zetterstrom et al., 1997) compared a lower dose of ICS plus theophylline versus a higher dose of ICS. Ukena, Harnest, Sakalauskas et al. (1997) compared 69 patients treated with theophylline plus 400 micrograms beclomethasone versus 64 patients treated with 800 micrograms beclomethasone plus placebo. Evans, Taylor, Zetterstrom et al. (1997) compared 31 patients treated with theophylline plus 800 micrograms beclomethasone with 31 patients treated with 1,600 micrograms beclomethasone plus placebo. The length of treatment observed was 6 weeks in the Ukena, Harnest, Sakalauskas et al. (1997) study and 12 weeks in the Evans, Taylor, Zetterstrom et al. (1997) study. Neither of these studies met all of the generic indicators for high quality, although Evans, Taylor, Zetterstrom et al. (1997) met two of the three criteria. Both studies met four of the six asthma-specific criteria.

#### Lung Function Outcomes

Evans, Taylor, Zetterstrom et al. (1997) reported an improvement in FEV1 of 0.21 L in the theophylline plus beclomethasone group (2.48 L to 2.69 L) as compared to an improvement of 0.11 L in the higher dose beclomethasone group (2.50 to 2.61). This treatment difference of 0.10 L was statistically significant at p=0.03. However, the changes in PEF were very similar between groups, with no statistically significant group differences. The theophylline plus beclomethasone group had a 23 L/min increase in PEF compared with a 25 L/min increase in the higher dose beclomethasone group, which was not statistically significant (p=0.16).

In the Ukena, Harnest, Sakalauskas et al. (1997) study, there was improvement in FEV1 for both treatment groups compared to baseline. The theophylline plus ICS group improved from 2.30 to 2.56 L at the end of the study. In the ICS-only group, FEV1 increased from 2.40 to 2.59 L. Comparison of the improvements showed no significant difference in change in FEV1. There were also improvements in home peak flow measurements for both groups. Although the change in peak flow was generally greater for the theophylline plus ICS group, comparisons between groups showed no statistically significant difference between groups. (The actual statistical criteria for the comparison of groups was posed as criteria which would allow the inference that theophylline plus ICS was at least as effective as ICS alone.)

#### Symptom and Medication Use Outcomes

Evans, Taylor, Zetterstrom et al. (1997) compared changes in daytime symptom scores, nighttime symptom scores, and beta-agonist use between the two groups. There were no statistically significant changes in these outcomes between the two groups. Using a 4-point scale, daytime symptom scores improved by a mean of 0.75 for the combined group and by a mean of 0.80 for the higher dose ICS group (p=0.26). Nighttime symptom scores improved by a mean of 0.7 for the combined group compared with 0.6 for the higher dose ICS group (p=0.59). Beta-agonist use also decreased to a similar degree in both groups. The combined group reduced their beta-2 agonist use from a median of 1.8 puffs/day to a median of 1.0 puffs/day, compared with a reduction of 2.0 puffs/day to 1.25 puffs/day in the higher beclomethasone group (p=0.57).

In the Ukena, Harnest, Sakalauskas et al. (1997) study, symptoms were compared between groups on a 0 to 4 scale for nighttime symptoms and daytime symptoms. For both treatment groups, there was significant improvement compared to the baseline period. There were no statistically significant differences between treatments (day: p=0.575; night: p=0.196). Both daytime and nighttime use of relief medications decreased significantly in both groups compared to baseline. There was no statistically significant difference between treatment groups (day: p=0.392, night: p=0.814).

#### Adverse Effects

Both studies briefly reported adverse events from treatment. Evans, Taylor, Zetterstrom et al. (1997) reported a total of nine adverse events in the theophylline group that were thought to be drug-related. Of these nine events, five were gastrointestinal upset, two palpitations, one sore throat, and one headache. In the higher dose beclomethasone group, there were seven adverse events thought to be drug related. Three of these were sore throat, two gastrointestinal upset, one palpitations, and one rash.

Ukena, Harnest, Sakalauskas et al. (1997) reported a total of 50 adverse events in the theophylline/ICS group, 27 of which were attributable to treatment or to asthma. The remaining 23 events were felt to be nontreatment related, comprising myalgia, nonrespiratory bacterial infections, and weakness. In the high-dose ICS group there were a total of 29 adverse events, 17 of which were attributable to treatment or asthma. There were 12 events in the high dose ICS group that were nontreatment related, comprising myalgia, nonrespiratory bacterial infections, and weakness.

#### Summary

Based on two relatively small randomized clinical trials, the addition of theophylline to ICS appears to produce roughly equivalent improvements in lung function and symptoms as compared to higher doses of ICS. In one of the two studies (Evans, Taylor, Zetterstrom et al., 1997), there was a significantly greater improvement in FEV1 for the theophylline group. However, there were no significant group differences in PEF, symptoms, or medication use reported in either study. The adverse events assessed were reported at a somewhat higher rate in the theophylline/ICS group for the Ukena, Harnest, Sakalauskas et al. (1997) study but not for the Evans, Taylor, Zetterstrom et al. (1997) study. Only short-term adverse events were reported in a limited fashion. None of the long-term effects of ICS were assessed in these trials of 6 and 12 weeks. This evidence is insufficient to permit conclusions on the comparative adverse effects for the two treatment regimens.

## Results. Addition of Leukotriene Antagonists to ICS

### Trials Comparing Addition of Leukotriene Antagonists to a Fixed ICS Dose

There were four studies evaluating 885 patients distributed among the pertinent treatment arms. The largest study by Laviolette, Malmstrom, Lu et al. (1999) contributed most of the patients (n=393), and evaluated the effects of treatment over the longest period of time, 16 weeks. This study used montelukast 10mg/day in their treatment arm. Christian Virchow, Prasse, Naya et al. (2000) had a similar sized population (n=368) but a shorter treatment period of six weeks. This study used zafirlukast at a dose of 160mg/day. The other two studies (Tomita, Hashimoto, Matsumoto et al., 1999; Tamaoki, Kondo, Sakai et al., 1997), were smaller (n=41 and 83 respectively) and evaluated patients over a shorter duration of treatment, 8 weeks and six weeks, respectively. Tomita, Hashimoto, Matsumoto et al. (1999) used pranlukast, a leukotriene antagonist only commercially available in Japan, at a dose of 450mg/day, while Tamaoki, Kondo, Sakai et al. (1997) used the same agent at a dose of 900mg/day.

None of the four trials met all three generic indicators for high quality studies. Two of the four (Christian Virchow, Prasse, Naya et al., 2000; Tamaoki, Kondo, Sakai et al., 1997) met two of the three generic indicators. Christian Virchow, Prasse, Naya et al. (2000) also met four of the asthma-specific indicators. There were no obvious differences in results comparing studies that met or did not meet quality criteria. Because of the limited number of studies, and the lack of studies meeting the definition for high quality, quantitative determination of the effect of study quality on outcomes is not possible.

All four studies evaluated patients initially in a run-in period where baseline lung function and symptoms were assessed. However, the Tomita study (Tomita, Hashimoto, Matsumoto et al., 1999) and Tamaoki study (Tamaoki, Kondo, Sakai et al., 1997) were designed as ICS withdrawal or dose reduction studies. After assessing patients at baseline at a particular dose of ICS, patients were randomized to a lower dose of ICS or a lower dose of ICS plus a leukotriene antagonist. Thus the question is whether the ICS dose reduction is tolerated or not with or without the addition of a leukotriene antagonist. In this case, it is expected that changes in lung function in the ICS alone group may be negative. The Laviolette, Malmstrom, Lu et al. (1999) and Christian Virchow, Prasse, Naya et al. (2000) studies examined the addition of a leukotriene antagonist to patients who were incompletely controlled on a specific dose of ICS. Thus there is no expected change in the ICS alone group, but the ICS plus leukotriene group may have improved lung function and/or symptoms.

#### Lung Function Outcomes

All four studies evaluated changes in PEF between groups, and three of the four studies evaluated changes in FEV1. For all of the comparisons of lung function measures, there were statistically significant improvements in favor of the leukotriene antagonist group.

In the study by Laviolette, Malmstrom, Lu et al. (1999), lung function improved in the group of patients receiving ICS and leukotriene antagonist. Morning FEV1 improved 0.14 L in the ICS plus leukotriene antagonist group whereas in the ICS alone group morning FEV1 declined 0.02 L (p<0.001). Morning PEF also improved relative to the ICS alone group (10.41 L/min vs. 2.65 L/min, p=0.004). Similar results were reported by the Christian Virchow, Prasse, Naya et al. (2000) study. In this study, FEV1 improved by 0.19L in the ICS plus leukotriene group, as compared to an improvement of 0.09L in the ICS alone group (p=0.014). PEF improved by 18.7L/min in the combined group as compared to 1.5L/min in the ICS alone group.

In the study by Tamaoki, Kondo, Sakai et al. (1997), changes in FEV1 and both morning and evening, patient-measured PEF were reported. In all comparisons the group which received only a maintenance dose of ICS had a significant decline from baseline in lung function at the end of the treatment period compared to the group which received the same dose of ICS and a leukotriene antagonist. For the ICS-only group vs. the ICS plus leukotriene antagonist group, there was a greater decline in FEV1 (−0.33 L vs. +0.08 L, p=0.007), a greater decline in morning PEF (−46 L/min vs. +5 L/min, p=.001), and a greater decline in evening PEF (−18 L/min vs. +4 L/min. p=0.030).

The study by Tomita, Hashimoto, Matsumoto et al. (1999) only reports changes in PEF between groups. At 8 weeks, for both morning and evening PEF, the group receiving only reduced dose ICS had a significant decline in PEF compared to the group receiving ICS and leukotriene antagonist. (Exact numbers not reported, only graphically shown, p<0.05).

#### Symptom and Medication Use Outcomes

In the study by Laviolette, Malmstrom, Lu et al. (1999), several measures of asthma symptoms showed greater improvement in the group treated with ICS plus leukotriene antagonist. The type of symptom score is not explained in the article, but the mean change in the symptom score was greater in the combined treatment group (− 0.13 vs. - 0.02, p=0.041). There were also fewer nocturnal awakenings and asthma exacerbations in the combined treatment group. Supplemental beta-2 agonist use was also decreased in the combined treatment group, but the difference was not statistically significant (6.04 percent change vs. - 5.51 percent change, p=0.08).

Christian Virchow, Prasse, Naya et al. (2000) reported a greater improvement in daytime symptom scores for the ICS plus leukotriene group. On a 0-3 scale, there was an improvement of 0.6 units for the combined group as compared to 0.3 units for the ICS alone group (p<0.001). This study also reported symptom frequencies. For the combined group, the percentage of symptom-free days increased from 2.2 percent to 22.9 percent, compared to an increase of 0.6 percent to 12.3 percent in the ICS alone group. There was a decline in nighttime awakenings/week of 0.9 in the combined group and 0.4 in the ICS alone group. Neither of these comparisons on symptom frequencies reached statistical significance. This study did report a statistically significant reduction in beta-agonist use for the combined group. The leukotriene plus ICS group decreased their beta-2 agonist use by a mean of 1.3 puffs/day, compared with a reduction of 0.2 puffs/day for the ICS alone group (p=0.007).

In the study by Tamaoki, Kondo, Sakai et al. (1997), asthma symptoms were evaluated by the number of episodes (of asthma symptoms) per week. In the ICS-only group, daytime asthma symptoms increased 6.3 episodes per week, whereas in the ICS plus leukotriene antagonist group, symptoms decreased −0.2 episodes per week (p<0.030). Changes in nighttime asthma symptoms did not differ between groups. The study also assessed the use of supplemental asthma medication. There was a significant difference in the daytime use of beta-2 agonist, where the ICS-only group increased their use much more than the ICS plus leukotriene antagonist group (+16.4 puffs/week vs. +0.8 puffs/week, p<0.026). Nighttime use showed no significant differences.

The study by Tomita, Hashimoto, Matsumoto et al. (1999) evaluated symptom scores and a therapeutic score for both treatment groups (not well characterized, article in Japanese). It is not clear that between-group statistical comparisons were carried out. The text states that there were no difference in symptom scores and therapeutic scores between the two groups.

#### Adverse Effects

The studies by Laviolette, Malmstrom, Lu et al. (1999) and Christian Virchow, Prasse, Naya et al. (2000) report adverse events in a thorough fashion. Laviolette, Malmstrom, Lu et al. (1999) report the percentages of patients with 11 types of adverse reactions. No statistical testing is reported, but there appear to be no differences in any of the adverse events. Christian Virchow, Prasse, Naya et al. (2000) reported that 46 percent of patients in the leukotriene group and 45 percent in the ICS-alone group reported adverse events. The only difference between groups in the frequency of adverse events was that more patients in the placebo group reported worsening asthma.

There were two serious adverse events in the leukotriene group (i.e., detached retina, exacerbation of asthma) and four in the ICS-alone group (i.e., chest pain, abdominal pain, sciatica, gastroenteritis). Two patients in the leukotriene group had transient elevations in liver transaminase levels. In one patient this spontaneously resolved without discontinuation of treatment. The second patient had resolution following discontinuation of the drug.

Two studies reported the number of patients that withdrew due to adverse events. Tamaoki, Kondo, Sakai et al. (1997) only report that no patients dropped out of the study due to adverse events. In the Christian Virchow, Prasse, Naya et al. (2000) study, there were 25 total patients who withdrew due to adverse events, 11 in the leukotriene group and 14 in the ICS-alone group.

#### Summary

The evidence from these studies is consistent in showing an improvement in asthma outcomes following the addition of a leukotriene antagonist to a fixed dose of ICS. All four studies showed that lung function was better when a leukotriene antagonist was added to a fixed dose of ICS. Three of the four studies showed that lung symptom scores were also improved. Two studies showed decreased use of beta-2 agonist under the combined regimen. This data is not sufficient to determine the comparative adverse effects of treatment, but from the available evidence, there appear to be no differences in adverse events.

### Trials Comparing Addition of Leukotriene Antagonists to Titrated ICS Dose

One study by Lofdahl, Reiss, Leff et al. (1999), enrolling 226 patients, used a different type of study design to evaluate the effect of adding a leukotriene antagonist to an ICS treatment regimen. In this study, after patients were stabilized on the minimum ICS dose necessary to maintain clinical stability, they were randomized to receive placebo or a leukotriene antagonist. Each 2 weeks, according to specific clinical criteria, the dose of ICS was either increased, maintained, or reduced. Thus, the outcome of the study is whether ICS can be successfully reduced, maintaining lung function and symptoms relatively constant. This study evaluated 113 patients in each treatment arm, and followed patients for 12 weeks.

#### Lung Function, Symptoms, and Beta-2 Agonist Use

Since the objective of the study (Lofdahl, Reiss, Leff et al., 1999) was to maintain these parameters at a constant level, by design there should be no differences in these measures throughout the study. No significant changes in these measures occurred.

#### Successful Tapering of ICS Dose

Compared with placebo, leukotriene antagonist significantly reduced the last tolerated dose of ICS. Mean percentage dose changes from baseline were 47 percent and 30 percent for the leukotriene antagonist group and placebo groups, respectively (p=0.046). Forty percent of patients on leukotriene antagonist and 29 percent of patients on placebo tapered completely off ICS.

#### Adverse Effects

The study (Lofdahl, Reiss, Leff et al., 1999) only states that there were no significant differences in the frequency of clinical and laboratory adverse experiences between treatment groups without elaborating in further detail.

#### Summary

This study showed that addition of leukotriene antagonist allowed greater numbers of patients to reduce the dosage of ICS under protocol-guided dosing guidelines.

## Conclusions

There is a large body of evidence on the addition of long-acting beta-2 agonists to ICS, consisting of 28 studies enrolling over 7,000 patients. However, there are only two pediatric studies that together report on only 167 children treated with addition of long-acting beta-2 agonists among 383 total. There is a small body of evidence on the addition of theophylline, consisting of six studies enrolling 408 patients; but only two were studies of children and together these reported on only 47 children treated with theophylline. The evidence on addition of leukotriene antagonists to ICS consists of five studies enrolling a total of 1,111 patients. These studies are mostly randomized controlled trials that report on short-term outcomes. The longest trials report outcomes at 1 year for long-acting beta-2 agonists, 6 months for theophylline, and 4 months for leukotriene antagonists. There was sufficient evidence on the addition of long-acting beta-2 agonists to ICS to perform quantitative meta-analysis of treatment outcomes. There was insufficient data to combine results of trials of addition of theophylline or leukotriene antagonists.

### Addition of Long-Acting Beta-2 Agonists

Sixteen randomized, double-blinded trials enrolling a total of 3,163 patients compared the addition of long-acting beta-2 agonists to a fixed dose of ICS. This evidence consistently showed improvements in lung function outcomes, symptom outcomes, and supplemental beta-2 agonist use. The combined estimate of treatment effect for FEV1 is 0.17L (95 percent CI, 0.12-0.22), or 3.71 percent predicted (95 percent CI, 2.67-4.75), based on 14 studies with 2,781 evaluable patients. For morning, patient-measured PEF, the combined estimate of treatment effect is 24.7 L/min (95 percent CI 17.7-31.7), or 7.3 percent predicted (95 percent CI, 5.3-9.3), based on nine studies with 1,678 evaluable patients. For supplemental beta-2 agonist use, the combined estimate of treatment effect was 1.18 fewer puffs/day (95 percent CI, −1.56 to −0.84)), based on six studies with 1,142 evaluable patients.

Three crossover trials enrolling a total of 151 patients evaluated reducing the dose of ICS after the addition of long-acting beta-2 agonists compared to placebo. The largest of these trials, which was randomized and double-blinded, reported on 84 patients treated for 6 months. All three trials demonstrated statistically significant reductions in ICS dosage for the long-acting beta-2 agonist group, ranging from 13.5 percent, to 23.4 percent less than placebo. The evidence suggests that the reduction in dose is achieved without diminishment of lung function or increase in symptoms; and there is limited evidence to suggest improvement in symptoms.

Twelve randomized trials, enrolling more than 4,000 patients compared the addition of a long-acting beta-2 agonist to low or moderate dose ICS with an increased dose of ICS. All trials but one were double-blinded. This evidence consistently showed improvements in lung function outcomes, symptom outcomes, and supplemental beta-2 agonist use. The combined estimate of the magnitude of the treatment effect for FEV1 is 0.11 L (95 percent CI, 0.07-0.15), or 2.32 percent predicted (95 percent CI, 1.48-3.16), based on 8 studies with 2,754 evaluable patients. For morning, patient-measured PEF, the combined estimate of treatment effect is 11.6 L/min (95 percent CI, 5.2-18.0), or 3.4 percent predicted (95 percent CI, 1.5-5.3), based on 10 studies with 3,042 evaluable patients. For supplemental beta-2 agonist use, the combined estimate of treatment effect was 0.19 fewer puffs/day (95 percent CI, −0.06 to −0.31), based on three studies with 725 evaluable patients.

Data on adverse events were abstracted from the clinical trials included in this review. In general, the adverse event profile for the addition of long-acting beta-2 agonists was similar to that for ICS alone. This analysis is limited in that it examines only short-term adverse events for patients enrolled in clinical trials.

### Addition of Theophylline

Six studies evaluating a total of 408 patients compared the addition of theophylline to ICS. Four of these compared the addition of theophylline to a fixed ICS dose, and two compared the addition of theophylline to a higher dose of ICS. The four studies on the addition of theophylline to fixed ICS dose are generally mixed in their results, but the qualitative direction of the results suggests that the addition of theophylline to a fixed ICS dose produces improved lung function and symptoms.

Based on two randomized clinical trials, theophylline plus ICS versus a higher dose of ICS appears to produce roughly equivalent improvements in lung function and symptoms.

### Addition of Leukotriene Antagonists

Five studies enrolling 1,111 patients compared the addition of leukotriene antagonists to ICS. Four compared the addition of a leukotriene antagonist to a fixed-dose ICS, and the fifth evaluated the ability to reduce the ICS dose after starting a leukotriene antagonist. Of the four studies using a fixed dose of ICS, all showed that lung function was better when a leukotriene antagonist was added to a fixed dose of ICS. Three of these four studies also showed that symptom scores were improved. Two of the studies showed decreased use of beta-2 agonist under the combined regimen. The fifth study showed that the addition of a leukotriene antagonist allowed greater numbers of patients to reduce the dosage of ICS under protocol-guided dosing guidelines.