# Results and Conclusions Part 2. Effects of Delayed ICS on Progression and Reversibility

Key Question 2. For patients with mild-to-moderate asthma, does early initiation of long-term controller therapy (i.e., ICS) prevent progression of asthma, as indicated by changes in lung function or severity of symptoms?

## Overview

Addressing this key question requires understanding of some inherent assumptions. In order for early initiation of long-term controller medications to be more beneficial than delayed initiation, at least two assumptions must be true. First is that mild-to-moderate asthmatics, as a group, have a progressive decline in lung function over time that is measurable and clinically significant. Second is that treatment with controller medications prevents or slows this long-term decline, in addition to providing control of asthma. If these assumptions are true, then it is possible that early initiation of long-term controller medication will improve long-term lung function in the population of mild-to-moderate asthmatics, as compared to delaying introduction of long-term controller medications until symptoms are more severe.

There were no studies that were prospectively designed to address this key question in the specific population of interest. As a result, the available evidence from studies that compared early with delayed ICS treatment has notable limitations with respect to the relevance of the population, time frames for study entry and followup, clarity of reporting with respect to the details of interest to the question, and the use of appropriate control groups. For some trials, it was not possible even to accurately calculate the number of enrolled or evaluable patients of interest to the question, because reporting of one or the other number was combined with other patient groups (e.g., COPD patients or severe asthmatics). Although the objective was to study the effects of any long-term controller medications (e.g., ICS, leukotriene antagonists, cromolyn/nedocromil, theophylline), the available studies were limited to ICS. Because the available studies are few, and do not offer a consistent approach to the question of interest, the review of evidence describes and critically reviews each study. (See Evidence Tables 2-1 through 2-7.)

In addition, the implications of a fifth and more recent study, the CAMP (Childhood Asthma Management Program Research Group, 2000a), are discussed. The CAMP trial is the most robust evidence to date on long-term lung function outcomes in a group of patients treated with ICS versus a placebo-treated control group. Although immediate and delayed initiation of ICS were not directly compared, CAMP provides the strongest prospective evidence available on the natural history of mild-to-moderate asthma managed without inhaled corticosteroids or other long-term controller medication.

Four studies reporting on a total of 475 asthma patients met the inclusion criteria for this key question: two randomized, controlled trials (Overbeek, Kerstjens, Bogaard et al., 1996; Haahtela, Jarvinen, Kava et al., 1994) and two single-arm studies (Selroos, Pietinalho, Lofroos et al., 1995; Agertoft and Pedersen, 1994). Tables 11-13 summarize the study characteristics and key findings for these studies. Each of the two randomized trials (Overbeek, Kerstjens, Bogaard et al., 1996; Haahtela, Jarvinen, Kava et al., 1994) was an open-label extension of a randomized, controlled trial originally intended to evaluate the efficacy of ICS. In these studies, the patients who were originally assigned to the noncorticosteroid-treated control group were subsequently administered ICS at the conclusion of the original randomized, controlled trial. Each of the single-arm studies (Selroos, Pietinalho, Lofroos et al., 1995; Agertoft and Pedersen, 1994) analyzed a cohort of patients treated in a hospital-based clinic, in which the patients were stratified by duration of asthma prior to initiating ICS treatment, and outcomes compared across the strata. Of the four studies, the randomized trial by Haahtela, Jarvinen, Kava et al. (1994), although small (n=52 evaluable), is the most relevant in terms of study design and population. The design includes comparisons that directly address the key question, and the population is limited to mild asthmatics who were enrolled into the study at a similar point in the history of their disease.

Table 11. Study characteristics and outcomes reported

Citation/Study Design | Eligibility | Estimated Disease Severity | Study Duration (years) | Study Arm | Delay/Duration of ICS Use (mos) ^a^ | # Enrolled # Evaluable | Baseline FEV1 | Mean Age +/− SD | Lung Function Outcomes | | | Sx / Meds | Utilization Outcomes
Citation/Study Design | Eligibility | Estimated Disease Severity | Study Duration (years) | Study Arm | Delay/Duration of ICS Use (mos) ^a^ | # Enrolled # Evaluable | Baseline FEV1 | Mean Age +/− SD | FEV1 | PEF | PC20 | Sx / Meds | Utilization Outcomes
Overbeek, Kerstjens, Bogaard et al., 1996-RCT open-label extension | 1) FEV1 minimum 1.2 L and 1.64 to 4.5 residual SDs below predicted, or FEV1/inspiratory VC ratio >1.64 residual SDs below predicted; 2) Histamine PC20 maximum 8 mg/ml | unable to estimate | 3.0 | CS-IMM | 0/36 | (91)/49 | 64.6 +/− 14.1% predicted | 36.8 +/− 11.9 | X | | X
Overbeek, Kerstjens, Bogaard et al., 1996-RCT open-label extension | 1) FEV1 minimum 1.2 L and 1.64 to 4.5 residual SDs below predicted, or FEV1/inspiratory VC ratio >1.64 residual SDs below predicted; 2) Histamine PC20 maximum 8 mg/ml | unable to estimate | 3.0 | CS-DEL | 30/6 | (183)/53 | 61.2 +/− 15.6% predicted | 37.7 +/− 12.6 | X | | X
Haahtela, Jarvinen, Kava, et al., 1994-RCT open-label extension | FEV1 minimum 80% of predicted; increase >15% after inhalation of B-agonist or decrease >15% after exercise test. Maximum duration of symptoms 12 months. | mild | 3.0 | CS-IMM | 0/36 | 50/16 | 3.17 +/− 0.8 L | 37.3 +/− 11.3 | X | X | X | X
Haahtela, Jarvinen, Kava, et al., 1994-RCT open-label extension | FEV1 minimum 80% of predicted; increase >15% after inhalation of B-agonist or decrease >15% after exercise test. Maximum duration of symptoms 12 months. | mild | 3.0 | CS-DEL | 24/12 | 53/36 | 3.05 +/− 0.7 L | 38.1 +/− 13.1 | X | X | X | X
Agertoft and Pedersen, 1994-Stratified single-arm study | Minimum of three prior visits to clinic within past year, with mild to moderate asthma. | mild-severe | 3.7 | CS-IMM | 0-12/24 | ?/? | 81.3% predicted (entire study population) | 6.2 (entire study population) | X
Agertoft and Pedersen, 1994-Stratified single-arm study | Minimum of three prior visits to clinic within past year, with mild to moderate asthma. | mild-severe | 3.7 | CS-DEL1 | 12-24/24 | ?/? | 81.3% predicted (entire study population) | 6.2 (entire study population) | X
Agertoft and Pedersen, 1994-Stratified single-arm study | Minimum of three prior visits to clinic within past year, with mild to moderate asthma. | mild-severe | 3.7 | CS-DEL2 | 24-36/24 | ?/? | 81.3% predicted (entire study population) | 6.2 (entire study population) | X
Agertoft and Pedersen, 1994-Stratified single-arm study | Minimum of three prior visits to clinic within past year, with mild to moderate asthma. | mild-severe | 3.7 | CS-DEL3 | 12-24/24 | ?/? | 81.3% predicted (entire study population) | 6.2 (entire study population) | X
Selroos, Pietinalho, Lofroos, et al., 1995 -- Stratified analysis of ICS treatment arm of a controlled trial | FEV1 maximum 75% of predicted or PEF maximum 75% of predicted; and/or use of inhaled bronchodilators >3x/week, and/or regular asthma symptoms during day or night, and/or reduced exercise tolerance | mild-severe | 2.0 | CS-IMM | 0-6/24 | 14 | 70 +/− 21% predicted | 42 +/− 10 | X | X
Selroos, Pietinalho, Lofroos, et al., 1995 -- Stratified analysis of ICS treatment arm of a controlled trial | FEV1 maximum 75% of predicted or PEF maximum 75% of predicted; and/or use of inhaled bronchodilators >3x/week, and/or regular asthma symptoms during day or night, and/or reduced exercise tolerance | mild-severe | 2.0 | CS-DEL1 | 6-12/24 | 35 | 70 +/− 21% predicted | 52 +/− 12 | X | X
Selroos, Pietinalho, Lofroos, et al., 1995 -- Stratified analysis of ICS treatment arm of a controlled trial | FEV1 maximum 75% of predicted or PEF maximum 75% of predicted; and/or use of inhaled bronchodilators >3x/week, and/or regular asthma symptoms during day or night, and/or reduced exercise tolerance | mild-severe | 2.0 | CS-DEL2 | 12-24/24 | 13 | 78 +/− 18% of predicted | 39 +/− 16 | X | X
Selroos, Pietinalho, Lofroos, et al., 1995 -- Stratified analysis of ICS treatment arm of a controlled trial | FEV1 maximum 75% of predicted or PEF maximum 75% of predicted; and/or use of inhaled bronchodilators >3x/week, and/or regular asthma symptoms during day or night, and/or reduced exercise tolerance | mild-severe | 2.0 | CS-DEL3 | 24-60/24 | 19 | 60 +/− 16% predicted | 49 +/− 16 | X | X
Selroos, Pietinalho, Lofroos, et al., 1995 -- Stratified analysis of ICS treatment arm of a controlled trial | FEV1 maximum 75% of predicted or PEF maximum 75% of predicted; and/or use of inhaled bronchodilators >3x/week, and/or regular asthma symptoms during day or night, and/or reduced exercise tolerance | mild-severe | 2.0 | CS-DEL4 | 60-120/24 | 15 | 62 +/− 18% predicted | 54 +/− 14 | X | X
Selroos, Pietinalho, Lofroos, et al., 1995 -- Stratified analysis of ICS treatment arm of a controlled trial | FEV1 maximum 75% of predicted or PEF maximum 75% of predicted; and/or use of inhaled bronchodilators >3x/week, and/or regular asthma symptoms during day or night, and/or reduced exercise tolerance | mild-severe | 2.0 | CS-DEL5 | >120/24 | 9 | 67 +/− 21% predicted | 62 +/− 9 | X | X

"X" indicates outcome reported

a For Agertoft and Pedersen (1994) and Selroos, Pietinalho, Lofroos, et al. (1995), these numbers indicate duration of asthma and duration of ICS treatment, respectively.

Table 12. Change in lung function outcomes reported

Citation | Study Arm | # Enrolled # Evaluable | Estimated Disease Severity | Study Duration (years) | Overall Change FEV1 ^a^ | Treatment Difference | Overall Change PEF | Treatment Difference | Overall Change PC20 | Treatment Difference | Comments
Overbeek, Kerstjens, Bogaard et al., 1996-RCT open-label extension | CS-IMM | (91)/49^b^ | unable to estimate | 3.0 | 13.8% pred (CI 7.7-18.7) | 5.3% pred | NR | | 1.77 DD (CI 1.07-2.56) | 0.98 DD | Number of patients enrolled includes both COPD and asthma patients, number evaluable includes only asthma patients. Comparison only made of rise in FEV1 during initial 3 mos treatment with ICS in both groups.
Overbeek, Kerstjens, Bogaard et al., 1996-RCT open-label extension | CS-DEL | (183)/53^b^ | unable to estimate | 3.0 | 8.5% pred (CI 3.3-15.9) | | NR | | 0.79 DD (CI 0.00-1.44)
Haahtela, Jarvinen, Kava, et al., 1994-RCT open-label extension | CS-IMM | 50/16 | mild | 3.0 | 0.15 L | 0.13 L | 46 L/min | 31 L/min | | | Values represent FEV1 at start of initial study and final FEV1 after 3 years. No statistical comparison performed on change in FEV1 from start of study until final endpoint
Haahtela, Jarvinen, Kava, et al., 1994-RCT open-label extension | CS-DEL | 53/36 | mild | 3.0 | 0.02 L | | 15 L/min | | | | Values represent FEV1 at start of initial study and final FEV1 after 3 years. No statistical comparison performed on change in FEV1 from start of study until final endpoint
Agertoft and Pedersen, 1994-Stratified single-arm study | CS-IMM | ?/? | mild-severe | 3.7 | 8.2% pred/yr (CI 6.1-10.3) | 5.8% pred/yr ^c^ | NR | | NR | | Calculation of % increase/yr in FEV1 by linear regression probably not appropriate. Final FEV1 % predicted 101 +/− 13.6% in CS-IMM group as compared to 96.2 +/− 9.5% in CS-DEL3 group, p<0.05.
Agertoft and Pedersen, 1994-Stratified single-arm study | CS-DEL1 | ?/? | mild-severe | 3.7 | 6.7% pred/yr (CI 5.0-8.4) | 4.3% pred/yr ^c^ | NR | | NR | | Calculation of % increase/yr in FEV1 by linear regression probably not appropriate. Final FEV1 % predicted 101 +/− 13.6% in CS-IMM group as compared to 96.2 +/− 9.5% in CS-DEL3 group, p<0.05.
Agertoft and Pedersen, 1994-Stratified single-arm study | CS-DEL2 | ?/? | mild-severe | 3.7 | 3.0% pred/yr (CI ??) | 0.6% pred/yr ^c^ | NR | | NR | | Calculation of % increase/yr in FEV1 by linear regression probably not appropriate. Final FEV1 % predicted 101 +/− 13.6% in CS-IMM group as compared to 96.2 +/− 9.5% in CS-DEL3 group, p<0.05.
Agertoft and Pedersen, 1994-Stratified single-arm study | CS-DEL3 | ?/? | mild-severe | 3.7 | 2.4% pred/yr (CI 1.1-3.7) | | NR | | NR | | Calculation of % increase/yr in FEV1 by linear regression probably not appropriate. Final FEV1 % predicted 101 +/− 13.6% in CS-IMM group as compared to 96.2 +/− 9.5% in CS-DEL3 group, p<0.05.
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-IMM | 14 | mild-severe | 2.0 | 17% pred | 17% pred ^d^ | 21% pred | 19% pred ^d^ | NR | | Pt groups not well-balanced on age, baseline lung function, smoking status
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL1 | 35 | mild-severe | 2.0 | 5% pred ^e^ | 5% pred ^d^ | 12% pred | 10% pred ^d^ | NR | | Pt groups not well-balanced on age, baseline lung function, smoking status
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL2 | 13 | mild-severe | 2.0 | 7% pred ^f^ | 7% pred ^d^ | 12% pred | 10% pred ^d^ | NR | | Pt groups not well-balanced on age, baseline lung function, smoking status
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL3 | 19 | mild-severe | 2.0 | 8% pred | 8% pred ^d^ | 6% pred | 4% pred ^d^ | NR | | Pt groups not well-balanced on age, baseline lung function, smoking status
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL4 | 15 | mild-severe | 2.0 | 4% pred ^f^ | 4% pred ^d^ | 2% pred | 0% pred ^d^ | NR | | Pt groups not well-balanced on age, baseline lung function, smoking status
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL5 | 9 | mild-severe | 2.0 | 0% pred ^e^ | | 2% pred | | NR | | Pt groups not well-balanced on age, baseline lung function, smoking status

a FEV1 prebronchodilator or postbronchodilator status was not specified for these studies.

b Number of patients enrolled includes both COPD and asthma patients, number evaluable includes only asthma patients.

c As compared to CS-DEL3 group

d As compared to CS-DEL5 group

e p<0.01 as compared to CS-IMM group

f p<0.05 as compared to CS-IMM group

Table 13. Symptoms and medication outcomes

Citation | Study Arm | # Enrolled # Evaluable | Estimated Disease Severity | Study Duration (years) | Change in Symptom Score | Treatment Difference | Oral Corticosteroid Use | p Value
Overbeek, Kerstjens, Bogaard et al., 1996-RCT open-label extension | CS-IMM | (91)/49 ^a^ | unable to estimate | 3.0 | NR | | NR
Overbeek, Kerstjens, Bogaard et al., 1996-RCT open-label extension | CS-DEL | (183)/53 ^a^ | unable to estimate | 3.0 | NR | | NR
Haahtela, Jarvinen, Kava, et al., 1994-RCT open-label extension | CS-IMM | 50/16 | mild | 3.0 | − 0.8 ?? (scale, 0-10) | 0.0 | 9 courses in 4 pts | NR
Haahtela, Jarvinen, Kava, et al., 1994-RCT open-label extension | CS-DEL | 53/36 | mild | 3.0 | − 0.8 (scale, 0-10) | | 12 courses in 8 pts
Agertoft and Pedersen, 1994-Stratified single-arm study | CS-IMM | ?/? | mild-severe | 3.7 | NR | | NR
Agertoft and Pedersen, 1994-Stratified single-arm study | CS-DEL1 | ?/? | mild-severe | 3.7 | NR | | NR
Agertoft and Pedersen, 1994-Stratified single-arm study | CS-DEL2 | ?/? | mild-severe | 3.7 | NR | | NR
Agertoft and Pedersen, 1994-Stratified single-arm study | CS-DEL3 | ?/? | mild-severe | 3.7 | NR | | NR
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-IMM | 14 | mild-severe | 2.0 | NR | | NR
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL1 | 35 | mild-severe | 2.0 | NR | | NR
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL2 | 13 | mild-severe | 2.0 | NR | | NR
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL3 | 19 | mild-severe | 2.0 | NR | | NR
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL4 | 15 | mild-severe | 2.0 | NR | | NR
Selroos, Pietinalho, Lofroos, et al., 1995-Stratified single-arm study | CS-DEL5 | 9 | mild-severe | 2.0 | NR | | NR

a Number of patients enrolled includes both COPD and asthma patients; number evaluable includes only asthma patients.

The duration of follow up was 3 years in the randomized trials, and 2 and 3.7 years respectively in the single arm studies. Haahtela, Jarvinen, Kava et al. (1994) treated one group with ICS for 24 months, then treated the delayed ICS group for 12 months. Overbeek, Kerstjens, Bogaard et al. (1996) treated one group with ICS for 30 months, then initiated ICS in the delayed group and followed both groups for an additional 6 months. In the single-arm studies, patients starting on ICS were followed for 2 years in one study (Selroos, Pietinalho, Lofroos et al., 1995) and for 2-6 years (mean: 3.7 years) in the final study (Agertoft and Pedersen, 1994).

All four trials were conducted in Europe, three in Scandinavia, and the fourth in the Netherlands. The two randomized trials were multicentered (Haahtela, Jarvinen, Kava et al., 1994; Overbeek, Kerstjens, Bogaard et al., 1996), while the two single-arm studies were from single institutions (Agertoft and Pedersen, 1994; Selroos, Pietinalho, Lofroos et al., 1995). Funding sources for three of the trials were not specified, for the fourth (Overbeek, Kerstjens, Bogaard et al., 1996) funding was through a combination of pharmaceutical and government grants.

## Patient Populations

Three of the four studies (Haahtela, Jarvinen, Kava et al., 1994; Overbeek, Kerstjens, Bogaard et al., 1996; Selroos, Pietinalho, Lofroos et al., 1995) enrolled an adult population; the fourth study (Agertoft and Pedersen, 1994) enrolled children between the ages of 3-11 years. Severity of illness as measured by baseline FEV1 values ranged from mild to moderate. Two studies (Haahtela, Jarvinen, Kava et al., 1994; Agertoft and Pedersen, 1994) had baseline FEV1 values in mild range (i.e., greater than 80 percent predicted); the other two (Overbeek, Kerstjens, Bogaard et al., 1996; Selroos, Pietinalho, Lofroos et al., 1995) had baseline FEV1 values in the moderate range (i.e., 60-80 percent predicted) according to the asthma classification guidelines of the NHLBI (National Heart, Lung, and Blood Institute, 1997).

All three adult trials used eligibility criteria based on lung function parameters, but no consistent or uniform set of severity parameters or eligibility criteria was common to all the trials. One trial (Overbeek, Kerstjens, Bogaard et al., 1996) had inclusion criteria based only on lung function parameters; two trials (Haahtela, Jarvinen, Kava et al., 1994; Selroos, Pietinalho, Lofroos et al., 1995) based inclusion criteria on lung function parameters and duration or frequency of symptoms. The pediatric study (Agertoft and Pedersen, 1994) had inclusion criteria based on stated severity of asthma and number of clinic visits. All studies had criteria that would exclude patients with prior ICS treatment, although the specific exclusion criteria were different for each of the four trials.

## Outcomes

All four trials reported lung function outcomes in some manner, but no two studies used the same measure to report change in lung function from baseline. Haahtela, Jarvinen, Kava et al. (1994) reported prebronchodilator and postbronchodilator FEV1 values in liters (L); Selroos, Pietinalho, Lofroos et al. (1995) reported prebronchodilator and postbronchodilator FEV1 values as percent of predicted normal values; Overbeek, Kerstjens, Bogaard et al. (1996) reported the absolute increase in FEV1 percent predicted; and Agertoft and Pedersen (1994) reported the calculated annual increase in FEV1 percent predicted. The two studies that reported PEF outcomes also used different measures: L/min in Haahtela, Jarvinen, Kava et al. (1994) and percent predicted in Agertoft and Pedersen (1994). Only Haahtela, Jarvinen, Kava et al. (1994) reported data for symptom-based outcomes and this was also the only trial that reported medication use outcomes (i.e., oral corticosteroid use). None of the studies reported outcomes based on utilization of clinical services (e.g., hospitalization, ER visits, unscheduled doctor visits) or on missed days of work, school, or activity.

## Study Quality

Quality of study design and conduct was assessed as described in the "Methodology" chapter. The objective was to identify a group of higher quality trials for purposes of sensitivity analysis. The definition for higher quality studies is applicable only to randomized controlled trials and excluded nonrandomized controlled trials and single arm studies. It includes generic quality indicators that have been shown to be associated with a bias in magnitude of effect, and disease specific indicators, particularly those that are potential confounders of outcomes.

Neither of the two randomized controlled trials included in the review of evidence for this chapter met the criteria defining higher quality studies (Table 14). This definition requires double-blinded, randomized controlled trials that met additional criteria for adequacy of randomization, percent of patients excluded from analysis, and handling of excluded patients. Neither study maintained blinding to treatment throughout the course of the study. For both, the rate of dropouts/withdrawals exceeded the threshold set. Analyses were not done by intent to treat, or in a manner to minimize dropout bias.

Table 14. Assessment of study quality

| General Quality Indicators | | | | Asthma-Specific Quality Indicators
Citation | Blinding (required) | Percentage of excluded subjects below specified threshold? (required) | Intent to treat analysis? | Allocation concealed? (NS=not specified) | Power calculations? | Accounted for excluded patients? | Reversibility established? | Controlled for other medication use? | Reported compliance? | Addressed seasonality?
Haahtela, Jarvinen, Kava et al., 1994 | No | No | No | NS | No | No | Yes | Yes | No | No
Overbeek, Kerstjens, Bogaard et al., 1996 | No | No | No | NS | No | No | Yes | Yes | No | No

With respect to asthma specific quality indicators, both randomized trials established reversibility on lung function measurements and controlled for use of other asthma medications. Neither reported power calculations for outcomes, adequately accounted for excluded patients, or specified a priori which were primary outcomes for analysis. Neither study reported compliance or controlled for the effects of seasonality on outcomes.

## Critical Review of Studies

### Randomized Controlled Trials

#### Haahtela, Jarvinen, Kava et al. (1994)

This study was a randomized clinical trial performed in two phases over a period of 3 years. The patient population consisted of mild asthmatics diagnosed within the previous 12 months. The first phase of the study evaluated the efficacy of ICS (n=50) compared to beta-2 agonists alone (n=53). Patients were randomized to inhaled budesonide (600 mcg twice a day) or inhaled terbutaline (375 mcg twice a day) and followed for 2 years. The second phase of the study was a 1-year open-label extension of the original study, in which patients (n=36) assigned to the terbutaline group were treated with ICS. During this third year, patients originally assigned to the ICS group were either continued on a reduced dose of ICS (budesonide 200 mcg twice daily, n=19) or given placebo (n=18). Outcomes were reported at the end of the 3-year period for both the immediate and delayed group, allowing comparisons at baseline and the final time point of the study for the immediate and delayed ICS group.

At the end of 3 years, lung function measures improved in both groups, with larger increases occurring in the immediate ICS group compared to the delayed ICS group, as follows: FEV1 (0.15 L. vs. 0.02 L); PEF (42 L/min vs. 15 L/min); PC15 (5.0 vs. 4.2 DD histamine). However, no tests of statistical significance were reported on these final outcome measures and insufficient information was provided to calculate p-values. Symptom scores also improved in both groups, with a larger absolute improvement in the immediate ICS group. The mean initial symptom score was 2.2 on a 0-10-point scale for both groups, and the final symptom score for the immediate ICS group was 1.4 compared to 1.8 in the delayed group.

This study also compared changes in lung function during the initial 12 months that each group received treatment with ICS, i.e., months 0-12 of the study for the immediate ICS group compared with months 24-36 for the delayed ICS group. The immediate ICS group showed a statistically significant greater absolute rise in PEF over these 12-month periods (36.0 vs. 14.7, p=0.006). There was also a greater absolute rise in the FEV1 for the immediate ICS group, but the difference was not statistically significant (0.13 L vs. 0.05 L, p=0.295).

Although these findings might appear to be consistent with the hypothesis that an irreversible decline in lung function can occur in untreated asthma, and that treatment with ICS may have an impact on decline, this study provides insufficient evidence to support such an inference. First, there was not a statistically significant difference in lung function measures between groups documented over the entire 3-year period. For the comparison of the initial 12 months of ICS use between the immediate and delayed groups, only PEF, but not FEV1, showed a significant difference. Second, selection or withdrawal bias may be present due to the limitations of the study design. Third, the first-year treatment intervals in the double-blind and open label phases of the study are not strictly comparable, and may be subject to confounding effects of varying ICS dosage and seasonality. Finally, the magnitude of difference between groups is of undetermined clinical significance, and is of a size that could be explained by bias.

In summary, features of the design, execution, and reporting of the Haahtela, Jarvinen, Kava et al. (1994) study limit its usefulness in addressing the question of whether early initiation of ICS prevents progressive decline in lung function. The initial double-blind phase of the Haahtela, Jarvinen, Kava et al. (1994) study was not intended to answer the question of the benefit of immediate versus delayed introduction of corticosteroids, and patients were offered continuation in the study for a third year in an open-label fashion. The open-label phase was not strictly controlled as to factors that might affect the comparability of the immediate and delayed ICS arms, most obviously ICS dosage and seasonality.

There was also a very high dropout rate during the open-label phase of the study: 36 of 53 patients in the delayed ICS group and only 16 of 50 patients in the immediate ICS group were available for analysis at 3 years. Withdrawals were not compared with rest of patients for comparability, and the analysis was not performed in an intent-to-treat manner or using other methods to incorporate dropouts, thereby leaving a high possibility for dropout/withdrawal bias. Although data on the initial and final 3-year outcomes were reported, these data were not complete. There were no statistical tests performed comparing the baseline and 3-year outcomes between the immediate and the delayed ICS groups. There were no SDs reported for the final lung function outcome measures, precluding calculation of these values; thus, the differences reported between the groups are of unknown statistical and clinical significance. For all the above reasons, no conclusions on the relative effects of immediate versus delayed ICS treatment can be drawn from this study.

#### Overbeek, Kerstjens, Bogaard et al. (1996)

The randomized controlled trial by Overbeek and coworkers (Overbeek, Kerstjens, Bogaard et al., 1996) is similar to the Haahtela, Jarvinen, Kava et al. (1994) study in that it is an open-label extension of a double-blind, randomized, controlled trial that was designed to evaluate the efficacy of ICS. An important difference is that the Overbeek, Kerstjens, Bogaard et al. (1996) study included patients with COPD as well as asthma, and there are relevant data that were not reported by diagnosis. Of total of 274 patients initially randomized, there were 102 asthmatic patients included in the analysis at the conclusion of the open-label phase of the study.

The original randomized controlled trial compared three treatment groups: inhaled beclomethasone 200 mcg four times daily; inhaled ipratropium 40 mcg four times daily; and placebo. All three groups also received inhaled terbutaline 500 mcg four times daily. After 30 months of treatment in the double-blind randomized controlled trial, the open-phase extension offered ICS to patients in the two groups who had not initially received ICS. Patients in the open-label phase were followed for an additional 6 months. Lung function outcomes were compared for the group of patients who had originally been randomized to ICS ("immediate ICS") and the patients who began ICS after a 30-month period ("delayed ICS").

This study included patients with both asthma and COPD. There were 49 asthmatic patients who received ICS at the start of the original randomized, controlled trial. There were 53 asthmatics among the two other groups who remained in the study during the second phase. Some outcome data were reported separately by diagnosis, but other information, such as withdrawals, was not, resulting in incomplete information on the group of asthmatics. A comparison of the magnitude of improvement seen in the first 3 months of ICS use was reported for the asthmatic population among the immediate ICS group (months 0-3) and the delayed ICS group (months 30-33). Patients in the immediate ICS group had a greater rise in FEV1 during their initial 3 months on ICS as compared to the delayed ICS group, but this difference was not statistically significant (13.8 percent vs. 8.5 percent, p=0.13). The change in PC15 values was compared between the immediate and delayed ICS group for the initial 6 months of ICS treatment (months 0-6 in the immediate group versus months 30-36 in the delayed ICS group). There was a statistically significant difference in the increase in doubling dose for the immediate group as compared to the delayed group (1.77 doubling dose vs. 0.79, p=0.03). It was stated that there were no statistically significant differences in symptom scores between the two groups, but symptom score values were not included in the report.

A number of factors limit the overall relevance of the Overbeek, Kerstjens, Bogaard et al. (1996) study to the key question and thus the ability to draw conclusions. First, the comparisons made in lung function outcomes between the immediate and delayed ICS group were not the most relevant to this key question, as data were not provided to compare baseline and final lung function measures at 36 months. Second, the study population was not confined to mild to moderate asthmatics. The eligibility criterion for FEV1 was somewhat unusual (i.e., 1.64-4.5 residual SDs below the predicted value), making it difficult to compare the severity level of this population to other studies. The mean FEV1 values for the two asthmatic groups were 64.6 (+/− 14.1) and 61.2 (+/− 15.6), indicating that many patients would be classified in the severe range. It is not known how many patients were included at various levels of severity, and results were not stratified by severity level. Third, the initial treatment given to patients in the delayed ICS may have been either as-needed beta-2 agonists only or as-needed beta-2 agonists plus ipratropium. It is possible that the effects of these different treatments on progression of asthma may have an impact on the subsequent response to ICS.

In summary, features of the design, execution, and reporting of the Overbeek, Kerstjens, Bogaard et al. (1996) study, even more so than Haahtela, Jarvinen, Kava et al. (1994), limit its usefulness in addressing the question of whether early initiation of ICS prevents progressive decline in lung function. The initial double-blind randomized controlled trial was not designed to answer the key question, and the second phase of the study was conducted in an open-label fashion. The comparisons reported were only between the initial 3-6 months of ICS treatment for each group, rather than changes over the entire period of the study. For this comparison, only the bronchial hyperresponsiveness outcomes, and not the FEV1 outcomes, were statistically different. The clinical significance of these hyperresponsiveness outcomes is undetermined. There was a high dropout rate, indicating the potential for withdrawal bias. The exact number of asthmatics who dropped out during the study cannot be determined, as these numbers were not reported separately for diagnosis. However, of the original 173 patients included in the placebo and ipratropium groups, only 76 remained in the study for the second phase, 53 of which were asthmatics.

### Single-Arm Studies

A major limitation of the single-arm studies is that patients enter the study at varying time points in the history of their disease; it is then impossible to compare outcome data at a uniform time point. For example, suppose a study starts with two patient groups; one with a prior duration of asthma of 1 year and another with a prior duration of 5 years and treats both groups with ICS for 1 year. With this design, final outcome data can only be compared 2 years from the time of diagnosis in the first group and 6 years from the time of diagnosis in the second group. For the group with the shorter duration, it cannot be determined what their outcome data will be like at the 6-year time point. A second major limitation in studies of this type is the high potential for selection bias. It is likely that patients with a longer duration of asthma will have more severe disease, both because of disease progression and because asthma is more likely to remit in milder cases. This also will limit the comparison of outcomes between patients with varying duration of disease.

#### Selroos, Pietinalho, Lofroos et al. (1995)

This study enrolled 105 consecutive patients started on ICS in one clinic over a 17-month period, and results were reported for 91 of these patients. The study was probably prospective, but this was not specifically stated. Patients were stratified for their prior duration of asthma: 0-6 months (n=14), 6-12 months (n=35), 12-24 months (n=13), 24-60 months (n=19), 60-120 months (n=15), and greater than 120 months (n=9). All patients were treated with inhaled budesonide for a period of 2 years, at a mean starting dose for the entire population of 374 mcg twice a day. Changes in lung function outcomes (percent predicted FEV1 and percent predicted PEF) was compared among the 6 groups of patients over the 2 years of the study.

All strata were compared to the 0-6 month duration group; and no comparison among strata was reported. The greatest increase in lung function measures occurred in the group with the shortest (0-6 months) duration of asthma (17 percent increase in percent predicted FEV1); and the least increase occurred in the group with the longest (>120 months) duration of asthma (0 percent increase, p<0.01). However, there was not a consistent relationship between asthma duration and outcomes among the six strata. Among the group with asthma of 24-60 months; duration, the change in FEV1 was not statistically significant compared to 0-6 month group, although all groups of shorter and longer duration demonstrated a significant difference in FEV1 change. For the intermediate groups, the improvement in FEV1 ranged between 5 and 8 percent, without a definite relationship demonstrated between duration and degree of increase. For PEF, the 0-6 month group had a 21 percent increase in their percent predicted values, compared with a 2 percent increase in the >120 month group (p<0.05). The intermediate groups had an improvement ranging from 2-12 percent, with statistically significant differences found for the 24-60 month group, the 60-120 month group, and the greater than 120 month group, as compared with the 0-6 month group. PEF increase among the 6-12 and 12-24 groups was not statistically significant compared to the 0-6 month group.

In addition to the general limitations of single-arm studies for this question, other methodologic features limit the ability to draw conclusions from the Selroos, Pietinalho, Lofroos et al. (1995) study. The groupings made on prior duration of asthma were somewhat arbitrary, and the analysis was performed categorically on what really is a continuous variable (duration of asthma). There was evidence of selection bias in that the patient groups had baseline differences in demographics and lung function. Approximately a third of the population were current or ex-smokers, and the proportion of current smokers varied among groups from 0 percent to 29 percent. The study was therefore prone to the confounding effects of age, severity of illness, and smoking in comparing outcomes across groups. Finally, there was inconsistency in the reporting of variance measures, with SDs reported for initial values and standard error of the mean reported for final outcome values. Conversion of standard error of the mean (SEM) to SD suggests that there was high variance in final outcome measures.

#### Agertoft and Pedersen (1994)

As with the open label extensions of the randomized controlled trials described above, the Agertoft and Pedersen (1994) study was not designed to compare the long-term outcomes of early and delayed initiation of ICS treatment. This study was a non-randomized, prospective controlled trial of long term outcomes in 216 children treated with ICS for a mean of 3.7 years compared to 62 children who declined the recommendation for ICS treatment. Patients in the ICS group were stratified by prior duration of asthma for purposes of a supplemental cohort analysis that is relevant to the key question.

Agertoft and Pedersen (1994) classified the duration of asthma in four categories for this analysis: 0-2 years, 2-3 years, 3-5 years, and greater than 5 years. As noted previously in the discussion of Selroos, Pietinalho, Lofroos et al. (1995), such classification schemes are somewhat arbitrary and result in an analysis that is performed categorically on what really is a continuous variable (i.e., duration of asthma). Moreover, the data provided on these strata were incomplete. For example, the baseline characteristics for each stratum were not reported, so that their comparability cannot be assessed. In particular, for this study of children with a mean age of 6.2 years, there is the possibility of confounding with factors associated with age and development. The group with the longest duration of disease consisted of older children (mean age 9.3 years) and the group of shortest duration consisting of younger children (mean age 4.7 years).

The main reported outcome was annual change in percent predicted FEV1, calculated by linear regression. The mean estimated change in FEV1 per year was 8.2 percent for the 0-2 year group, 6.7 percent for the 2-3 year group, 3 percent for the 3-5 year group, and 2.4 percent for the greater than 5 year group. There was a statistically significant correlation between the duration of asthma and the estimated change in FEV1 per year. However, this estimate of annual change in FEV1 by linear regression was not appropriate for the data, since it assumes a linear change in outcomes over the entire course of the study. The change in FEV1 was not linear across duration of study, but rather showed an initial rise associated with initiation of ICS treatment, followed by a plateau. Indeed, a pattern of a sharp initial rise in FEV1 during the first 3 months of ICS treatment is well documented in the literature. The confidence intervals reported indicate that there was no significant difference between the less than 2 and 2-3 year strata or the 3-5 and greater than 5 year strata. This is also suggested by the final FEV1 data, which was reported only for the group of shortest (<2 years) and longest (>5 years) duration.

Thus, Agertoft and Pedersen's (1994) presentation of the data overestimates the treatment differences among groups; and the analysis is prone to the confounding effects of age, duration of asthma and duration of followup. The final FEV1 percent predicted for the less than 2 year group was 101 percent compared with 96.2 percent for the greater than 5 year group (p<0.05). This modest difference between groups of 4.8 percent over a mean of 3.7 years is much less than the 5.8 percent per year difference between these two groups estimated by linear regression. Furthermore, the difference is not adjusted for baseline differences in age and severity of disease, which might decrease the magnitude of difference reported.

### Implications of the CAMP Trial

The CAMP study (Childhood Asthma Management Program Research Group, 2000a) was a three-arm randomized controlled trial evaluating the outcome effects of ICS or nedocromil sodium compared to placebo in 1,041 children over a mean followup of 4.3 years. The primary outcome measure was postbronchodilator FEV1. Although the design of this study does not directly address the question of immediate versus delayed ICS treatment, the CAMP study provides the most robust evidence to date on long term lung function outcomes in a group of patients treated with ICS and a placebo control group (Childhood Asthma Management Program Research Group, 2000a). As such, the results provide evidence on changes in lung function that occurs over 4 years in children with mild to moderate asthma, and whether treatment with ICS or nedocromil prevents a decline in lung function.

CAMP found no significant difference between treatment and control groups for change in postbronchodilator FEV1, which was the primary outcome (Childhood Asthma Management Program Research Group, 2000a). Postbronchodilator FEV1 was used as the preferred indicator of disease progression to minimize effects of reversible airway constriction and individual variability over time that are observed with prebronchodilator FEV1. The baseline postbronchodilator FEV1 was 103 (+/− 12) percent predicted for the placebo group, 103 (+/− 13) percent predicted for the ICS group, and 102 (+/− 12) percent predicted for the nedocromil group, indicating normal or near normal lung function at the outset of the trial. Overall, changes in postbronchodilator FEV1 were minimal: there was a mean decline of 0.1 percent predicted in the placebo group and 0.5 percent in the nedocromil group, while there was a 0.6 percent increase in the ICS group. These means are adjusted for characteristics at study entry, including baseline value, severity and duration of asthma, age, sex, race, and ethnicity (SD=9.6, estimated by regression model).

The finding of no difference in postbronchodilator FEV1 and minimal change overall in lung function for the entire study population does not support the hypothesis that treatment with ICS can prevent a long-term decline in lung function in mild to moderate asthmatics. CAMP did not find progressive decline in lung function in the placebo group, or significant improvement in the treatment groups (Childhood Asthma Management Program Research Group, 2000a). Had the study reported significant differences in lung function outcomes, then the data would not have allowed a determination of whether early initiation of ICS was superior to delayed initiation. A direct comparison of early versus delayed ICS initiation would then be necessary to evaluate whether irreversible decline in lung function occurs when ICS treatment is delayed.

Similar to the case with lung function outcomes, there was not a progressive decline in symptoms for the placebo group. Symptom scores improved over the course of the study in both the ICS and placebo group, with a greater improvement reported for the ICS group (−0.44 vs. −0.37 on a 0-3 scale, p<0.005). The number of night awakenings also improved in both groups, with no difference between ICS and placebo (−0.7 vs. −0.6 awakenings per month, p=NS). These symptom scores indicate that ICS lead to better symptom control in this population. However, the data do not indicate that there is a progression in severity of symptoms for patients with mild to moderate asthma in the absence of treatment with ICS.

In summary, the CAMP trial did not find progressive decline in lung function over a 4-year period in a population of children with mild-to-moderate asthma managed without ICS; nor was there a significant difference between treated and control groups in change in postbronchodilator FEV1. However, several possibilities limit the generalizability of the results of the CAMP trial. First, it is possible that this length of followup was not adequate to detect significant changes. A trial with longer followup might detect a preventable decline, although the trajectory of changes in lung function for the CAMP population does not suggest that this is likely to be of a large magnitude. A second possibility, as suggested by the CAMP investigators, is that a decline in lung function occurs early in the course of disease and that the patients in the CAMP study, with a prior duration of asthma averaging approximately 5 years, were too far along in their disease course to prevent such an early decline.

Third, it is possible that progressive decline in lung function occurs in patients with more severe disease, but not in the mild to moderate asthmatic population selected for the CAMP trial. Finally, it is possible that the lack of decline in the lung function parameters is due to the care given in the trial apart from ICS. The trial employed an intensive intervention and followup in all groups. This high level of care may have maintained optimal lung function and symptom control to a greater extent than can be achieved under the conditions of usual care.

## Conclusions

The evidence on this key question is insufficient to permit conclusions on whether early intervention with long-term controller medications is superior to delayed introduction. The best available evidence does not support the assumption that mild to moderate asthmatics have a progressive decline in lung function that can be prevented by early initiation of long-term controller medications.

The CAMP trial (n=1,041) is the most robust evidence to date on long-term lung function outcomes in a group of patients treated with ICS and a placebo-control group (Childhood Asthma Management Program Research Group, 2000a). Although immediate and delayed initiation of ICS were not directly compared, CAMP provides the strongest prospective evidence available on the natural history of mild to moderate asthma managed without ICS or other long-term controller medication. The CAMP trial did not find progressive decline in lung function over a 4-year period in a population of children with mild to moderate asthma managed without ICS; nor was there a significant difference between treated and control groups in change in postbronchodilator FEV1.

It is possible that the findings of the CAMP study are not generalizable to patients with less intensive overall care. The findings may also not be generalizable over longer periods of followup, to populations newly diagnosed with asthma, to groups of patients with more severe asthma, or to a subset of patients with a more variable disease course. But for the general group of children with mild-to-moderate asthma, there is no convincing evidence that there is a progressive, clinically measurable decline in lung function that can be altered by early initiation of ICS.

The available evidence on immediate vs. delayed initiation of ICS is from four studies that have notable limitations with respect to the relevance of the population, time frames for study entry and followup, clarity of reporting with respect to the details of interest to our question, and the use of appropriate control groups. None of these studies were prospectively designed to address the key question in the specific population of interest. Two studies (n=52 and n=102, respectively) were open-label extensions of randomized controlled trials of the efficacy of ICS, in which the patients initially assigned to the control group were subsequently treated with ICS. There were also two single-arm studies, one of adults (n=105) and one of children (n=216), in which the patients were stratified by duration of asthma prior to initiating ICS treatment and outcomes compared across the strata.

Due to high withdrawal rates, the most relevant of the extension phase randomized trials reported on only 16 patients who received immediate corticosteroid treatment; and no data were provided to test the statistical significance of results at the final 3-year time point. The larger of the extension phase randomized trials did not report on the patient population and outcomes most relevant to this key question. Neither of the single-arm studies clearly demonstrated a relationship between asthma duration and outcomes that was consistent among all strata analyzed.