# Introduction

This chapter provides an introduction to selected issues that are relevant to the interpretation and evaluation of the asthma literature. First, an overview of the epidemiology and pathophysiology of asthma is presented, followed by a discussion of asthma outcome measures and severity classification systems. An overview of current asthma medications will be presented. Finally, pertinent issues critical to the evaluation of the literature for each of the key questions are presented.

## Definition of Asthma

Asthma is a heterogeneous clinical disorder characterized by episodic wheezing, chronicity, hyperresponsiveness of airways to a variety of stimuli, and largely reversible obstruction of airways. Accompanying these clinical manifestations is an inflammatory process in walls of the airways. Environmental and genetic factors interact in susceptible individuals to cause the inflammation and the clinical manifestations of asthma.

Asthma is a variable and episodic condition characterized by exacerbations and remissions. Episodes of asthma are usually associated with widespread but variable airflow obstruction that is often reversible either spontaneously or with treatment.

### Burden of Illness

Asthma is estimated to affect 14 million to 15 million persons in the U.S. It is the most common chronic disease of childhood, estimated to affect 4.8 million children (National Heart, Lung, and Blood Institute, 1997). As many as 10-15 percent of boys and 7-10 percent of girls may have asthma at some time during childhood (Behrman, Kliegman, and Jensen, 2000).

There are 70,000 asthma-related hospitalizations annually, and more than 5,000 people die of asthma each year. Hospitalization rates have been highest among blacks and children, and death rates have been consistently highest among blacks aged 15 to 24 years. Rates of asthma have increased or remained stable over the past decade (National Heart, Lung, and Blood Institute, 1997).

### Epidemiology and Natural History of Asthma

Asthma commonly arises in childhood, but may have its onset at any age. Prevalence among young children varies according to definition, but the 1988 Health Interview Survey indicated a prevalence of asthma of nearly 5 percent in the United States among children 10 to 17 years of age (Behrman, Kliegman, and Jensen, 2000). However, the long-term prognosis for childhood asthma is quite variable. Longitudinal studies show that about 50 percent of asthmatic children are free from symptoms within 10-20 years, but recurrences may occur. Children with severe asthma are less likely to have disease remission. Although the majority of childhood asthmatics have a good prognosis, some are at risk of impaired maturation of lung function and growth of lung tissue during childhood, lower attained level of lung function at adulthood, and decline of lung function during adulthood (Ulrik, 1999). Because of disease variability between individuals, it is difficult to predict the natural history of asthma in any given patient and difficult to know if treatment can alter the natural history of the disease.

Although most asthma arises during childhood, the annual incidence of asthma after the age of 20 is about 100 per 100,000 for the rest of the life span (Reed, 1999). An adult with asthma may have had the symptoms consistently since childhood, have recovered from the disease in childhood only to relapse, or have acquired the disease later in life. Unlike asthma in childhood, family history has not been demonstrated for adult-onset asthma. Occupational and environmental exposures, respiratory infections, and smoking have been implicated in the etiology of adult-onset asthma. Complicating the understanding of asthma in adults is the existence of other common conditions such as chronic obstructive pulmonary disease and chronic bronchitis, which may coexist in certain individuals. In persons who exhibit characteristics of asthma and either chronic obstructive pulmonary disease or chronic bronchitis, it may be difficult or impossible to determine which condition is the cause or result of worsening lung function over time. Thus, in both adults and children the natural history of asthma is poorly understood, and the effect of long-term control medication on long-term prognosis needs to be assessed in light of this context.

### Pathophysiology and Pathology of Asthma

The important pathophysiologic feature of asthma that causes its classic clinical symptoms is an exaggerated bronchoconstrictor response. Wheezing, shortness of breath, and declines in lung function tests occur in response to exposure to allergens, environmental irritants, viral infections, cold air, exercise, or other poorly defined factors. Current research has demonstrated that inflammation is a critical process involved in the pathophysiology of asthma. Airway markers of inflammation correlate with measures of bronchial hyperresponsiveness. Secondly, treatment of asthma with certain anti-inflammatory medications reduces inflammation and diminishes airway hyperresponsiveness.

In addition to acute bronchoconstriction, inflammation is thought to contribute to acute asthma symptoms by contributing to airway edema and by causing formation of chronic mucous plugs.

Although the changes in lung function induced by inflammation are largely reversible with appropriate treatment, inflammatory cell infiltration coupled with airway smooth muscle spasm, mucosal edema, and chronic mucous plugging of smaller airways can result in airway remodeling. In some patients, this leads to airflow limitations that are only partially reversible. A pathologic feature of asthma is an alternation in the amount and composition of extracellular material in the airway wall, which may cause permanent changes in airway anatomy. Although airway remodeling is not fully understood, the irreversible changes in lung function in some asthma patients suggests that long-term anti-inflammatory therapy which is started early and continued according to a management plan may modify the long-term course of the disease.

### Asthma Severity

Because asthma is a chronic disease characterized by differing frequencies of daily symptoms, exacerbations and remissions, characterizing the severity of the disease is problematic. Level of symptoms may be confounded by current treatment, which may be adequate or inadequate. Tests of lung function may not correlate with the severity and frequency of symptoms. However, in order to facilitate useful clinical guidelines for management and to classify patients consistently to evaluate outcomes, the National Heart, Lung, and Blood Institute (NHLBI) currently classifies asthma into four levels of severity based on pretreatment measures and symptoms: mild intermittent, mild persistent, moderate persistent, and severe persistent (National Heart, Lung, and Blood Institute, 1997). The classification system uses symptom frequency, exacerbation severity and frequency, frequency of nighttime symptoms, and lung function (as assessed by forced expiratory volume in one second [FEV1] or peak expiratory flow [PEF] variability). The presence of the most severe features in any category places a patient in that category of asthma severity.

The current classification system differs from the prior NHLBI Expert Panel report on asthma (National Asthma Education and Prevention Program, 1992). Most published reports of clinical research on asthma do not use the NHLBI classification system. The classification schemes in most studies are quite variable. Comparisons of patients outside of or between clinical trials can be problematic. In addition, other aspects of asthma not captured by the NHLBI classification scheme are likely to be associated with many outcome measures. Duration of asthma diagnosis, prior treatment with corticosteroids or other long-term medication, or presence of atopy are just a few possible characteristics that may be unmeasured in a research study.

### Objectives of Asthma Treatment

Since asthma is a chronic condition for which no treatment has been proven to be curative (although remissions are common), the overall goal of treatment is to control asthma symptoms as much as possible with as few adverse effects of treatment as possible. The NHLBI defines control of asthma as: 1) prevention of chronic and troublesome symptoms, 2) maintenance of (near) "normal" pulmonary function, 3) maintenance of normal activity levels, 4) prevention of recurrent exacerbations of asthma and minimization of emergency department visits, 5) minimal or no adverse effects from pharmacotherapy, and 6) fulfillment of patients' and families' expectations of asthma care.

Recognition of the need to balance control of asthma against possible adverse effects of treatment is reflected in the NHLBI treatment guidelines, which are stratified by severity of asthma. For the moderate and severe categories of asthma, different regimens are recommended for control of a potentially life-threatening condition. However, for the milder categories of asthma, and particularly the mild persistent category, controversy exists about the strategies that will best control asthma at the lowest risk of adverse effects. Both medications and dosages can be varied to obtain a certain level of control, and different patients may have different opinions regarding benefits and risks of treatment.

Another aspect of treatment addressed relates to strategies patients use to self-manage fluctuations in asthma symptoms -- asthma management plans. In addition to controlling asthma with specific medications, there are different ways to have patients manage their own asthma to control fluctuations in asthma symptoms, which may reduce exacerbations and risk of hospitalization. The objective is to have patients optimally manage fluctuations in their disease to minimize asthma morbidity.

A final pertinent objective of treatment, for the purposes of this report, is prevention of progression of asthma, in addition to concurrent control of asthma. Although patients may be well controlled on certain regimens of medications, over time asthma can worsen, as manifested by increasing doses of medications needed for the same degree of control, worsening lung function over time, increasing frequency of exacerbations, or evidence of permanent lung dysfunction. If treatment with a long-term anti-inflammatory medication were proven to prevent progression of asthma in addition to providing improved control of acute exacerbations, then it would be useful even for asthmatics with milder classes of disease, for whom other medications or combinations of medications could provide equivalent control of symptoms.

## Outcome Assessment of Asthma

Assessment of treatment outcomes for asthma is complicated by the multiplicity of possible outcome measures for assessing the disease and lack of a universally accepted gold standard for assessing clinical outcome. Assessment of asthma outcomes falls into three categories: lung function measurements, symptom assessment, and health care utilization measures.

It is also important to distinguish between the specific outcome measurements being used as to whether they are intended to represent control of asthma versus long-term deterioration of lung function.

### Lung Function Measures

Several measures of lung function as assessed with spirometry are commonly used in asthma studies. Instrumentation and techniques for obtaining standard lung function values have been well standardized by the American Thoracic Society, so that values obtained between studies are likely to be comparable (American Thoracic Society, 1995). However, careful attention to proper technique is critical, and full effort and cooperation of subjects is essential. Spirometry can be used to generate several possible parameters of lung function, but the most common one employed for assessing asthma is the forced expiratory volume in 1 second, FEV1. FEV1 values vary by gender, age, height, and ethnicity. In studies of children and in studies assessing changes over long periods of time, FEV1 values are usually transformed into normalized values (expressed as percent predicted) based on comparisons to large reference populations.

It is critical to note under which conditions a particular FEV1 value is obtained in order to make the correct inference from comparisons. The baseline value of FEV1 in many clinical trials is usually assessed after a washout period of several weeks, during which time patients are taken off all medications to assess the FEV1 in the absence of any treatment. It is common to obtain values at baseline and during the treatment period at regular intervals. The prebronchodilator FEV1 is measured during treatment, several hours after any daily medication that is being taken. The postbronchodilator FEV1 is measured right after taking a dose of bronchodilator administered during the testing session.

FEV1 is the most common lung function assessed in clinical trials of asthma treatment carried out in the United States. In most studies examining the benefits of asthma medication on control of asthma, baseline FEV1 is compared to prebronchodilator FEV1. In studies examining the effect of asthma medication on changes in long-term lung function, serial postbronchodilator FEV1 measurements provide the best measure of long-term changes in lung function. Serial FEV1 measurements over a relatively long time span are also a reasonable surrogate for lung growth in children as it correlates well with lung volumes, but is easier to measure (Childhood Asthma Management Program Research Group, 1999).

Bronchial hyperresponsiveness, a key element of the definition of asthma, can be directly assessed by inducing bronchial constriction with inhalations of methacholine or histamine aerosol solutions. Two common ways that the patient's bronchial hyperresponsiveness is measured are 1) the amount or concentration of solution needed to induce a 20 percent fall in FEV1 (i.e., PC 20) or 2), whether the patient has a 20 percent fall in FEV1 at a particular dose of solution. Changes in bronchial hyperresponsiveness between baseline and during treatment are thought to correlate with improvements in asthma control. However, the relationship between bronchial hyperresponsiveness and clinical asthma is complicated. Although hyperresponsiveness is modestly predictive of concurrent or future asthma, many studies show poor correlation between hyperresponsiveness and severity of asthma and adequacy of treatment.

Peak flow meters (PFMs) are used to measure the PEF. Peak flow meters are small portable devices much simpler to use than spirometers and can be used by patients at home to monitor asthma. However, there is no standardization of these devices, and values from different manufacturers' devices are not comparable. For research purposes, it is critical that a reference set of values be available to adequately assess changes over time as patients age and children grow. Over short periods of time, changes in PEF can be assessed simply as changes compared to baseline or to another prior value. Some studies rely on patients' self-report of daily or periodic PEFs as recorded at home at specific times.

### Symptoms

Several methods are used to assess symptoms in patients over time.

#### Symptom Diaries

Although studies vary as to the number of symptoms to be assessed and the number of units of the ordinal scale, the general format is for patients to report on a zero (representing no symptoms) to a maximum number (representing severe symptoms) scale for several asthma symptoms, including dyspnea, cough, and wheezing. These values are recorded every day for morning and evening periods. There appears to be no uniform or best method for integrating these different symptoms and their differing intensities and frequencies into an outcome measure which best assesses the totality of asthma control over a given period. For most studies, these data are reduced to any of a number of possible binary outcomes, such as percent symptom-free days, percent days with severe symptoms, or percent of subjects reporting a severe symptom over a time interval.

#### Use of Acute Bronchodilator Medication

If patients sense a worsening of asthma symptoms, they are usually instructed to use a short-acting beta-2 agonist to relieve symptoms and to potentially prevent a worse exacerbation. Increased use of a short-acting agent in the setting of long-term medication use may be an indicator of worsening control of asthma. Percent of days needing a short-acting beta-2 agonist or mean number of short-acting beta-2 agonist inhalations needed over a period of time are common ways to express this particular outcome.

#### Other Measures Indicating Severe Symptoms

If use of a short-acting beta-2 agonist fails to relieve acute symptoms, some clinical trial protocols call for a standard course of oral corticosteroids to be administered. This has been used as an outcome measure indicating an asthma exacerbation of certain minimal severity. Other measures reported in studies include days missed from school due to asthma symptoms, and withdrawal from the study itself. A common reason for withdrawing from a study is increase in asthma symptoms such that the patient cannot maintain the medication schedule in the assigned treatment arm.

For all these symptom-based outcome measures, it is critical to note that they rely on the accuracy of patients' self-report of symptoms or medication use. Both patients' and physicians' assessments of asthma symptoms correlate only modestly with objective measures of lung function. In addition, several measures rely on counting patients' responses to symptoms, which can be highly variable and depend on different exposures and activity levels as well as the patients' behavioral response to increased symptoms. Thus, these measures may have more variability than lung function outcomes and clinical studies must have sufficient sample size to detect differences in these types of measures.

### Health Care Utilization

Certain measures of health care utilization such as emergency room visits, unscheduled physician visits, and hospitalizations represent failures of long term and acute medical interventions and other maneuvers that patients can initiate themselves. These events are relatively rare, and thus most clinical trials of small or medium size are statistically underpowered to detect differences in these outcomes, particularly in trials among patients with mild-to-moderate asthma. However, in studies examining the role of asthma self-management programs, these measures provide one of the direct intended outcomes of these interventions.

## Medications

The different classes of medications used both in the short- ("quick-relief") and long-term control of asthma were reviewed in detail in the Expert Panel Report 2 (National Heart, Lung, and Blood Institute, 1997). The following is a brief summary of the pharmacology, mechanisms of action, and adverse effects of the drugs most commonly used for long-term management of chronic asthma, as well as an update of information available since the Expert Panel Report 2. Table 1 shows the different long-term control agents both available commercially in the U.S. and those pending approval or available internationally, routes of administration, and usual dosages. Long-term control asthma medications are taken daily on a long-term basis to achieve and maintain control of persistent asthma; these medications may also be called "long-term preventive," "controller," or "maintenance" medications (National Heart, Lung, and Blood Institute, 1997). Generally, these agents act to decrease pulmonary inflammation and bronchoconstriction (Anonymous, 2000).

Table 1. Long-term control agents for asthma management

Different agents | Routes of administration | Usual dosages/Age recommendations | Comments
Long-acting Beta-2 adrenergic agonists
salmeterol xinafoate | aerosol for inhalation | patients 12 years of age and older: 2 inhalations (42 mcg) twice daily, approximately 12 hours apart
albuterol ^a^ | long-acting tablets | patients 6-11 years of age: 4 mg every 12 hours patients 12 years of age and older: 12 mg every 12 hours (maximum recommended dosage) | - other dosage formulations of albuterol (e.g., syrup, standard tablets) are not long-acting formulations
formoterol ^b^ | ** | ** | **
Corticosteroids (Inhaled) | | | - Some ICS may be administered once daily
beclomethasone dipropionate | aerosol for inhalation | patients 6-12 years of age: 42-84 mcg 3 or 4 times daily patients 12 years of age and older: 84 mcg 3 or 4 times daily | - The recommended number of puffs of HFA beclomethasone product (Qvar^®^) is approximately half that of CFC (chlorofluorocarbon) beclomethasone products.
budesonide | powder for inhalation suspension for nebulization | children: 200 mcg twice daily (powder) or 0.25-2 mg (suspension) adults: 200-800 mcg twice daily (powder) or 0.5-4 mg daily (suspension) | - starting dosage depends on severity of asthma and concomitant therapy
flunisolide | aerosol for inhalation | patients 6-15 years of age: 500 mcg twice daily patients 15 years of age and older: 500 mcg twice daily
fluticasone propionate | aerosol/powder for inhalation | patients 4-11 years of age: 50-100 mcg twice daily (powder) patients 12 years of age and older: 88 mcg-880 mcg twice daily (aerosol) or 100-1,000 mcg twice daily (powder) | - starting dosage depends on presence and type of concomitant therapy
triamcinolone acetonide | aerosol for inhalation | patients 6-12 years of age: 100-200 mcg 3 to 4 times daily or 300-400 mcg twice daily patients 12 years of age and older: 200 mcg 3 to 4 times daily or 400 mcg twice daily
Leukotriene modifiers
montelukast sodium | tablets, chewable tablets | patients 2-5 years of age: 4-mg chewable tablet taken at night patients 6-14 years of age: 5-mg chewable tablet taken at night patients 15 years of age and older: 10 mg taken at night | - Can be taken without regard to meals
pranlukast ^b^ | ** | ** | **
zafirlukast | Tablets | patients 12 years of age or older: 20 mg twice daily patients 7-11 years of age: 10 mg twice daily | - Food decreases zafirlukast bioavailability; patients should take 1-2 hours prior to a meal.; - Drug interactions with theophylline
zileuton | Tablets | patients 12 years of age and older: 600 mg four times daily | - For ease of administration, the drug may be given with the three main daily meals and at bedtime
Mast-cell stabilizers
cromolyn sodium | Aerosol/nebulization solution/capsules (powder) for inhalation | patients 2 years of age and older: 20 mg 4 times daily (nebulization) patients 5 years of age and older: 2 mg 4 times daily (aerosol) | - optimal clinical effect may be delayed
nedocromil sodium | Aerosol for inhalation | patients 6 years of age and older: 3.5 mg 4 times daily | - optimal clinical effect may be delayed
Other agents
theophylline | regular- and delayed-release capsules and tablets; sprinkles; solutions | variable; based on dosage form | - tolerance to the caffeine-like adverse effects generally develops with chronic therapy; - affects the kinetics of and is affected by other cytochrome P450-metabolized drugs

a also available in short-acting formulations

b not commercially available in the United States

According to the Expert Panel Report 2, the most effective agents available for long-term control of asthma are those agents that attenuate airway inflammation (National Heart, Lung, and Blood Institute, 1997). The Expert Panel defined anti-inflammatory medications as "those that cause a reduction in markers of airway inflammation in airway tissues or in airway secretions (e.g., eosinophils, mast cells, activated lymphocytes, macrophages and cytokines; or eosinophilic cationic protein and tryptase; or extravsascular leakage of albumin, fibrinogen or other vascular protein) and thus decrease the intensity of airway hyperresponsiveness" (National Heart, Lung, and Blood Institute, 1997).

Because airway inflammation is multifactorial, involving several cell types and multiple cytokines and soluble mediators, the drugs used to decrease inflammation may act at several different steps in the inflammatory process (National Heart, Lung, and Blood Institute, 1997). At the time the Expert Panel Report 2 was written, the anti-inflammatory actions "responsible for therapeutic effects, such as reduction in symptoms, improvement in expiratory flow, reduction in airway hyperresponsiveness, prevention of exacerbations, or prevention of airway wall remodeling," had not yet been established (National Heart, Lung, and Blood Institute, 1997).

### Beta-2 Adrenergic Agonists

#### Description/Pharmacology

As described in the Expert Panel Report 2 (National Heart, Lung, and Blood Institute, 1997), the principal action of beta-2 adrenergic agonists is to relax airway smooth muscle via stimulation of beta-2 adrenergic receptors, increasing production of cyclic adenosine monophosphate (AMP) (GlaxoWelcome, Inc., 2000). Although "short-acting" beta-2 agonists (e.g., terbutaline, pirbuterol, albuterol for inhalation) are used to treat bronchospasm in asthma, the intention of "long-acting" beta-2 agonist therapy is as an adjunct to inhaled corticosteroid (ICS) therapy, providing long-term control of symptoms, especially nocturnal symptoms (Yates, Sussman, Shaw et al., 1995) and bronchospasm caused by exercise.

Long-acting beta-2 adrenergic agonists can be oral or inhaled, and have a duration of action of up to 12 hours or more after a single dose (Becker and Simons, 1989; D'Alonzo, Nathan, Henochowicz et al., 1994). While the long-acting properties of oral albuterol are related to the delayed-release properties of its formulation, the long-acting properties of salmeterol are based on its high-affinity binding with the beta-2 adrenoreceptor (Adkins and McTavish, 1997). According to the Expert Panel Report 2 long-acting beta-2 adrenergic agonists should not be used in the management of acute exacerbations of asthma, nor should they be used in place of anti-inflammatory therapy (National Heart, Lung, and Blood Institute, 1997; GlaxoWelcome, Inc., 2000). However, concomitant use of long-acting beta-2 agonist therapy may allow the inhaled corticosteroid dosage to be decreased and addition of long-acting beta-2 agonist therapy to ICS appears to have a more beneficial effect than simply increasing the dosage of ICS (National Heart, Lung, and Blood Institute, 1997).

A combination product containing salmeterol plus fluticasone (Advair^®^ Diskus) was approved in 2000 (Glaxo Wellcome, 2000) and formoterol fumarate (Foradil^®^) was deemed "approvable" by the U.S. Food and Drug Administration (FDA) on May 24, 2000.

#### Adverse Effects

The most common adverse effects of these drugs are related to their pharmacologic action in stimulating the beta adrenergic receptors; however, the selectivity of these agents for the beta-2 subtype adrenoreceptor makes them less likely than nonspecific beta adrenergic agents to have systemic, largely cardiac, effects (Anonymous, 2000). Adverse effects such as tremor, palpitations, tachycardia, and paradoxical bronchospasm have been reported (Adkins and McTavish, 1997; Anonymous 2000; GlaxoWelcome, Inc., 2000). There is no evidence to suggest any differences in the adverse event profiles of the long-acting beta-2 agonists (Bartow and Brogden, 1998; Brogden and Faulds, 1991; Nelson, 1995; Svedmyr and Lofdahl, 1996).

An association between overuse of inhaled beta-2 agonists and increased mortality has been observed; however, this may reflect a worsening of disease rather than an actual drug effect (Anonymous 2000). A diminished bronchoprotective effect against various challenges (e.g., exercise, methacholine) may be observed within 1 week of initiating chronic beta-adrenergic therapy (National Heart, Lung, and Blood Institute, 1997); however, the clinical effect of this diminishment is uncertain (National Heart, Lung, and Blood Institute, 1997). Although some evidence suggests that tolerance to the bronchodilator effects of salmeterol does not occur (National Heart, Lung, and Blood Institute, 1997), other evidence does suggest that tolerance to the bronchoprotective effects of salmeterol on exercise-induced bronchoconstriction does occur (Ramage, Cree, and Dhillon, 1994; Villaran, O'Neill, Helbling et al., 1999).

Postmarketing experience with salmeterol has shown that serious exacerbations of asthma, some of which were fatal, have occurred during salmeterol therapy; however, a causal relationship to the drug has not been established (GlaxoWelcome, Inc., 2000). Other adverse events reported in the postmarketing experience include rare reports of upper airway laryngeal spasm, irritation or swelling (e.g., stridor or choking), and hypertension or arrhythmias (e.g., supraventricular tachycardia, extrasystoles) (GlaxoWelcome, Inc., 2000); again, a causal relationship to the drug has not been established (GlaxoWelcome, Inc., 2000).

### Corticosteroids (Oral and Inhaled)

#### Description/Pharmacology

According to the Expert Panel Report 2, "[c]orticosteroids are the most potent and consistently effective long-term-control medication for asthma" (National Heart, Lung, and Blood Institute, 1997). Corticosteroids act to decrease and prevent bronchial inflammation and airway hyperreactivity (National Heart, Lung, and Blood Institute, 1997); possibly via direct inhibition of the cellular mediators of airway inflammation (including macrophages, T-lymphocytes, eosinophils, and airway epithelial cells) (Barnes, 1995). As noted in the Expert Panel Report 2, corticosteroids are used systemically (i.e., orally) in the acute management of asthma in order to gain prompt control of the disease when instituting long-term therapy (National Heart, Lung, and Blood Institute, 1997). ICS are used in the long-term management of the disease and are not generally used for use in acute disease exacerbations (National Heart, Lung, and Blood Institute, 1997), although more recent data suggest a role for these agents in the acute setting (Rodrigo and Rodrigo, 1999). Evidence suggests that due to differences in both molar potency and delivery systems, the ICS are not equipotent on a microgram basis (Kelly, 1998). In addition, some evidence indicates that newer ICS such as fluticasone and budesonide may be relatively more effective than older agents such beclomethasone or triamcinolone (Pauwels, Yernault, Demedts et al., 1998; Condemi, Chervinsky, Goldstein et al., 1997).

In September 2000, the FDA approved a nonchlorofluorocarbon propellant (hydrofluoroalkane, HFA) inhaled corticosteroid product (QVAR^®^, beclomethasone dipropionate extra-fine inhalation aerosol) (Burgt, Busse, Martin et al., 2000; 3M Company, 2000).

#### Adverse Effects

There is a wide spectrum of adverse effects related to oral corticosteroid use, that varies according to the dose of drug being administered and the length of treatment (e.g., short-term versus long-term) (Lipworth, 1999). As noted in the Expert Panel Report 2, corticosteroids can suppress the endogenous HPA axis, making patients more susceptible to infection and decreasing rates of wound healing, especially at higher systemic drug concentrations (National Heart, Lung, and Blood Institute, 1997). Other metabolic changes that can occur with orally administered corticosteroids include decreased bone mineral density, osteoporosis, changes in glucose metabolism, and sodium and water retention (National Heart, Lung, and Blood Institute, 1997). Peptic ulcer, mood changes, ocular effects such as the development of glaucoma or cataract, or decreased growth velocity in children also can occur (National Heart, Lung, and Blood Institute, 1997).

The most common local adverse effects of ICS are cough, oral candidiasis, or dysphonia (Barnes, 1995; National Heart, Lung, and Blood Institute, 1997). Systemic effects of inhaled agents such as decreased growth and effect on bone metabolism are important considerations especially in the treatment of children with these agents (National Heart, Lung, and Blood Institute, 1997); however, the role of ICS in the development of systemic adverse effects has been the subject of much debate (Barnes, 1995; U.S. Food and Drug Administration Center for Drug Evaluation and Research, 1998).

### Leukotriene Modifiers

#### Description/Pharmacology

Endogenous leukotrienes, produced by cells such as eosinophils, neutrophils, macrophages, and mast cells, are implicated in the pathogenesis of asthma, most specifically, the cysteinyl leukotrienes C4, D4, and E4 (Adkins and Brogden, 1998; Drazen, Israel, and O'Byrne, 1999; Garcia-Marcos and Schuster, 1999; Markham and Faulds, 1998a). The leukotriene-modifier class of asthma agents either inhibits the synthesis/production of leukotrienes via inhibition of the enzyme 5-lipooxygenase (i.e., leukotriene inhibitors such as zileuton) or the selective, competitive inhibition of leukotrienes (specifically D4 and E4) with their target receptors (i.e., leukotriene receptor antagonists such as zafirlukast, montelukast sodium, and pranlukast) (Abbott, 1998; Adkins and Brogden, 1998; Drazen, Israel, and O'Byrne, 1999; Markham and Faulds, 1998a; Merck & Co., 2000; National Heart, Lung, and Blood Institute, 1997; Zeneca, 2000). At the time that the Expert Panel Report 2 was published, the only agents marketed in the United States were zafirlukast and zileuton (National Heart, Lung, and Blood Institute, 1997); currently, pranlukast is available only in Japan (Drazen, Israel, and O'Byrne, 1999).

#### Adverse Effects

Since the publication of the Expert Panel Report in 1997, there have been postmarketing reports of patients who have developed clinical features of vasculitis consistent with Churg-Strauss syndrome, a systemic eosinophilic vasculitis, while receiving concomitant leukotriene modifier (montelukast sodium, zafirlukast) and often corticosteroid therapy when the corticosteroid dosage is decreased/tapered (Adkins and Brogden, 1998; Anonymous, 2000; AstraZeneca, 1997; Merck & Co., Inc. 1998, 2000; Zeneca, 2000). A causal relationship to the leukotriene modifier therapy has not been established; it has been hypothesized that development of the syndrome may be related to the withdrawal of the corticosteroid therapy (Wechsler, Finn, Gunawardena et al., 2000; Wechsler, Pauwels, and Drazen, 1999; Wechsler and Drazen, 1999; Zeneca, 2000); however, development of the syndrome also has been reported in patients not receiving concomitant corticosteroids (Zeneca, 2000). The syndrome is characterized by eosinophilia, vasculitic rash, worsening pulmonary symptoms, cardiac complications, and/or neuropathy. The syndrome can be treated by reinstitution of corticosteroid therapy or initiation of cyclophosphamide therapy; however, it can be fatal if left untreated.

Both zileuton and zafirlukast can cause adverse hepatic effects (e.g., increased liver enzymes, hepatitis) (Abbott, 1998; Zeneca, 2000) and there have been rare postmarketing reports of hepatic failure in patients receiving zafirlukast (Reinus, Persky, Burkiewicz et al., 2000; Zeneca, 2000). In addition, product information for zileuton recommends that patients undergo monitoring of liver enzymes both at the initiation of and periodically during therapy (Abbott, 1998). Although both drugs should be discontinued temporarily in patients who develop signs or symptoms of liver dysfunction (Abbott, 1998; Zeneca, 2000), if laboratory tests confirm hepatotoxicity in patients receiving zafirlukast, the drug must be discontinued (Adkins and Brogden, 1998; Markham and Faulds, 1998a; Zeneca, 2000). Additional adverse events reported during the postmarketing period with zileuton include rash and urticaria (Abbott, 1998).

Zileuton and zafirlukast are metabolized by the cytochrome P450 liver isoenzyme system and can interfere with hepatic metabolism of other drugs (e.g., theophylline, erythromycin, warfarin) (Abbott, 1998; Adkins and Brogden, 1998; Anonymous, 2000; Zeneca, 2000).

The most common adverse effects associated with leukotriene modifier therapy include headache, nausea, infection/cough, and diarrhea (Adkins and Brogden, 1998; Zeneca, 2000; Merck & Co., Inc., 2000).

### Mast-Cell Stabilizing Agents

#### Description/Pharmacology

These agents stabilize mast cell membranes and modulate activation and release of inflammatory cell mediators and inhibit the recruitment and chemotaxis of eosinophils and other inflammatory cells, interfering with both the early and late reaction to allergens (Brogden and Sorkin, 1993; National Heart, Lung, and Blood Institute, 1997). These agents also have been shown to decrease airway hyperresponsiveness acutely (Brogden and Sorkin, 1993).

#### Adverse Effects

In the Expert Panel Report 2, it was noted that "Safety is the primary advantage of these agents."Since the publication of the Expert Report 2, there has been no postmarketing notification of unusual or serious adverse events associated with the use of these agents. In clinical trials of nedocromil, adverse event rates were similar in patients receiving drug or placebo (Brogden and Sorkin, 1993). The most commonly reported adverse effects include unpleasant taste (particularly with nedocromil) (National Heart, Lung, and Blood Institute, 1997).

### Theophylline

#### Description/Pharmacology

Theophylline is a bronchodilator agent, related structurally to caffeine, and is principally used as adjuvant therapy in asthma management (National Heart, Lung, and Blood Institute, 1997). The drug directly relaxes smooth muscle in the bronchial airways and in the pulmonary blood vessels; additionally, it has been shown to have immunomodulatory, anti-inflammatory, and bronchoprotective effects (Markham and Faulds, 1998b; Weinberger and Hendeles, 1996). Theophylline appears to be particularly effective in decreasing nocturnal asthma symptoms (National Heart, Lung, and Blood Institute, 1997) and in low doses, has the potential for allowing for a decrease in the corticosteroid dose, when administered as concomitant therapy with ICS (Markham and Faulds, 1998b).

Theophylline has a relatively narrow therapeutic index and requires routine monitoring to ensure that the serum concentration is maintained at 5-15 mcg/mL (National Heart, Lung, and Blood Institute, 1997; Weinberger and Hendeles, 1996); the rate of toxicity increases when the serum concentrations are greater than 20 mcg/mL (Weinberger and Hendeles, 1996). Theophylline also affects the hepatic clearance of other drugs and its own clearance can be affected by other drugs cleared by the cytochrome P450 system and by smoking.

#### Adverse Effects

The most frequently observed adverse effects of theophylline are generally related to its structural similarity to caffeine and other methylxanthines (Weinberger and Hendeles, 1996). Therefore, headache, irritability, nausea/vomiting, tachycardia, and tachypnea occur commonly (National Heart, Lung, and Blood Institute, 1997). Adverse effects of theophylline are dose-related; serious adverse effects associated with high blood levels of the drug include seizures, cardiac arrhythmias, hematemesis, and metabolic abnormalities (National Heart, Lung, and Blood Institute, 1997).

## Rationale and Background for Key Questions

The following section will briefly review the rationale for each specific key question, and where necessary, provide additional background material necessary for interpreting the evidence for that particular question.

Question 1a: Does chronic use of ICS improve long-term outcomes for children with mild-to-moderate asthma?

The NHLBI guidelines recommend that no daily medication is needed for mild intermittent asthma, and that ICS are one of the recommended choices for mild persistent asthma. Given the potentially higher risk of adverse side effects of ICS than other medications, an important question is whether ICS are necessary for mild asthmatics if they can achieve adequate control on other medication regimens. The concern over the long-term benefits and risks of chronic medication is heightened when treatment begins in childhood.

A difficult issue in this question is the classification of mild asthmatics, which varies between studies. Because ICS improve asthma control among more severe asthmatics, if a study has enrolled more severe asthma patients, then the study will tend to show greater effectiveness of ICS. Conversely, mild asthmatics have fewer symptoms and better lung function at baseline, so that the amount of improvement in such patients will be small and more difficult to detect in small trials.

Question 1b: What are the long-term adverse effects of chronic ICS use in children on vertical growth, bone mineral density (BMD), ocular toxicity, and suppression of adrenal/pituitary axis?

Concern over use of ICS is due to well-known and documented effects of oral corticosteroids on growth, BMD, ocular toxicity (glaucoma and cataracts), and adrenal/pituitary suppression (Cave, Arlett, and Lee, 1999). Although ICS have other minor adverse effects, this evidence report only sought data on these most serious potential adverse effects in children.

An important general methodologic issue in determining whether ICS cause adverse effects is the effect of asthma and/or asthma control on physiology and development. For example, asthma may delay puberty and suppress growth, but better or worse asthma control may also affect puberty and growth. Appropriate comparison groups and statistical approaches are necessary to evaluate the adverse effects of treatment but also to evaluate the effects of disease progression. A second issue is that use of intermittent oral corticosteroids may also confound an apparent association between ICS and certain adverse effects. Again, appropriate comparison groups, assessment of oral corticosteroid use, and appropriate statistical adjustment are necessary.

A final, most important issue is the methodologies for establishing adverse effects themselves. Most randomized clinical trials are not designed to specifically address adverse effects, and thus may be statistically underpowered to detect them. Biases in the way subjects are recruited for clinical trials may also affect generalizability of findings. Clinical trials are rarely conducted long enough for adverse effects associated with long standing corticosteroid use to manifest themselves. Thus observational studies are necessary to address these issues, but such studies may be subject to bias and confounding and provide less definitive conclusions.

### Growth

There are several methods to assess growth over varying intervals of time, but each method has problems in relation to evaluating the potential effect of ICS. Over the very short term (i.e., less than 100 days), lower leg growth can be assessed using knemometry. However, knemometry does not correlate well with linear growth rate. Over periods of 6 months or more, height measured with stadiometry can provide a sufficiently precise measure called growth velocity. Finally, measurement of final adult height could be considered a gold standard -- however, other factors which may influence final adult height, especially height of parents, needs to be considered. Most studies of adult attained height use the height of both parents plus a correction factor for gender to calculate the predicted adult height. All studies that have used final adult height as an outcome are observational, and thus may have problems such as high loss to follow up, confounding by severity of asthma, and unmeasured oral corticosteroid use.

The most rigorous evidence on the effect of ICS on growth velocity comes from randomized clinical trials that used sufficiently precise growth measurement techniques and followed patients for sufficiently long periods of time (i.e., at least 1 year). A meta-analysis of such randomized clinical trials was recently published by Sharek and Bergman (2000) and will be reviewed in this evidence report in lieu of an original review of these data.

It should be noted that another meta-analysis by Allen, Mullen, and Mullen (1994) is commonly cited as evidence that attainment of expected adult height is not affected by ICS (National Heart, Blood, and Lung Institute, 1997). Examination of this analysis reveals that it does not assess adult height in most of the included studies, but measures attained height as compared to predicted height for a given age, mostly different childhood ages.

### Bone Mineral Density

There are many potential laboratory measurements that could be used to assess different aspects of bone metabolism, but BMD would appear to be the best, because it can be quickly and reliably measured and is a very strong risk factor for the ultimate outcome of interest, fractures.

The problems of studying a potential adverse effect of ICS on BMD are very similar to those of studying the effect of ICS on growth. The duration of therapy and the interval for assessing BMD in clinical trials is usually very short. Evaluation of BMD in this setting results in differences in BMD that might be attributed to ICS, but may not be clinically relevant. Finally, physical activity might be affected by improved asthma treatment, which in turn has an effect on long-term changes in BMD.

Additionally complicating the matter is that BMD is constantly changing throughout life, increasing over time until early adulthood and then gradually declining, with accelerating decline in older ages. The effect of ICS on BMD may be different when the body is building up BMD at younger ages versus when BMD is generally declining at older ages. A subtle effect on BMD would not become clinically relevant until it was additive to other risk factors, such as age. Any effect possibly attributable to childhood use of ICS might be confounded by continued use of ICS into adulthood.

### Ocular Toxicity

Oral corticosteroids are known to be associated with subcapsular cataracts. In children with chronic diseases taking high doses of oral corticosteroids, the prevalence of subcapsular cataracts has been noted to be between 21 and 38 percent (Tripathi, Kipp, Tripathi et al., 1992; Limaye, Pillai, and Tina, 1988). ICS could conceivably also cause cataracts either by systemic absorption or by direct contact during inhalation that might occur due to incorrect use of metered dose inhalers.

Prior research has suggested an association between ICS and cataracts among adults (Garbe, Suissa, and LeLorier, 1998, Cumming, Mitchell, and Leeder, 1997). In both studies, most cataracts occurred among the much older subjects, who could not have taken ICS as children because the drugs did not yet exist.

Thus, the question of the effect of childhood use of ICS on cataracts must necessarily be limited to effects on cataracts that occur during childhood up to early adulthood. Since the incidence of childhood cataracts is extremely low, and the expected effect of ICS is expected to be much lower than for oral corticosteroids, studies must be carefully evaluated for sufficient statistical power to study this outcome.

Ocular hypertension or glaucoma is another recognized adverse effect of topical ophthalmic corticosteroids. It occurs in 1 to 2 percent of persons above age 60. The condition in its early stages is asymptomatic and detected only by measuring intraocular pressure. An effect of sufficient size of ICS on intraocular pressure could be assessed in randomized clinical trials, because intraocular pressure can be easily and precisely measured as an additional outcome. However, if the effect is small or rare, then it would only be detectable in observational studies with sufficient statistical power such as a large case-control or cross-section study.

Two studies in older adults indicate a possible association between ICS and glaucoma (Garbe, LeLorier, Boivin et al., 1997; Mitchell, Cumming, and Mackey, 1999). These studies on adults may or may not be generalizable to children, because the baseline risk of glaucoma is very low in children.

### Suppression of Adrenal/Pituitary Axis

Corticosteroids can cause hypothalamic-pituitary-adrenal (HPA)-axis suppression by reducing adrenocorticotropin (ACTH) production, via negative feedback, which in turn leads to a reduced cortisol secretion by the adrenal gland (Cave, Arlett, and Lee, 1999). Following prolonged systemic therapy, atrophy of the adrenal gland may result, resulting in subnormal response of the adrenal gland to ACTH stimulation. If severe enough, clinical symptoms can result when patients undergo stress or when corticosteroid doses are reduced.

There are three related but different phenomena that are potentially caused by ICS, that may occur independently or together, and in different degrees. Patients can show evidence of hypercortisolism or iatrogenic Cushing's, in which systemic absorption of the inhaled corticosteroid causes clinical symptoms associated with high cortisol levels, the excess being caused by the inhaled corticosteroid. Second, patients can show laboratory evidence of low cortisol levels, measured in various ways, due to the suppression of ACTH by systemic absorption of inhaled corticosteroid. Third, patients can show laboratory evidence of a subnormal response to ACTH stimulation, in that cortisol levels will not rise as high as they would normally.

Further complicating this area is the variety of tests that can be used to detect low cortisol or subnormal stimulation and the methods of analyzing the data. Cortisol can be measured by a single plasma level, multiple plasma levels over a day, or by measuring urinary cortisol over a day. Because "normal" values vary widely for all these tests, using the occurrence of abnormal values for analysis is an insensitive measure of function. Measuring change from baseline between groups is more sensitive, but then the clinical significance of any statistically significant difference is uncertain. The same problems hold for the stimulation tests. Varying the dose of the agent used to stimulate the adrenal gland can vary the sensitivity of the test, and different methods of analyzing the data can detect statistically significant differences of uncertain clinical significance.

Thus it is difficult to determine the clinical significance of any abnormal cortisol level or stimulation test without knowledge of clinical correlates of these abnormalities. The clinical presentation of iatrogenic Cushing's may or may not be accompanied by abnormal cortisol levels or abnormal stimulation tests.

Question 2: For patients with mild-moderate asthma, does early initiation of long-term controller therapy prevent progression of asthma?

Although the effectiveness of ICS in controlling symptoms of asthma and improving pulmonary function is unquestioned, an important question is whether ICS may modify the natural history of the disease. If the causal chain of events for some asthmatic patients is from inflammation to airway remodeling to irreversible airway obstruction, then anti-inflammatory medications may be able to prevent permanent declines in lung function. However, the question is whether there is evidence of a long-term benefit in terms of minimizing loss of lung function over time.

Except for the recently published Childhood Asthma Management Program (CAMP; Childhood Asthma Management Program Research Group, 2000a) study, none of the current studies cited to support this hypothesis were designed specifically to test this hypothesis. The logistics of carrying out clinical trials over sufficiently long periods of time to detect differences in asthma progression are extremely difficult. For observational cohort studies, assessments of asthma would be necessary at equivalent points in the patients' course of disease in order to adequately adjust for severity of asthma. Finally, appropriate measurements that assess changes in lung function or severity of asthma need to be obtained, versus measurements that merely assess the improvement in lung function noted when patients are initially started on ICS therapy.

Question 3: In patients with moderate asthma who are receiving ICS, does adding another long-term control agent improve outcomes?

Although ICS are recommended for patients with moderate and severe asthma, the desire to minimize corticosteroid dosage has led to consideration of use of combinations of drugs to treat these patients. Several classes of drugs can potentially be used in combination with ICS, including leukotriene antagonists, long-acting beta-2 agonists, and theophylline preparations. Patients who are successfully controlled with ICS alone may have equally effective control with a lower dose of ICS in combination with another medication.

Alternatively, patients who are inadequately controlled on a certain dose of ICS may achieve good control with the addition of another medication, rather than increasing the dose of corticosteroid. A limitation of the available literature is that studies of patients inadequately controlled on ICS did not demonstrate that patients prior to entering the study were taking the ICS consistently. Numerous studies have documented that adherence to ICS averages around 50 percent of doses prescribed (Kelloway, Wyatt, and Adlis, 1994; Sherman, Hutson, Baumstein et al., 2000) Nonetheless, ICS may not be uniformly effective in all patients; and among patients who are adherent and not well controlled on ICS, addition of other agents may increase symptom control and further reduce inflammation.

Question 4: Does addition of antibiotics to standard care improve the outcomes of treatment for acute exacerbation of asthma?

As stated in the NHLBI guidelines, antibiotics are not recommended for treatment of asthma exacerbations, but may be necessary for comorbid conditions (National Heart, Lung, and Blood Institute, 1997). According to the guidelines, bacterial respiratory tract infections are thought to contribute only infrequently to exacerbations of asthma, and antibiotics should be reserved for those patients with evidence of pneumonia, fever and purulent sputum, or evidence of bacterial sinusitis.

Although there is scant recent literature reporting the prevalence of use of antibiotics for asthma exacerbations, recent surveys of physicians seem to indicate that antibiotics may be overused in their management. A survey by Connolly, Murthy, Prescott et al. (1991) of Scottish physicians revealed that 43 to 83 percent of survey respondents believed that the risk of bacterial infection in asthma exacerbations was greater than 20 percent. The majority of respondents felt they frequently prescribed antibiotics for treatment of asthma. In a cross-national survey of physician practice, Lagerlov, Veninga, Muskova et al. (2000) report data that indicates that large proportions of physicians believe that asthma exacerbations are commonly associated with bacterial infection.

The role of bacterial infections in asthma etiology, severity, and exacerbation is currently not completely understood. Theories of bacterial involvement in asthma may be roughly differentiated by whether bacterial infections are a cause of asthma or a trigger for asthma exacerbations. According to some theories, infections such as chronic sinusitis and chlamydial infection may cause asthma and/or contribute to its severity (Cypcar, Stark, and Lemanske Jr., 1992). This aspect of bacterial infections and asthma will not be specifically addressed as part of this evidence report.

Others have investigated the role of bacterial infections not as causative agents of asthma, but as triggers for exacerbations among those with established asthma. This small body of research compares the frequency of bacterial and viral infections in acute exacerbations of asthma (MacIntosh, Ellis, Hoffman et al., 1973; Hudgel 1979; Nicholson, Kent, and Ireland, 1993; Johnston, Pattemore, Sanderson et al., 1996). These studies have reported that viral infection can be documented in up to half or more of acute asthma exacerbations, although some of these studies (Johnston, Pattemore, Sanderson et al., 1996; Nicholson, Kent, and Ireland, 1993) have included Chlamydia as a viral infection. Bacterial infections are less commonly associated with acute exacerbations as compared to viral infections in these studies, especially in children (Johnston, Pattemore, Sanderson et al., 1996). However, these studies do not rule out the possibility that a substantial proportion of asthma exacerbations are triggered by bacterial infections.

Even if bacterial infections, however defined, were demonstrated to be a trigger for asthma exacerbation in some cases, whether a routine diagnostic workup for bacterial infection should be done for all exacerbations has not been determined. It is unknown whether certain clinical criteria such as purulent or discolored sputum should be considered as presumptive evidence of bacterial infection, or whether additional diagnostic tests (e.g., cultures, gram stains) should be used to detect the presence of bacterial infection to direct antibiotic treatment.

Question 5a: Compared to medical management alone, does the use of a written asthma action plan improve outcomes, and Question 5b: Compared to a written action plan based on symptoms, does use of a written action plan based on peak flow monitoring improve outcomes?

The goal of self-management in asthma is to reduce morbidity through early recognition of signs and symptoms indicative of worsening of disease, and appropriate modification of asthma treatment to prevent and/or reverse deterioration in respiratory status. Self-management interventions have been widely promoted by health plans and specialty societies with the expectation that they will improve care. The 1997 NHLBI guidelines on treatment of asthma emphasize self-management activities as a crucial component of asthma care (National Heart, Lung, and Blood Institute, 1997). Within these recommendations, self-management programs can vary considerably. For example, among educational interventions, there is wide variability in the objectives of the programs, the duration and number of sessions, who delivers the educational sessions, the setting in which education is delivered, and the tools that are used for training (Sudre, Jacquemet, Uldry et al., 1999).

A relatively large body of literature has accumulated focusing on primarily the effect of asthma education interventions. Several literature syntheses of primary studies (Devine, 1996; Bernard-Bonnin, Stachenko, Bonin et al., 1995; Gibson, Coughlan, Wilson et al., 2000a) have been performed. These reviews have revealed mixed results. The Devine (1996) meta-analysis of 31 studies showed beneficial effects of such programs on a variety of outcomes, such as frequency of asthma attacks, PEF, functional status, adherence, use of as-needed medication, and utilization of medical services. The analysis by Bernard-Bonnin, Stachenko, Bonin et al. (1995), evaluating 23 randomized controlled trials on asthma self-management teaching programs showed little effect on the outcomes of asthma attacks, hospitalizations, emergency room (ER) visits, or school absenteeism. The analysis by Gibson, Coughlan, Wilson et al., (2000a) reviewed 11 such studies and found no effect for these limited education programs on hospitalizations, doctor visits, lung function, or medication use.

From this body of research, it is not possible to determine the impact of education alone on outcomes, nor is it possible to determine whether the impact depends on the type of educational program delivered, the type of recipient, or other specific factors. However, it is likely that educational interventions alone do not produce a large and consistent improvement in outcomes for the general population of asthmatics.

Other research studies have focused on the effect of interventions which include additional self-management activities in addition to education. This body of research shows a more consistent positive effect of self-management interventions on outcomes. A Cochrane collaboration systematic review of the effects of regular practitioner review and self-management education was completed by Gibson, Coughlan, Wilson et al. (2000b). A total of 24 controlled clinical trials were evaluated, and such programs were associated with a reduced rate of hospitalization (Odds Ratio [OR] 0.58, 95 percent Confidence Interval [CI] 0.38-0.88) and ER visits (OR 0.71, 95 percent CI 0.57-0.90).

Due to the multidimensional nature of asthma self-management interventions, it is not clear which specific components may contribute to improved outcomes. This evidence review will focus on two components, PFMs and written action plans, and whether they contribute to improved outcomes.

Peak flow meters are most commonly used in conjunction with a written action plan, indicating peak flow levels at which changes in medications and/or other interventions are triggered. Related to this, written action plans can be constructed such that triggers for change in management are either based on peak flow readings or on symptoms. Previous studies that have attempted to evaluate the utility of PFMs have not consistently demonstrated improvements in association with PFM use (Partridge, 1994; Ruffin and Pierce, 1994; Chee, 1998; National Heart, Lung, and Blood Institute, 1997). Furthermore, compliance with PFM use may be problematic. In a study of inner city asthmatics (Redline, Wright, Kattan et al., 1996), by the third week of PFM use in their study, readings were not being correctly recorded on more than 50 percent of days.

In attempting to determine the impact of specific components of multimodal disease management interventions, several challenges are present. First, isolating the specific effect of each component, such as PFM use, from the effect of other interventional components is difficult as disease management interventions are intended to be multifactorial. Second, relative to other interventions, such as optimization of medication regimens, the effect of self-management interventions is likely to be relatively small, particularly on outcomes such as lung function or symptom control. Therefore, trials of self-management interventions are prone to being underpowered, unless the researchers perform careful power calculations that include an accurate determination of the base rate for the outcomes and the expected impact of the intervention.