# Appendix C. Acronyms and Abbreviations

Refer to Table

AAFP | American Academy of Family Physicians
AAP | American Academy of Pediatrics
abs. | absolute
abx | antibiotics
ACTH | adrenocorticotropic hormone
AHRQ | Agency for Healthcare Research and Quality
a.m. | morning
AQLQ | Asthma Quality of Life Questionnaire
avg. | average
BDP | beclomethasone dipropionate
BMD | bone mineral density
BMI | body mass index
BUD | budesonide
CAMP | Childhood Asthma Management Program
CI | confidence interval
cm | centimeter
COPD | chronic obstructive pulmonary disease
ctl | control arm
DD | doubling dose
DEL | delayed
dept. | department
elig | eligibility/eligible
equiv | equivalent
ER | emergency room
eval | evaluable
exp | experimental arm
fig | figure
FEV1 | forced expiratory volume in one second
FP | fluticasone propionate
freq. | frequency
f/u | followup
gov't | government
GP | general practitioner
GRASSIC | Grampian Asthma Study of Integrated Care
hosp | hospital
HPA | hypothalamic-pituitary axis
hx | history
ICS | inhaled corticosteroid
IMM | immediate
IV | intravenous
L | liter(s)
meds | medications
mcg | micrograms
mcmol | micromoles
mgt. | management
min | minute
mo. | month(s)
mod | moderate
mth(s) | month(s)
mg | milligrams
NA | not available
NHLBI | National Heart, Lung, and Blood Institute
NR | not reported
NS | not significant
outpt. | outpatient
PC20 | "provocative concentration" of bronchoconstrictor that induces a 20% drop in FEV1
PEF | peak expiratory flow
PF | peak flow
PFM | peak flow monitoring
Pharm. Ind. | Pharmaceutical Industry
p.m. | evening/night
pop. | population
pred | predicted
pt | patient
QOL | quality of life
RCT | randomized controlled trial
salmet | salmeterol
SD | standard deviation
stat. sig. | statistically significant
sx | symptoms
TAA | triamcinolone acetonide
theo | theophylline
tx | treatment
univ | university
URI | upper respiratory infection
U.S. | United States
VC | ventilatory capacity
wks | weeks
Xover | crossover
yr | year(s)