# Appendix B. Search Strategy Details

## MEDLINE Search Strategy

1) S (asthma/de OR asthma) AND py:1980:2000

2) S clinical trials! OR intervention studies/de OR double-blind method/de OR single-blind method/de OR placebos/de OR random allocation/de

3) S dt=controlled clinical trial OR dt=randomized controlled trial

4) S control? OR placebo? OR random? OR blind?

5) S s2 or s3 or s4

6) S s5/human and py=1980:2000

7) S cohort studies/de

8) S leukotriene antagonists! OR zileuton OR montelukast OR zafirlukast OR cromolyn OR nedocromil OR theophylline! OR albuterol/de OR albuterol OR salmeterol OR flunisolide OR fluticasone OR beclomethasone OR budesonide OR dexamethasone OR triamcinolone OR steroids!

9) S adrenergic beta-agonists! OR albuterol OR bitolterol OR isoetharine OR isoproterenol OR metaproterenol OR orciprenaline/de OR pirbuterol OR terbutaline OR ipratropium OR adrenal cortex hormones!

10) S (peak expiratory flow rate/de OR (peak AND flow))

11) S s10 and (meter OR meters OR monitor OR monitors OR monitoring)

12) S (action AND (plan OR plans)) OR self care/de OR patient care planning/de OR patient participation/de

13) S s11 OR s12

14) S beclomethasone OR budesonide OR dexamethasone OR flunisolide OR fluticasone OR triamcinolone

15) S leukotriene antagonists! OR zileuton OR montelukast OR zafirlukast

16) S cromolyn OR nedocromil

17) S theophylline!

18) S adrenergic beta-agonists! OR orciprenaline/de OR albuterol OR bitolterol OR isoetharine OR isoproterenol OR metaproterenol OR pirbuterol OR terbutaline OR salmeterol

19) S antibiotics!

20) S child!

21) S s1 AND (S6 OR s7) AND S8

22) S s1 AND s6 AND S14 AND S20

23) S s1 AND s6 AND S19

24) S s1 AND (s6 OR s7) AND S8 AND s20

25) S s1 AND s6 AND S8

26) S s1 and s6 and S11

27) S s1 and s6 and s12

28) S s21 or s22 or s23 or s24 or s25 or s26 or s27

29) S s28/eng

## Embase Search Strategy

S (asthma/de OR asthma)

S clinical trial! OR dt=clinical trial OR (double()blind) OR (single()blind) OR control? OR placebo? OR random? OR blind?

S cohort

S leukotriene antagonists! OR leukotriene receptor blocking agent! OR zileuton/de OR montelukast/de OR zafirlukast/de OR cromoglycate disodium/de OR nedocromil/de OR nedocromil sodium/de OR theophylline/de OR theophylline derivative/de OR salbutamol/de OR glucocorticoid! OR steroids!

S adrenergic beta-agonists! OR beta adrenergic receptor stimulating agent! OR isoprenaline/de OR corticosteroid! OR adrenal cortex hormones!

S peak expiratory flow/de OR peak expiratory flow rate/de OR (peak AND flow)

S [previous set] AND (meter OR meters OR monitor OR monitors OR monitoring)

S ((action OR management) AND (plan OR plans)) OR self care/de OR patient care planning/de OR patient participation/de

S OR previous 2 sets

S beclomethasone OR budesonide OR dexamethasone OR flunisolide OR fluticasone OR triamcinolone

S beta adrenergic receptor stimulating agent!

S cromoglycate disodium/de OR nedocromil OR cromolyn

S theophylline! OR theophylline derivative!

S antibiotics! OR DC=D20.10?

S child/de OR child!

Do the years in bunches to get sets below 5000 to be able to reduce duplicates

RD set number

S set number from 155

S (reduced duplicates set number) not (MEDLINE set number)