# Appendix A. Technical Advisory Group Peer Reviewers Medical Advisory Panel

## Technical Advisory Group

- Stanley Szefler, M.D.
- Department of PediatricsNational Jewish Medical and Research Center

- William Kelly, Pharm.D.
- Professor of Pharmacology/PediatricsUniversity of New Mexico Health Sciences Center

- William Busse, M.D.
- Professor of MedicineUniversity of Wisconsin Hospital

- Noreen Clark, Ph.D.
- Professor, School of Public HealthUniversity of Michigan

- Romain Pauwels, M.D., Ph.D.
- Head of Department of Respiratory DiseasesUniversity Hospital, Ghent, Belgium

- Barbara P. Yawn, M.D., M.S., M.S.P.H.
- Director of Research, Department of Research and EducationOlmsted Medical Center

- Lee Albert Green, M.D., M.P.H.
- Associate Professor, Department of Family MedicineUniversity of Michigan Medical School

- Louis M. Mendelson, M.D.
- Clinical Associate Professor of PediatricsUniversity of Connecticut School of Medicine

## Task Order Officer

- Harry Handelsman, D.O.
- Center for Health Care TechnologyAHRQ

## Peer Reviewers

- Ken Adams, Ph.D.
- Researcher, Representing National Institute of Allergy and Infections Diseases

- Hanan Bell, Ph.D.
- Methodologist, Independent Consultant

- Thomas Casale, MD
- Professor, Department of MedicineCreighton UniversityRepresenting the American Thoracic Society

- Barry David Dickinson, Ph.D.
- ResearcherRepresenting the American Medical Association

- Norman H. Edelman, M.D.
- Vice President, Health Sciences Center, Dean, School of Medicine,Stony Brook Health Sciences Center, Stony Brook New York,Representing the American Lung Association.

- James Fish, MD
- Professor of MedicineJefferson Medical CollegeRepresenting the American College of Chest Physicians

- George Georges, MD
- Director, US Medical Research-Respiratory & AllergyAventis Pharmaceuticals Products Inc., (formerly Rhone-Poulenc Rorer)Representing Aventis Pharmaceuticals Products, Inc.

- Leslie Hendeles, Pharm.D.
- National Asthma Education and Prevention Program, Coordinating CommitteeProfessor of Pharmacy and Pediatrics, The University of FloridaClinical Pharmacist, Pediatric Pulmonary Division, University of FloridaRepresenting the American Society of Health-System Pharmacists.

- Edwin Kuffner, M.D.
- Attending Toxicologist, Rocky Mountain Poison and Drug CenterInstructor, School of Pharmacy, University of Colorado Health Sciences CenterRepresenting the American College of Emergency Physicians.

- Michael LeNoir, MD
- Clinical Allergist and PediatricianRepresenting the National Medical Association

- James T. C. Li, M.D., Ph.D.
- Professor of Medicine, Mayo Clinic and FoundationProgram Director, Allergy and Immunology Training Program

- Joram Seggev, M.D., FAAAAI, FACAAI
- Clinical Professor of Medicine, Department of Internal MedicineUniversity of Nevada School Las VegasRepresenting the American College of Allergy, Asthma and Immunology.

- Albert Sheffer, M.D.
- Clinical Professor Of MedicineHarvard Medical School

- Herbert Slade, M.D.
- Director, US and International Medical Affairs, 3M PharmaceuticalsRepresenting 3M Pharmaceuticals.

- Lewis Smith, M.D.
- Professor of Medicine, Northwestern University School of MedicineAssociate Director, Northwestern University Office of Clinical Research and TrainingDirector, Clinical Investigator Training Program, Northwestern University

- Michael Welch, MD
- Clinical Professor, University of California, San DiegoRepresenting the American Academy of Pediatrics

## Blue Cross and Blue Shield Association Medical Advisory Panel

- Allan M. Korn, M.D., F.A.C.P. (Chair)
- Senior Vice President, Clinical AffairsMedical Director, Blue Cross Blue Shield Association

- David M. Eddy, M.D., Ph.D. (Scientific Advisor)
- Kaiser PermanenteSouthern California RegionScientific Advisor for Health Policy and Management

- Peter C. Albertsen, M.D.
- University of Connecticut Health CenterDivision of Urology

- James O. Armitage, M.D.
- University of Nebraska Medical CenterInternal Medicine

- Helen Darling, M.A.
- Practice Leader, Group Benefits & Health CareWatson Wyatt & Company

- Josef E. Fischer, M.D., F.A.C.S.
- Chair, Department of SurgeryUniversity of Cincinnati Medical Center

- Alan M. Garber, M.D., Ph.D.
- Director, Center for Primary Care and Outcomes ResearchCenter for Health Policy

- Michael A. W. Hattwick, M.D.
- Woodburn Internal Medicine Associates, Ltd.

- I. Craig Henderson, M.D.
- University of California, San FranciscoProfessor of Medicine, Chief of Oncology

- Albert R. Jonsen, Ph.D.
- University of WashingtonDepartment of Medical History and Ethics

- Peter A. Margolis, M.D., Ph.D.
- Assistant Professor, Department of PediatricsClinical Assistant Professor, Department of EpidemiologyChildren's Primary Care Research Group

- Barbara J. McNeil, M.D., Ph.D.
- Harvard Medical SchoolDepartment of Health Care Policy

- Anne L. Meneghetti, M.D.
- Acting Chief Medical OfficerBlue Cross Blue Shield of Massachusetts

- Richard G. Roberts, M.D., J.D.
- Department of Family MedicineUniversity of Wisconsin School of Medicine

- Patrick E. Ryce, M.D.
- Senior Vice President and Medical DirectorBlue Cross and Blue Shield of Alabama

- Earl P. Steinberg, M.D., M.P.P.
- Senior Vice President of Research and Development and Industry AffairsResolution Health Strategies

- Paul J. Wallace, M.D.
- Director, Clinical Practice Guidelines ProgramKaiser Permanente Northwest

- Jed Weissberg, M.D.
- Associate Executive DirectorQuality and Performance ImprovementThe Permanente Federation