# Appendixes

Appendix A. Technical Advisory Group Peer Reviewers Medical Advisory Panel

Appendix B. Search Strategy Details

Appendix C. Acronyms and Abbreviations