# Appendix: List of Contributors

## Editorial Board

- Kaveh G. Shojania, MD
- Assistant Professor Department of Medicine University of California, San Francisco San Francisco, CA

- Bradford W. Duncan, MD
- AHRQ Patient Safety Fellow Center for Primary Care & Outcomes Research Stanford University Stanford, CA

- Kathryn M. McDonald, MM
- Executive Director Center for Primary Care & Outcomes Research Stanford University Stanford, CA

- Robert M. Wachter, MD
- Professor and Associate Chairman Department of Medicine University of California, San Francisco San Francisco, CA

## Contributors

- Joseph V. Agostini, MD
- Robert Wood Johnson Clinical Scholar Yale University School of Medicine New Haven, CT Chapters 26-30

- Andrew D. Auerbach, MD, MPH
- Assistant Professor of Medicine University of California, San Francisco San Francisco, CA Chapters 18-20, 22-25

- Dorothy I. Baker, PhD, RNCS
- Research Scientist, Chronic Disease Epidemiology Department of Epidemiology and Public Health Associate Director, Claude Pepper Older Americans Independence Center Yale University School of Medicine New Haven, CT Chapters 26-30

- David W. Bates, MD, MSc
- Associate Professor of Medicine Harvard Medical School Chief, Division of General Internal Medicine Brigham and Women's Hospital Boston, MA Chapters 6-9, 41, 42, 45, and 46

- Sidney T. Bogardus, Jr., MD
- Assistant Professor of Medicine Yale University School of Medicine Medical Director, Adler Geriatric Assessment Center Yale-New Haven Hospital New Haven, CT Chapters 26-30

- Erica Brownfield, MD
- Assistant Professor of Medicine Emory University School of Medicine Grady Memorial Hospital Atlanta, GA Chapter 37

- Harold R. Collard, MD
- Fellow in Pulmonary & Critical Care Medicine University of Colorado Health Sciences Center Denver, CO Chapter 17

- Lorenzo Di Francesco, MD
- Assistant Professor of Medicine Emory University School of Medicine Department of Medicine Grady Memorial Hospital Atlanta, GA Chapter 32

- Daniel D. Dressler, MD
- Instructor of Medicine Emory University School of Medicine Hospital Medicine Fellow Grady Memorial Hospital Atlanta, GA Chapter 34

- Bradford W. Duncan, MD
- AHRQ Patient Safety Fellow Center for Health Policy Center for Primary Care & Outcomes Research Stanford University Stanford, CA Chapters 45 and 46

- Sharon K. Inouye, MD, MPH
- Associate Professor of Medicine Yale University School of Medicine Investigative Medicine Program New Haven, CT Chapters 28 and 29

- Salim D. Islam, MD
- Assistant Clinical Professor Department of Anesthesia and Perioperative Care University of California, San Francisco San Francisco VA Medical Center San Francisco, CA 94121 Chapters 23 and 24

- Ashish K. Jha, MD
- Assistant Professor of Medicine University of California, San Francisco Division of General Internal Medicine San Francisco VA Medical Center San Francisco, CA Chapters 45 and 46

- Rainu Kaushal, MD, MPH
- Instructor in Medicine Harvard Medical School Division of General Internal Medicine Brigham and Women's Hospital Boston, MA Chapter 6 and 7

- Jennifer Kleinbart, MD
- Assistant Professor of Medicine Emory University School of Medicine Atlanta, GA Chapter 31

- Sunil Kripalani, MD
- Instructor of Medicine Emory University School of Medicine Division of General Medicine Grady Memorial Hospital Atlanta, Georgia Chapter 35

- Ebbing Lautenbach, MD, MPH, MSCE
- Assistant Professor of Medicine and Epidemiology University of Pennsylvania School of Medicine Hospital Epidemiologist, Presbyterian Medical Center Philadelphia, PA Chapters 12-14

- Susana B. Martins, MD, MSc
- Fellow, Institute for Health Policy Studies University of California, San Francisco Foster City, CA Chapter 47

- Harvey J. Murff, MD
- Fellow, Division of General Internal Medicine Brigham and Women's Hospital Boston, MA Chapters 23, 41 and 42

- Michael D. Murray, PharmD, MPH
- Professor of Pharmacy Purdue University School of Pharmacy Scientist, Regenstrief Institute for Healthcare Regenstrief Health Center, Sixth Floor Indianapolis, Indiana Chapters 10 and 11

- David B. Nash, MD, MBA
- Associate Dean and Director Office of Health Policy and Clinical Outcomes Thomas Jefferson University Philadelphia, PA Chapters 40, 44, 48 and 50

- Steven Z. Pantilat, MD
- Assistant Professor of Medicine University of California, San Francisco Project on Death in America Faculty Scholar San Francisco, CA Chapter 49

- Laura T. Pizzi, PharmD
- Project Director Office of Health Policy and Clinical Outcomes Thomas Jefferson University Philadelphia, PA Chapters 40, 44, 48 and 50

- Jeffrey M. Rothschild, MD, MPH
- Instructor in Medicine Harvard Medical School Division of General Medicine Brigham and Women's Hospital Boston, MA Chapters 21 and 38

- Kimberly Rask, MD, PhD
- Assistant Professor of Medicine and Health Policy Emory University Schools of Medicine and Public Health Grady Memorial Hospital Atlanta, GA Chapters 31,34, and 35

- Sanjay Saint, MD, MPH
- Assistant Professor of Medicine Director, Patient Safety Enhancement Program University of Michigan School of Medicine Research Scientist Ann Arbor VA Health Services Research & Development Field Program Ann Arbor, MI Chapters 15-17

- Jean Ann Seago, PhD, RN
- Assistant Professor of Nursing University of California, San Francisco Research Fellow Center for California Health Workforce Studies San Francisco, CA Chapter 39

- Kaveh G. Shojania, MD
- Assistant Professor Department of Medicine University of California, San Francisco San Francisco, CA Chapters 4, 5, 9, 10, 43, and 47

- Robert Trowbridge, MD
- Clinical Instructor Department of Medicine University of California, San Francisco San Francisco, CA Chapters 51-55

- Robert M. Wachter, MD
- Professor and Associate Chairman Department of Medicine University of California, San Francisco Chief of the Medical Service Moffitt-Long Hospitals San Francisco, CA Chapter 55

- Heidi Wald, MD
- Assistant Professor in Medicine University of Pennsylvania Director, Penn Hospital Care Group Hospital of the University of Pennsylvania Philadelphia, PA Chapters 4,5 and 43

- Scott Weingarten, MD, MPH
- Associate Professor of Medicine University of California, Los Angeles Director, Health Services Research Cedars-Sinai Health System Beverly Hills, CA Chapters 51-54

- Mark V. Williams, MD
- Associate Professor of Medicine Director, Hospital Medicine Unit Emory University School of Medicine Medical Director, Center for Clinical Effectiveness Grady Memorial Hospital Atlanta, GA Chapters 31-35

- Neil Winawer, MD
- Assistant Professor of Medicine Emory University School of Medicine Grady Memorial Hospital Atlanta, GA Chapter 33