# 59 Listing of All Practices, Categorical Ratings, and Comments

## Comments Section