# Bibliography

Aaron LA, Buchwald D. Tobacco use and chronic fatigue syndrome, fibromyalgia, and temporomandibular disorder. Arch Intern Med. 2000;160:2398-401. Exclude: not suitable for any question. [pmid: 10927749].
Aaron LA, Burke MM, Buchwald D. Overlapping conditions among patients with chronic fatigue syndrome, fibromyalgia, and temporomandibular disorder. Arch Intern Med. 2000;160:221-7. Exclude: did not meet inclusion criteria. [pmid: 10647761].
Abbey SE. Somatization, illness attribution and the sociocultural psychiatry of chronic fatigue syndrome. [Review]. Ciba Found Symp. 1993;173:238-52. Exclude: not suitable for any question. [pmid: 8491101].
Abbey SE, Garfinkel PE. Chronic fatigue syndrome and depression: cause, effect, or covariate. Rev Infect Dis. 1991;13:S73-S83. Exclude: not suitable for any question. [pmid: 2020805].
Abbey SE, Garfinkel PE. Chronic fatigue syndrome and the psychiatrist. [Review]. Can J Psychiatry. 1990;35:625-33. Exclude: not suitable for any question. [pmid: 2268845].
Abbey SE, Garfinkel PE. Neurasthenia and chronic fatigue syndrome: the role of culture in the making of a diagnosis: reply. Am J Psychiatry. 1992;149:1756-7. Exclude: not suitable for any question. [pmid: 1443263].
Abbey SE, Garfinkel PE. Neurasthenia and chronic fatigue syndrome: the role of culture in the making of a diagnosis. [Review]. Am J Psychiatry. 1991;148:1638-46. Exclude: not suitable for any question. [pmid: 1957925].
Abbey SE. Psychiatric diagnostic overlap in chronic fatigue syndrome. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.48-71. Exclude: not suitable for any question.
Abbey SE. Psychotherapeutic perspectives on chronic fatigue syndrome. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.185-211. Exclude: not suitable for any question.
Abbey SE, Demitrack MA. Psychiatric assessment of patients with chronic fatigue syndrome. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.130-53. Exclude: not suitable for any question.
Abbot NC, Spence VA, Lowe JG, et al. Chronic fatigue syndrome. Immunological findings vary between populations. BMJ. 1994;308. Exclude: not suitable for any question.
Ablashi DV. Viral studies of chronic fatigue syndrome. [Review]. Clin Infect Dis. 1994;18:S130-3. Exclude: not suitable for any question. [pmid: 8148440].
Ablashi DV, Salahuddin SZ, Josephs SF, Balachandran N, Krueger GR, Gallo RC. Human herpesvirus-6 (HHV-6) (short review). [Review]. In Vivo. 1991;5:193-9. Exclude: not suitable for any question. [pmid: 1654146].
Aikman LP. A phenomenological study of six chronic fatigue immune dysfunction syndrome survivors. Diss Abstr Int A: Hum Soc Sci. 1995;55. Exclude: not suitable for any question.
Albrecht F. Chronic fatigue syndrome. J Am Acad Child Adolesc Psychiatry. 2000;39:808-9. Exclude: not suitable for any question. [pmid: 10892219].
Albrecht F, Wallace M. Detecting chronic fatigue syndrome: the role of counselors. J Counsel Dev. 1998;76:183-8. Exclude: not suitable for any question.
Albus C. [Chronic fatigue syndrome--a disease entity or an unspecified psychosomatic disorder?]. [German]. Z Arztl Fortbild Qualitatssich. 1997;91:717-21. Exclude: not suitable for any question. [pmid: 9487622].
Aleksandrovskii IuA, Bobkov IuG, Neznamov GG, Serebriakova TV, Boiko SS. [Use of the new psychotropic preparation bemitil in treating asthenic disorders (clinico-pharmacological research)]. [Russian]. Zh Nevropatol Psikhiatr Im S S Korsakova. 1988;88:109-15. Exclude: not suitable for any question.
Alexander EL, Kumar AJ, Kozachuk WE. The chronic fatigue syndrome controversy. Ann Intern Med. 1992;117:343-4. Exclude: not suitable for any question.
Ali HM. Chronic fatigue syndrome. Physiotherapy. 1998;84:331-4. Exclude: not suitable for any question.
Ali HM. Chronic fatigue syndrome. Physiotherapy. 1998;84:521-2. Exclude: not suitable for any question.
Alisky JM, Iczkowski KA, Foti AA. Chronic fatigue syndrome [published erratum appears in Am Fam Physician 1991 Aug; 44(2):406]. Am Fam Physician. 1991;44. Exclude: not suitable for any question.
Allain TJ, Bearn JA, Coskeran P, et al. Changes in growth hormone, insulin, insulinlike growth factors (IGFs), and IGF-binding protein-1 in chronic fatigue syndrome. Biol Psychiatry. 1997;41:567-73. Exclude: not suitable for any question. [pmid: 9046989].
Allen AD. Is RA27/3 rubella immunization a cause of chronic fatigue?. Med Hypotheses. 1988;27:217-20. Exclude: not suitable for any question. [pmid: 3211019].
Ambrogetti A, Olson LG. Consideration of narcolepsy in the differential diagnosis of chronic fatigue syndrome. Med J Aust. 1994;160:426-9. Exclude: not suitable for any question. [pmid: 8007866].
Ambrogetti A, Olson LG, Sutherland DC, Malcolm JA, Bliss D, Gyulay SG. Daytime sleepiness and REM sleep abnormalities in chronic fatigue: A case series. J Chronic Fatigue Syndr. 1998;4:23-35. Exclude: not suitable for any question.
Anand AC, Kumar R, Rao MK, Dham SK. Low grade pyrexia: is it chronic fatigue syndrome?. J Assoc Physicians India. 1994;42:606-8. Exclude: not suitable for any question. [pmid: 7868552].
Anderson JS, Ferrans CE. The quality of life of persons with chronic fatigue syndrome. J Nerv Ment Dis. 1997;185:359-67. Include. [pmid: 9205421].
Anderson JS, Kayner D. Milieu issues in the treatment of a person with chronic fatigue syndrome on an inpatient psychiatric unit. J Am Psychiatr Nurs Assoc. 1995;1:12-5. Exclude: not suitable for any question.
Anderson N. Chronic fatigue syndrome. ... and study them separately [letter]. BMJ. 1994;308. Exclude: letter.
Andersson JP. Clinical aspects on Epstein-Barr virus infection. [Review]. Scand J Infect Dis Suppl. 1991;80:94-104. Exclude: not suitable for any question. [pmid: 1666450].
Andersson M, Bagby JR, Dyrehag LE, Gottfries CG. Effects of staphylococcus toxoid vaccine on pain and fatigue in patients with fibromyalgia/chronic fatigue syndrome. Eur J Pain. 1998;2:133-42. Include. [pmid: 10700309].
Anfinson TJ. Diagnostic assessment of chronic fatigue syndrome. In: Stoudemire A, Fogel BS, editors. Medical-psychiatric practice, vol. 3. Washington. American Psychiatric Press. 1995:p.215-55. Exclude: not suitable for any question.
Ang DC, Calabrese LH. A common-sense approach to chronic fatigue in primary care. [Review]. Cleve Clin J Med. 1999;66:343-50, 352. Exclude: not suitable for any question. [pmid: 10375843].
Alleged link between hepatitis B vaccine and chronic fatigue syndrome. Can Dis Wkly Rep. 1991;17:215-6. Exclude: not suitable for any question. [pmid: 1835672].
Alleged link between hepatitis B vaccine and chronic fatigue syndrome. CMAJ. 1992;146:37-8. Exclude: not suitable for any question. [pmid: 1530818]. [pmcid: 1488229].
CFS patients improve on ampligen, study finds. Am Pharm. 1992;32:21-2. Exclude: not suitable for any question.
Chronic fatigue controversy. Postgrad Med. 1991;90:23-4. Exclude: not suitable for any question.
Chronic fatigue: psyche or sleep?. Arch Intern Med. 1990;150. Exclude: not suitable for any question.
Chronic fatigue syndrome. Br J Psychiatry. 1990;157:447-50. Exclude: not suitable for any question. [pmid: 2245282].
Chronic fatigue syndrome. Dtsch Med Wochenschr. 1991;116. Exclude: not suitable for any question.
Chronic fatigue syndrome. JAMA. 1991;265:357-8. Exclude: not suitable for any question. [pmid: 1845816].
Chronic fatigue syndrome. Am Fam Physician. 1992;45. Exclude: not suitable for any question.
Chronic fatigue syndrome: current concepts. Conference proceedings. Albany New York, 3-4 October 1992. Clin Infect Dis. 1994;18:S1-167. Exclude: not suitable for any question. [pmid: 7908540].
[Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1991;135:2347-9. Exclude: not suitable for any question. [pmid: 1809896].
Chronic Fatigue Syndrome. Proceedings of a workshop. Toronto, Ontario, 28-29 September 1989. Can Dis Wkly Rep. 1991;17:1-71. Exclude: not suitable for any question.
Chronic fatigue syndrome: therapeutic guidelines. S Afr Med J. 1993;83:P152-3. Exclude: not suitable for any question.
Chronic fatigue, viruses, and depression. Lancet. 1991;337:564-5. Exclude: not suitable for any question. [pmid: 1671935].
[Chronic infection caused by Epstein-Barr virus and chronic fatigue syndrome]. [Spanish]. Med Clin (Barc). 1990;94:315-6. Exclude: not suitable for any question. [pmcid: 263984]. [pmid: 2342394].
Considerations in the design of studies of chronic fatigue syndrome. Pittsburgh, Pennsylvania, 15-16 September 1988. Rev Infect Dis. 1991;13:S1-140. Exclude: not suitable for any question. [pmid: 1673573].
[Fatigue syndromes, neurasthenia, psychasthenia, thymasthenia, dysthymia. Proceedings of a symposium. Bordeaux, France, October 23, 1993]. [French]. Encephale. 1994;20:541-618. Exclude: not suitable for any question.
From the Centers for Disease Control and Prevention. Inability of retroviral tests to identify persons with chronic fatigue syndrome, 1992. JAMA. 1993;269. Exclude: not suitable for any question.
Frustrating survey of chronic fatigue. Lancet. 1996;348. Exclude: not suitable for any question.
Immunological abnormalities in the chronic fatigue syndrome. Med J Aust. 1990;152:50-2. Exclude: not suitable for any question. [pmid: 2294379].
Inability of retroviral tests to identify persons with chronic fatigue syndrome, 1992. MMWR Morb Mortal Wkly Rep. 1993;42:183, 189-90. Exclude: not suitable for any question. [pmid: 8446093].
Magnesium and chronic fatigue syndrome. Lancet. 1991;337:1094-5. Exclude: not suitable for any question.
Multiple chemical sensitivity: a 1999 consensus. Arch Environ Health. 1999;54:147-9. Exclude: did not meet inclusion criteria. [pmid: 10444033].
Report of the working group on the possible relationship between hepatitis B vaccination and the chronic fatigue syndrome. Can Commun Dis Rep. 1993;19:25-8. Exclude: not suitable for any question. [pmid: 8453393].
Report of the working group on the possible relationship between hepatitis B vaccination and the chronic fatigue syndrome. CMAJ. 1993;149:314-9. Exclude: not suitable for any question. [pmid: 8339178]. [pmcid: 1485526].
Treatment and diagnosis of chronic fatigue immunodysfunction syndrome. Cur Opin Ther Patents. 1992;2:1016-7. Exclude: not suitable for any question.
Antoni MH, Brickman A, Lutgendorf S, et al. Psychosocial correlates of illness burden in chronic fatigue syndrome. Clin Infect Dis. 1994;18:S73-8. Exclude: not suitable for any question. [pmid: 8148457].
Aoki T, Miyakoshi H, Usuda Y, Herberman RB. Low NK syndrome and its relationship to chronic fatigue syndrome. [Review]. Clin Immunol Immunopathol. 1993;69:253-65. Exclude: not suitable for any question. [pmid: 8242898].
Apel-Paz M, Lior B, Shemesh-Kegli R. [Chronic fatigue syndrome: approaches to treatment]. Harefuah. 2000;139:141-9. Exclude: not suitable for any question. [pmid: 10979475].
Apfelbaum B. Neurasthenia and chronic fatigue syndrome: the role of culture in the making of a diagnosis: comment. Am J Psychiatry. 1992;149:1754-57. Exclude: not suitable for any question. [pmid: 1443260].
Arav-Boger R, Spirer Z. Chronic fatigue syndrome: pediatric aspects. [Review]. Isr J Med Sci. 1995;31:330-4. Exclude: not suitable for any question. [pmid: 7759230].
Arber M, Macintyre A. Chronic fatigue syndrome or myalgic encephalitis. Lancet. 1994;343:242-3. Exclude: not suitable for any question.
Archard LC, Bowles NE, Behan PO, Bell EJ, Doyle D. Postviral fatigue syndrome: persistence of enterovirus RNA in muscle and elevated creatine kinase. J R Soc Med. 1988;81:326-9. Exclude: not suitable for any question. [pmid: 3404526]. [pmcid: 1291623].
Armon C, Kurland LT. Chronic fatigue syndrome: issues in the diagnosis and estimation of incidence. [Review]. Rev Infect Dis. 1991;13:S68-72. Exclude: not suitable for any question. [pmid: 2020804].
Arnason BG. Nervous system-immune system communication. Rev Infect Dis. 1991;13:S134-7. Exclude: not suitable for any question. [pmid: 2020798].
Arnetz BB. Causes of change in the health of populations: a biopsychosocial viewpoint. [Review]. Soc Sci Med. 1996;43:605-8. Exclude: not suitable for any question. [pmid: 8870126].
Aronowitz RA. The trouble with chronic fatigue. J Gen Intern Med. 1991;6:378-9. Exclude: not suitable for any question. [pmid: 1819250].
Artsimovich NG, Chugunov VS, Kornev AV, Ivanova TM, Chugunov AV, Oprishchenko MA. [The chronic fatigue syndrome]. [Review] [Russian]. Zh Nevropatol Psikhiatr Im S S Korsakova. 1994;94:47-50. Exclude: not suitable for any question.
Arya DK. Chronic fatigue syndrome. Br J Gen Pract. 1991;41. Exclude: not suitable for any question.
Arzomand ML. Chronic fatigue syndrome among school children and their special educational needs. J Chronic Fatigue Syndr. 1998;4:59-69. Exclude: not suitable for any question.
Ash-Bernal R, Wall C 3rd, Komaroff AL, et al. Vestibular function test anomalies in patients with chronic fatigue syndrome. Acta Otolaryngol (Stockh). 1995;115:9-17. Exclude: physiologic/n<20. [pmid: 7762393].
Auger PL, Gourdeau P, Miller JD. Clinical experience with patients suffering from a chronic fatigue-like syndrome and repeated upper respiratory infections in relation to airborne molds. Am J Ind Med. 1994;25:41-2. Exclude: not suitable for any question. [pmid: 8116649].
Awdry R. Homeopathy may help ME. Int J Altern Complement Med. 1996;14:12-6. Include.
Awdry R. Homeopathy and chronic fatigue: the search for proof. Int J Altern Complement Med. 1996;14:12, 19-20. Include.
Ax S, Gregg VH, Jones D. Chronic fatigue syndrome: sufferers' evaluation of medical support. J R Soc Med. 1997;90:250-4. Exclude: not suitable for any question. [pmid: 9204018]. [pmcid: 1296257].
Axe E, Satz P. Psychiatric correlates in chronic fatigue syndrome. Ann Epidemiol. 2000;10. Exclude: not suitable for any question.
Aylward M. Government's expert group has reached consensus on prognosis of chronic fatigue syndrome. BMJ. 1996;313. Exclude: not suitable for any question.
Baer D, Raetzo MA, Restellini A, Stalder H. [“I am tired”]. [Review] [German]. Schweiz Rundsch Med Prax. 1999;88:764-7. Exclude: not suitable for any question. [pmid: 10373790].
Bakheit AM, Behan PO, Dinan TG, Gray CE, O'Keane V. Possible upregulation of hypothalamic 5-hydroxytryptamine receptors in patients with postviral fatigue syndrome. BMJ. 1992;304:1010-2. Exclude: not suitable for any question. [pmid: 1586780]. [pmcid: 1881733].
Bakheit AM, Behan PO, Watson WS, Morton JJ. Abnormal arginine-vasopressin secretion and water metabolism in patients with postviral fatigue syndrome. Acta Neurol Scand. 1993;87:234-8. Exclude: not suitable for any question. [pmid: 8475696].
Balestreri R, Bertolini S, Barban G, et al. [Effect of bis-(isobutyryloxy-2-ethyl)-1-N-(amino-4-methyl-2-pyrimidyl-5) methyl formamido-2-propene-1-yl disulfide (Sulbutiamin) in neurasthenic and neuroastheniform syndromes]. [Italian]. Arch Maragliano Patol Clin. 1979;35:19-34. Exclude: not suitable for any question. [pmid: 400511].
Ballow M, Seeley J, Purtilo DT, St. Onge S, Sakamoto K, Rickles FR. Familial chronic mononucleosis. Ann Intern Med. 1982;97:821-5. Include. [pmid: 7149489].
Baraniuk JN, Clauw D, MacDowell-Carneiro AL, et al. IgE concentrations in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:13-21. Exclude: not suitable for any question.
Baraniuk JN, Clauw D, Yuta A, et al. Nasal secretion analysis in allergic rhinitis, cystic fibrosis, and nonallergic fibromyalgia/chronic fatigue syndrome subjects. Am J Rhinol. 1998;12:435-40. Exclude: not suitable for any question. [pmid: 9883301].
Baraniuk JN, Clauw DJ, Gaumond E. Rhinitis symptoms in chronic fatigue syndrome. Ann Allergy Asthma Immunol. 1998;81:359-65. Include. [pmid: 9809501].
Bardzil P. Chronic fatigue syndrome. Psychologist. 1998;11:418-9. Exclude: not suitable for any question.
Barker E, Fujimura SF, Fadem MB, Landay AL, Levy JA. Immunologic abnormalities associated with chronic fatigue syndrome. Clin Infect Dis. 1994;18:S136-41. Exclude: not suitable for any question. [pmid: 8148441].
Barnes CL, Fleming CA, Poinsett-Holmes K, Kennedy LD. Chronic fatigue syndrome: what are the facts?. J Pract Nurs. 1993;43:24-31; quiz 32-4. Exclude: not suitable for any question.
Barnes PR, Taylor DJ, Kemp GJ, Radda GK. Skeletal muscle bioenergetics in the chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1993;56:679-83. Exclude: not suitable for any question. [pmid: 8509783].
Barofsky I, Legro MW. Definition and measurement of fatigue. [Review]. Rev Infect Dis. 1991;13:S94-7. Exclude: not suitable for any question. [pmid: 2020809].
Barrows DM. Functional capacity evaluations of persons with chronic fatigue immune dysfunction syndrome. [Review]. Am J Occup Ther. 1995;49:327-37. Exclude: not suitable for any question. [pmid: 7785715].
Barsky AJ, Borus JF. Functional somatic syndromes. Ann Intern Med. 1999;130:910-21. Exclude: not suitable for any question. [pmid: 10375340].
Baschetti R. The 1microg Synacthen test in chronic fatigue syndrome. Clin Endocrinol (Oxf). 2000;52:797-9. Exclude: not suitable for any question. [pmcid: 298219]. [pmid: 10848890].
Baschetti R. Chronic fatigue syndrome. QJM. 1997;90. Exclude: not suitable for any question.
Baschetti R. Chronic fatigue syndrome. JAMA. 1998;279:431-2. Exclude: not suitable for any question. [pmid: 9466629].
Baschetti R. Chronic fatigue syndrome. Postgrad Med J. 1998;74. Exclude: not suitable for any question.
Baschetti R. Chronic fatigue syndrome. N Z Med J. 1999;112. Exclude: not suitable for any question.
Baschetti R. Chronic fatigue syndrome: a form of Addison's disease. J Intern Med. 2000;247:737-9. Exclude: not suitable for any question. [pmid: 10886497].
Baschetti R. Chronic fatigue syndrome and liquorice [letter]. N Z Med J. 1995;108:156-7. Exclude: not suitable for any question. [pmid: 7761058].
Baschetti R. Chronic fatigue syndrome and neurally mediated hypotension. JAMA. 1996;275. Exclude: not suitable for any question.
Baschetti R. Cortisol deficiency may account for elevated apoptotic cell population in patients with chronic fatigue syndrome. J Intern Med. 1999;245:409-10. Exclude: not suitable for any question. [pmid: 10356605].
Baschetti R. Etiology of chronic fatigue syndrome. Am J Med. 1997;102:422-3. Exclude: not suitable for any question. [pmid: 9217628].
Baschetti R. Fibromyalgia, chronic fatigue syndrome, and Addison disease. Arch Intern Med. 1999;159. Exclude: not suitable for any question.
Baschetti R. High androgen levels in chronic fatigue patients. J Clin Endocrinol Metab. 1996;81:2752-3. Exclude: not suitable for any question. [pmid: 8675610].
Baschetti R. Hydrocortisone and chronic fatigue syndrome [letter]. Lancet. 1999;353. Exclude: not suitable for any question.
Baschetti R. Investigations of hydrocortisone and fludrocortisone in the treatment of chronic fatigue syndrome [letter]. J Clin Endocrinol Metab. 1999;84:2263-4. Exclude: not suitable for any question. [pmid: 10372750].
Baschetti R. Liquorice and chronic fatigue syndrome [letter]. N Z Med J. 1995;108. Exclude: not suitable for any question.
Baschetti R. Low-dose hydrocortisone for chronic fatigue syndrome [letter]. JAMA. 1999;281. Exclude: not suitable for any question.
Baschetti R. Lung function test findings in patients with chronic fatigue syndrome (CFS). Aust N Z J Med. 1997;27. Exclude: not suitable for any question.
Baschetti R. Overlap of chronic fatigue syndrome with primary adrenocortical insufficiency. Horm Metab Res. 1999;31. Exclude: not suitable for any question.
Baschetti R. Psychological factors and chronic fatigue syndrome. N Z Med J. 1999;112:58-9. Exclude: not suitable for any question. [pmid: 10091899].
Baschetti R. Similarity of symptoms in chronic fatigue syndrome and Addison's disease. Eur J Clin Invest. 1997;27:1061-2. Exclude: not suitable for any question. [pmid: 9466137].
Baschetti R. Treating chronic fatigue with exercise. Results are contradictory for patients meeting different diagnostic criteria [letter]. BMJ. 1998;317. Exclude: not suitable for any question. [pmcid: 58840].
Baschetti R. Treatment for chronic fatigue syndrome [letter]. Arch Intern Med. 1998;158:2266-7. Exclude: not suitable for any question. [pmid: 9818808].
Baschetti R. Viral illness and chronic fatigue (syndrome). Lancet. 1995;346. Exclude: not suitable for any question.
Baschetti R. What causes chronic fatigue?. CMAJ. 1999;160. Exclude: not suitable for any question.
Bates DW, Buchwald D, Lee J, et al. Clinical laboratory test findings in patients with chronic fatigue syndrome. Arch Intern Med. 1995;155:97-103. Exclude: not suitable for any question. [pmid: 7632202].
Bates DW, Buchwald D, Lee J, et al. A comparison of case definitions of chronic fatigue syndrome. Clin Infect Dis. 1994;18:S11-5. Exclude: not suitable for any question. [pmid: 8148436].
Bates DW, Schmitt W, Buchwald D, et al. Prevalence of fatigue and chronic fatigue syndrome in a primary care practice. Arch Intern Med. 1993;153:2759-65. Include. [pmid: 8257251].
Bauermeister CD, Wagner C, Brede HD. [What is the relation of human herpesvirus 6 to chronic fatigue syndrome?]. [Review] [German]. Med Monatsschr Pharm. 1992;15:165-8. Exclude: not suitable for any question. [pmid: 1319541].
Bazelmans E, Bleijenberg G, Vercoulen JH, van der Meer JW, Folgering H. The chronic fatigue syndrome and hyperventilation [published erratum appears in J Psychosom Res 1998 Mar-Apr; 44(3-4):517]. J Psychosom Res. 1997;43:371-7. Include. [pmid: 9330236].
Bazelmans E, Vercoulen JH, Galama JM, van Weel C, van der Meer JW, Bleijenberg G. [Prevalence of chronic fatigue syndrome and primary fibromyalgia syndrome in The Netherlands (published erratum appears in Ned Tijdschr Geneeskd 1997 Sep 13;141(37):2686)]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:1520-3. Exclude: not suitable for any question. [pmid: 9543739].
Bazelmans E, Vercoulen JH, Swanink CM, et al. Chronic fatigue syndrome and primary fibromyalgia syndrome as recognized by GPs. Fam Pract. 1999;16:602-4. Include. [pmid: 10625135].
Beard TC. Chronic fatigue syndrome and neurally mediated hypotension. JAMA. 1996;275. Exclude: not suitable for any question.
Bearn J, Allain T, Coskeran P, et al. Neuroendocrine responses to d-fenfluramine and insulin-induced hypoglycemia in chronic fatigue syndrome. Biol Psychiatry. 1995;37:245-52. Exclude: not suitable for any question. [pmid: 7711161].
Bearn J, Wessely S. Neurobiological aspects of the chronic fatigue syndrome. [Review]. Eur J Clin Invest. 1994;24:79-90. Exclude: not suitable for any question. [pmid: 8206084].
Becker JT. Methodologic considerations in assessment of cognitive function in chronic fatigue syndrome. [Review]. Rev Infect Dis. 1991;13:S112-3. Exclude: not suitable for any question. [pmid: 2020796].
Beh HC. Effect of noise stress on chronic fatigue syndrome patients. J Nerv Ment Dis. 1997;185:55-8. Exclude: not suitable for any question. [pmid: 9040535].
Behan PO, Behan WM, Horrobin D. Effect of high doses of essential fatty acids on the postviral fatigue syndrome. Acta Neurol Scand. 1990;82:209-16. Include. [pmid: 2270749].
Behan PO, Hannifah H. 5-HT reuptake inhibitors in CFS. EOS: Rivista Di Immunologia Ed Immunofarmacologia. 1995;15:66-9. Exclude: atypical depression.
Behan WM, Behan PO. The role of viral infection in polymyositis, dermatomyositis and chronic fatigue syndrome. [Review]. Baillieres Clin Neurol. 1993;2:637-57. Exclude: not suitable for any question. [pmid: 8156146].
Behan WM, More IA, Behan PO. Mitochondrial abnormalities in the postviral fatigue syndrome. Acta Neuropathol. 1991;83:61-5. Exclude: not suitable for any question. [pmid: 1792865].
Behan WMH, Holt IJ, Kay DH, Moonie P. In vitro study of muscle aerobic metabolism in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1999;5:3-16. Exclude: not suitable for any question.
Bell DS. Chronic fatigue syndrome. Recent advances in diagnosis and treatment. [Review]. Postgrad Med. 1992;91:245-52. Exclude: not suitable for any question. [pmid: 1579531].
Bell DS. Chronic fatigue syndrome update. Findings now point to CNS involvement. [Review]. Postgrad Med. 1994;96:73-6, 79-81. Exclude: not suitable for any question. [pmid: 7971614].
Bell DS. Illness onset characteristics in children with chronic fatigue syndrome and idiopathic chronic fatigue. J Chronic Fatigue Syndr. 1997;3:43-52. Exclude: not suitable for any question.
Bell DS. Neurasthenia and chronic fatigue syndrome: the role of culture in the making of a diagnosis: comment. Am J Psychiatry. 1992;149. Exclude: not suitable for any question.
Bell DS, Bell KM, Cheney PR. Primary juvenile fibromyalgia syndrome and chronic fatigue syndrome in adolescents. Clin Infect Dis. 1994;18:S21-3. Exclude: not suitable for any question. [pmid: 8148447].
Bell EJ, McCartney RA, Riding MH. Coxsackie B viruses and myalgic encephalomyelitis. J R Soc Med. 1988;81:329-31. Exclude: not suitable for any question. [pmid: 2841461]. [pmcid: 1291624].
Bell IR, Baldwin CM, Schwartz GE. Illness from low levels of environmental chemicals: relevance to chronic fatigue syndrome and fibromyalgia. Am J Med. 1998;105:74S-82S. Include. [pmid: 9790486].
Bell IR, Walsh ME, Goss A, Gersmeyer J, Schwartz GE, Kanof P. Cognitive dysfunction and disability in geriatric veterans with self- reported intolerance to environmental chemicals. J Chronic Fatigue Syndr. 1997;3:15-42. Exclude: not suitable for any question.
Bell KM, Cookfair D, Bell DS, Reese P, Cooper L. Risk factors associated with chronic fatigue syndrome in a cluster of pediatric cases. Rev Infect Dis. 1991;13:S32-8. Exclude: not suitable for any question. [pmid: 2020801].
Bellanti JA. [Chronic fatigue syndrome (editorial)]. [Spanish]. Rev Alerg Mex. 1994;41:65-8. Exclude: not suitable for any question. [pmid: 9377107].
Bennett A. A view of the violence contained in chronic fatigue syndrome. J Anal Psychol. 1997;42:237-51. Exclude: not suitable for any question. [pmid: 9161123].
Bennett AL, Chao CC, Hu S, et al. Elevation of bioactive transforming growth factor-beta in serum from patients with chronic fatigue syndrome. J Clin Immunol. 1997;17:160-6. Exclude: not suitable for any question. [pmid: 9083892].
Bennett AL, Fagioli L, Komaroff AL, Raoult D. Persistent infection with Bartonella (Rochalimaea) henselae or Afipia felis is unlikely to be a cause of chronic fatigue syndrome. Clin Infect Dis. 1994;19:804-5. Exclude: not suitable for any question. [pmid: 7528553].
Bennett AL, Fagioli LR, Schur PH, Schacterle RS, Komaroff AL. Immunoglobulin subclass levels in chronic fatigue syndrome. J Clin Immunol. 1996;16:315-20. Exclude: not suitable for any question. [pmid: 8946275].
Bennett AL, Mayes DM, Fagioli LR, Guerriero R, Komaroff AL. Somatomedin C (insulin-like growth factor I) levels in patients with chronic fatigue syndrome. J Psychiatr Res. 1997;31:91-6. Exclude: not suitable for any question. [pmid: 9201651].
Bennett R. Fibromyalgia, chronic fatigue syndrome, and myofascial pain. [Review]. Curr Opin Rheumatol. 1998;10:95-103. Exclude: not suitable for any question. [pmid: 9567202].
Bentall RP, Wood GC, Marrinan T, Deans C, Edwards RH. A brief mental fatigue questionnaire. Br J Clin Psychol. 1993;32:375-9. Exclude: not suitable for any question. [pmid: 7902751].
Berends GM, Peeters MF, Lepoutre JMM, Van Liebergen FJHM, Kurstjens RMA, Koolen MI. [Chronic fatigue syndrome. Does Epstein-Barr virus play any part?] [Dutch]. Ned Tijdschr Geneeskd. 1988;132:874-8. Exclude: not suitable for any question. [pmid: 3374676].
Berg D, Berg LH, Couvaras J, Harrison H. Chronic fatigue syndrome and/or fibromyalgia as a variation of antiphospholipid antibody syndrome: an explanatory model and approach to laboratory diagnosis. Blood Coagul Fibrinolysis. 1999;10:435-8. Exclude: not suitable for any question. [pmid: 10695770].
Berger RM. Chronic fatigue syndrome and women: can therapy help?. Soc Work. 1992;37:477-8. Exclude: not suitable for any question. [pmid: 1411711].
Berger S. Chronic fatigue syndrome: a self psychological perspective. Clin Soc Work J. 1993;21:71-84. Exclude: not suitable for any question.
Berkhof I, Van Dusseldorp M, Swanink CMA, Van Der Meer JWM. Dietary treatment of chronic fatigue due to Candida albicans?. Ned Tijdschr Geneeskd. 1991;135:2017-9. Exclude: not suitable for any question. [pmid: 1944668].
Berlin RM, King SL, Blythe DG. Symptomatic improvement of chronic fatigue with fluoxetine in ciguatera fish poisoning. Med J Aust. 1992;157. Exclude: not suitable for any question.
Berman DS, Wenglin BD. Chronic fatigue syndrome and psychiatric disorders. Am J Med. 1992;92. Exclude: not suitable for any question.
Berne KH. Chronic fatigue and immune dysfunction syndrome: a comprehensive analysis with emphasis on psychosocial aspects. Diss Abstr Int. 1990;50. Exclude: not suitable for any question.
Bertagnolli A, Morris S. Cognitive-behavioral interventions with chronic fatigue syndrome: a single case study. J Cogn Psychother. 1997;11:127-39. Exclude: not suitable for any question.
Bertolin Guillen JM, Bedate Villar J. [Therapeutic guidelines in chronic fatigue syndrome]. [Review] [Spanish]. Actas Luso Esp Neurol Psiquiatr Cienc Afines. 1994;22:127-30. Exclude: not suitable for any question. [pmid: 7484295].
Bertolin JM, Bertolin V. [Chronic fatigue syndrome: biologic and psychopathologic investigations]. [Review] [Spanish]. Med Clin (Barc). 1993;101:67-75. Exclude: not suitable for any question. [pmcid: 263984]. [pmid: 8510480].
Bertolin JM, Calvo J. [Chronic fatigue syndrome. To be or not to be? (editorial)]. [Spanish]. Med Clin (Barc). 1997;108:577-9. Exclude: not suitable for any question. [pmcid: 263984]. [pmid: 9280789].
Berwaerts J, Moorkens G, Abs R. Secretion of growth hormone in patients with chronic fatigue syndrome. Growth Horm IGF Res. 1998;8:127-9. Exclude: not suitable for any question. [pmid: 10990147].
Besdine RW. Chronic fatigue syndrome in the elderly: another geriatric syndrome. In: Yehuda S, Mostofsky DI, editors. Chronic fatigue syndrome. New York: Plenum Press. 1997:p.15-27. Exclude: not suitable for any question.
Bianchedi M, Croce A, Moretti A, et al. [Auditory brain stem evoked potentials in the evaluation of chronic fatigue syndrome]. [Italian]. Acta Otorhinolaryngol Ital. 1995;15:403-10. Exclude: not suitable for any question. [pmid: 8711992].
Bickerton S. How she learned to live with chronic fatigue syndrome. Nurs Times. 1999;95. Exclude: not suitable for any question.
Bjorkegren K. [Vitamin B12, chronic fatigue and injection treatment]. [Swedish]. Lakartidningen. 1999;96. Exclude: not suitable for any question.
Blackwood SK, MacHale SM, Power MJ, Goodwin GM, Lawrie SM. Effects of exercise on cognitive and motor function in chronic fatigue syndrome and depression. J Neurol Neurosurg Psychiatry. 1998;65:541-6. Exclude: sample size. [pmid: 9771781].
Blake L. Immunizations may pose risks. Nurs BC. 1992;24:7-8. Exclude: not suitable for any question. [pmid: 1532747].
Blake LS. “It's not in my head”. Can Nurse. 1993;89:29-32. Exclude: not suitable for any question. [pmid: 8348518].
Blake LS. Sick and tired. Can Nurse. 1993;89:25-8. Exclude: not suitable for any question. [pmid: 8348517].
Blakely AA, Howard RC, Sosich RM, Murdoch JC, Menkes DB, Spears GF. Psychiatric symptoms, personality and ways of coping in chronic fatigue syndrome. Psychol Med. 1991;21:347-62. Include. [pmid: 1876640].
Blatch C, Blatt T. Chronic fatigue syndrome. Role of psychological factors overemphasised. BMJ. 1994;308. Exclude: not suitable for any question.
Bleijenberg G. [Attributions and chronic fatigue]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:1510-2. Exclude: not suitable for any question. [pmid: 9543736].
Blenkiron P, Edwards R, Lynch S. Associations between perfectionism, mood, and fatigue in chronic fatigue syndrome: a pilot study. J Nerv Ment Dis. 1999;187:566-70. Include. [pmid: 10496512].
Blondel-Hill E, Shafran SD. Treatment of the chronic fatigue syndrome. A review and practical guide. [Review]. Drugs. 1993;46:639-51. Exclude: not suitable for any question. [pmid: 7506650].
Boda WL, Natelson BH, Sisto SA, Tapp WN. Gait abnormalities in chronic fatigue syndrome. J Neurol Sci. 1995;131:156-61. Exclude: not suitable for any question. [pmid: 7595641].
Bode L, Komaroff AL, Ludwig H. No serologic evidence of borna disease virus in patients with chronic fatigue syndrome. Clin Infect Dis. 1992;15. Exclude: not suitable for any question.
Bohr T. Sociosomatics and illness in CFS. Psychosom Med. 1999;61. Exclude: not suitable for any question.
Bojic I, Mijuskovic P, Lilic D, et al. [The chronic fatigue syndrome associated with Epstein-Barr virus infection]. [Serbo-Croatian (Roman)]. Vojnosanit Pregl. 1993;50:304-7. Exclude: not suitable for any question. [pmid: 8212660].
Bombardier CH, Buchwald D. Chronic fatigue, chronic fatigue syndrome, and fibromyalgia. Disability and health-care use. Med Care. 1996;34:924-30. Include. [pmid: 8792781].
Bombardier CH, Buchwald D. Outcome and prognosis of patients with chronic fatigue vs chronic fatigue syndrome. Arch Intern Med. 1995;155:2105-10. Include. [pmid: 7575071].
Bond PA. A role for herpes simplex virus in the aetiology of chronic fatigue syndrome and related disorders. [Review]. Med Hypotheses. 1993;40:301-8. Exclude: not suitable for any question. [pmid: 8394501].
Bonner D, Ron M, Chalder T, Butler S. Chronic fatigue syndrome: reply. J Neurol Neurosurg Psychiatry. 1995;58. Exclude: not suitable for any question.
Bonner D, Ron M, Chalder T, Butler S, Wessely S. Chronic fatigue syndrome: a follow up study. J Neurol Neurosurg Psychiatry. 1994;57:617-21. Include. [pmid: 8201336].
Borish L, Schmaling K, DiClementi JD, Streib J, Negri J, Jones JF. Chronic fatigue syndrome: identification of distinct subgroups on the basis of allergy and psychologic variables. J Allergy Clin Immunol. 1998;102:222-30. Exclude: not suitable for any question. [pmid: 9723665].
Borok G. Chronic fatigue syndrome: An atopic state. J Chronic Fatigue Syndr. 1998;4:39-57. Exclude: not suitable for any question.
Bosse D, Ades EW. Immunotherapy and enhanced antibody-dependent cell-mediated cytotoxicity using virally-infected target cells. J Clin Lab Immunol. 1989;29:109-10. Exclude: not suitable for any question. [pmid: 2561291].
Bou-Holaigah I, Rowe PC, Kan J, Calkins H. The relationship between neurally mediated hypotension and the chronic fatigue syndrome. JAMA. 1995;274:961-7. Exclude: not suitable for any question. [pmid: 7674527].
Bounous G, Molson J. Competition for glutathione precursors between the immune system and the skeletal muscle: pathogenesis of chronic fatigue syndrome. Med Hypotheses. 1999;53:347-9. Exclude: not suitable for any question. [pmid: 10608272].
Bowles NE, Bayston TA, Zhang HY, et al. Persistence of enterovirus RNA in muscle biopsy samples suggests that some cases of chronic fatigue syndrome result from a previous, inflammatory viral myopathy. J Med. 1993;24:145-60. Exclude: not suitable for any question. [pmid: 8409778].
Bowman MA, Kirk JK, Michielutte R, Preisser JS. Use of amantadine for chronic fatigue syndrome. Arch Intern Med. 1997;157:1264-5. Exclude: not suitable for any question. [pmid: 9183239].
Bradley CA. Psychiatric diagnoses and chronic fatigue syndrome. J Clin Psychiatry. 1990;51. Exclude: not suitable for any question.
Bradley LA, McKendree-Smith NL, Alarcon GS. Pain complaints in patients with fibromyalgia versus chronic fatigue syndrome. Curr Rev Pain. 2000;4:148-57. Exclude: not suitable for any question. [pmid: 10998728].
Braganza D, Kuruvilla A, Jacob KS. Criteria for neurasthenia. Aust N Z J Psychiatry. 2000;34. Exclude: not suitable for any question.
Brancati FL. Intravenous immunoglobulin treatment of chronic fatigue syndrome [letter]. Am J Med. 1991;91:320-1. Exclude: not suitable for any question. [pmid: 1892156].
Breau LM, McGrath PJ, Ju LH. Review of juvenile primary fibromyalgia and chronic fatigue syndrome. [Review]. J Dev Behav Pediatr. 1999;20:278-88. Exclude: not suitable for any question. [pmid: 10475602].
Bresci G, Parisi G, Metrangolo S, Bertoni M, Capria A. Comparison among different types, dosages and duration of interferon therapy in chronic hepatitis C. Clin Drug Invest. 1998;15:271-7. Exclude: not suitable for any question.
Brickman AL, Fins AI. Psychological and cognitive aspects of chronic fatigue syndrome. In: Goodnick PJ, Klimas NG, editors. Chronic fatigue and related immune deficiency syndromes. Washington: American Psychiatric Press. 1993:p.67-93.
Briggs NC, Levine PH. A comparative review of systemic and neurological symptomatology in 12 outbreaks collectively described as chronic fatigue syndrome, epidemic neuromyasthenia, and myalgic encephalomyelitis. [Review]. Clin Infect Dis. 1994;18:S32-42. Exclude: not suitable for any question. [pmid: 8148451].
Brook MG, Bannister BA, Weir WR. Interferon-alpha therapy for patients with chronic fatigue syndrome. J Infect Dis. 1993;168:791-2. Include. [pmid: 8354926].
Broom B. Somatic illness and the patient's other story: a practical integrative mind/body approach to disease for doctors and psychotherapists. London, England: Free Association Books. 1997. Exclude: not suitable for any question. [pmcid: 176006].
Brouwer B, Packer T. Corticospinal excitability in patients diagnosed with chronic fatigue syndrome. Muscle Nerve. 1994;17:1210-2. Exclude: not suitable for any question. [pmid: 7935529].
Brown S, Cox DL. Supporting pupils with chronic fatigue syndrome. Educ Psychol Pract. 1999;15:183-9. Exclude: not suitable for any question.
Brown TM, Fleishman SA, Casanova MF. Gulf War Syndrome: Polysomnographic study of eight cases. J Chronic Fatigue Syndr. 1996;2:41-51. Exclude: not suitable for any question.
Brunello N, Akiskal H, Boyer P, et al. Dysthymia: clinical picture, extent of overlap with chronic fatigue syndrome, neuropharmacological considerations, and new therapeutic vistas. [Review]. J Affect Disord. 1999;52:275-90. Exclude: not suitable for any question. [pmid: 10357046].
Bruno RL. Chronic fatigue, fainting and autonomic dysfunction: Further similarities between post-polio fatigue and chronic fatigue syndrome?. J Chronic Fatigue Syndr. 1997;3:109-16. Exclude: not suitable for any question.
Bruno RL, Creange S, Zimmerman JR, Frick NM. Elevated plasma prolactin and EEG slow wave power in post-polio fatigue: Implications for a dopamine deficiency underlying post-viral fatigue syndromes. J Chronic Fatigue Syndr. 1998;4:61-75. Exclude: not suitable for any question.
Bruno RL, Creange SJ, Frick NM. Parallels between post-polio fatigue and chronic fatigue syndrome: a common pathophysiology?. Am J Med. 1998;105:66S-73S. Exclude: not suitable for any question. [pmid: 9790485].
Bruno RL, Frick NM, Creange S, Zimmerman JR, Lewis T. Polioencephalitis and the brain fatigue generator model of post-viral fatigue syndromes. J Chronic Fatigue Syndr. 1996;2:5-27. Exclude: not suitable for any question.
Bryan CS. The chronic fatigue syndrome: caveat emptor. J S C Med Assoc. 1992;88:79-81. Exclude: not suitable for any question. [pmid: 1548854].
Buchan SJ. Chronic fatigue and women. Diss Abstr Int. 1993;53. Exclude: not suitable for any question.
Buchwald D. Fibromyalgia and chronic fatigue syndrome: similarities and differences. Rheum Dis Clin North Am. 1996;22:219-43. Include. [pmid: 9157484].
Buchwald D, Ashley RL, Pearlman T, Kith P, Komaroff AL. Viral serologies in patients with chronic fatigue and chronic fatigue syndrome. J Med Virol. 1996;50:25-30. Exclude: not suitable for any question. [pmid: 8890037].
Buchwald D, Garrity D. Comparison of patients with chronic fatigue syndrome, fibromyalgia, and multiple chemical sensitivities. Arch Intern Med. 1994;154:2049-53. Include. [pmid: 8092909].
Buchwald D, Garrity D, Pascualy R, et al. Chronic fatigue syndrome. [Review]. Toxicol Ind Health. 1992;8:157-73. Exclude: not suitable for any question.
Buchwald D, Herrell R, Ashton S, Belcourt M, Schmaling K, Goldberg J. The Chronic Fatigue Twin Registry: method of construction, composition, and zygosity assignment. Twin Res. 1999;2:203-11. Exclude: not suitable for any question. [pmid: 10555131].
Buchwald D, Komaroff AL. Review of laboratory findings for patients with chronic fatigue syndrome. [Review]. Rev Infect Dis. 1991;13:S12-8. Exclude: not suitable for any question. [pmid: 1902321].
Buchwald D, Manson SM, Pearlman T, Umali J, Kith P. Race and ethnicity in patients with chronic fatigue. J Chronic Fatigue Syndr. 1996;2:53-66. Exclude: not suitable for any question.
Buchwald D, Pascualy R, Bombardier C, Kith P. Sleep disorders in patients with chronic fatigue. Clin Infect Dis. 1994;18:S68-72. Exclude: not suitable for any question. [pmid: 8148456].
Buchwald D, Pearlman T, Kith P, Katon W, Schmaling K. Screening for psychiatric disorders in chronic fatigue and chronic fatigue syndrome. J Psychosom Res. 1997;42:87-94. Exclude: gHQ performance. [pmid: 9055216].
Buchwald D, Pearlman T, Kith P, Schmaling K. Gender differences in patients with chronic fatigue syndrome. J Gen Intern Med. 1994;9:397-401. Exclude: did not meet inclusion criteria. [pmid: 7931750].
Buchwald D, Pearlman T, Umali J, Schmaling K, Katon W. Functional status in patients with chronic fatigue syndrome, other fatiguing illnesses, and healthy individuals. Am J Med. 1996;101:364-70. Include. [pmid: 8873506].
Buchwald D, Sullivan JL, Komaroff AL. Frequency of ‘chronic active Epstein-Barr virus infection’ in a general medical practice. JAMA. 1987;257:2303-7. Include. [pmid: 3033338].
Buchwald D, Umali J, Pearlman T, Kith P, Ashley R, Wener M. Postinfectious chronic fatigue: a distinct syndrome?. Clin Infect Dis. 1996;23:385-7. Exclude: not suitable for any question. [pmid: 8842279].
Buchwald D, Umali J, Stene M. Insulin-like growth factor-I (somatomedin C) levels in chronic fatigue syndrome and fibromyalgia. J Rheumatol. 1996;23:739-42. Include. [pmid: 8730136].
Buchwald D, Umali P, Umali J, Kith P, Pearlman T, Komaroff AL. Chronic fatigue and the chronic fatigue syndrome: prevalence in a Pacific Northwest health care system. Ann Intern Med. 1995;123:81-8. Include. [pmid: 7778839].
Buchwald D, Wener MH, Komaroff AL. Anti-neuronal antibody levels in chronic fatigue syndrome patients with neurologic abnormalities. Arthritis Rheum. 1991;34:1485-6. Exclude: not suitable for any question. [pmid: 1953828].
Buchwald D, Wener MH, Pearlman T, Kith P. Markers of inflammation and immune activation in chronic fatigue and chronic fatigue syndrome. J Rheumatol. 1997;24:372-6. Exclude: not suitable for any question. [pmid: 9034999].
Buckley L, MacHale SM, Cavanagh JT, Sharpe M, Deary IJ, Lawrie SM. Personality dimensions in chronic fatigue syndrome and depression. J Psychosom Res. 1999;46:395-400. Exclude: not suitable for any question. [pmid: 10340240].
Bugard P. [The chronic fatigue syndrome]. [French]. Psychol Medicale. 1992;24:1575-81. Exclude: not suitable for any question.
Burke SG. Chronic fatigue syndrome and women: can therapy help?. Soc Work. 1992;37:35-9. Exclude: not suitable for any question. [pmid: 1542805].
Burnet RB, Yeap BB, Chatterton BE, Gaffney RD. Chronic fatigue syndrome: is total body potassium important?. Med J Aust. 1996;164. Exclude: not suitable for any question.
Butler S, Chalder T, Ron M, Wessely S. Cognitive behaviour therapy in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1991;54:153-8. Exclude: not suitable for any question. [pmid: 2019842].
Byrne E. Aetiological considerations on some conditions in the borderlands of neurology: chronic fatigue syndrome, pan allergy syndrome and repetitive strain injury--a personal view. J Clin Neurosci. 2000;7:9-12. Exclude: not suitable for any question. [pmid: 10847642].
Byrne E. The chronic fatigue syndrome: a reappraisal and unifying hypothesis. [Review]. Clin Exp Neurol. 1991;28:128-38. Exclude: not suitable for any question. [pmid: 1821821].
Bystron J, Vizinova H, Masnikosova D, et al. [Comprehensive examination of patients with chronic fatigue]. [Czech]. Prakt Zubn Lek. 1999;79:408-11. Exclude: not suitable for any question.
Caccappolo E, Kipen H, Kelly-McNeil K, et al. Odor perception: multiple chemical sensitivities, chronic fatigue, and asthma. J Occup Environ Med. 2000;42:629-38. Exclude: not suitable for any question. [pmid: 10874656].
Caffery BE, Josephson JE, Samek MJ. The ocular signs and symptoms of chronic fatigue syndrome. J Am Optom Assoc. 1994;65:187-91. Include. [pmid: 8201170].
Calabrese L, Danao T, Camara E, Wilke W. Chronic fatigue syndrome. [Review]. Am Fam Physician. 1992;45:1205-13. Exclude: not suitable for any question. [pmid: 1543105].
Calabrese LH, Danao T, Camara EG, Wilke WS. Chronic fatigue and immune dysfunction. Cleve Clin J Med. 1992;59:123-4. Exclude: not suitable for any question. [pmid: 1587013].
Calabrese LH, Davis ME, Wilke WS. Chronic fatigue syndrome and a disorder resembling Sjogren's syndrome: preliminary report. Clin Infect Dis. 1994;18:S28-31. Exclude: not suitable for any question. [pmid: 8148449].
Calder BD, Warnock PJ. Chronic fatigue syndrome. BMJ. 1991;302. Exclude: not suitable for any question.
Calder BD, Warnock PJ, McCartney RA, Bell EJ. Coxsackie B viruses and the post-viral syndrome: a prospective study in general practice. J R Coll Gen Pract. 1987;37:11-4. Exclude: not suitable for any question. [pmid: 3668915]. [pmcid: 1710584].
Caligiuri M, Murray C, Buchwald D, et al. Phenotypic and functional deficiency of natural killer cells in patients with chronic fatigue syndrome. J Immunol. 1987;139:3306-13. Exclude: not suitable for any question. [pmid: 2824604].
Camacho JM, Jason LA. Psychosocial factors show little relationship to chronic fatigue syndrome recovery. J Psychol Behav Sci. 1998;12:60-70. Exclude: not suitable for any question.
Campion PD, Dowrick CF, Edwards RH. Illness behaviour in the chronic fatigue syndrome and multiple sclerosis. Choice of multiple sclerosis as comparison condition was inappropriate [letter]. BMJ. 1995;311:1092-3. Exclude: not suitable for any question.
Campion PD, Lynch SPJ, Blenkiron P. Chronic fatigue syndrome: A UK primary care perspective. Prim Care Psychiatry. 1999;5:31-6. Exclude: not suitable for any question.
Campistol J. Chronic fatigue syndrome in adolescents. Pediatr Catalina. 1997;57:294-302. Exclude: not suitable for any question.
Camps Bansell J, Prieto Valtuena J. [Chronic fatigue syndrome (editorial)]. [Spanish]. An Med Interna. 1990;7:497-9. Exclude: not suitable for any question. [pmid: 2104093].
Camus F, Henzel D, Janowski M, Raguin G, Leport C, Vilde JL. Unexplained fever and chronic fatigue: abnormal circadian temperature pattern. Eur J Med. 1992;1:30-6. Include. [pmid: 1341974].
Cannon JG, Angel JB, Abad LW, et al. Hormonal influences on stress-induced neutrophil mobilization in health and chronic fatigue syndrome. J Clin Immunol. 1998;18:291-8. Exclude: not suitable for any question. [pmid: 9710746].
Cannon JG, Angel JB, Abad LW, et al. Interleukin-1 beta, interleukin-1 receptor antagonist, and soluble interleukin-1 receptor type II secretion in chronic fatigue syndrome. J Clin Immunol. 1997;17:253-61. Exclude: not suitable for any question. [pmid: 9168406].
Cannon JG, Angel JB, Ball RW, Abad LW, Fagioli L, Komaroff AL. Acute phase responses and cytokine secretion in chronic fatigue syndrome. J Clin Immunol. 1999;19:414-21. Exclude: not suitable for any question. [pmid: 10634215].
Capen K. Chronic fatigue syndrome get court's nod of approval as legitimate disorder. CMAJ. 1998;159:533-4. Exclude: not suitable for any question. [pmid: 9757183]. [pmcid: 1229657].
Caplan C. Chronic fatigue syndrome or just plain tired? [Review]. CMAJ. 1998;159:519-20. Exclude: not suitable for any question. [pmid: 9757180]. [pmcid: 1229654].
Capuano Sgambati JR. The relationships among anger expression, coping, impact of sickness, in chronic fatigue syndrome. Diss Abstr Int B: Sci Engineeer. 1998;59. Exclude: not suitable for any question.
Caragliano A, Caragliano V, Riolo S. [Neurasthenia-like syndrome: a modern therapeutic approach with a combined vitamin-mineral preparation]. [Italian]. Clin Ter. 1984;108:209-13. Exclude: not suitable for any question. [pmid: 6232058].
Carter BD, Edwards JF, Kronenberger WG, Michalczyk L, Marshall GS. Case control study of chronic fatigue in pediatric patients. Pediatrics. 1995;95:179-86. Exclude: not suitable for any question. [pmid: 7838632].
Carter BD, Edwards JF, Marshall GS. Chronic fatigue in children: illness or disease?. Pediatrics. 1993;91:163-4. Exclude: not suitable for any question. [pmid: 8416493].
Carter BD, Kronenberger WG, Edwards JF, Michalczyk L, Marshall GS. Differential diagnosis of chronic fatigue in children: behavioral and emotional dimensions. J Dev Behav Pediatr. 1996;17:16-21. Exclude: not suitable for any question. [pmid: 8675709].
Carter BD, Marshall GS. New developments: diagnosis and management of chronic fatigue in children and adolescents. [Review]. Curr Probl Pediatr. 1995;25:281-93. Exclude: not suitable for any question. [pmid: 8582157].
Cassel W, Archer-Duste H. The new epidemic: chronic fatigue syndrome. Pa Nurse. 1991;46:8-9. Exclude: not suitable for any question.
Castilla A, Subira ML, Civeira MP, Cuende JI. [Surface T-lymphocyte markers and monocyte dysfunction in the chronic fatigue syndrome]. [Spanish]. An Med Interna. 1992;9:207-8. Exclude: not suitable for any question. [pmid: 1581462].
Cater RE 2nd. Chronic intestinal candidiasis as a possible etiological factor in the chronic fatigue syndrome. Med Hypotheses. 1995;44:507-15. Exclude: not suitable for any question. [pmid: 7476598].
Cathebras P. Neurasthenia, spasmophilia and chronic fatigue syndromes in France. Transcult Psychiatr Res Rev. 1994;31:259-70. Exclude: not suitable for any question.
Cathebras P, Bouchou K, Charmion S, Rousset H. [Chronic fatigue syndrome: a critical review]. [Review] [French]. Rev Med Interne. 1993;14:233-42. Exclude: not suitable for any question. [pmid: 8378654].
Cathebras P, Jacquin L, le Gal M, Fayol C, Bouchou K, Rousset H. Correlates of somatic causal attributions in primary care patients with fatigue. Psychother Psychosom. 1995;63:174-80. Exclude: not suitable for any question. [pmid: 7624463].
Cau C. Yuppies's syndrome. The obscure disease of the twenty-first century?. Gazz Med Ital. 1998;157:79-83. Exclude: not suitable for any question.
CFS, #?: 4: diagnosis, #4: orthostasis/adolescenceCFS, et al. Lymphocyte phenotype and function in the chronic fatigue syndrome. J Clin Immunol. 1993;13:30-40. Exclude: not suitable for any question. [pmid: 8095270].
Chagpar A. Chronic fatigue syndrome: a prodrome to psychosis?. Can J Psychiatry. 1996;41:536-7. Exclude: not suitable for any question. [pmid: 8899244].
Chalder T. Chronic fatigue syndrome. Br J Psychiatry. 1995;167:549-50. Exclude: not suitable for any question. [pmid: 8829730].
Chalder T, Berelowitz G, Pawlikowska T, et al. Development of a fatigue scale. J Psychosom Res. 1993;37:147-53. Exclude: not suitable for any question. [pmid: 8463991].
Chalder T, Butler S, Wessely S. In-patient treatment of chronic fatigue syndrome. Behav Cogn Psychother. 1996;24:351-65. Exclude: not suitable for any question.
Chalder T, Deale A. Don't dismiss exercise. Nurs Times. 1993;89:22-3. Exclude: not suitable for any question.
Chalder T, Deale A, Wessely S. Cognitive behavioral therapy for chronic fatigue syndrome [letter]. Clin Infect Dis. 1995;20:717-8. Exclude: not suitable for any question. [pmid: 7756505].
Chalder T, Deale A, Wessely S, Marks I. Cognitive behavior therapy for chronic fatigue syndrome [letter]. Am J Med. 1995;98:419-20. Exclude: not suitable for any question. [pmid: 7709961].
Chalder T, Power MJ, Wessely S. Chronic fatigue in the community: ‘a question of attribution’. Psychol Med. 1996;26:791-800. Exclude: not suitable for any question. [pmid: 8817714].
Chalder T, Wallace P, Wessley S. Self-help treatment of chronic fatigue in the community: A randomized controlled trial. Br J Health Psychol. 1997;2:189-97. Exclude: not suitable for any question.
Chalder T, Wessely S, Wallace P, Hirsch S, Wright D. Viral illness and chronic fatigue (syndrome). Lancet. 1995;346. Exclude: not suitable for any question.
Chambers CR. Fireworks over fibromyalgia, CFS, and IBS. Postgrad Med. 1997;102. Exclude: not suitable for any question.
Chambers MJ, Docktor BJ. Fatigue scale lacks adequate validation. Psychiatry Res. 1993;46:207-10. Exclude: not suitable for any question. [pmid: 8483979].
Chao CC, Gallagher M, Phair J, Peterson PK. Serum neopterin and interleukin-6 levels in chronic fatigue syndrome. J Infect Dis. 1990;162:1412-3. Exclude: not suitable for any question.
Chao CC, Janoff EN, Hu SX, et al. Altered cytokine release in peripheral blood mononuclear cell cultures from patients with the chronic fatigue syndrome. Cytokine. 1991;3:292-8. Exclude: not suitable for any question. [pmid: 1873478].
Charnock D, Shepperd S, Needham G, Gann R. DISCERN: an instrument for judging the quality of written consumer health information on treatment choices. J Epidemiol Community Health. 1999;53:105-11. Exclude: not suitable for any question. [pmid: 10396471].
Chaudhuri A, Behan PO. Chronic fatigue syndrome is an acquired neurological channelopathy. Hum Psychopharmacol Clin Exper. 1999;14:7-17. Exclude: not suitable for any question.
Chaudhuri A, Behan WMH, Behan PO. Chronic fatigue syndrome. Proc R Coll Physicians Edinburgh. 1998;28:150-63.
Chaudhuri A, Majeed T, Dinan T, Behan PO. Chronic fatigue syndrome: a disorder of central cholinergic transmission. J Chronic Fatigue Syndr. 1997;3:3-16. Exclude: not suitable for any question.
Chaudhuri A, Watson WS, Pearn J, Behan PO. The symptoms of chronic fatigue syndrome are related to abnormal ion channel function. Med Hypotheses. 2000;54:59-63. Exclude: not suitable for any question. [pmid: 10790725].
Cheraskin E. Vitamin C and fatigue. J Orthomol Med. 1994;9:39-45. Exclude: not suitable for any question.
Cherfas J. Chronic fatigue as chameleon [news]. Science. 1990;249. Exclude: not suitable for any question.
Chester A. Unexplained chronic fatigue is linked to sinusitis. Am Fam Physician. 1991;44. Exclude: not suitable for any question.
Chester AC. Chronic fatigue cured by nasal surgery. Md Med J. 1993;42:365-7. Exclude: not suitable for any question. [pmid: 8515694].
Chester AC. Chronic fatigue relieved by a nasal dilator. Am J Otolaryngol. 1993;14. Exclude: not suitable for any question.
Chester AC. Chronic fatigue syndrome. JAMA. 1998;279. Exclude: not suitable for any question.
Chester AC. Chronic fatigue syndrome criteria in patients with other forms of unexplained chronic fatigue. J Psychiatr Res. 1997;31:45-50. Exclude: n=<30. [pmid: 9201646].
Chester AC. Neurally mediated hypotension, chronic fatigue syndrome and upper aerodigestive tract reflexes [letter]. Integr Physiol Behav Sci. 1997;32:160-1. Exclude: letter. [pmid: 9229243].
Chester AC, Levine PH. Concurrent sick building syndrome and chronic fatigue syndrome: epidemic neuromyasthenia revisited. Clin Infect Dis. 1994;18:S43-8. Exclude: not suitable for any question. [pmid: 8148452].
Chester AC, Levine PH. The natural history of concurrent sick building syndrome and chronic fatigue syndrome. J Psychiatr Res. 1997;31:51-7. Exclude: n<30. [pmid: 9201647].
Cheung FM. The indigenization of neurasthenia in Hong Kong. Cult Med Psychiatry. 1989;13:227-41. Exclude: not suitable for any question. [pmid: 2766796].
Chia JK, Chia LY. Chronic Chlamydia pneumoniae infection: a treatable cause of chronic fatigue syndrome. Clin Infect Dis. 1999;29:452-3. Exclude: not suitable for any question. [pmid: 10476765].
Chilton SA. Cognitive behaviour therapy for the chronic fatigue syndrome. Evening primrose oil and magnesium have been shown to be effective [letter]. BMJ. 1996;312. Exclude: not suitable for any question.
Cho WK, Stollerman GH. Chronic fatigue syndrome. [Review]. Hosp Pract (Off Ed). 1992;27:221-4, 227-30, 233-6. Exclude: not suitable for any question.
Choppa PC, Vojdani A, Tagle C, Andrin R, Magtoto L. Multiplex PCR for the detection of Mycoplasma fermentans, M. hominis and M. penetrans in cell cultures and blood samples of patients with chronic fatigue syndrome. Mol Cell Probes. 1998;12:301-8. Exclude: not suitable for any question. [pmid: 9778455].
Christodoulou C, Deluca J, Johnson SK, Lange G, Gaudino EA, Natelson BH. Examination of cloninger's basic dimensions of personality in fatiguing illness: chronic fatigue syndrome and multiple sclerosis. J Psychosom Res. 1999;47:597-607. Exclude: not suitable for any question. [pmid: 10661606].
Christodoulou C, DeLuca J, Lange G, et al. Relation between neuropsychological impairment and functional disability in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1998;64:431-4. Exclude: not suitable for any question. [pmid: 9576531].
Christodoulou C, DeLuca J, Johnson SK, Lange G, Natelson BH. Efforts to reduce heterogeneity in chronic fatigue syndrome research. In: Yehuda S, Mostofsky DI, editors. Chronic fatigue syndrome. New York: Plenum Press. 1997:p.73-94. Exclude: not suitable for any question.
Chubb HL, Jones I, Hillier J, et al. Chronic fatigue syndrome--personality and attributional style of patients in comparison to healthy controls and depressed individuals. J Ment Health. 1999;8:351-9. Exclude: not suitable for any question.
Ciba Foundation Symposium. Chronic Fatigue Syndrome. Symposium proceedings. London, 12-14 May 1992. Ciba Found Symp. 1993;173:1-357. Exclude: not suitable for any question. [pmid: 8098280].
Clague JE, Edwards RH, Jackson MJ. Intravenous magnesium loading in chronic fatigue syndrome [letter]. Lancet. 1992;340:124-5. Exclude: not suitable for any question.
Clapp LL, Richardson MT, Smith JF, Wang M, Clapp AJ, Pieroni RE. Acute effects of thirty minutes of light-intensity, intermittent exercise on patients with chronic fatigue syndrome. Phys Ther. 1999;79:749-56. Exclude: not suitable for any question. [pmid: 10440661].
Clark MR, Katon W, Russo J, Kith P, Sintay M, Buchwald D. Chronic fatigue: risk factors for symptom persistence in a 2 1/2-year follow-up study. Am J Med. 1995;98:187-95. Include. [pmid: 7847436].
Clarke JN. Chronic fatigue syndrome: gender differences in the search for legitimacy. Aust NZ J Ment Health Nurs. 1999;8:123-33. Exclude: not suitable for any question.
Clarke JN. The search for legitimacy and the “expertization” of the lay person: the case of chronic fatigue syndrome. Soc Work Health Care. 2000;30:73-93. Exclude: not suitable for any question. [pmid: 10880009].
Clauw DJ, Chrousos GP. Chronic pain and fatigue syndromes: overlapping clinical and neuroendocrine features and potential pathogenic mechanisms. [Review]. Neuroimmunomodulation. 1997;4:134-53. Exclude: not suitable for any question. [pmid: 9500148].
Cleare AJ, Bearn J, Allain T, et al. Contrasting neuroendocrine responses in depression and chronic fatigue syndrome. J Affect Disord. 1995;34:283-9. Exclude: not suitable for any question. [pmid: 8550954].
Cleare AJ, Heap E, Malhi GS, Wessely S, O'Keane V, Miell J. Low-dose hydrocortisone in chronic fatigue syndrome: a randomised crossover trial. Lancet. 1999;353:455-8. Include. [pmid: 9989716].
Cleare AJ, O'Keane V. Re: Endocrine responses to fenfluramine challenge in chronic fatigue syndrome. Can J Psychiatry. 1996;41:129-31. Exclude: not suitable for any question. [pmid: 8705960].
Cleare AJ, Wessely SC. Chronic fatigue syndrome: a stress disorder?. [Review]. Br J Hosp Med. 1996;55:571-4. Exclude: not suitable for any question. [pmid: 8735034].
Cleare AJ, Wessely SC. Fluoxetine and chronic fatigue syndrome [letter]. Lancet. 1996;347:1770; discussion 1771-2. Exclude: not suitable for any question.
Cleary KJ, White PD. Gilbert's and chronic fatigue syndromes in men. Lancet. 1993;341. Exclude: not suitable for any question.
Clemenger ACI. Functional somatic syndromes. Ann Intern Med. 2000;132. Exclude: not suitable for any question.
Clements A, Sharpe M, Simkin S, Borrill J, Hawton K. Chronic fatigue syndrome: a qualitative investigation of patients' beliefs about the illness. J Psychosom Res. 1997;42:615-24. Exclude: not suitable for any question. [pmid: 9226609].
Clements GB, McGarry F, Nairn C, Galbraith DN. Detection of enterovirus-specific RNA in serum: the relationship to chronic fatigue. J Med Virol. 1995;45:156-61. Exclude: not suitable for any question. [pmid: 7775934].
Cohen MM Jr. Syndrome designations. J Med Genet. 1976;13:266-70. Exclude: not suitable for any question. [pmid: 957375].
Cohen P. Tired of waiting. Nurs Times. 1997;93:29-31. Exclude: not suitable for any question. [pmid: 9095926].
Cohen SI. Increased illness experience preceding chronic fatigue syndrome. J R Coll Physicians Lond. 1998;32. Exclude: not suitable for any question.
Cohn S. Taking time to smell the roses: accounts of people with chronic fatique syndrome and their struggle for legitimisation. Anthropol Med. 1999;6:195-215. Exclude: not suitable for any question.
Chronic fatigue syndrome: clinical practice guidelines [Web page]. Collège des Médecins de Quèbec. Last updated: 8/1998. Available from: URL: http://www.cmq.org/Fatigang.pdfExclude: not suitable for any question.
Collignon P. Immunoglobulin treatment for chronic fatigue syndrome [letter]. Am J Med. 1991;91:443-4. Exclude: not suitable for any question. [pmid: 1951395].
Colquhoun D, Senn S. Is NADH effective in the treatment of chronic fatigue syndrome?. Ann Allergy Asthma Immunol. 2000;84:639-40. Include. [pmid: 10875497].
Chronic fatigue syndrome. Committee for Science and Education, Medical Association of South Africa. S Afr Med J. 1995;85:780-2. Exclude: not suitable for any question. [pmid: 8553151].
Comtois R. [Chronic fatigue: myth or reality?]. [Review] [French]. Union Med Can. 1991;120:10-6. Exclude: not suitable for any question. [pmid: 2021024].
Conn HF, Clohecy RJ, Conn RB. Current Diagnosis. Philadelphia (PA): W.B. Saunders. 1997. Include.
Connolly S, Fowler CJ. Single fibre EMG studies in chronic fatigue syndrome: a reappraisal. J Neurol Neurosurg Psychiatry. 1994;57. Exclude: not suitable for any question.
Connolly S, Smith DG, Doyle D, Fowler CJ. Chronic fatigue: electromyographic and neuropathological evaluation. J Neurol. 1993;240:435-8. Exclude: not suitable for any question. [pmid: 8410086].
Conti F, Magrini L, Priori R, Valesini G, Bonini S. Eosinophil cationic protein serum levels and allergy in chronic fatigue syndrome. Allergy. 1996;51:124-7. Exclude: not suitable for any question. [pmid: 8738520].
Conti F, Pittoni V, Sacerdote P, Priori R, Meroni PL, Valesini G. Decreased immunoreactive beta-endorphin in mononuclear leucocytes from patients with chronic fatigue syndrome. Clin Exp Rheumatol. 1998;16:729-32. Exclude: not suitable for any question. [pmid: 9844768].
Conti F, Priori R, De Petrillo G, Rusconi AC, Arpino C, Valesini G. Prevalence of chronic fatigue syndrome in Italian patients with persistent fatigue. Ann Ital Med Int. 1994;9:219-22. Exclude: not suitable for any question. [pmid: 7893570].
Cook NF, Boore JR. Managing patients suffering from acute and chronic fatigue. [Review]. Br J Nurs. 1997;6:811-5. Exclude: not suitable for any question. [pmid: 9283306].
Cook TD, Campbell DT. Quasi-experimentation: design and analysis issues for field settings. Chicago: Rand McNally College Pub Co. 1979. Exclude: not suitable for any question. [pmcid: 281483].
Cope H. Fatigue: a non-specific complaint?. Int Rev Psychiatry. 1992;4:273-9. Exclude: not suitable for any question.
Cope H, David A, Pelosi A, Mann A. Chronic fatigue syndrome. Lancet. 1995;345. Exclude: not suitable for any question.
Cope H, David A, Pelosi A, Mann A. Predictors of chronic “postviral” fatigue. Lancet. 1994;344:864-8. Exclude: not suitable for any question. [pmid: 7916407].
Cope H, David AS. Neuroimaging in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1996;60:471-3. Exclude: not suitable for any question. [pmid: 8778248].
Cope H, David AS. Outcome in the chronic fatigue syndrome [letter]. BMJ. 1992;305. Exclude: not suitable for any question.
Cope H, Mann A, Pelosi A, David A. Psychosocial risk factors for chronic fatigue and chronic fatigue syndrome following presumed viral illness: a case-control study. Psychol Med. 1996;26:1197-209. Exclude: not suitable for any question. [pmid: 8931166].
Cope H, Pernet A, Kendall B, David A. Cognitive functioning and magnetic resonance imaging in chronic fatigue. Br J Psychiatry. 1995;167:86-94. Exclude: not suitable for any question. [pmid: 7551617].
Cordero DL, Sisto SA, Tapp WN, LaManca JJ, Pareja JG, Natelson BH. Decreased vagal power during treadmill walking in patients with chronic fatigue syndrome. Clin Auton Res. 1996;6:329-33. Exclude: not suitable for any question. [pmid: 8985621].
Cornelison CM, Gray GC. Topical bibliography of published works regarding the health of veterans of the Persian Gulf war. In: US Naval Health Research Center report. San Diego (CA): US Naval Health Research Center. 1995:p. 71. No. 95-3C.
Corrado G, Riezzo G, Rea P, Pacchiarotti C, Cavaliere M, Cardi E. Normal gastric emptying time and myoelectrical activity in an adolescent with chronic fatigue syndrome. Ital J Gastroenterol Hepatol. 1998;30:444-5. Exclude: not suitable for any question.
Costa DC, Tannock C, Brostoff J. Brainstem perfusion is impaired in chronic fatigue syndrome. QJM. 1995;88:767-73. Exclude: not suitable for any question. [pmid: 8542261].
Cotton P. Treatment proposed for chronic fatigue syndrome; research continues to compile data on disorder [news]. JAMA. 1991;266:2667-8. Exclude: not suitable for any question. [pmid: 1942408].
Coulter P. Chronic fatigue syndrome: An old virus with a new diagnosis. J Community Health Nurs. 1988;5:87-95. Exclude: not suitable for any question. [pmid: 2836564].
Covington EC. Depression and chronic fatigue in the patient with chronic pain. Prim Care. 1991;18:341-58. Exclude: not suitable for any question. [pmid: 1876618].
Cox D, Findley L. Chronic fatigue syndrome in adolescence. Br J Hosp Med. 1994;51. Exclude: not suitable for any question.
Cox DL. Chronic fatigue. Br J Occup Ther. 1999;62:434-5. Exclude: not suitable for any question.
Cox DL, Findley LJ. Chronic fatigue syndrome [letter]. BMJ. 1993;307. Exclude: not suitable for any question.
Cox DL, Findley LJ. Is chronic fatigue syndrome treatable in an NHS environment?. Clin Rehabil. 1994;8:76-80. Exclude: not suitable for any question.
Cox DL, Findley LJ. The management of chronic fatigue syndrome in an inpatient setting: presentation of an approach and perceived outcome. Br J Occup Ther. 1998;61:405-9. Exclude: not suitable for any question.
Cox IM, Campbell MJ, Dowson D. Red blood cell magnesium and chronic fatigue syndrome. Lancet. 1991;337:757-60. Include. [pmid: 1672392].
Crocq L. [Research about fatigue in France over the past 20 years]. [Review] [French]. Encephale. 1994;20:615-8. Exclude: not suitable for any question. [pmid: 7843059].
Crofford LJ. The hypothalamic-pituitary-adrenal stress axis in fibromyalgia and chronic fatigue syndrome. [Review]. Z Rheumatol. 1998;57:67-71. Exclude: not suitable for any question. [pmid: 10025087].
Crofford LJ, Demitrack MA. Evidence that abnormalities of central neurohormonal systems are key to understanding fibromyalgia and chronic fatigue syndrome. [Review]. Rheum Dis Clin North Am. 1996;22:267-84. Exclude: not suitable for any question. [pmid: 8860799].
Crowley JP. Chronic fatigue syndrome. R I Med J. 1991;74:310-1. Exclude: not suitable for any question. [pmid: 1896756].
Csef H. [Differential diagnosis of chronic fatigue]. [German]. Z Allgemeinmed. 1998;74:674-8. Exclude: not suitable for any question.
Csef H. [Similarities of chronic fatigue syndrome, fibromyalgia and multiple chemical sensitivity]. [Review] [German]. Dtsch Med Wochenschr. 1999;124:163-9. Exclude: not suitable for any question. [pmid: 10081482].
Cuenca E, Alamo C, Lopez-Munoz F, Coullaut-Jaureigui J. Venlafaxina: indicaciones terapeuticas potenciales: venlafaxine: potential therapeutic indications. Anales De Psiquiatria. 1998;14:203-7. Exclude: not suitable for any question.
Cuende JI, Civeira P, Diez N, Prieto J. [High prevalence without reactivation of herpes virus 6 in subjects with chronic fatigue syndrome]. [Spanish]. An Med Interna. 1997;14:441-4. Exclude: not suitable for any question. [pmid: 9453750].
Cunningham L, Bowles NE, Archard LC. Persistent virus infection of muscle in postviral fatigue syndrome. [Review] [48 refs]. Br Med Bull. 1991;47:852-71. Exclude: not suitable for any question. [pmid: 1665379].
Cuykx V, Van Houdenhove B, Neerinckx E. Childhood abuse, personality disorder and chronic fatigue syndrome. Gen Hosp Psychiatry. 1998;20:382-4. Exclude: not suitable for any question. [pmid: 9854653].
Czarnowski D, Panasiuk B, Wiercinska-Drapalo A, Puzanowska B, Prokopowicz D. [Chronic fatigue syndrome]. [Review] [Polish]. Pol Arch Med Wewn. 1996;96:161-4. Exclude: not suitable for any question. [pmid: 9122005].
Dale JK, Di Bisceglie AM, Hoofnagle JH, Straus SE. Chronic fatigue syndrome: lack of association with hepatitis C virus infection. J Med Virol. 1991;34:119-21. Exclude: not suitable for any question. [pmid: 1653818].
Dale JK, Straus SE. The chronic fatigue syndrome: considerations relevant to children and adolescents. [Review]. Adv Pediatr Infect Dis. 1992;7:63-83. Exclude: not suitable for any question. [pmid: 1616687].
Dantzer R. [Current studies on the neurobiology of chronic fatigue syndrome]. [Review] [French]. Encephale. 1994;20:597-602. Exclude: not suitable for any question. [pmid: 7843056].
Daugherty SA, Henry BE, Peterson DL, Swarts RL, Bastien S, Thomas RS. Chronic fatigue syndrome in northern Nevada. Rev Infect Dis. 1991;13:S39-44. Exclude: not suitable for any question. [pmid: 1850542].
David A, Cope H, Pelosi A, Mann A. Viral illness and chronic fatigue (syndrome). Lancet. 1995;346. Exclude: not suitable for any question.
David A, Pelosi A, McDonald E, et al. Tired, weak, or in need of rest: fatigue among general practice attenders. BMJ. 1990;301:1199-202. Include. [pmid: 2261560]. [pmcid: 1664364].
David A, Wessely S. Chronic fatigue syndrome. Lancet. 1996;348. Exclude: not suitable for any question.
David AS, Wessely S, Pelosi AJ. Chronic fatigue syndrome: signs of a new approach. [Review]. Br J Hosp Med. 1991;45:158-63. Exclude: not suitable for any question. [pmid: 2029596].
David AS, Wessely S, Pelosi AJ. Postviral fatigue syndrome: time for a new approach. [Review]. Br Med J (Clin Res Ed). 1988;296:696-9. Exclude: not suitable for any question.
Davison KP, Pennebaker JW, Petrie KJ. Virtual naratives: illness representations in online support groups. In: Weinman JA. Perceptions of health and illness: current research and applications. Singapore: Harwood Academic Publishers. 1997:p.463-86. Exclude: not suitable for any question.
De Becker P, De Meirleir K, Joos E, et al. Dehydroepiandrosterone (DHEA) response to i.v. ACTH in patients with chronic fatigue syndrome. Horm Metab Res. 1999;31:18-21. Exclude: not suitable for any question. [pmid: 10077344].
De Becker P, Dendale P, De Meirleir K, Campine I, Vandenborne K, Hagers Y. Autonomic testing in patients with chronic fatigue syndrome. Am J Med. 1998;105:22S-6S. Exclude: not suitable for any question.
de Jong LW, Prins JB, Fiselier TJ, Weemaes CM, Meijer-van den BEM, Bleijenberg G. [Chronic fatigue syndrome in young persons]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:1513-6. Exclude: not suitable for any question. [pmid: 9543737].
de Loos WS. Chronic fatigue syndrome: fatigue of unknown origin. Eur J Clin Invest. 1997;27:268-9. Exclude: not suitable for any question. [pmid: 9134373].
De Lorenzo F, Hargreaves J, Kakkar VV. Lung function test findings in patients with chronic fatigue syndrome (CFS). Aust N Z J Med. 1996;26:563-4. Exclude: not suitable for any question. [pmid: 8873946].
De Lorenzo F, Hargreaves J, Kakkar VV. Pathogenesis and management of delayed orthostatic hypotension in patients with chronic fatigue syndrome. Clin Auton Res. 1997;7:185-90. Exclude: not suitable for any question. [pmid: 9292244].
De Lorenzo F, Hargreaves J, Kakkar VV. Phosphate diabetes in patients with chronic fatigue syndrome. Postgrad Med J. 1998;74:229-32. Exclude: not suitable for any question. [pmid: 9683977].
De Lorenzo F, Hargreaves J, Kakkar VV. Possible relationship between chronic fatigue and postural tachycardia syndromes. Clin Auton Res. 1996;6:263-4. Exclude: not suitable for any question. [pmid: 8899252].
De Lorenzo F, Kakkar VV. Twenty-four-hour urine analysis in patients with orthostatic hypotension and chronic fatigue syndrome (CFS). Aust N Z J Med. 1996;26:849-50. Exclude: not suitable for any question. [pmid: 9028523].
De Lorenzo F, Xiao H, Mukherjee M, et al. Chronic fatigue syndrome: physical and cardiovascular deconditioning. QJM. 1998;91:475-81. Exclude: not suitable for any question. [pmid: 9797930].
De Meirleir K, Bisbal C, Campine I, et al. A 37 kDa 2-5A binding protein as a potential biochemical marker for chronic fatigue syndrome. Am J Med. 2000;108:99-105. Exclude: not suitable for any question. [pmid: 11126321].
De Ridder DT, Schreurs KMG, Bensing JM. Adaptive tasks, coping and quality of life of chronically ill patients: the cases of parkinson's disease and chronic fatigue syndrome. J Health Psychol. 1998;3:87-101. Exclude: not suitable for any question.
De Vinci C, Levine PH, Pizza G, et al. Lessons from a pilot study of transfer factor in chronic fatigue syndrome. Biotherapy. 1996;9:87-90. Include. [pmid: 8993764].
De Vries J, Van Heck GL. The World Health Organization quality of life assessment instrument (WHOqol-100): validation study with the Dutch version. Eur J Psychol Assessment. 1997;13:164-78. Exclude: not suitable for any question.
Deale A, Chalder T, Marks I, Wessely S. Cognitive behavior therapy for chronic fatigue syndrome: a randomized controlled trial. Am J Psychiatry. 1997;154:408-14. Include. [pmid: 9054791].
Deale A, Chalder T, Wessely S. Cognitive behavior therapy for chronic fatigue syndrome: ms. Deale and colleagues reply. Am J Psychiatry. 1998;155:1461-2. Exclude: not suitable for any question.
Deale A, Chalder T, Wessely S. Commentary on: randomised, double-blind, placebo-controlled trial of fluoxetine and graded exercise for chronic fatigue syndrome. Br J Psychiatry. 1998;172:491-2. Exclude: not suitable for any question. [pmid: 9828988].
Deale A, Chalder T, Wessely S. Illness beliefs and treatment outcome in chronic fatigue syndrome. J Psychosom Res. 1998;45:77-83. Include. [pmid: 9720857].
Deale A, David AS. Chronic fatigue syndrome: evaluation and management. J Neuropsychiatry Clin Neurosci. 1994;6:189-94. Exclude: not suitable for any question. [pmid: 8044045].
Deale A, Husain K., Chalder T, Wessely S. Long term outcome of cognitive behaviour therapy versus relaxation for chronic fatigue syndrome: a 5-year follow-up study. [unpublished manuscript]. Include.
Deale A, Wessely S. Diagnosis of psychiatric disorder in clinical evaluation of chronic fatigue syndrome. J R Soc Med. 2000;93:310-2. Exclude: not suitable for any question. [pmid: 10911826]. [pmcid: 1298034].
Deary IJ. A taxonomy of medically unexplained symptoms. J Psychosom Res. 1999;47:51-9. Include. [pmid: 10511420].
Dechene L. Chronic fatigue syndrome: influence of histamine, hormones and electrolytes. [Review]. Med Hypotheses. 1993;40:55-60. Exclude: not suitable for any question. [pmid: 8455468].
DeFreitas E, Hilliard B, Cheney PR, et al. Retroviral sequences related to human T-lymphotropic virus type II in patients with chronic fatigue immune dysfunction syndrome. Proc Natl Acad Sci U S A. 1991;88:2922-6. Exclude: not suitable for any question. [pmcid: 51352]. [pmid: 1672770].
DeGroot HA. Symptomatology, uncertainty, hope, and anxiety in chronic fatigue immune dysfunction syndrome. Diss Abstr Int. 1990;51:1741-2. Exclude: not suitable for any question.
Delage G, Salit I, Pennie R, Alary M, Duval B, Ward B. [The possible relation between hepatitis B vaccination and chronic fatigue syndrome]. [French]. Union Med Can. 1993;122:278-9. Exclude: not suitable for any question. [pmid: 8367918].
Delbanco TL, Daley J, Hartman EE. A 56-year-old woman with chronic fatigue syndrome, 1 year later. JAMA. 1998;280. Exclude: not suitable for any question.
DeLuca J, Johnson SK, Beldowicz D, Natelson BH. Neuropsychological impairments in chronic fatigue syndrome, multiple sclerosis, and depression. J Neurol Neurosurg Psychiatry. 1995;58:38-43. Exclude: not suitable for any question. [pmid: 7823065].
DeLuca J, Johnson SK, Ellis SP, Natelson BH. Cognitive functioning is impaired in patients with chronic fatigue syndrome devoid of psychiatric disease. J Neurol Neurosurg Psychiatry. 1997;62:151-5. Exclude: not suitable for any question. [pmid: 9048715].
DeLuca J, Johnson SK, Ellis SP, Natelson BH. Sudden vs gradual onset of chronic fatigue syndrome differentiates individuals on cognitive and psychiatric measures. J Psychiatr Res. 1997;31:83-90. Exclude: not suitable for any question. [pmid: 9201650].
DeLuca J, Johnson SK, Natelson BH. Information processing efficiency in chronic fatigue syndrome and multiple sclerosis. Arch Neurol. 1993;50:301-4. Exclude: not suitable for any question. [pmid: 8442710].
Demitrack MA. Chronic fatigue syndrome: a disease of the hypothalamic-pituitary-adrenal axis?. [Review]. Ann Med. 1994;26:1-5. Exclude: not suitable for any question. [pmid: 8166984].
Demitrack MA. Chronic fatigue syndrome and fibromyalgia. Dilemmas in diagnosis and clinical management. [Review]. Psychiatr Clin North Am. 1998;21:671-92. Exclude: not suitable for any question. [pmid: 9774804].
Demitrack MA. Neuroendocrine aspects of chronic fatigue syndrome: a commentary. [Review]. Am J Med. 1998;105:11S-4S. Exclude: not suitable for any question. [pmid: 9790476].
Demitrack MA. Neuroendocrine correlates of chronic fatigue syndrome: a brief review. J Psychiatr Res. 1997;31:69-82. Exclude: not suitable for any question. [pmid: 9201649].
Demitrack MA. Neuroendocrine research strategies in chronic fatigue syndrome. In: Goodnick PJ, Klimas NG, editors. Chronic fatigue and related immune deficiency syndromes. Washington: American Psychiatric Press. 1993:p.45-66.
Demitrack MA. The psychobiology of chronic fatigue: the central nervous system as a final common pathway. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: The Guilford Press. 1996:p.72-109. Exclude: not suitable for any question.
Demitrack MA. Psychopharmacological principles in the treatment of chronic fatigue syndrome. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.263-86. Exclude: not suitable for any question.
Demitrack MA, Abbey SE. Historical overview and evolution of contemporary definitions of chronic fatigue states. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: The Guilford Press. 1996:p.3-35. Exclude: not suitable for any question.
Demitrack MA, Crofford LJ. Evidence for and pathophysiologic implications of hypothalamic-pituitary-adrenal axis dysregulation in fibromyalgia and chronic fatigue syndrome. [Review]. Ann N Y Acad Sci. 1998;840:684-97. Exclude: not suitable for any question. [pmid: 9629295].
Demitrack MA, Engleberg NC. Chronic fatigue syndrome. Curr Ther Endocrinol Metab. 1994;5:135-42. Exclude: not suitable for any question. [pmid: 7704698].
Demitrack MA, Engleberg NC. Chronic fatigue syndrome. [Review]. Curr Ther Endocrinol Metab. 1997;6:152-60. Exclude: not suitable for any question. [pmid: 9174726].
Demitrack MA, Gold PW, Dale JK, Krahn DD, Kling MA, Straus SE. Plasma and cerebrospinal fluid monoamine metabolism in patients with chronic fatigue syndrome: preliminary findings. Biol Psychiatry. 1992;32:1065-77. Exclude: not suitable for any question. [pmid: 1282370].
Demitrack MA, Greden JF. Chronic fatigue syndrome: the need for an integrative approach. [Review]. Biol Psychiatry. 1991;30:747-52. Exclude: not suitable for any question. [pmid: 1751618].
Demitrack MA, Abbey SE., editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996. Exclude: not suitable for any question. [pmcid: 190016].
Deniker P, Peron-Magnan P, Eliet-Le Guillou C, Hanus M. [Clinical trials of an original antidepressive amphetamine, d-l-parachloro-N-methyl-amphetamine or Ro 46861]. [French]. Therapie. 1971;26:219-26. Exclude: not suitable for any question. [pmid: 5576175].
Denman AM. The chronic fatigue syndrome: a return to common sense. [Review]. Postgrad Med J. 1990;66:499-501. Exclude: not suitable for any question. [pmid: 2217006].
Denz-Penhey H, Murdoch JC. General practitioners acceptance of the validity of chronic fatigue syndrome as a diagnosis. N Z Med J. 1993;106:122-4. Exclude: not suitable for any question. [pmid: 8474729].
Denz-Penhey H, Murdoch JC. Service delivery for people with chronic fatigue syndrome: a pilot action research study. Fam Pract. 1993;10:14-8. Exclude: not suitable for any question. [pmid: 8477887].
Dessein PH, Shipton EA. Hydrocortisone and chronic fatigue syndrome [letter]. Lancet. 1999;353. Exclude: not suitable for any question.
Deulofeu R, Gascon J, Gimenez N, Corachan M. Magnesium and chronic fatigue syndrome [letter]. Lancet. 1991;338. Exclude: not suitable for any question.
Devitt NF. Chronic fatigue syndrome. JAMA. 1998;279. Exclude: not suitable for any question.
Di Luca D, Zorzenon M, Mirandola P, Colle R, Botta GA, Cassai E. Human herpesvirus 6 and human herpesvirus 7 in chronic fatigue syndrome. J Clin Microbiol. 1995;33:1660-61. Exclude: not suitable for any question. [pmcid: 228240]. [pmid: 7650209].
Diamantis I. [A case from practice (343). Chronic fatigue syndrome following Lyme borreliosis]. [German]. Schweiz Rundsch Med Prax. 1996;85:287-8. Exclude: not suitable for any question. [pmid: 8685574].
Dickinson CJ. Chronic fatigue syndrome--aetiological aspects. [Review]. Eur J Clin Invest. 1997;27:257-67. Exclude: not suitable for any question. [pmid: 9134372].
Dille JR. Chronic fatigue syndrome. Aviat Space Environ Med. 1991;62:1008-9. Exclude: not suitable for any question. [pmid: 1764001].
Dimitrov M, Grafman J. Neuropsychological assessment of chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:31-42. Exclude: not suitable for any question.
Dimova P, Belopitova L, Yotova R. Neurological syndromes in chronic recurrent Epstein-Barr virus infection in two children - Diagnostic and differential diagnostic problems. Pediatriya. 1997;36:34-6, 45. Exclude: not suitable for any question.
Dinan TG, Majeed T, Lavelle E, Scott LV, Berti C, Behan P. Blunted serotonin-mediated activation of the hypothalamic-pituitary-adrenal axis in chronic fatigue syndrome. Psychoneuroendocrinology. 1997;22:261-7. Exclude: not suitable for any question. [pmid: 9226729].
DiPino RK, Kane RL. Neurocognitive functioning in chronic fatigue syndrome. [Review]. Neuropsychol Rev. 1996;6:47-60. Exclude: not suitable for any question. [pmid: 9144668].
Djaldetti R, Ziv I, Achiron A, Melamed E. Fatigue in multiple sclerosis compared with chronic fatigue syndrome: A quantitative assessment. Neurology. 1996;46:632-5. Exclude: not suitable for any question. [pmid: 8618658].
Dobbins JG, Randall B, Reyes M, Steele L, Livens EA, Reeves WC. The prevalence of chronic fatiguing illnesses among adolescents in the United States. J Chronic Fatigue Syndr. 1997;3:15-28. Exclude: not suitable for any question.
Dodge JH, Kita MW. The chronic fatigue syndrome. Ann Intern Med. 1995;123. Exclude: not suitable for any question.
Donnay A, Ziem G. Prevalence and overlap of chronic fatigue syndrome and fibromyalgia syndrome among 100 new patients with multiple chemical sensitivity syndrome. J Chronic Fatigue Syndr. 1999;5:71-80. Exclude: not suitable for any question.
Dooley DP. Commercial laboratory testing for chronic fatigue syndrome. JAMA. 1992;268:873-4. Exclude: not suitable for any question. [pmid: 1640611].
Dougall AL, Baum A, Jenkins FJ. Daily fluctuation in chronic fatigue syndrome severity and symptoms. J Appl Biobehav Res. 1998;3:12-28. Exclude: not suitable for any question.
Dove A. GAO reports on CFS funding controversy. Nat Med. 2000;6. Exclude: not suitable for any question.
Downey DC. Fatigue syndromes: new thoughts and reinterpretation of previous data. [Review]. Med Hypotheses. 1992;39:185-90. Exclude: not suitable for any question. [pmid: 1461185].
Dowsett EG. Conversation piece [interview by P. D. Welsby]. Postgrad Med J. 1992;68:63-5. Exclude: not suitable for any question. [pmid: 1561197].
Dowsett EG, Colby J. Chronic fatigue syndrome in children. Journal was wrong to critizise study in schoolchildren. BMJ. 1997;315. Exclude: not suitable for any question.
Dowsett EG, Colby J. Long-term sickness absence due to ME/CFS in UK schools: An epidemiological study with medical and educational implications. J Chronic Fatigue Syndr. 1997;3:29-42. Exclude: retrospective/wrong denomination.
Drago F, Romagnoli M, Loi A, Rebora A. Epstein-Barr virus-related persistent erythema multiforme in chronic fatigue syndrome. Arch Dermatol. 1992;128:217-22. Exclude: not suitable for any question. [pmid: 1310844].
DuBois RE. Gamma globulin therapy for chronic mononucleosis syndrome. AIDS Res. 1986;2 Suppl 1:S191-5. Exclude: not suitable for any question. [pmid: 2435296].
DuBois RE, Seeley JK, Brus I, et al. Chronic mononucleosis syndrome. South Med J. 1984;77:1376-82. Include. [pmid: 6093268].
Duncan I. Insomnia in chronic fatigue syndrome: due to daytime dozing [letter]. Br Med J. 1993;306. Exclude: not suitable for any question.
Dunningham W, Aguiar WM, Mascarenhas G. The newest findings about viral etiology of chronic fatigue syndrome. Psiqulatr Biol. 1999;7:31-6. Exclude: not suitable for any question.
Dunstan RH, Donohoe M, Taylor W, et al. Chlorinated hydrocarbons and chronic fatigue syndrome. Med J Aust. 1996;164. Exclude: not suitable for any question.
Dunstan RH, Donohoe M, Taylor W, et al. A preliminary investigation of chlorinated hydrocarbons and chronic fatigue syndrome. Med J Aust. 1995;163:294-7. Exclude: not suitable for any question. [pmid: 7565234].
Dunstan RH, McGregor NR, Butt HL, Roberts TK. Biochemical and microbiological anomalies in chronic fatigue syndrome: The development of laboratory based tests and the possible role of toxic chemicals. J Nutr Med. 1999;9:97-108. Exclude: not suitable for any question.
Dunstan RH, McGregor NR, Watkins JA, et al. Changes in plasma lipid homeostasis observed in chronic fatigue syndrome patients. J Nutr Med. 1999;9:267-79. Exclude: not suitable for any question.
Duprez DA, De Buyzere ML, Drieghe B, et al. Long- and short-term blood pressure and RR-interval variability and psychosomatic distress in chronic fatigue syndrome. Clin Sci. 1998;94:57-63. Exclude: not suitable for any question. [pmid: 9505867].
Durlach J. Chronic fatigue syndrome and chronic primary magnesium deficiency (CFS and CPMD). Magnes Res. 1992;5. Exclude: not suitable for any question.
Dworkin HJ, Lawrie C, Bohdiewicz P, Lerner AM. Abnormal left ventricular myocardial dynamics in eleven patients with chronic fatigue syndrome. Clin Nucl Med. 1994;19:675-7. Exclude: not suitable for any question. [pmid: 7955743].
Dwyer J. Intravenous IgG helps in chronic fatigue syndrome. Ann Intern Med. 1991;114:50-1. Exclude: not suitable for any question.
Dykman KD, Tone C, Ford C, Dykman RA. The effects of nutritional supplements on the symptoms of fibromyalgia and chronic fatigue syndrome. Integr Physiol Behav Sci. 1998;33:61-71. Exclude: not suitable for any question. [pmid: 9594356].
Eaton KK. Cognitive behaviour therapy for the chronic fatigue syndrome. Use an interdisciplinary approach [letter]. BMJ. 1996;312. Exclude: not suitable for any question.
Edwards JF. The psychosocial functioning of children and adolescents with chronic fatigue in comparison to depressed and healthy contrast groups. Diss Abstr Int B: Sci Engineeer. 1994;55:6709. Exclude: not suitable for any question.
Edwards RH, Gibson H, Clague JE, Helliwell T. Muscle histopathology and physiology in chronic fatigue syndrome. Ciba Found Symp. 1993;173:102-17. Exclude: not suitable for any question. [pmid: 8491096].
Egger M, Smith GD, Phillips AN. Meta-analysis: principles and procedures. BMJ. 1997;315:1533-7. Exclude: not suitable for any question. [pmid: 9432252].
Egyedi P. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:1790-1. Exclude: not suitable for any question. [pmid: 9545729].
Elliot DL, Goldberg L, Loveless MO. Graded exercise testing and chronic fatigue syndrome [letter]. Am J Med. 1997;103:84-6. Exclude: not suitable for any question. [pmid: 9236492].
Empson M. Celiac disease or chronic fatigue syndrome--can the current CDC working case definition discriminate? [letter]. Am J Med. 1998;105:79-80. Exclude: not suitable for any question. [pmid: 9688026].
Enbom M, Linde A, Evengard B. No evidence of active infection with human herpesvirus 6 (HHV-6) or HHV-8 in chronic fatigue syndrome. J Clin Microbiol. 2000;38. Exclude: not suitable for any question. [pmcid: 86845].
Endicott NA. Chronic fatigue syndrome in private practice psychiatry: family history of physical and mental health. J Psychosom Res. 1999;47:343-54. Exclude: not suitable for any question. [pmid: 10616228].
Endicott NA. Chronic fatigue syndrome in psychiatric patients: Evidence of premorbid anomalous patterns of brain organization. J Chronic Fatigue Syndr. 1999;5:29-45. Exclude: not suitable for any question.
Endicott NA. Chronic fatigue syndrome in psychiatric patients: lifetime and premorbid personal history of physical health. Psychosom Med. 1998;60:744-51. Exclude: not suitable for any question. [pmid: 9847035].
Engelborghs S, Michiels K, De Deyn PP. [Role of the central nervous system in the pathophysiology of chronic fatigue syndrome. A review of the literature]. [Dutch]. Tijdschrift Voor Geneeskunde. 1998;54:25-31. Exclude: not suitable for any question.
Englander K. Chronic fatigue syndrome and women: can therapy help?. Soc Work. 1992;37. Exclude: not suitable for any question.
Engleberg NC. Medically oriented therapy for chronic fatigue syndrome and related conditions. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.287-309. Exclude: not suitable for any question.
Enserink M. Chronic fatigue syndrome. CDC struggles to recover from debacle over earmark [news]. Science. 2000;287:22-3. Exclude: not suitable for any question. [pmid: 10644214].
Epstein KR. The chronically fatigued patient. [Review]. Med Clin North Am. 1995;79:315-27. Exclude: not suitable for any question. [pmid: 7877393].
Essame CS, Phelan S, Aggett P, White PD. Pilot study of a multidisciplinary inpatient rehabilitation of severely incapacitated patients with the chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:51-60. Exclude: not suitable for any question.
Esty ML. Learning behavioral medicine techniques for groups from the inside out. Diss Abstr Int B: Sci Engineeer. 1995;56:3442. Exclude: not suitable for any question.
Euba R, Chalder T, Deale A, Wessely S. A comparison of the characteristics of chronic fatigue syndrome in primary and tertiary care. Br J Psychiatry. 1996;168:121-6. Exclude: not suitable for any question. [pmid: 8770441].
Evans AS. Chronic fatigue syndrome: thoughts on pathogenesis. Rev Infect Dis. 1991;13:S56-9. Exclude: not suitable for any question. [pmid: 1850544].
Evans P. Chronic fatigue syndrome. Aust Fam Physician. 2000;29:625-6. Exclude: not suitable for any question. [pmid: 10914444].
Evengard B, Briese T, Lindh G, Lee S, Lipkin WI. Absence of evidence of Borna disease virus infection in Swedish patients with Chronic Fatigue Syndrome. J Neurovirol. 1999;5:495-9. Exclude: not suitable for any question. [pmid: 10568886].
Evengard B, Komaroff AL. [Chronic fatigue syndrome does exist. Changes of biological parameters are measurable]. [Review] [Swedish]. Lakartidningen. 1999;96:3166-9. Exclude: not suitable for any question. [pmid: 10423976].
Evengard B, Nilsson CG, Lindh G, et al. Chronic fatigue syndrome differs from fibromyalgia. No evidence for elevated substance P levels in cerebrospinal fluid of patients with chronic fatigue syndrome. Pain. 1998;78:153-5. Exclude: not suitable for any question. [pmid: 9839828].
Evengard B, Sachs L. [CFS, the condition with the thousands different names. “The tired nomad”--a modern epidemic?]. [Swedish]. Lakartidningen. 1994;91:4001-5. Exclude: not suitable for any question. [pmid: 7967975].
Evengard B, Schacterle RS, Komaroff AL. Chronic fatigue syndrome: new insights and old ignorance. [Review]. J Intern Med. 1999;246:455-69. Exclude: not suitable for any question. [pmid: 10583715].
Ewig S. [The chronic fatigue syndrome]. [Review] [German]. Dtsch Med Wochenschr. 1993;118:1373-80. Exclude: not suitable for any question. [pmid: 8404480].
Faas RJ. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1992;136:2037-8. Exclude: not suitable for any question. [pmid: 1407200].
Fairhurst D, Waterman M, Lynch S. Cognitive slowing in chronic fatigue syndrome (CFS). Psychosom Med. 1997;59. Exclude: not suitable for any question.
Fallon BA, Liebowitz MR, Klein DF. Neurasthenia and chronic fatigue syndrome: the role of culture in the making of a diagnosis: comment. Am J Psychiatry. 1992;149. Exclude: not suitable for any question.
Fallon BA, Liebowitz MR, Klein DF. Taking chronic fatigue syndrome seriously. Am J Psychiatry. 1992;149. Exclude: not suitable for any question.
Fark AR. Infectious mononucleosis, Epstein-Barr virus, and chronic fatigue syndrome: a prospective case series. J Fam Pract. 1991;32:202, 205-6, 209. Exclude: not suitable for any question. [pmid: 1846641].
Farmer A, Chubb H, Jones I, Hillier J. Screening for psychiatric morbidity in subjects presenting with chronic fatigue syndrome. Br J Psychiatry. 1996;168:354-58. Exclude: gHQ performance. [pmid: 8833692].
Farmer A, Jones I, Hillier J, Llewelyn M, Borysiewicz L, Smith A. Neuraesthenia revisited: ICD-10 and DSM-III-R psychiatric syndromes in chronic fatigue patients and comparison subjects. Br J Psychiatry. 1995;167:503-6. Exclude: not suitable for any question. [pmid: 8829720].
Farrar DJ, Locke SE, Kantrowitz FG. Chronic fatigue syndrome. 1: Etiology and pathogenesis. [Review]. Behav Med. 1995;21:5-16. Exclude: not suitable for any question. [pmid: 7579775].
Fava GA, Freyberger H., editors. Handbook of psychosomatic medicine. Madison (CT): International Universities Press. 1998. Exclude: not suitable for any question. [pmcid: 325579].
Feinberg M. Chronic fatigue syndrome and the aviator. Aviat Space Environ Med. 2000;71. Exclude: not suitable for any question.
Fiedler N, Kipen H, Natelson B, Ottenweller J. Chemical sensitivities and the Gulf War: Department of Veterans Affairs Research Center in basic and clinical science studies of environmental hazards. Regul Toxicol Pharmacol. 1996;24:S129-38. Exclude: not suitable for any question. [pmid: 8921568].
Fiedler N, Kipen HM, DeLuca J, Kelly-McNeil K, Natelson B. A controlled comparison of multiple chemical sensitivities and chronic fatigue syndrome. Psychosom Med. 1996;58:38-49. Exclude: did not meet inclusion criteria. [pmid: 8677287].
Field TM, Sunshine W, Hernandez-Reif M, et al. Massage therapy effects on depression and somatic symptoms in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:43-51. Include.
File S. Please believe me. Nurs Times. 1996;92:38-9. Exclude: not suitable for any question. [pmid: 8716285].
Findley JC, Kerns R, Weinberg LD, Rosenberg R. Self-efficacy as a psychological moderator of chronic fatigue syndrome. J Behav Med. 1998;21:351-62. Exclude: not suitable for any question. [pmid: 9789165].
Findley LS, Cox DL. Letter to the editor. J Chronic Fatigue Syndr. 1999;5:127-8. Exclude: not suitable for any question.
Fins AI. Cognitive appraisals, coping profiles and perceived stress and their relationship to illness burden and affect in chronic fatigue syndrome. Diss Abstr Int B: Sci Engineeer. 1994;55. Exclude: not suitable for any question.
Fischler B. The communication of diagnosis, etiology and prognosis to patients with Chronic Fatigue Syndrome. Psychol Med. 1993;25:247-8. Exclude: not suitable for any question.
Fischler B. Review of clinical and psychobiological dimensions of the chronic fatigue syndrome: Differentiation from depression and contribution of sleep dysfunctions. Sleep Med Rev. 1999;3:131-46. Exclude: not suitable for any question. [pmid: 15310482].
Fischler B, Cluydts R, De Gucht Y, Kaufman L, De Meirleir K. Generalized anxiety disorder in chronic fatigue syndrome. Acta Psychiatr Scand. 1997;95:405-13. Exclude: not suitable for any question. [pmid: 9197905].
Fischler B, D'Haenen H, Cluydts R, et al. Comparison of 99m Tc HMPAO SPECT scan between chronic fatigue syndrome, major depression and healthy controls: an exploratory study of clinical correlates of regional cerebral blood flow. Neuropsychobiology. 1996;34:175-83. Exclude: not suitable for any question. [pmid: 9121617].
Fischler B, Dendale P, Michiels V, Cluydts R. Physical fatigability and exercise capacity in chronic fatigue syndrome: association with disability, somatization and psychopathology. J Psychosom Res. 1997;42:369-78. Exclude: sample size. [pmid: 9160276].
Fischler B, Flamen P, Everaert H, Bossuyt A, De Meirleir K. Physiopathological significance of 99mTc HMPAO SPECT scan anomalies in chronic fatigue syndrome: A replication study. J Chronic Fatigue Syndr. 1998;4:15-30. Exclude: not suitable for any question.
Fischler B, Le Bon O, Hoffmann G, Cluydts R, Kaufman LDMK. Sleep anomalies in the chronic fatigue syndrome: a comorbidity study. Neuropsychobiology. 1997;35:115-22. Include. [pmid: 9170115].
Fisher L. Chronic fatigue syndrome. [Review]. Prof Nurse. 1997;12:578-81. Exclude: not suitable for any question. [pmid: 9171712].
Fisk JD, Ritvo PG, Ross L, Haase DA, Marrie TJ, Schlech WF. Measuring the functional impact of fatigue: initial validation of the fatigue impact scale. Clin Infect Dis. 1994;18:S79-83. Exclude: not suitable for any question. [pmid: 8148458].
Fisk JW. Chronic fatigue syndrome. N Z Med J. 1995;108. Exclude: not suitable for any question.
Fitzgibbon EJ, Murphy D, O'Shea K, Kelleher C. Chronic debilitating fatigue in Irish general practice: a survey of general practitioners' experience. Br J Gen Pract. 1997;47:618-22. Exclude: not suitable for any question. [pmid: 9474823]. [pmcid: 1410094].
Flanigan MJ, Morehouse RL, Shapiro CM. Determination of observer-rated alpha activity during sleep. Sleep. 1995;18:702-6. Exclude: not suitable for any question. [pmid: 8560138].
Florenzano R. Neurasthenia and chronic fatigue syndrome: The rise, fall and revival of a disease entity. Rev Chil Neuro-Psiquiatr. 1997;35:175-85. Exclude: not suitable for any question.
Flugel RM, Mahnke C, Geiger A, Komaroff AL. Absence of antibody to human spumaretrovirus in patients with chronic fatigue syndrome. Clin Infect Dis. 1992;14:623-4. Exclude: not suitable for any question. [pmid: 1313314].
Folks TM, Heneine W, Khan A, Woods T, Chapman L, Schonberger L. Investigation of retroviral involvement in chronic fatigue syndrome. Ciba Found Symp. 1993;173:160-6. Exclude: not suitable for any question. [pmid: 8387909].
Forsyth LM, Preuss HG. Chronic fatigue syndrome and the elderly. Mature Med Can. 1999;2:141-3. Exclude: not suitable for any question.
Forsyth LM, Preuss HG, MacDowell AL, Chiazze L Jr, Birkmayer GD, Bellanti JA. Therapeutic effects of oral NADH on the symptoms of patients with chronic fatigue syndrome. Ann Allergy Asthma Immunol. 1999;82:185-91. Include. [pmid: 10071523].
Fox C. The flu that won't leave. RDH. 1991;11. Exclude: not suitable for any question.
Fox DS. Chronic fatigue syndrome: a review and practical guide. [Review]. J Am Acad Nurse Pract. 1994;6:565-70. Exclude: not suitable for any question. [pmid: 7848743].
Franklin A. How I manage chronic fatigue syndrome. Arch Dis Child. 1998;79:375-8. Exclude: not suitable for any question. [pmid: 9875055].
Freeman R, Komaroff AL. Does the chronic fatigue syndrome involve the autonomic nervous system?. Am J Med. 1997;102:357-64. Exclude: not suitable for any question. [pmid: 9217617].
Friedberg F. Chronic fatigue syndrome: a new clinical application. Prof Psychol. Res Pract. 1996;27:487-94. Exclude: not suitable for any question.
Friedberg F. Symptom of persistent fatigue. Conn Med. 1995;59. Exclude: not suitable for any question.
Friedberg F, Dechene L, McKenzie MJI, Fontanetta R. Symptom patterns in long-duration chronic fatigue syndrome. J Psychosom Res. 2000;48:59-68. Include. [pmid: 10750631].
Friedberg F, Jason LA. Understanding chronic fatigue syndrome: an empirical guide to assessment and treatment. Washington: American Psychological Association. 1998. Include.
Friedberg F, Krupp LB. A comparison of cognitive behavioral treatment for chronic fatigue syndrome and primary depression. Clin Infect Dis. 1994;18:105S-10S. Include.
Friedman TC, Adesanya A, Poland RE. Low-dose hydrocortisone for chronic fatigue syndrome [letter]. JAMA. 1999;281:1888-9. Exclude: not suitable for any question. [pmid: 10349886].
Frolov VM, Barylyak IR, Demenkov VR. [Chronic ENT-pathology in patients with chronic fatigue syndrome (Clinical immunologic and cytogenetic investigations)]. [Greek]. Zh Ushn Nos Gorl Bolezn. 1999;29. Exclude: not suitable for any question.
Fry AM, Martin M. Cognitive idiosyncrasies among children with the chronic fatigue syndrome: anomalies in self-reported activity levels. J Psychosom Res. 1996;41:213-23. Exclude: not suitable for any question. [pmid: 8910244].
Fry AM, Martin M. Fatigue in the chronic fatigue syndrome: a cognitive phenomenon? [Review]. J Psychosom Res. 1996;41:415-26. Exclude: not suitable for any question. [pmid: 9032706].
Fuchs D, Weiss G, Wachter H. Pathogenesis of chronic fatigue syndrome. J Clin Psychiatry. 1992;53. Exclude: not suitable for any question.
Fucikova T, Petanova J. [Chronic fatigue syndrome]. [Czech]. Vnitr Lek. 1993;39:995-1002. Exclude: not suitable for any question. [pmid: 8236872].
Fudenberg NH. Treatment for chronic fatigue syndrome [letter]. Am J Med. 1994;97:493-4. Exclude: not suitable for any question. [pmid: 7848475].
Fukuda K, Dobbins JG, Wilson LJ, Dunn RA, Wilcox K, Smallwood D. An epidemiologic study of fatigue with relevance for the chronic fatigue syndrome. J Psychiatr Res. 1997;31:19-29. Exclude: not suitable for any question. [pmid: 9201644].
Fukuda K, Straus SE, Hickie I, Sharpe MC, Dobbins JG, Komaroff A. The chronic fatigue syndrome: a comprehensive approach to its definition and study. International Chronic Fatigue Syndrome Study Group. Ann Intern Med. 1994;121:953-9. Include. [pmid: 7978722].
Fulcher KY, White PD. CFS heart rate miscalculation. Physiotherapy. 1998;84. Exclude: not suitable for any question.
Fulcher KY, White PD. Chronic fatigue syndrome: A description of graded exercise treatment. Physiotherapy. 1998;84:223-6. Exclude: not suitable for any question.
Fulcher KY, White PD. Randomised controlled trial of graded exercise in patients with the chronic fatigue syndrome. BMJ. 1997;314:1647-52. Include. [pmid: 9180065].
Fulcher KY, White PD. Strength and physiological response to exercise in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 2000;69:302-7. Exclude: not suitable for any question. [pmid: 10945803].
Fuller NS, Morrison RE. Chronic fatigue syndrome. Helping patients cope with this enigmatic illness. [Review]. Postgrad Med. 1998;103:175-84. Exclude: not suitable for any question. [pmid: 9448682].
Furman JM. Testing of vestibular function: an adjunct in the assessment of chronic fatigue syndrome. [Review]. Rev Infect Dis. 1991;13:S109-11. Exclude: not suitable for any question. [pmid: 2020795].
Galbraith DN, Nairn C, Clements GB. Phylogenetic analysis of short enteroviral sequences from patients with chronic fatigue syndrome. J Gen Virol. 1995;76:1701-7. Exclude: not suitable for any question. [pmid: 9049375].
Galindo-Ciocon D, Ciocon JO. Chronic fatigue in the elderly. J Clin Geropsychol. 1997;3:291-8. Exclude: not suitable for any question.
Gantz NM. Magnesium and chronic fatigue [letter]. Lancet. 1991;338. Exclude: not suitable for any question.
Gantz NM, Holmes GP. Treatment of patients with chronic fatigue syndrome. [Review]. Drugs. 1989;38:855-62. Exclude: not suitable for any question. [pmid: 2693044].
Garcia-Borreguero D, Dale JK, Rosenthal NE, et al. Lack of seasonal variation of symptoms in patients with chronic fatigue syndrome. Psychiatry Res. 1998;77:71-7. Exclude: not suitable for any question. [pmid: 9541142].
Gardner W. Hyperventilation and chronic fatigue syndrome. QJM. 1994;87. Exclude: not suitable for any question.
Garralda E, Rangel L, Levin M, Roberts H, Ukoumunne O. Psychiatric adjustment in adolescents with a history of chronic fatigue syndrome. J Am Acad Child Adolesc Psychiatry. 1999;38:1515-21. Exclude: not suitable for any question. [pmid: 10596251].
Garralda ME. Severe chronic fatigue syndrome in childhood: a discussion of psychopathological mechanisms. Eur Child Adolesc Psychiatry. 1992;1:111-8. Exclude: not suitable for any question.
Gascon J, Marcos T, Vidal J, Forcada AG, Corachan M. Cytomegalovirus and Epstein-Barr virus infection as a cause of chronic fatigue syndrome in travellers to tropical countries. Rev Pisqiatria Fac Med Barcelona. 1997;24:212-5. Exclude: not suitable for any question.
Gaudino EA, Coyle PK, Krupp LB. Post-Lyme syndrome and chronic fatigue syndrome. Neuropsychiatric similarities and differences. Arch Neurol. 1997;54:1372-6. Exclude: not suitable for any question. [pmid: 9362985].
Gaudino EA, Pollina DA, Krupp LB. Neuropsychological findings in chronic medical illness. In: Calev A, editor. Assessment of neuropsychological functions in psychiatric disorders. Washington: American Psychiatric Press. 1999:p.281-327. Exclude: not suitable for any question.
George DK, Evans RM, Gunn IR. Familial chronic fatigue. Postgrad Med J. 1997;73:311-3. Exclude: not suitable for any question. [pmid: 9196712].
Geraint James D. Complications of sarcoidosis. Chronic fatigue syndrome. Sarcoidosis. 1993;10:1-3. Exclude: not suitable for any question. [pmid: 8134708].
Gerow G, Poierier MB, Alt R. Chronic fatigue syndrome [published erratum appears in J Manipulative Physiol Ther 1992 Nov-Dec; 15(9):following table of contents]. J Manipulative Physiol Ther. 1992;15:529-35. Exclude: not suitable for any question. [pmid: 1492874].
Gibbons R, Macintyre A, Richards C. Cognitive behaviour therapy for the chronic fatigue syndrome. Patients were not representative of all patients with the syndrome [letter]. BMJ. 1996;312:1096-7. Exclude: not suitable for any question.
Gibbons R, Pheby DFH, Richards C, Bray FI. Severe CFS/ME of juvenile onset - A report from the CHROME database. J Chronic Fatigue Syndr. 1998;4:67-80. Include.
Gibson H, Carroll N, Clague JE, Edwards RH. Exercise performance and fatiguability in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1993;56:993-8. Exclude: not suitable for any question. [pmid: 8410041].
Gibson SLM, Gibson RG. A multidimensional treatment plan for chronic fatigue syndrome. J Nutr Med. 1999;9:47-54. Exclude: not suitable for any question.
Gil'miiarova FN, Radomskaia VM, Kretova IG, et al. [Chronic fatigue syndrome:objective criteria of metabolic defects]. Klin Lab Diagn. 1999:9-11. Exclude: not suitable for any question.
Gilbert R. B., Kaan R., Lipkin D. M., Lepp M., Ehrlich GE. Chronic fatigue: syndrome or disease? [letters]. JAMA. 2000;283:744-5. Exclude: not suitable for any question. [pmid: 10683049].
Gimenez HB, Cash P, Laing RBS, Douglas JG. Cytokine expression and morphology of in vitro grown monocytes from patients with chronic fatigue syndrome. J Chronic Fatigue Syndr. 1999;5:47-60. Exclude: not suitable for any question.
Glaser R, Kiecolt-Glaser JK. Stress-associated immune modulation: relevance to viral infections and chronic fatigue syndrome. [Review]. Am J Med. 1998;105:35S-42S. Exclude: not suitable for any question. [pmid: 9790480].
Gold D, Bowden R, Sixbey J, et al. Chronic fatigue. A prospective clinical and virologic study. JAMA. 1990;264:48-53. Include. [pmid: 2162397].
Goldberg M, Lichten J. High androgen levels in chronic fatigue patients. J Clin Endocrinol Metab. 1995;80:3390-1. Exclude: not suitable for any question. [pmid: 7593460].
Goldberg MJ, Mena I, Darcourt J. NeuroSPECT findings in children with chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:61-7. Exclude: not suitable for any question.
Golden HE. Clinical laboratory test findings in patients with chronic fatigue syndrome. Arch Intern Med. 1995;155. Exclude: not suitable for any question.
Goldenberg DL. Fibromyalgia and its relation to chronic fatigue syndrome, viral illness and immune abnormalities. J Rheumatol Suppl. 1989;19:91-3. Exclude: not suitable for any question. [pmid: 2607516].
Goldenberg DL. Fibromyalgia, chronic fatigue, and myofascial pain syndromes. [Review]. Curr Opin Rheumatol. 1992;4:247-57. Exclude: not suitable for any question. [pmid: 1581154].
Goldenberg DL. Fibromyalgia, chronic fatigue syndrome, and myofascial pain. [Review]. Curr Opin Rheumatol. 1996;8:113-23. Exclude: not suitable for any question. [pmid: 8732795].
Goldenberg DL. Fibromyalgia, chronic fatigue syndrome, and myofascial pain syndrome. Curr Opin Rheumatol. 1993;5:199-208. Exclude: not suitable for any question. [pmid: 8452771].
Goldenberg DL. Fibromyalgia, chronic fatigue syndrome, and myofascial pain syndrome. [Review]. Curr Opin Rheumatol. 1991;3:247-58. Exclude: not suitable for any question. [pmid: 2064904].
Goldenberg DL. Fibromyalgia, chronic fatigue syndrome, and myofascial pain syndrome. [Review]. Curr Opin Rheumatol. 1994;6:223-33. Exclude: not suitable for any question. [pmid: 8024971].
Goldenberg DL. Fibromyalgia, chronic fatigue syndrome, and myofascial pain syndrome. [Review]. Curr Opin Rheumatol. 1995;7:127-35. Exclude: not suitable for any question. [pmid: 7766493].
Goldenberg DL, Simms RW, Geiger A, Komaroff AL. High frequency of fibromyalgia in patients with chronic fatigue seen in a primary care practice. Arthritis Rheum. 1990;33:381-7. Exclude: did not meet inclusion criteria. [pmid: 2317224].
Goldstein JA. Betrayal by the brain: the neurologic basis of chronic fatigue syndrome, fibromyalgia syndrome, and related neural network disorders. Binghampton (NY): Haworth Medical Press/Haworth Press. 1996. Exclude: not suitable for any question. [pmcid: 190016].
Gomborone JE, Gorard DA, Dewsnap PA, Libby GW, Farthing MJ. Prevalence of irritable bowel syndrome in chronic fatigue. J R Coll Physicians Lond. 1996;30:512-3. Exclude: did not meet inclusion criteria. [pmid: 8961203].
Gompels MM, Spickett GP. Chronic fatigue, arthralgia, and malaise. Ann Rheum Dis. 1996;55:502-3. Exclude: not suitable for any question. [pmid: 8774176]. [pmcid: 1010225].
Gonzalez MB, Cousins JC, Doraiswamy PM Neurobiology of chronic fatigue syndrome. [Review] Prog Neuropsychopharmacol Biol Psychiatry 1996 20 749 59 Exclude: not suitable for any question8870062 8870062
Goodman KI, Strauss Jr JF, Kroenke K. Chronic fatigue controversy. Postgrad Med. 1991;90:23-4. Exclude: not suitable for any question.
Goodnick PJ. Bupropion in chronic fatigue syndrome. Am J Psychiatry. 1990;147. Exclude: not suitable for any question.
Goodnick PJ. Treatment of chronic fatigue syndrome with venlafaxine. Am J Psychiatry. 1996;153. Exclude: not suitable for any question.
Goodnick PJ, Jorge CM. Treatment of chronic fatigue syndrome with nefazodone. Am J Psychiatry. 1999;156:797-8. Exclude: not suitable for any question.
Goodnick PJ, Klimas NG., editors. Chronic fatigue and related immune deficiency syndromes. Washington (DC): American Psychiatric Press. 1993. Include. [pmcid: 372939].
Goodnick PJ, Sandoval R. Psychotropic treatment of chronic fatigue syndrome and related disorders. [Review]. J Clin Psychiatry. 1993;54:13-20. Exclude: not suitable for any question.
Goodnick PJ, Sandoval R. Treatment of chronic fatigue syndrome and related disorders: immunological approaches. In: Goodnick PJ, Klimas NG, editors. Chronic fatigue and related immune deficiency syndromes. Washington (DC): American Psychiatric Press. 1993:p.109-29.
Goodnick PJ, Sandoval R. Treatment of chronic fatigue syndrome and related disorders: psychotropic agents. In: Goodnick PJ, Klimas NG, editors. Chronic fatigue and related immune deficiency syndromes. Washington (DC): American Psychiatric Press. 1993:p.131-59.
Goodrich W. Neurasthenia and chronic fatigue syndrome: the role of culture in the making of a diagnosis: comment. Am J Psychiatry. 1992;149. Exclude: not suitable for any question.
Goodrich W. Taking chronic fatigue syndrome seriously. Am J Psychiatry. 1992;149. Exclude: not suitable for any question.
Goodwin S. The marital relationship and health in women with chronic fatigue and immune dysfunction syndrome: views of wives and husbands. Nurs Res. 1997;46:138-46. Exclude: not suitable for any question. [pmid: 9176503].
Gordon R, Michalewski HJ, Nguyen T, Gupta S, Starr A. Cortical motor potential alterations in chronic fatigue syndrome. Int J Mol Med. 1999;4:493-9. Exclude: not suitable for any question. [pmid: 10534571].
Goshorn RK. Chronic fatigue syndrome: a review for clinicians. [Review]. Semin Neurol. 1998;18:237-42. Exclude: not suitable for any question. [pmid: 9608620].
Goudsmit E. Functional somatic syndromes. Ann Intern Med. 2000;132. Exclude: not suitable for any question.
Goudsmit E. Treating chronic fatigue with exercise. Exercise, and rest, should be tailored to individual needs [letter]. BMJ. 1998;317. Exclude: not suitable for any question. [pmcid: 58840].
Goudsmit E, Shepherd C. Functional somatic syndromes. Lancet. 1999;354. Exclude: not suitable for any question.
Goudsmit EM. Chronic fatigue syndrome. Distinguish between syndromes. BMJ. 1994;308:1297-8. Exclude: not suitable for any question. [pmid: 8205027].
Goudsmit EM. Graded exercise in chronic fatigue syndrome. Chronic fatigue syndrome is heterogeneous condition [letter]. BMJ. 1997;315. Exclude: not suitable for any question.
Goudsmit EM. Learning to cope with post-infectious fatigue syndrome. A follow-up study. In: Goudsmit EM. The Psychological Aspects and Management of Chronic Fatigue Syndrome [dissertation]. Middlesex, England: Brunel University. 1996. Include. [pmcid: 190016].
Goudsmit EM, Howes S. Cognitive functioning with chronic fatigue. Br J Psychiatry. 1995;167:818-9. Exclude: not suitable for any question. [pmid: 8829753].
Goudsmit EM, Macintyre A. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1992;136:708-9. Exclude: not suitable for any question. [pmid: 1560861].
Goudsmit EM, Macintyre A, Sullivan M. Chronic fatigue syndrome. Br J Gen Pract. 1991;41:479-80. Exclude: not suitable for any question. [pmid: 1807317]. [pmcid: 1371802].
Goudsmit EM, Shepherd C. Chronic fatigue syndrome. Br J Psychiatry. 1992;160:127-8. Exclude: not suitable for any question.
Gow JW, Behan PO. Viruses and chronic fatigue syndrome. J Chronic Fatigue Syndr. 1996;2:67-83. Exclude: not suitable for any question.
Gow JW, Behan WM. Amplification and identification of enteroviral sequences in the postviral fatigue syndrome. [Review]. Br Med Bull. 1991;47:872-85. Exclude: not suitable for any question. [pmid: 1665380].
Gow JW, Behan WM, Clements GB, Woodall C, Riding M, Behan PO. Enteroviral RNA sequences detected by polymerase chain reaction in muscle of patients with postviral fatigue syndrome. BMJ. 1991;302:692-6. Exclude: not suitable for any question. [pmid: 1850635]. [pmcid: 1669122].
Gow JW, Behan WM, Simpson K, McGarry F, Keir S, Behan PO. Studies on enterovirus in patients with chronic fatigue syndrome. Clin Infect Dis. 1994;18:S126-9. Exclude: not suitable for any question. [pmid: 8148439].
Gow JW, Simpson K, Schliephake A, et al. Search for retrovirus in the chronic fatigue syndrome. J Clin Pathol. 1992;45:1058-61. Exclude: not suitable for any question. [pmid: 1479030]. [pmcid: 494996].
Gracious B, Wisner KL. Nortriptyline in chronic fatigue syndrome: a double blind, placebo-controlled single case study. Biol Psychiatry. 1991;30:405-8. Exclude: not suitable for any question. [pmid: 1912132].
Grafman J. Neuropsychological assessment of patients with chronic fatigue syndrome. Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.113-29. Exclude: not suitable for any question.
Grafman J, Johnson R Jr, Scheffers M. Cognitive and mood-state changes in patients with chronic fatigue syndrome. [Review]. Rev Infect Dis. 1991;13:S45-52. Exclude: not suitable for any question. [pmid: 1850543].
Grafman J, Schwartz V, Dale JK, Scheffers M, Houser C, Straus SE. Analysis of neuropsychological functioning in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1993;56:684-9. Exclude: not suitable for any question. [pmid: 8509784].
Graham H. Family interventions in general practice: a case of chronic fatigue. J Fam Ther. 1991;13:225-30. Exclude: not suitable for any question.
Grant JE, Veldee MS, Buchwald D. Analysis of dietary intake and selected nutrient concentrations in patients with chronic fatigue syndrome. J Am Diet Assoc. 1996;96:383-6. Exclude: not suitable for any question. [pmid: 8598441].
Granzow B. [Mutual features of chronic fatigue syndrome, fibromyalgia and multiple chemical sensitivity]. [German]. Dtsch Med Wochenschr. 1999;124. Exclude: not suitable for any question.
Grau JM, Casademont J, Pedrol E, et al. Chronic fatigue syndrome: studies on skeletal muscle. Clin Neuropathol. 1992;11:329-32. Exclude: not suitable for any question. [pmid: 1473316].
Gray GC, Kaiser KS, Hawksworth AW, Hall FW, Barrett-Connor E. Increased postwar symptoms and psychological morbidity among U.S. Navy Gulf War veterans. Am J Trop Med Hyg. 1999;60:758-66. Exclude: not suitable for any question. [pmid: 10344649].
Gray JB, Martinovic AM. Eicosanoids and essential fatty acid modulation in chronic disease and the chronic fatigue syndrome [published erratum appears in Med Hypotheses 1995 Aug; 45(2):219]. [Review]. Med Hypotheses. 1994;43:31-42. Exclude: not suitable for any question. [pmid: 7968718].
Greco A, Tannock C, Brostoff J, Costa DC. Brain MR in chronic fatigue syndrome. AJNR Am J Neuroradiol. 1997;18:1265-9. Exclude: not suitable for any question. [pmid: 9282853].
Green J, Romei J, Natelson BH. Stigma and chronic fatigue syndrome. J Chronic Fatigue Syndr. 1999;5:63-75. Include.
Greenberg DB. Neurasthenia in the 1980s: chronic mononucleosis, chronic fatigue syndrome, and anxiety and depressive disorders. [Review]. Psychosomatics. 1990;31:129-37. Exclude: not suitable for any question. [pmid: 2184452].
Greenberg DB. Beyond neurasthenia and chronic fatigue. In: Akiskal HS, Cassano GB, editors. Dysthymia and the spectrum of chronic depressions. New York: Guilford Press. 1997:p.148-64. Exclude: not suitable for any question.
Gregg VH. Hypnosis in chronic fatigue syndrome. J R Soc Med. 1997;90:682-3. Exclude: not suitable for any question. [pmid: 9496296]. [pmcid: 1296740].
Gregg VH, Jones D. Hypnosis and the chronic fatigue syndrome: a case study. Contemporary Hypnosis. 1995;12:87-91. Exclude: not suitable for any question.
Griffiths RA, Beumont PJ, Moore GM, Touyz SW. Chronic fatigue syndrome and dieting disorders: diagnosis and management problems. Aust N Z J Psychiatry. 1996;30:834-8. Exclude: not suitable for any question. [pmid: 9034474].
Grivois H, Deniker P, Ganry H. [Efficacy of tianeptine in the treatment of psychasthenia. A study versus placebo]. [French]. Encephale. 1992;18:591-9. Exclude: studied psychasthenia. [pmid: 1340807].
Grufferman S Issues and problems in the conduct of epidemiologic research on chronic fatigue syndrome. [Review] Rev Infect Dis 1991 13 S60 7 Exclude: not suitable for any question2020803 2020803
Gulledge AD. [Preface]. Prim Care. 1991;18:xi-xii. Exclude: not suitable for any question.
Gunn WJ, Connell DB, Randall B. Epidemiology of chronic fatigue syndrome: the Centers for Disease Control Study. Ciba Found Symp. 1993;173:83-93. Include. [pmid: 8387910].
Gunn WJ, Komaroff AL, Bell DS, Connell DB, Levine SM, Cheney PR. Inability of retroviral tests to identify persons with chronic fatigue syndrome, 1992. JAMA. 1993;269. Exclude: not suitable for any question.
Gupta S, Aggarwal S, See D, Starr A. Cytokine production by adherent and non-adherent mononuclear cells in chronic fatigue syndrome. J Psychiatr Res. 1997;31:149-56. Exclude: not suitable for any question. [pmid: 9201656].
Gupta S, Vayuvegula B. A comprehensive immunological analysis in chronic fatigue syndrome. Scand J Immunol. 1991;33:319-27. Exclude: not suitable for any question. [pmid: 1849315].
Hadler NM. Fibromyalgia, chronic fatigue, and other iatrogenic diagnostic algorithms. Do some labels escalate illness in vulnerable patients? [Review]. Postgrad Med. 1997;102:161-2, 165-6, 171-2. Exclude: not suitable for any question. [pmid: 9270707].
Hagglof M. [Vitamin B12 and chronic fatigue]. [Swedish]. Lakartidningen. 2000;97. Exclude: not suitable for any question.
Hahn SR. The meaning of symptoms: reflections in Alice's looking-glass [editorial]. Am J Med. 1999;107:519-21. Exclude: not suitable for any question. [pmid: 10569310].
Hakimi R. [Chronic fatigue syndrome--also an insurance medicine problem]. [German]. Versicherungsmedizin. 1996;48:59-61. Exclude: not suitable for any question. [pmid: 8659056].
Hale M, Matthews DA. Depression and chronic fatigue. Indications for psychiatric consultation. Prim Care. 1991;18:435-49. Exclude: not suitable for any question. [pmid: 1876623].
Haley RW, Kurt TL, Hom J. Is there a Gulf War Syndrome? Searching for syndromes by factor analysis of symptoms [published erratum appears in JAMA 1997 Aug 6; 278(5):388]. JAMA. 1997;277:215-22. Exclude: not suitable for any question. [pmid: 9005271].
Hall DG, Sanders SD, Replogle WH. Fatigue: a new approach to an old problem. J Miss State Med Assoc. 1994;35:155-60. Include. [pmid: 8064846].
Hall GH, Hamilton WT, Round AP. Increased illness experience preceding chronic fatigue syndrome. J R Coll Physicians Lond. 1998;32. Exclude: not suitable for any question.
Hall GH, Hamilton WT, Round AP. Increased illness experience preceding chronic fatigue syndrome: a case control study. J R Coll Physicians Lond. 1998;32:44-8. Exclude: not suitable for any question. [pmid: 9507441].
Hamilos DL, Nutter D, Gershtenson J, et al. Core body temperature is normal in chronic fatigue syndrome. Biol Psychiatry. 1998;43:293-302. Exclude: not suitable for any question. [pmid: 9513740].
Hamre HJ. [Chronic fatigue syndrome--a review of the literature]. [Review] [Norwegian]. Tidsskr Nor Laegeforen. 1995;115:3042-5. Exclude: not suitable for any question. [pmid: 7570537].
Hamre HJ. [Chronic fatigue syndrome and cognitive therapy]. [Norwegian]. Tidsskr Nor Laegeforen. 1996;116. Exclude: not suitable for any question.
Hamre HJ. [Chronic fatigue syndrome]. [Norwegian]. Tidsskr Nor Laegeforen. 1995;115. Exclude: not suitable for any question.
Handa KK, Sra JS, Akhtar M. Successful treatment of a patient with chronic fatigue using head-up tilt guided therapy. Wis Med J. 1997;96:40-2. Exclude: not suitable for any question.
Harlow BL, Signorello LB, Hall JE, Dailey C, Komaroff AL. Reproductive correlates of chronic fatigue syndrome. Am J Med. 1998;105:94S-9S. Exclude: not suitable for any question. [pmid: 9790489].
Harmon DL, McMaster D, McCluskey DR, Shields D, Whitehead AS. A common genetic variant affecting folate metabolism is not over-represented in chronic fatigue syndrome. Ann Clin Biochem. 1997;34:427-9. Exclude: not suitable for any question. [pmid: 9247678].
Harrigan P. Controversy continues over chronic fatigue syndrome [news]. Lancet. 1998;351. Exclude: not suitable for any question.
Hart B, Grace VM. Fatigue in chronic fatigue syndrome: a discourse analysis of women's experiential narratives. Health Care Women Int. 2000;21:187-201. Include. [pmid: 11111465].
Hartz AJ, Kuhn EM, Bentler SE, Levine PH, London R. Prognostic factors for persons with idiopathic chronic fatigue. Arch Fam Med. 1999;8:495-501. Include. [pmid: 10575388].
Hartz AJ, Kuhn EM, Levine PH. Characteristics of fatigued persons associated with features of chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:71-97. Exclude: not suitable for any question.
Hashimoto N. [Chronic fatigue syndrome]. [Review] [Japanese]. Nippon Rinsho. 1993;51:1107-14. Exclude: not suitable for any question. [pmid: 8459536].
Hashimoto N. [Definition of the chronic fatigue syndrome and its issues]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2591-9. Exclude: not suitable for any question. [pmid: 1287235].
Hashimoto N, Kuraishi Y, Yokose T, et al. [Chronic fatigue syndrome--51 cases in the Jikei University School of Medicine]. [Japanese]. Nippon Rinsho. 1992;50:2653-64. Exclude: not suitable for any question. [pmid: 1287241].
Hassan IS, Bannister BA, Akbar A, Weir W, Bofill M. A study of the immunology of the chronic fatigue syndrome: correlation of immunologic parameters to health dysfunction. Clin Immunol Immunopathol. 1998;87:60-7. Exclude: not suitable for any question. [pmid: 9576011].
Hauben M. Quinacrine and chronic fatigue syndrome [letter]. Am Fam Physician. 1994;49. Exclude: not suitable for any question.
Hausotter W. [Expert assessment of chronic fatigue syndrome]. [German]. Versicherungsmedizin. 1996;48:57-9. Exclude: not suitable for any question. [pmid: 8659055].
Hawton KE, Hengeveld MW. [Chronic fatigue syndrome; psychiatric aspects]. [Dutch]. Ned Tijdschr Geneeskd. 1991;135:2014-7. Exclude: not suitable for any question. [pmid: 1944667].
Heap LC, Peters TJ, Wessely S. Vitamin B status in patients with chronic fatigue syndrome. J R Soc Med. 1999;92:183-5. Exclude: not suitable for any question. [pmid: 10450194]. [pmcid: 1297139].
Heard M. Functional somatic syndromes. Ann Intern Med. 2000;132. Exclude: not suitable for any question.
Hedges LV, Olkin I. Statistical methods for meta-analysis. Orlando (FL): Academic Press. 1985. Include. [pmcid: 397982].
Hedrick TE. Chronic fatigue syndrome. QJM. 1997;90:723-5. Exclude: not suitable for any question. [pmid: 9474354].
Hedrick TE. Functional somatic syndromes. Ann Intern Med. 2000;132. Exclude: not suitable for any question.
Heijmans M, de Ridder D. Assessing illness representations of chronic illness: explorations of their disease-specific nature. J Behav Med. 1998;21:485-503. Exclude: not suitable for any question. [pmid: 9836133].
Heijmans M, de Ridder D, Bensing J. Dissimilarity in patients' and spouses' representations of chronic illness: exploration of relations to patient adaptation. Psychol Health. 1999;14:451-66. Exclude: not suitable for any question.
Heijmans MJW. Coping and adaptive outcome in chronic fatigue syndrome: importance of illness cognitions. J Psychosom Res. 1998;45:39-51. Exclude: not suitable for any question. [pmid: 9720854].
Hellinger WC, Smith TF, Van Scoy RE, Spitzer PG, Forgacs P, Edson RS. Chronic fatigue syndrome and the diagnostic utility of antibody to Epstein-Barr virus early antigen. JAMA. 1988;260:971-3. Exclude: not suitable for any question. [pmid: 2840523].
Henderson DA. Reflections on epidemic neuromyasthenia (chronic fatigue syndrome). Clin Infect Dis. 1994;18:S3-S6. Exclude: not suitable for any question. [pmid: 8148450].
Heneine W, Woods TC, Sinha SD, et al. Lack of evidence for infection with known human and animal retroviruses in patients with chronic fatigue syndrome. Clin Infect Dis. 1994;18:S121-5. Exclude: not suitable for any question. [pmid: 8148438].
Heuft L, Bravenboer B, Ziekenhuis C. Functional hypoglycaemia postulated as cause of chronic fatigue syndrome. BMJ. 1993;307. Exclude: not suitable for any question.
Heyll U, Wachauf P, Senger V, Diewitz M. [Definition of “chronic fatigue syndrome” (CFS)]. [Review][German]. Med Klin. 1997;92:221-7. Exclude: not suitable for any question.
Hick JF. The etiology of chronic fatigue syndrome. Minn Med. 1991;74:7-8. Exclude: not suitable for any question. [pmid: 1944035].
Hickie I, Hadzi-Pavlovic D, Ricci C. Reviving the diagnosis of neurasthenia. Psychol Med. 1997;27:989-94. Exclude: not suitable for any question. [pmid: 9300504].
Hickie I, Kirk K, Martin N. Unique genetic and environmental determinants of prolonged fatigue: a twin study. Psychol Med. 1999;29:259-68. Exclude: not suitable for any question. [pmid: 10218917].
Hickie I, Koschera A, Hadzi-Pavlovic D, Bennett B, Lloyd A. The temporal stability and co-morbidity of prolonged fatigue: a longitudinal study in primary care. Psychol Med. 1999;29:855-61. Include. [pmid: 10473312].
Hickie I, Lloyd A, Hadzi-Pavlovic D, Parker G, Bird K, Wakefield D. Can the chronic fatigue syndrome be defined by distinct clinical features?. Psychol Med. 1995;25:925-35. Include. [pmid: 8588011].
Hickie I, Lloyd A, Wakefield D. Chronic fatigue syndrome and depression. Lancet. 1991;337:922-3. Exclude: not suitable for any question.
Hickie I, Lloyd A, Wakefield D. Immunological and psychological dysfunction in patients receiving immunotherapy for chronic fatigue syndrome. Aust N Z J Psychiatry. 1992;26:249-56. Exclude: not suitable for any question. [pmid: 1642616].
Hickie I, Lloyd A, Wakefield D, Parker G. The psychiatric status of patients with the chronic fatigue syndrome. Br J Psychiatry. 1990;156:534-40. Include. [pmid: 2386862].
Hickie I, Lloyd A, Wilson A, Wakefield D. Neurasthenia and chronic fatigue syndrome: the role of culture in the making of a diagnosis. Am J Psychiatry. 1992;149:1755-6. Exclude: not suitable for any question.
Hickie IB, Hooker AW, Hadzi-Pavlovic D, Bennett BK, Wilson AJ, Lloyd AR. Fatigue in selected primary care settings: sociodemographic and psychiatric correlates. Med J Aust. 1996;164:585-8. Include. [pmid: 8637460].
Hickie IB, Lloyd AR, Wakefield D. Chronic fatigue syndrome: current perspectives on evaluation and management. [Review]. Med J Aust. 1995;163:314-8. Exclude: not suitable for any question. [pmid: 7565238].
Hickie IB, Wilson AJ, Wright JM, Bennett BK, Wakefield D, Lloyd AR. A randomized, double-blind placebo-controlled trial of moclobemide in patients with chronic fatigue syndrome. J Clin Psychiatry. 2000;61:643-8. Include. [pmid: 11030484].
Higgins D. Sceptical of sceptics [letter]. N Z Med J. 1995;108:324-5. Exclude: not suitable for any question. [pmid: 7644170].
Higgins ES. Chronic fatigue syndrome: a depressive disorder. [Review]. J S C Med Assoc. 1992;88:51-7. Exclude: not suitable for any question. [pmid: 1548851].
Hilden J. [Chronic fatigue syndrome--a psychosocial syndrome?]. [Danish]. Ugeskr Laeger. 1995;157. Exclude: not suitable for any question.
Hilger GS. Depression, social support, coping skills, and adjustment to illness in women who have chronic fatigue syndrome. Diss Abstr Int B: Sci Engineeer. 1995;56. Exclude: not suitable for any question.
Hilgers A, Frank J. [Chronic fatigue immunodysfunction syndrome by 103 patients: diagnosis, results and therapy]. [German]. Z Klin Med. 1992;47:152-64. Exclude: not suitable for any question.
Hilgers A, Frank J. Chronic fatigue syndrome: evaluation of a 30-criteria-score and correlation with immune activation. J Chronic Fatigue Syndr. 1996;2:35-47. Exclude: not suitable for any question.
Hilgers A, Frank J. [Chronic fatigue syndrome: immune dysfunction, role of pathogens and toxic agents and neurological and cardial changes]. [German]. Wien Med Wochenschr. 1994;144:399-406. Exclude: not suitable for any question. [pmid: 7856214].
Hilgers A, Frank J, Bolte P. Prolongation of central motor conduction time in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:23-32. Exclude: not suitable for any question.
Hilgers A, Krueger GR, Lembke U, Ramon A. Postinfectious chronic fatigue syndrome: case history of thirty-five patients in Germany. In Vivo. 1991;5:201-5. Exclude: not suitable for any question. [pmid: 1893076].
Hilgers A, Schoenherr G. [Chronic fatigue syndrome: differential diagnosis at the laboratory of immunology]. [German]. Arztez Naturheilverfahren. 1999;40:208-12. Exclude: not suitable for any question.
Hill NF, Tiersky LA, Scavalla VR, Lavietes M, Natelson BH. Natural history of severe chronic fatigue syndrome. Arch Phys Med Rehabil. 1999;80:1090-4. Include. [pmid: 10489014].
Himmel PB, Seligman TM. A pilot study employing Dehydroepiandrosterone (DHEA) in the treatment of chronic fatigue syndrome. J Clin Rheumatol. 1999;5:56-9. Exclude: not suitable for any question. [pmid: 19078357].
Hinds G, Bell NP, McMaster D, McCluskey DR. Normal red cell magnesium concentrations and magnesium loading tests in patients with chronic fatigue syndrome. Ann Clin Biochem. 1994;31:459-61. Exclude: not suitable for any question. [pmid: 7832571].
Hinds G, McCluskey DR. A retrospective study of the chronic fatigue syndrome. Proc R Coll Physicians Edinburgh. 1993;23:10-4. Include.
Hissink Muller W. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1992;136. Exclude: not suitable for any question.
Ho-Yen DO. Chronic fatigue syndrome and fibromyalgia. BMJ. 1994;309. Exclude: not suitable for any question.
Ho-Yen DO. Cognitive behaviour therapy for the chronic fatigue syndrome. Patients' beliefs about their illness were probably not a major factor [letter]. BMJ. 1996;312:1097-8. Exclude: not suitable for any question. [pmid: 8616430].
Ho-Yen DO. The epidemiology of post viral fatigue syndrome. Scott Med J. 1988;33:368-9. Exclude: not suitable for any question. [pmid: 2854300].
Ho-Yen DO, Grant A. Chronic fatigue syndrome. Self help groups give valuable support [letter]. BMJ. 1994;308:1298-9. Exclude: not suitable for any question.
Ho-Yen DO, McNamara I. General practitioners' experience of the chronic fatigue syndrome. Br J Gen Pract. 1991;41:324-6. Exclude: not suitable for any question. [pmid: 1777276]. [pmcid: 1371754].
Ho-Yen DO, Shanks M. Chronic fatigue syndrome. Prevalence study overlooked. BMJ. 1994;308. Exclude: not suitable for any question.
Hock AD. Fatigue and 25-hydroxyvitamin D levels. J Chronic Fatigue Syndr. 1997;3:117-27. Exclude: not suitable for any question.
Hoey M. Chronic fatigue syndrome. What is happening to M.E.?. Aust Nurs J. 1994;2:18-20. Exclude: not suitable for any question. [pmid: 7952139].
Hoffmann A, Linder R, Kroger B, Schnabel A, Kruger GR. [Fibromyalgia syndrome and chronic fatigue syndrome. Similarities and differences]. [Review] [German]. Dtsch Med Wochenschr. 1996;121:1165-8. Exclude: not suitable for any question. [pmid: 8925737].
Holland P. Coniunctio--in bodily and psychic modes: dissociation, devitalization and integration in a case of chronic fatigue syndrome. J Anal Psychol. 1997;42:217-36. Exclude: not suitable for any question. [pmid: 9161122].
Holmes GP. Defining the chronic fatigue syndrome. Rev Infect Dis. 1991;13:S53-5. Exclude: not suitable for any question. [pmid: 2020802].
Holmes GP. Recent developments in the chronic fatigue syndrome. Curr Opin Infect Dis. 1992;5:647-53. Exclude: not suitable for any question.
Holmes GP, Kaplan JE, Gantz NM, et al. Chronic fatigue syndrome: a working case definition. Ann Intern Med. 1988;108:387-9. Exclude: not suitable for any question. [pmid: 2829679].
Holmes GP, Kaplan JE, Stewart JA, Hunt B, Pinsky PF, Schonberger LB. A cluster of patients with a chronic mononucleosis-like syndrome. Is Epstein-Barr virus the cause?. JAMA. 1987;257:2297-302. [pmid: 3033337].
Holmes MJ, Diack DS, Easingwood RA, Cross JP, Carlisle B. Electron microscopic immunocytological profiles in chronic fatigue syndrome. J Psychiatr Res. 1997;31:115-22. Exclude: not suitable for any question. [pmid: 9201653].
Holmwood C, Shannon C. Chronic fatigue syndrome. A review from the general practice perspective. Aust Fam Physician. 1992;21:278-9, 283-5. Exclude: not suitable for any question. [pmid: 1318714].
Honda M, Kitamura K, Nakasone T, et al. Japanese patients with chronic fatigue syndrome are negative for known retrovirus infections. Microbiol Immunol. 1993;37:779-84. Exclude: not suitable for any question. [pmid: 7507200].
Hooge J. Chronic fatigue syndrome: cause, controversy and care. Br J Nurs. 1992;1:440-1, 443, 445-6. Exclude: not suitable for any question. [pmid: 1446147].
Hope H, David A. “Cognitive functioning with chronic fatigue”: reply. Br J Psychiatry. 1995;167:818-9. Exclude: not suitable for any question. [pmid: 8829753].
Horstink MW, Gonera EG, Berger HJ, van Weel C. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1992;136. Exclude: not suitable for any question.
Hoskin L, Clifton-Bligh P, Hansen R, Fulcher G, Gates F. Bone density and body composition in young women with chronic fatigue syndrome. Ann N Y Acad Sci. 2000;904:625-7. Exclude: not suitable for any question. [pmid: 10865817].
Hotopf M, Noah N, Wessely S. Chronic fatigue and minor psychiatric morbidity after viral meningitis: a controlled study. J Neurol Neurosurg Psychiatry. 1996;60:504-9. Exclude: not suitable for any question. [pmid: 8778253].
Hotopf M, Wessely S. Chronic fatigue syndrome--mapping the interior. Psychol Med. 1999;29:255-8. Exclude: not suitable for any question. [pmid: 10218916].
Houde SC, Kampfe-Leacher R. Chronic fatigue syndrome: an update for clinicians in primary care. [Review]. Nurse Pract. 1997;22:30, 35-6, 39-40. Exclude: not suitable for any question. [pmid: 9253014].
House A. Alleged link between hepatitis B vaccine and chronic fatigue syndrome. CMAJ. 1992;146. Exclude: not suitable for any question.
Howard JM, Davies S, Hunnisett A. Magnesium and chronic fatigue syndrome. Lancet. 1992;340. Exclude: not suitable for any question.
Howes S. Chronic fatigue syndrome. ME Association is honest about prognosis. BMJ. 1994;308:1299-300. Exclude: not suitable for any question. [pmid: 8205033].
Howlett M, Lindegger G. Attributional style and illness behaviour in chronic fatigue syndrome. S Afr J Psychol. 1996;26:39-46. Exclude: not suitable for any question.
Hudson JI, Goldenberg DL, Pope Jr HG, Keck Jr PE, Schlesinger L. Comorbidity of fibromyalgia with medical and psychiatric disorders. Am J Med. 1992;92:363-7. Exclude: not suitable for any question. [pmid: 1558082].
Hudson JI, Pope HG. The concept of affective spectrum disorder: relationship to fibromyalgia and other syndromes of chronic fatigue and chronic muscle pain. [Review]. Baillieres Clin Rheumatol. 1994;8:839-56. Exclude: not suitable for any question. [pmid: 7850883].
Hudson M, Cleare AJ. The 1 mug short Synacthen test in chronic fatigue syndrome. Clin Endocrinol (Oxf). 1999;51:625-30. Exclude: not suitable for any question. [pmcid: 298219]. [pmid: 10594524].
Hughey DR. A phenomenological-psychological study of the experience of chronic fatigue syndrome. Diss Abstr Int. 1991;52:1721-2. Exclude: not suitable for any question.
Hume M. Chronic fatigue syndrome in children. All studies must be subjected to rigorous scrutiny. BMJ. 1997;315. Exclude: not suitable for any question.
Hutchison AS. Exercise responses in the chronic fatigue syndrome. Objective assessment of study is difficult without knowledge of data [letter]. BMJ. 1995;311. Exclude: not suitable for any question.
Hyams KC. Developing case definitions for symptom-based conditions: the problem of specificity. [Review]. Epidemiol Rev. 1998;20:148-56. Exclude: not suitable for any question. [pmid: 9919435].
Hyams KC, Wignall FS, Roswell R. War syndromes and their evaluation: from the U.S. Civil War to the Persian Gulf War. [Review]. Ann Intern Med. 1996;125:398-405. Exclude: not suitable for any question. [pmid: 8702091].
Hyde BM. Myalgic encephalomyelitis (chronic fatigue syndrome): an historic perspective. Can Dis Wkly Rep. 1991;17:5-8. Exclude: not suitable for any question. [pmid: 1669354].
Hyman H, Wasser TE. Gastrointestinal manifestations of chronic fatigue syndrome (CFS): symptom perceptions and quality of life. J Chronic Fatigue Syndr. 1998;4:43-52. Exclude: not suitable for any question.
Hynick TJ. An examination of factors associated with successful adaptation to chronic fatigue immune dysfunction syndrome in adolescence. Diss Abstr Int B: Sci Engineeer. 1997;58. Exclude: not suitable for any question.
Ichise M, Salit IE, Abbey SE, et al. Assessment of regional cerebral perfusion by 99Tcm-HMPAO SPECT in chronic fatigue syndrome. Nucl Med Commun. 1992;13:767-72. Exclude: not suitable for any question. [pmid: 1491843].
Itoh Y, Fukunaga Y, Igarashi T, et al. Autoimmunity in chronic fatigue syndrome in children. Jpn J Rheumatol. 1998;8:429-37. Exclude: not suitable for any question.
Izquierdo Clemente C, Ibanez Estella JA, Sanchez Ibanez A. [Chronic fatigue syndrome]. [Spanish]. Aten Primaria. 1995;16. Exclude: not suitable for any question.
Izquierdo Clemente C, Ibanez Estella JA, Sanchez Ibanez A, Rubio Montanes ML, Malumbres Juarros P. [Chronic fatigue syndrome. Diagnostic strategy in primary care]. [Spanish]. An Med Interna. 1993;10:622-3. Exclude: not suitable for any question. [pmid: 8049338].
Jackson EL. The effects on siblings in families with a child with chronic fatigue syndrome. [Review]. J Child Health Care. 1999;3:27-32. Exclude: not suitable for any question. [pmid: 10451339].
Jacobs G. Chronic fatigue syndrome in children. Patient organisations are denied a voice. BMJ. 1997;315. Exclude: not suitable for any question.
Jacobson SK, Daly JS, Thorne GM, McIntosh K. Chronic parvovirus B19 infection resulting in chronic fatigue syndrome: case history and review. Clin Infect Dis. 1997;24:1048-51. Exclude: not suitable for any question. [pmid: 9195056].
Jacobson W, Saich T, Borysiewicz LK, Behan WM, Behan PO, Wreghitt TG. Serum folate and chronic fatigue syndrome. Neurology. 1993;43:2645-7. Exclude: not suitable for any question. [pmid: 8255470].
Jain SS, DeLisa JA. Chronic fatigue syndrome: a literature review from a physiatric perspective. [Review]. Am J Phys Med Rehabil. 1998;77:160-7. Exclude: not suitable for any question. [pmid: 9558019].
James DG. Complications of sarcoidosis. Chronic fatigue syndrome. Sarcoidosis. 1993;10:1-3. Exclude: not suitable for any question. [pmid: 8134708].
James DG, Brook MG, Bannister BA. The chronic fatigue syndrome. [Review]. Postgrad Med J. 1992;68:611-4. Exclude: not suitable for any question. [pmid: 1448399].
Janse Van Rensburg E. Unacceptable trends in the diagnosis of chronic fatigue syndrome. S Afr Med J. 1992;81:172-3. Exclude: not suitable for any question.
Jason LA. Chronic fatigue syndrome: new hope from psychoneuroimmunology and community psychology. J Prim Prev. 1993;14:51-72. Exclude: not suitable for any question.
Jason LA, Holden JG, Taylor SL, Melrose HJ. Monitoring energy levels in chronic fatigue syndrome. Psychol Rec. 1995;45:643-54. Exclude: not suitable for any question.
Jason LA, Jordan KM, Richman JA, et al. A community-based study of prolonged fatigue and chronic fatigue. J Health Psychol. 1999;4:9-26. Include.
Jason LA, King CP, Richman JA, Taylor RR, Torres SR, Song S. U.S. Case definition of chronic fatigue syndrome: Diagnostic and theoretical issues. J Chronic Fatigue Syndr. 1999;5:3-33. Exclude: not suitable for any question.
Jason LA, King CP, Taylor RR, Kennedy C. Defining chronic fatigue syndrome: methodological challenges. J Chronic Fatigue Syndr. 2000;7:17-32. Include.
Jason LA, Melrose H, Lerman A, et al. Managing chronic fatigue syndrome: overview and case study. [Review]. AAOHN J. 1999;47:17-21. Exclude: not suitable for any question. [pmid: 10205371].
Jason LA, Richman JA, Friedberg F, Wagner L, Taylor R, Jordan KM. More on the biopsychosocial model of chronic fatigue syndrome. Am Psychol. 1998;53:1081-2. Exclude: not suitable for any question.
Jason LA, Richman JA, Friedberg F, Wagner L, Taylor R, Jordan KM. Politics, science, and the emergence of a new disease. The case of chronic fatigue syndrome. Am Psychol. 1997;52:973-83. Exclude: not suitable for any question. [pmid: 9301342].
Jason LA, Richman JA, Rademaker AW, et al. A community-based study of chronic fatigue syndrome. Arch Intern Med. 1999;159:2129-37. Include. [pmid: 10527290].
Jason LA, Ropacki MT, Santoro NB, et al. A screening instrument for chronic fatigue syndrome: Reliability and validity [published eratum: Journal of Chronic Fatigue Syndrome 1997 3(2): 79]. J Chronic Fatigue Syndr. 1997;3:39-59. Exclude: not suitable for any question.
Jason LA, Taylor R, Wagner L, et al. Estimating rates of chronic fatigue syndrome from a community-based sample: a pilot study. Am J Community Psychol. 1995;23:557-68. Include. [pmid: 8546110].
Jason LA, Taylor RR. Applying cluster analysis to define a topology of chronic fatigue syndrome in a medically-evaluated, random community sample [unpublished manuscript]. Include.
Jason LA, Taylor RR, Kennedy CL. Chronic fatigue syndrome, fibromyalgia, and multiple chemical sensitivities in a community-based sample of persons with chronic fatigue syndrome-like symptoms. Psychosom Med. 2000;62:655-63. Include. [pmid: 11020095].
Jason LA, Taylor RR, Kennedy CL. A factor analysis of chronic fatigue symptoms in a community-based sample. [unpublished manuscript]. Include.
Jason LA, Taylor RR, Kennedy CL, Song S, Johnson D, Torres S. Chronic fatigue syndrome: occupation, medical utilization, and subtypes in a community-based sample. J Nerv Ment Dis. 2000;188:568-76. Exclude: not suitable for any question. [pmid: 11009329].
Jason LA, Taylor SL. Monitoring chronic fatigue syndrome. J Nerv Ment Dis. 1994;182:243-4. Exclude: sample size. [pmid: 10678325].
Jason LA, Taylor SL, Johnson S, Goldston SE. Prevalence of chronic fatigue syndrome-related symptoms among nurses. Eval Health Prof. 1993;16:385-99. Include. [pmid: 10130552].
Jason LA, Torres-Harding SR, Taylor RR, Carrico AW. A comparison of the 1988, 1994, and myalgic encephalomyelitis diagnostic criteria for chronic fatigue syndrome [unpublished manuscript]. Exclude: not suitable for any question.
Jason LA, Tryon WW, Taylor RR, King C, Frankenberry EL, Jordan KM. Monitoring and assessing symptoms of chronic fatigue syndrome: use of time series regression. Psychol Rep. 1999;85:121-30. Exclude: sample size. [pmid: 10575979].
Jason LA, Wagner L, Rosenthal S, et al. Estimating the prevalence of chronic fatigue syndrome among nurses. Am J Med. 1998;105:91S-3S. Include. [pmid: 9790488].
Jason LA, Wagner L, Taylor R, Ropacki MT. Chronic fatigue syndrome: a new challenge for health care professionals. J Community Psychol. 1995;23:143-64. Exclude: not suitable for any question.
Jay SJ. Tobacco use and chronic fatigue syndrome, fibromyalgia, and temporomandibular disorder. Arch Intern Med. 2000;160:2398-401. Exclude: not suitable for any question. [pmid: 10927749].
Jeffcoate WJ. Chronic fatigue syndrome and functional hypoadrenia--fighting vainly the old ennui. Lancet. 1999;353:424-5. Exclude: not suitable for any question. [pmid: 9989708].
Jha RR, Masson EA, Lindow SW. Detailed description of a pregnancy associated with severe chronic fatigue syndrome. J Obstet Gynaecol. 1999;19:306-7. Exclude: not suitable for any question. [pmid: 15512306].
Jiaxu C, Weiyi Y. Treatment of chronic fatigue syndrome with Chinese medicine. J Chronic Fatigue Syndr. 1999;5:61-5. Exclude: not suitable for any question.
Johnson SK. The biopsychosocial model and chronic fatigue syndrome. Am Psychol. 1998;53:1080-2. Exclude: not suitable for any question. [pmid: 9841580].
Johnson SK, DeLuca J, Diamond BJ, Natelson BH. Selective impairment of auditory processing in chronic fatigue syndrome: a comparison with multiple sclerosis and healthy controls. Percept Mot Skills. 1996;83:51-62. Exclude: not suitable for any question. [pmid: 8873173].
Johnson SK, DeLuca J, Fiedler N, Natelson BH. Cognitive functioning of patients with chronic fatigue syndrome. Clin Infect Dis. 1994;18:S84-5. Exclude: not suitable for any question. [pmid: 8148459].
Johnson SK, DeLuca J, Natelson BH. Assessing somatization disorder in the chronic fatigue syndrome. Psychosom Med. 1996;58:50-7. Exclude: not suitable for any question. [pmid: 8677289].
Johnson SK, DeLuca J, Natelson BH. Chronic fatigue syndrome: reviewing the research findings. [Review]. Ann Behav Med. 1999;21:258-71. Exclude: not suitable for any question. [pmid: 10626034].
Johnson SK, DeLuca J, Natelson BH. Depression in fatiguing illness: comparing patients with chronic fatigue syndrome, multiple sclerosis and depression. J Affect Disord. 1996;39:21-30. Include. [pmid: 8835650].
Johnson SK, DeLuca J, Natelson BH. Personality dimensions in the chronic fatigue syndrome: a comparison with multiple sclerosis and depression. J Psychiatr Res. 1996;30:9-20. Exclude: not suitable for any question. [pmid: 8736462].
Johnston JH. Chronic fatigue syndrome in Army general practice. J R Army Med Corps. 1994;140:59-60. Exclude: not suitable for any question. [pmid: 8907830].
Joncas JH. Search for an association between Epstein-Barr virus infection and the chronic fatigue syndrome. Can Dis Wkly Rep. 1991;17:43-7. Exclude: not suitable for any question. [pmid: 1669352].
Jones E, Wessely S. Case of chronic fatigue syndrome after Crimean war and Indian mutiny. BMJ. 1999;319:1645-7. Exclude: not suitable for any question. [pmid: 10600980]. [pmcid: 1127098].
Jones JF. Viral etiology of chronic fatigue syndrome. In: Goodnick PJ, Klimas NG, editors. Chronic fatigue and related immune deficiency syndromes. Washington: American Psychiatric Press. 1993:p.23-43.
Jones JF, Ray CG, Minnich LL, Hicks MJ, Kibler R, Lucas DO. Evidence for active Epstein-Barr virus infection in patients with persistent, unexplained illnesses: elevated anti-early antigen antibodies. Ann Intern Med. 1985;102:1-7. Include. [pmid: 2578266].
Jones JF, Streib J, Baker S, Herberger M. Chronic fatigue syndrome: I. Epstein-Barr virus immune response and molecular epidemiology. J Med Virol. 1991;33:151-8. Exclude: not suitable for any question. [pmid: 1679118].
Jones JF, Williams M, Schooley RT, Robinson C, Glaser R. Antibodies to Epstein-Barr virus-specific DNase and DNA polymerase in the chronic fatigue syndrome. Arch Intern Med. 1988;148:1957-60. Exclude: not suitable for any question. [pmid: 2843138].
Jordan KM, Kolak AM, Jason LA. Research with children and adolescents with chronic fatigue syndrome: Methodologies, designs, and special considerations. J Chronic Fatigue Syndr. 1997;3:3-14. Exclude: not suitable for any question.
Jordan KM, Landis DA, Downey MC, Osterman SL, Thurm AE, Jason LA. Chronic fatigue syndrome in children and adolescents: a review. [Review]. J Adolesc Health. 1998;22:4-18. Exclude: not suitable for any question. [pmid: 9436061].
Jorge CM, Goodnick PJ. Chronic fatigue syndrome and depression: biological differentiation and treatment. Psychiatr Ann. 1997;27:365-71. Exclude: not suitable for any question.
Josephs SF, Henry B, Balachandran N, et al. HHV-6 reactivation in chronic fatigue syndrome. Lancet. 1991;337:1346-7. Exclude: not suitable for any question. [pmid: 1674318].
Jovanovic J, Cvjetkovic D, Brkic S, Madle-Samardzija N. [The Epstein-Barr virus and chronic fatigue syndrome]. [Serbo-Croatian (Roman)]. Med Pregl. 1995;48:391-3. Exclude: not suitable for any question. [pmid: 8643052].
Joyce E, Blumenthal S, Wessely S. Memory, attention, and executive function in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1996;60:495-503. Exclude: not suitable for any question. [pmid: 8778252].
Joyce J, Hotopf M, Wessely S. The prognosis of chronic fatigue and chronic fatigue syndrome: a systematic review. [Review]. QJM. 1997;90:223-33. Exclude: not suitable for any question. [pmid: 9093600].
Joyce J, Wessely S. Chronic fatigue syndrome. Ir J Psychol Med. 1996;13:46-50. Exclude: not suitable for any question.
Jungmayr P. [Glucocorticoids for the treatment of chronic fatigue syndrome?]. [German]. Dtsch Apoth Ztg. 1999;139:33-4. Exclude: not suitable for any question.
Kaemingk KL. Cardiovascular reflex function, fatigue and depression in chronic fatigue syndrome. Diss Abstr Int. 1993;53. Exclude: not suitable for any question.
Kanayama Y. [Chronic fatigue syndrome--symptoms, signs, laboratory tests, and prognosis]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2586-90. Exclude: not suitable for any question. [pmid: 1287234].
Kane RL, Gantz NM, DiPino RK. Neuropsychological and psychological functioning in chronic fatigue syndrome. Neuropsychiatry Neuropsychol Behav Neurol. 1997;10:25-31. Exclude: not suitable for any question. [pmid: 9118194].
Kantrowitz FG, Farrar DJ, Locke SE. Chronic fatigue syndrome. 2: Treatment and future research. [Review]. Behav Med. 1995;21:17-24. Exclude: not suitable for any question. [pmid: 7579771].
Kaplan HI, Sadock BJ. Kaplan and sadock's synopsis of psychiatry: behavioral sciences/clinical psychiatry. 8th ed. Baltimore (MD): Williams & Wilkins Co. 1998. Exclude: not suitable for any question. [pmcid: 325579].
Kaplan KH, Goldenberg DL, Galvin-Nadeau M. Neurasthenia and chronic fatigue syndrome: the role of culture in the making of a diagnosis: comment. Am J Psychiatry. 1992;149. Exclude: not suitable for any question.
Karetzky MS. Chronic fatigue syndrome. N J Med. 1992;89:191-2. Exclude: not suitable for any question. [pmid: 1574197].
Kaslow JE, Rucker L, Onishi R. Liver extract-folic acid-cyanocobalamin vs placebo for chronic fatigue syndrome. Arch Intern Med. 1989;149:2501-3. Include. [pmid: 2684076].
Katerndahl DA. Differentiation of physical and psychological fatigue. Fam Pract Res J. 1993;13:81-91. Exclude: not suitable for any question. [pmid: 8484345].
Kato Y, Kamijima S, Kashiwagi A, Oguri T. [Chronic fatigue syndrome, a case of high anti-HHV-6 antibody titer and one associated with primary hyperaldosteronism]. [Japanese]. Nippon Rinsho. 1992;50:2673-8. Exclude: not suitable for any question. [pmid: 1337563].
Kato Y, Mihara H, Kato H, et al. Chronic fatigue syndrome associated with primary hyperaldosteronism. A case report. J Aichi Med Univ Assoc. 1992;20:379-83. Exclude: not suitable for any question.
Katon W, Russo J. Chronic fatigue syndrome criteria. A critique of the requirement for multiple physical complaints. Arch Intern Med. 1992;152:1604-9. Exclude: not suitable for any question. [pmid: 1497394].
Katon WJ, Buchwald DS, Simon GE, Russo JE, Mease PJ. Psychiatric illness in patients with chronic fatigue and those with rheumatoid arthritis. J Gen Intern Med. 1991;6:277-85. Exclude: not suitable for any question. [pmid: 1890495].
Katz BZ, Andiman WA. Chronic fatigue syndrome. J Pediatr. 1988;113:944-7. Exclude: not suitable for any question. [pmid: 2846810].
Kawa K. [Chronic fatigue syndrome in school children]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2606-11. Exclude: not suitable for any question. [pmid: 1287237].
Kawai K, Kawai A. Studies on the relationship between chronic fatigue syndrome and Epstein-Barr virus in Japan. Intern Med. 1992;31:313-8. Exclude: not suitable for any question. [pmid: 1319246].
Kawakami N, Iwata N, Fujihara S, Kitamura T. Prevalence of chronic fatigue syndrome in a community population in Japan. Tohoku J Exp Med. 1998;186:33-41. Include. [pmid: 9915105].
Keenan PA. Brain MRI abnormalities exist in chronic fatigue syndrome. J Neurol Sci. 1999;171:1-2. Exclude: not suitable for any question. [pmid: 10567041].
Keller RH, Lane JL, Klimas N, et al. Association between HLA class II antigens and the chronic fatigue immune dysfunction syndrome. Clin Infect Dis. 1994;18:S154-6. Exclude: not suitable for any question. [pmid: 8148444].
Kellner R. Psychosomatic syndromes, somatization, and somatoform disorders. In: Fava GA, Freyberger H, editors. Handbook of psychosomatic medicine. Madison (CT): International Universities Press. 1998:p.125-60. Exclude: not suitable for any question.
Kellner R. Treatment approaches to somatizing and hypochondriacal patients. In: Kirmayer LJ, Robbins JM, editors. Current concepts of somatization: research and clinical perspectives. Washington: American Psychiatric Press. 1991:p.159-79. Exclude: not suitable for any question.
Kelly KS, Soderlund K, Albert C, McGarrahan AG. Social support and chronic fatigue syndrome. Health Commun. 1999;11:21-34. Exclude: not suitable for any question. [pmid: 16370968].
Kelly R. Myalgic encephalomyelitis and chronic fatigue syndrome. N Z Med J. 1995;108. Exclude: not suitable for any question.
Kendell R, Turnberg L, Toby J. Chronic fatigue syndrome. Lancet. 1996;348. Exclude: not suitable for any question.
Kendell RE. Chronic fatigue, viruses, and depression. Lancet. 1991;337:160-2. Exclude: not suitable for any question. [pmid: 1670800].
Kenner C. Fibromyalgia and chronic fatigue: the holistic perspective. [Review]. Holist Nurs Pract. 1998;12:55-63. Exclude: not suitable for any question. [pmid: 9624958].
Kent-Braun JA, Sharma KR, Weiner MW, Massie B, Miller RG. Central basis of muscle fatigue in chronic fatigue syndrome. Neurology. 1993;43:125-31. Exclude: not suitable for any question. [pmid: 8423875].
Kenter EG, Okkes IM. [Patients with fatigue in family practice: prevalence and treatment]. [Dutch]. Ned Tijdschr Geneeskd. 1999;143:796-801. Exclude: not suitable for any question. [pmid: 10347643].
Kermode-Scott B. Don't worry about the label. Diagnose underlying perpetuating factors in chronic fatigue syndrome [news]. Can Fam Physician. 1995;41:1126-8. Exclude: not suitable for any question. [pmid: 7780320].
Kerr JR, Barrett AM, Curran MD, Behan WMH, Middleton D, Behan PO. Parvovirus B19 and chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:101-7. Exclude: not suitable for any question.
Khan AS, Heneine WM, Chapman LE, et al. Assessment of a retrovirus sequence and other possible risk factors for the chronic fatigue syndrome in adults. Ann Intern Med. 1993;118:241-5. Exclude: not suitable for any question. [pmid: 8420441].
Khawaja SS, Van Boxel P. Chronic fatigue syndrome in childhood: Seven-year follow-up study. Psychiatr Bull. 1998;22:198-202. Exclude: not suitable for any question.
Khoury PB. Chronic fatigue syndrome (CFS) and psychiatric disorders. Am J Med. 1994;96:485-6. Exclude: not suitable for any question. [pmid: 8031395].
Kiener S. [A case from practice (279). 1. Chronic fatigue syndrome (CFS). 2. Psychosocial problems]. [German]. Schweiz Rundsch Med Prax. 1993;82:1142-3. Exclude: not suitable for any question. [pmid: 8210889].
Kilburn KH. Symptoms, syndrome, and semantics: multiple chemical sensitivity and chronic fatigue syndrome. Arch Environ Health. 1993;48:368-9. Exclude: not suitable for any question. [pmid: 8215605].
Kim E. A brief history of chronic fatigue syndrome. JAMA. 1994;272:1070-1. Exclude: not suitable for any question. [pmid: 8089894].
Kipen HM, Hallman W, Kang H, Fiedler N, Natelson BH. Prevalence of chronic fatigue and chemical sensitivities in Gulf Registry Veterans. Arch Environ Health. 1999;54:313-8. Include. [pmid: 10501146].
Kirchhoff B. [Current environmental medicine. Facts and hypotheses - A critical review]. [German]. Z Allgemeinmed. 1999;75:189-91. Exclude: not suitable for any question.
Kirk KM, Hickie IB, Martin NG. Fatigue as related to anxiety and depression in a community-based sample of twins aged over 50. Soc Psychiatry Psychiatr Epidemiol. 1999;34:85-90. Exclude: not suitable for any question. [pmid: 10189814].
Kirmayer LJ, Robbins JM. Functional somatic syndromes. In: Kirmayer LJ, Robbins JM, editors. Current concepts of somatization: research and clinical perspectives. Washington: American Psychiatric Press. 1991:p.79-106. Exclude: not suitable for any question.
Kitani T. [Chronic fatigue syndrome]. [Japanese]. Nippon Naika Gakkai Zasshi. 1993;82:1571-6. Exclude: not suitable for any question. [pmid: 8245661].
Kitani T. [Chronic fatigue syndrome: the present concept and historical perspective]. [Japanese]. Nippon Rinsho. 1992;50:2581-5. Exclude: not suitable for any question. [pmid: 1287233].
Kitani T, Kuratsune H. [Chronic fatigue syndrome]. [Japanese]. Nippon Naika Gakkai Zasshi. 1992;81:573-82. Exclude: not suitable for any question. [pmid: 1619339].
Kitani T, Kuratsune H, Fuke I, et al. Possible correlation between Borna disease virus infection and Japanese patients with chronic fatigue syndrome. Microbiol Immunol. 1996;40:459-62. Exclude: not suitable for any question. [pmid: 8839433].
Kitani T, Kuratsune H, Yamaguchi K. [Diagnostic criteria for chronic fatigue syndrome by the CFS Study Group in Japan]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2600-5. Exclude: not suitable for any question. [pmid: 1287236].
Klebanova VA. [Chronic fatigue syndrome]. [Review] [Russian]. Gig Sanit. 1995:35-8. Exclude: not suitable for any question.
Klein R, Berg PA. High incidence of antibodies to 5-hydroxytryptamine, gangliosides and phospholipids in patients with chronic fatigue and fibromyalgia syndrome and their relatives: evidence for a clinical entity of both disorders. Eur J Med Res. 1995;1:21-6. Exclude: not suitable for any question. [pmid: 9392689].
Kleinman A The moral economy of depression and neurasthenia in china. A few comments on “diagnosis postponed: shenjing shuairuo and the transformation of psychiatry in post-mao china,” by sing lee Cult Med Psychiatry 1999 23(3):389 92 Exclude: not suitable for any question
Klimas N. Pathogenesis of chronic fatigue syndrome and fibromyalgia. Growth Hormone IGF Research. 1998;8:123-6. Exclude: not suitable for any question. [pmid: 10990146].
Klimas N, Wallace M. Toward optimal health: the experts discuss chronic fatigue syndrome. Interviewed by Jodi Godfrey Meisler. J Womens Health Gend Based Med. 2000;9:477-82. Exclude: not suitable for any question. [pmid: 10883938].
Klimas NG, Patarca-Montero R. Multidisciplinary innovations in research, theory and clinical practice. J Chronic Fatigue Syndr. 1998;4. Exclude: not suitable for any question.
Klimas NG, Salvato FR, Morgan R, Fletcher MA. Immunologic abnormalities in chronic fatigue syndrome. J Clin Microbiol. 1990;28:1403-10. Exclude: not suitable for any question. [pmcid: 267940]. [pmid: 2166084].
Klimas NG, Morgan R, Van Riel F, Fletcher MA. Observations regarding use of an antidepressant, fluoxetine, in chronic fatigue syndrome. In: Goodnick PJ, Klimas NG, editors. Chronic fatigue and related immune deficiency syndromes. Washington: American Psychiatric Press. 1993:p.95-108.
Klonoff DC. Chronic fatigue syndrome and neurally mediated hypotension. JAMA. 1996;275:359-60. Exclude: not suitable for any question. [pmid: 8569010].
Klonoff DC. Chronic fatigue syndrome. [Review]. Clin Infect Dis. 1992;15:812-23. Exclude: not suitable for any question. [pmid: 1445980].
Kminek A. [Chronic fatigue syndrome]. [Review] [Czech]. Cesk Pediatr. 1992;47:226-9. Exclude: not suitable for any question. [pmid: 1628359].
Kminek A, Simunek I. Chronic fatigue immune dysfunction syndrome: an epidemic?. Pediatrics. 1992;89. Exclude: not suitable for any question.
Knepper S. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141. Exclude: not suitable for any question.
Knussen C, Lee D. Chronic fatigue syndrome: symptoms, appraisal and ways of coping. Br J Health Psychol. 1998;3:111-21. Exclude: not suitable for any question.
Koehoorn J, Fechter MM, de Vries H. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:2362-3. Exclude: not suitable for any question. [pmid: 9550834].
Kohler D. [Sleep apnea as the cause of chronic fatigue syndrome]. [German]. Med Klin. 1994;89. Exclude: not suitable for any question.
Komaroff A, Joncas JH. Definition of the syndrome and differential diagnosis. Can Dis Wkly Rep. 1991;17:59-61. Exclude: not suitable for any question.
Komaroff AL. A 56-year-old woman with chronic fatigue syndrome [clinical conference]. JAMA. 1997;278:1179-85. Exclude: not suitable for any question. [pmid: 9326479].
Komaroff AL. The biology of chronic fatigue syndrome. Am J Med. 2000;108:169-71. Exclude: not suitable for any question. [pmid: 11126311].
Komaroff AL. Chronic fatigue syndromes: a preliminary overview. [Review]. Can Dis Wkly Rep. 1991;17:23-8. Exclude: not suitable for any question. [pmid: 1669349].
Komaroff AL. Chronic fatigue syndromes: relationship to chronic viral infections. [Review]. J Virol Methods. 1988;21:3-10. Exclude: not suitable for any question. [pmid: 2846619].
Komaroff AL. Chronic “post-infectious” fatigue syndrome. [Review]. Trans Am Acad Insur Med. 1993;76:82-95. Exclude: not suitable for any question. [pmid: 8337774].
Komaroff AL. Clinical presentation of chronic fatigue syndrome. [Review]. Ciba Found Symp. 1993;173:43-54. Exclude: not suitable for any question. [pmid: 8491106].
Komaroff AL, Bell DS, Cheney PR, Lo SC. Absence of antibody to Mycoplasma fermentans in patients with chronic fatigue syndrome. Clin Infect Dis. 1993;17:1074-5. Exclude: not suitable for any question. [pmid: 8110942].
Komaroff AL, Buchwald D. Symptoms and signs of chronic fatigue syndrome. Rev Infect Dis. 1991;13:S8-11. Exclude: not suitable for any question. [pmid: 2020806].
Komaroff AL, Buchwald DS. Chronic fatigue syndrome: an update. [Review]. Annu Rev Med. 1998;49:1-13. Exclude: not suitable for any question. [pmid: 9509246].
Komaroff AL, Fagioli LR, Doolittle TH, et al. Health status in patients with chronic fatigue syndrome and in general population and disease comparison groups. Am J Med. 1996;101:281-90. Include. [pmid: 8873490].
Komaroff AL, Fagioli LR, Geiger AM, et al. An examination of the working case definition of chronic fatigue syndrome. Am J Med. 1996;100:56-64. Include. [pmid: 8579088].
Komaroff AL, Goldenberg D. The chronic fatigue syndrome: definition, current studies and lessons for fibromyalgia research. [Review]. J Rheumatol Suppl. 1989;19:23-7. Exclude: not suitable for any question. [pmid: 2691680].
Komaroff AL, Wang SP, Lee J, Grayston JT. No association of chronic Chlamydia pneumoniae infection with chronic fatigue syndrome. J Infect Dis. 1992;165. Exclude: not suitable for any question.
Komaroff AL, Fagioli L. Medical assessment of fatigue and chronic fatigue syndrome. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.154-81. Exclude: not suitable for any question.
Konstantinov K, von Mikecz A, Buchwald D, Jones J, Gerace L, Tan EM. Autoantibodies to nuclear envelope antigens in chronic fatigue syndrome. J Clin Invest. 1996;98:1888-96. Exclude: not suitable for any question. [pmid: 8878441]. [pmcid: 507629].
Koo D. Chronic fatigue syndrome. A critical appraisal of the role of Epstein-Barr virus. [Review]. West J Med. 1989;150:590-6. Exclude: not suitable for any question. [pmid: 2545048]. [pmcid: 1026689].
Korszun A, Papadopoulos E, Demitrack M, Engleberg C, Crofford L. The relationship between temporomandibular disorders and stress-associated syndromes. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1998;86:416-20. Exclude: did not meet inclusion criteria. [pmid: 9798224].
Korszun A, Sackett-Lundeen L, Papadopoulos E, et al. Melatonin levels in women with fibromyalgia and chronic fatigue syndrome. J Rheumatol. 1999;26:2675-80. Exclude: not suitable for any question. [pmid: 10606381].
Korszun A, Young EA, Engleberg NC, et al. Follicular phase hypothalamic-pituitary-gonadal axis function in women with fibromyalgia and chronic fatigue syndrome. J Rheumatol. 2000;27:1526-30. Exclude: not suitable for any question. [pmid: 10852283].
Korzon M, Bukowska W, Szlagatys-Sidorkiewicz A. Chronic fatigue syndrome. Med Sci Monit. 1998;4:388-92. Exclude: not suitable for any question.
Kranzler HR, Manu P, Hesselbrock VM, Lane TJ. Substance use disorders in patients with chronic fatigue. Hosp Community Psychiatry. 1991;42:924-8. Exclude: not suitable for any question. [pmid: 1743663].
Krasnov VN, Vel'tishev DIu. [Neurasthenia as a variant of the asthenic syndrome: a pharmacotherapeutic analysis modelled on tanakan therapy]. [Russian]. Zh Nevrol Psikhiatr Im S S Korsakova. 1999;99:37-40. Exclude: not suitable for any question.
Kreyberg S. [A close meeting with chronic fatigue syndrome]. [Norwegian]. Tidsskr Nor Laegeforen. 1999;119:2229-31. Exclude: not suitable for any question. [pmid: 10402922].
Kreyberg S. [Management of chronic fatigue syndrome reflects the physician's “illness belief” letter)]. [Swedish]. Lakartidningen. 1999;96. Exclude: not suitable for any question.
Krilov LR. Chronic fatigue syndrome. Pediatr Ann. 294; 24:290-2. Exclude: not suitable for any question. [pmid: 10826324].
Krilov LR, Fisher M, Friedman SB, Reitman D, Mandel FS. Course and outcome of chronic fatigue in children and adolescents. Pediatrics. 1998;102:360-6. Exclude: not suitable for any question. [pmid: 9685439].
Kroenke K. Chronic fatigue syndrome: is it real? [Review]. Postgrad Med. 1991;89:44-6, 49-50, 53-5. Exclude: not suitable for any question. [pmid: 1990396].
Kroenke K, Swindle R. Cognitive-behavioral therapy for somatization and symptom syndromes: a critical review of controlled clinical trials. Psychother Psychosom. 2000;69:205-15. Exclude: not suitable for any question. [pmid: 10867588].
Kroneman H, Croon NH. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141. Exclude: not suitable for any question.
Krueger GR, Klueppelberg U, Hoffmann A, Ablashi DV. Clinical correlates of infection with human herpesvirus-6. [Review]. In Vivo. 1994;8:457-85. Exclude: not suitable for any question. [pmid: 7893974].
Kruesi MJ, Dale J, Straus SE. Psychiatric diagnoses in patients who have chronic fatigue syndrome. [published erratum appears in J Clin Psychiatry 1989;50:148]. J Clin Psychiatry. 1989;50:53-6. Include. [pmid: 2536690].
Krupp LB, Jandorf L, Coyle PK, Mendelson WB. Sleep disturbance in chronic fatigue syndrome. J Psychosom Res. 1993;37:325-31. Include. [pmid: 8510058].
Krupp LB, Mendelson WB, Friedman R. An overview of chronic fatigue syndrome. [Review]. J Clin Psychiatry. 1991;52:403-10. Exclude: not suitable for any question. [pmid: 1938975].
Krupp LB, Pollina D. Neuroimmune and neuropsychiatric aspects of chronic fatigue syndrome. Adv Neuroimmunol. 1996;6:155-67. Exclude: not suitable for any question. [pmid: 8876771].
Krupp LB, Sliwinski M, Masur DM, Friedberg F. Cognitive functioning and depression in patients with chronic fatigue syndrome and multiple sclerosis. Arch Neurol. 1994;51:705-10. Exclude: sample size. [pmid: 8018045].
Kundu SK, Ahronheim GA, Menezes J. Immunodysregulation and chronic fatigue syndrome. Can Dis Wkly Rep. 1991;17:49-50. Exclude: not suitable for any question.
Kuratsune H, Yamaguti K, Hattori H, et al. [Symptoms, signs and laboratory findings in patients with chronic fatigue syndrome]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2665-72. Exclude: not suitable for any question. [pmid: 1337562].
Kuratsune H, Yamaguti K, Lindh G, et al. Low levels of serum acylcarnitine in chronic fatigue syndrome and chronic hepatitis type C, but not seen in other diseases. Int J Mol Med. 1998;2:51-6. Exclude: not suitable for any question. [pmid: 9854142].
Kuratsune H, Yamaguti K, Sawada M, et al. Dehydroepiandrosterone sulfate deficiency in chronic fatigue syndrome. Int J Mol Med. 1998;1:143-6. Exclude: not suitable for any question. [pmid: 9852212].
Kuratsune H, Yamaguti K, Takahashi M, Misaki H, Tagawa S, Kitani T. Acylcarnitine deficiency in chronic fatigue syndrome. Clin Infect Dis. 1994;18:S62-7. Exclude: not suitable for any question. [pmid: 8148455].
Kutemeyer M. [The chronic fatigue syndrome: A type of anxiety neurosis].[German]. Aktuelle Neurol. 1991;18:188-91. Exclude: not suitable for any question.
Kutemeyer M. [Comments on the review by Wilfrid A. Nix. Chronic fatigue syndrome--a new disease picture?].[German]. Nervenarzt. 1991;62:64-6. Exclude: not suitable for any question. [pmid: 2027424].
Kyle DV, deShazo RD. Chronic fatigue syndrome: a conundrum. [Review]. Am J Med Sci. 1992;303:28-34. Exclude: not suitable for any question. [pmid: 1309484].
Lakein DA, Fantie BD, Grafman J, et al. Patients with chronic fatigue syndrome and accurate feeling-of-knowing judgments. J Clin Psychol. 1997;53:635-45. Exclude: sample size. [pmid: 9356893].
Lam RW. Seasonal affective disorder presenting as chronic fatigue syndrome. Can J Psychiatry. 1991;36:680-2. Exclude: not suitable for any question. [pmid: 1773405].
LaManca JJ, Peckerman A, Walker J, et al. Cardiovascular response during head-up tilt in chronic fatigue syndrome. Clin Physiol. 1999;19:111-20. Exclude: not suitable for any question. [pmid: 10200892].
LaManca JJ, Sisto SA, DeLuca J, et al. Influence of exhaustive treadmill exercise on cognitive functioning in chronic fatigue syndrome. Am J Med. 1998;105:59S-65S. Exclude: not suitable for any question. [pmid: 9790484].
LaManca JJ, Sisto SA, Zhou XD, et al. Immunological response in chronic fatigue syndrome following a graded exercise test to exhaustion. J Clin Immunol. 1999;19:135-42. Exclude: not suitable for any question. [pmid: 10226888].
Land JM, Kemp GJ, Taylor DJ, Standing SJ, Radda GK, Rajagopalan B. Oral phosphate supplements reverse skeletal muscle abnormalities in a case of chronic fatigue with idiopathic renal hypophosphatemia. Neuromuscul Disord. 1993;3:223-5. Exclude: not suitable for any question. [pmid: 8400863].
Landay AL, Jessop C, Lennette ET, Levy JA. Chronic fatigue syndrome: clinical condition associated with immune activation. Lancet. 1991;338:707-12. Exclude: not suitable for any question. [pmid: 1679864].
Lane DA, Kramer MS. Determining exposure underreporting in pharmacoepidemiologic case-control studies: methods and example. J Clin Epidemiol. 1999;52:1279-87. Exclude: not suitable for any question. [pmid: 10580792].
Lane R. Chronic fatigue syndrome: is it physical?. J Neurol Neurosurg Psychiatry. 2000;69. Exclude: not suitable for any question.
Lane RJ, Barrett MC, Taylor DJ, Kemp GJ, Lodi R. Heterogeneity in chronic fatigue syndrome: evidence from magnetic resonance spectroscopy of muscle. Neuromuscul Disord. 1998;8:204-9. Exclude: not suitable for any question. [pmid: 9631403].
Lane RJ, Barrett MC, Woodrow D, Moss J, Fletcher R, Archard LC. Muscle fibre characteristics and lactate responses to exercise in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1998;64:362-7. Exclude: not suitable for any question. [pmid: 9527150].
Lane RJ, Burgess AP, Flint J, Riccio M, Archard LC. Exercise responses and psychiatric disorder in chronic fatigue syndrome. BMJ. 1995;311:544-5. Exclude: physiologic. [pmid: 7663210].
Lane RJ, Woodrow D, Archard LC. Lactate responses to exercise in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1994;57:662-3. Exclude: not suitable for any question.
Lane TJ, Manu P, Matthews DA. Depression and somatization in the chronic fatigue syndrome. Am J Med. 1991;91:335-44. Exclude: not suitable for any question. [pmid: 1951377].
Lane TJ, Matthews DA, Manu P. The low yield of physical examinations and laboratory investigations of patients with chronic fatigue. Am J Med Sci. 1990;299:313-8. Exclude: not suitable for any question. [pmid: 2337122].
Lange G, DeLuca J, Maldjian JA, Lee H, Tiersky LA, Natelson BH. Brain MRI abnormalities exist in a subset of patients with chronic fatigue syndrome. J Neurol Sci. 1999;171:3-7. Exclude: not suitable for any question. [pmid: 10567042].
Lange G, Wang S, DeLuca J, Natelson BH. Neuroimaging in chronic fatigue syndrome. [Review]. Am J Med. 1998;105:50S-3S. Exclude: not suitable for any question. [pmid: 9790482].
Lapp CW. Exercise limits in chronic fatigue syndrome. Am J Med. 1997;103:83-4. Exclude: not suitable for any question. [pmid: 9236491].
Lapp CW. Management of chronic fatigue syndrome in children: A practicing clinician's approach. J Chronic Fatigue Syndr. 1997;3:59-76. Exclude: not suitable for any question.
Lapp CW, Cheney PR. The chronic fatigue syndrome. Ann Intern Med. 1995;123:74-5. Exclude: not suitable for any question. [pmid: 7762921].
Lapp CW, Hyman HL. Diagnosis of chronic fatigue syndrome. Arch Intern Med. 1997;157:2663-4. Exclude: not suitable for any question. [pmid: 9531237].
Lathan SR. Chronic fatigue? Consider hypothyroidism. Physician Sportsmed. 1991;19:67-70. Exclude: not suitable for any question.
Lavietes MH, Bergen MT, Natelson BH. Measurement of CO2 in chronic fatigue syndrome patients. J Chronic Fatigue Syndr. 1998;4:3-11. Exclude: not suitable for any question.
Lawrie SM. Cognitive behaviour therapy for the chronic fatigue syndrome. Essential elements of the treatment must be identified. BMJ. 1996;312. Exclude: not suitable for any question.
Lawrie SM, MacHale SM. Chronic fatigue syndrome. Lancet. 1994;344. Exclude: not suitable for any question.
Lawrie SM, MacHale SM, Cavanagh JT, O'Carroll RE, Goodwin GM. The difference in patterns of motor and cognitive function in chronic fatigue syndrome and severe depressive illness. Psychol Med. 2000;30:433-42. Exclude: not suitable for any question. [pmid: 10824663].
Lawrie SM, MacHale SM, Power MJ, Goodwin GM. Is the chronic fatigue syndrome best understood as a primary disturbance of the sense of effort?. Psychol Med. 1997;27:995-9. Exclude: not suitable for any question. [pmid: 9300505].
Lawrie SM, Manders DN, Geddes JR, Pelosi AJ. A population-based incidence study of chronic fatigue. Psychol Med. 1997;27:343-53. Include. [pmid: 9089827].
Lawrie SM, Pelosi AJ. Chronic fatigue syndrome and myalgic encephalomyelitis. BMJ. 1994;309. Exclude: not suitable for any question.
Lawrie SM, Pelosi AJ. Chronic fatigue syndrome in the community. Prevalence and associations. Br J Psychiatry. 1995;166:793-7. Include. [pmid: 7663830].
Lawrie SM, Pelosi AJ. Chronic fatigue syndrome: prevalence and outcome. BMJ. 1994;308:732-3. Exclude: not suitable for any question. [pmid: 8142823].
Laylander JA. A nutrient/toxin interaction theory of the etiology and pathogenesis of chronic pain-fatigue syndromes. Part I. J Chronic Fatigue Syndr. 1999;5:67-91. Exclude: not suitable for any question.
Laylander JA. A nutrient/toxin interaction theory of the etiology and pathogenesis of chronic pain-fatigue syndromes. Part II. J Chronic Fatigue Syndr. 1999;5:93-126. Exclude: not suitable for any question.
Layzer RB. Asthenia and the chronic fatigue syndrome. [Review]. Muscle Nerve. 1998;21:1609-11. Exclude: not suitable for any question. [pmid: 9843061].
Lechky O. Life insurance MDs sceptical when chronic fatigue syndrome diagnosed. CMAJ. 1990;143:413-5. Exclude: not suitable for any question. [pmid: 2390755]. [pmcid: 1452254].
Lee P. Recent developments in chronic fatigue syndrome. Am J Med. 1998;105. Exclude: not suitable for any question.
Lee S. Diagnosis postponed: shenjing shuairuo and the transformation of psychiatry in post-Mao China. Cult Med Psychiatry. 1999;23(3):349-80. Exclude: not suitable for any question. [pmid: 10572739].
Lee S. Neurasthenia and Chinese psychiatry in the 1990s. J Psychosom Res. 1994;38:487-91. Exclude: not suitable for any question. [pmid: 7990056].
Leitch AG. Neurasthenia, myalgic encephalitis or cryptogenic chronic fatigue syndrome?. QJM. 1995;88:447-50. Exclude: not suitable for any question. [pmid: 7648237].
Lelievre O, Souweine B, Schmidt J, et al. Cytomegalovirus infections and chronic fatigue syndrome: 4 cases. Rev Med Interne. 1992;13. Exclude: not suitable for any question.
Lemke MR. [Chronic fatigue syndrome--psychiatric aspects]. [Review] [German]. Fortschr Neurol Psychiatr. 1996;64:132-41. Exclude: not suitable for any question. [pmid: 8655125].
Lemke MR. [Chronic fatigue syndrome. The necessity for an integrated, interdisciplinary approach]. [German]. Dtsch Med Wochenschr. 1995;120. Exclude: not suitable for any question.
Leonhardt T. [Chronic fatigue syndrome--old wine in new bottles]. [Review] [Swedish]. Lakartidningen. 2000;97:182-4. Exclude: not suitable for any question. [pmid: 10687349].
Lerner AM, Lawrie C, Dworkin HS. Repetitively negative changing T waves at 24-h electrocardiographic monitors in patients with the chronic fatigue syndrome. Left ventricular dysfunction in a cohort. Chest. 1993;104:1417-21. Exclude: not suitable for any question. [pmid: 8222798].
Levine PH. Chronic fatigue syndrome comes of age. [Review]. Am J Med. 1998;105:2S-6S. Exclude: not suitable for any question. [pmid: 9790474].
Levine PH. The elusive Gulf War syndrome. J Chronic Fatigue Syndr. 1996;2:55-63. Exclude: not suitable for any question.
Levine PH. Epidemic neuromyasthenia and chronic fatigue syndrome: epidemiological importance of a cluster definition. Clin Infect Dis. 1994;18:S16-20. Exclude: not suitable for any question. [pmid: 8148446].
Levine PH. Epidemiologic advances in chronic fatigue syndrome. J Psychiatr Res. 1997;31:7-18. Exclude: not suitable for any question. [pmid: 9201643].
Levine PH. Epidemiology of chronic fatigue syndrome. [Review]. Clin Infect Dis. 1994;18:S57-60. Exclude: not suitable for any question. [pmid: 8148454].
Levine PH. The use of transfer factors in chronic fatigue syndrome: prospects and problems. [Review]. Biotherapy. 1996;9:77-9. Exclude: not suitable for any question. [pmid: 8993762].
Levine PH. What we know about chronic fatigue syndrome and its relevance to the practicing physician. [Review]. Am J Med. 1998;105:100S-3S. Exclude: not suitable for any question. [pmid: 9790490].
Levine PH, Atherton M, Fears T, Hoover R. An approach to studies of cancer subsequent to clusters of chronic fatigue syndrome: use of data from the Nevada State Cancer Registry. Clin Infect Dis. 1994;18:S49-53. Exclude: not suitable for any question. [pmid: 8148453].
Levine PH, Dale JK, Benson-Grigg E, Fritz S, Grufferman S, Straus SE. A cluster of cases of chronic fatigue and chronic fatigue syndrome: clinical and immunologic studies. Clin Infect Dis. 1996;23:408-9. Exclude: not suitable for any question. [pmid: 8842294].
Levine PH, Fears TR, Cummings P, Hoover RN. Cancer and a fatiguing illness in Northern Nevada--a causal hypothesis. Ann Epidemiol. 1998;8:245-9. Exclude: not suitable for any question. [pmid: 9590603].
Levine PH, Jacobson S, Pocinki AG, et al. Clinical, epidemiologic, and virologic studies in four clusters of the chronic fatigue syndrome. Arch Intern Med. 1992;152:1611-6. Include. [pmid: 1323246].
Levine PH, Komaroff AL. Human herpesvirus type 6 and chronic fatigue syndrome. Arch Intern Med. 1993;153. Exclude: not suitable for any question.
Levine PH, Krueger GR, Straus SE. A postviral chronic fatigue syndrome: a round table. J Infect Dis. 1989;160:722-4. Exclude: not suitable for any question.
Levine PH, Peterson D, McNamee FL, et al. Does chronic fatigue syndrome predispose to non-Hodgkin's lymphoma?. Cancer Res. 1992;52:5516s-8s. Exclude: not suitable for any question. [pmid: 1394166].
Levine PH, Snow PG, Ranum BA, Paul C, Holmes MJ. Epidemic neuromyasthenia and chronic fatigue syndrome in west Otago, New Zealand. A 10-year follow-up. Arch Intern Med. 1997;157:750-4. Include. [pmid: 9125006].
Levine PH, Whiteside TL, Friberg D, Bryant J, Colclough G, Herberman RB. Dysfunction of natural killer activity in a family with chronic fatigue syndrome. Clin Immunol Immunopathol. 1998;88:96-104. Exclude: not suitable for any question. [pmid: 9683556].
Levine S. Borna disease virus proteins in patients with CFS. J Chronic Fatigue Syndr. 1999;5:199-206. Exclude: not suitable for any question.
Levy JA. Viral studies of chronic fatigue syndrome. [Review]. Clin Infect Dis. 1994;18:S117-20. Exclude: not suitable for any question. [pmid: 8148437].
Lewis G, Wessely S. The epidemiology of fatigue: more questions than answers. J Epidemiol Community Health. 1992;46:92-7. Exclude: not suitable for any question. [pmid: 1583440].
Lewis S, Cooper CL, Bennett D. Psychosocial factors and chronic fatigue syndrome. [Review]. Psychol Med. 1994;24:661-71. Exclude: not suitable for any question. [pmid: 7991748].
Lewis SF, Haller RG. Physiologic measurement of exercise and fatigue with special reference to chronic fatigue syndrome. [Review]. Rev Infect Dis. 1991;13:S98-S108. Exclude: not suitable for any question. [pmid: 2020810].
Lewis S. Personality, stress, and chronic fatigue syndrome. In: Cooper CL, editors. Handbook of stress, medicine, and health. Boca Raton (FL). CRC Press. 1996:p.233-49. Exclude: not suitable for any question.
Leyton E. Disagreeing on how to treat CFS patients. Can Fam Physician. 1993;39:1022-4. Exclude: not suitable for any question. [pmid: 8347205].
Leyton E, Pross H. Chronic fatigue syndrome. Do herbs of homeopathy help?. Can Fam Physician. 1992;38:2021-6. Exclude: not suitable for any question. [pmid: 21221272].
Lieb K, Dammann G, Berger M, Bauer J. [Chronic fatigue syndrome. Definition, diagnostic measures and therapeutic possibilities]. [Review] [53 refs] [German]. Nervenarzt. 1996;67:711-20. Exclude: not suitable for any question. [pmid: 8992368].
Lieberman J, Bell DS. Serum angiotensin-converting enzyme as a marker for the chronic fatigue-immune dysfunction syndrome: a comparison to serum angiotensin-converting enzyme in sarcoidosis. Am J Med. 1993;95:407-12. Exclude: not suitable for any question. [pmid: 8213873].
Lin KM. Does crisis foster opportunity? A commentary on “diagnosis postponed: shenjing shuairuo and the transformation of psychiatry in post-mao china,” by sing lee. Cult Med Psychiatry. 1999;23(3):381-8. Exclude: not suitable for any question.
Lindberg NE, Lindberg E. [Use available knowledge--also when it is not complete. Current example: chronic fatigue syndrome, fibromyalgia]. [Swedish]. Lakartidningen. 2000;97:2651-2. Exclude: not suitable for any question. [pmid: 10881532].
Linde A, Andersson B, Svenson SB, et al. Serum levels of lymphokines and soluble cellular receptors in primary Epstein-Barr virus infection and in patients with chronic fatigue syndrome. J Infect Dis. 1992;165:994-1000. Exclude: not suitable for any question. [pmid: 1316417].
Lindh G, Samuelson A, Hedlund KO, Evengard B, Lindquist L, Ehrnst A. No findings of enteroviruses in Swedish patients with chronic fatigue syndrome. Scand J Infect Dis. 1996;28:305-7. Exclude: not suitable for any question. [pmid: 8863367].
Lipkin DM, Papernik M, Kaan R. Chronic fatigue. Am J Psychiatry. 1997;154. Exclude: letter.
Lipkin DM, Robin R, Vasquez L, Plioplys A. Chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1995;58:764-5. Exclude: not suitable for any question. [pmid: 7608693].
Liu SX. Neurasthenia in China: modern and traditional criteria for its diagnosis. Cult Med Psychiatry. 1989;13:163-86. Exclude: not suitable for any question. [pmid: 2766792].
Lloyd A, Gandevia S, Brockman A, Hales J, Wakefield D. Cytokine production and fatigue in patients with chronic fatigue syndrome and healthy control subjects in response to exercise. Clin Infect Dis. 1994;18:S142-6. Exclude: not suitable for any question. [pmid: 8148442].
Lloyd A, Hickie I, Hickie C, Dwyer J, Wakefield D. Cell-mediated immunity in patients with chronic fatigue syndrome, healthy control subjects and patients with major depression. Clin Exp Immunol. 1992;87:76-9. Exclude: not suitable for any question. [pmid: 1733640]. [pmcid: 1554231].
Lloyd A, Hickie I, Wakefield D, Boughton C, Dwyer J. A double-blind, placebo-controlled trial of intravenous immunoglobulin therapy in patients with chronic fatigue syndrome. Am J Med. 1990;89:561-8. Include. [pmid: 2146875].
Lloyd AR. Chronic fatigue and chronic fatigue syndrome: shifting boundaries and attributions. [Review]. Am J Med. 1998;105:7S-10S. Exclude: not suitable for any question. [pmid: 9790475].
Lloyd AR. Muscle versus brain: chronic fatigue syndrome. Med J Aust. 1990;153:530-4. Exclude: not suitable for any question. [pmid: 2233475].
Lloyd AR, Gandevia SC, Hales JP. Muscle performance, voluntary activation, twitch properties and perceived effort in normal subjects and patients with the chronic fatigue syndrome. Brain. 1991;114:85-98. Exclude: not suitable for any question. [pmid: 1998892].
Lloyd AR, Hickie I, Boughton CR, Spencer O, Wakefield D. Prevalence of chronic fatigue syndrome in an Australian population. Med J Aust. 1990;153:522-8. Include. [pmid: 2233474].
Lloyd AR, Hickie I, Brockman A, et al. Immunologic and psychologic therapy for patients with chronic fatigue syndrome: a double-blind, placebo-controlled trial. Am J Med. 1993;94:197-203. Include. [pmid: 8430715].
Lloyd AR, Hickie I, Peterson PK. Chronic fatigue syndrome: current concepts of pathogenesis and treatment. [Review]. Curr Clin Top Infect Dis. 1999;19:135-59. Exclude: not suitable for any question. [pmid: 10472484].
Lloyd AR, Hickie IB, Loblay RH. Illness or disease? The case of chronic fatigue syndrome. Med J Aust. 2000;172:471-2. Exclude: not suitable for any question. [pmid: 10901768].
Lloyd AR, Pender H. The economic impact of chronic fatigue syndrome. Med J Aust. 1992;157:599-601. Exclude: not suitable for any question. [pmid: 1406420].
Lloyd AR, Wakefield D, Boughton C, Dwyer J. What is myalgic encephalomyelitis?. Lancet. 1988;1:1286-7. Exclude: not suitable for any question. [pmid: 2897549].
Lloyd AR, Wakefield D, Boughton CR, Dwyer JM. Immunological abnormalities in the chronic fatigue syndrome. Med J Aust. 1989;151:122-4. Exclude: not suitable for any question. [pmid: 2787888].
Lloyd AR, Wakefield D, Hickie I. Immunity and the pathophysiology of chronic fatigue syndrome. [Review]. Ciba Found Symp. 1993;173:176-87. Exclude: not suitable for any question. [pmid: 8491097].
Lloyd K. Insurance issues: beyond the small print. J Psychosom Res. 1997;43:103-5. Exclude: not suitable for any question. [pmid: 9263936].
Loblay RH. Chronic fatigue syndrome. Lancet. 1998;351. Exclude: not suitable for any question.
Loblay RH. Chronic fatigue syndrome: what's in a name?. Med J Aust. 1995;163:285-6. Exclude: not suitable for any question. [pmid: 7565230].
Lonsdale D. Letter to the Editor. J Nutr Med. 1999;9. Exclude: not suitable for any question.
Lopis R. A personal encounter with a mystery illness. Aust Fam Physician. 1991;20:316-7. Exclude: not suitable for any question. [pmid: 2039419].
Lovell DM. Chronic fatigue syndrome among overseas development workers: A qualitative study. J Travel Med. 1999;6:16-23. Exclude: not suitable for any question. [pmid: 10071368].
Lund-Olesen LH, Lund-Olesen K. The etiology and possible treatment of chronic fatigue syndrome/fibromyalgia. Med Hypotheses. 1994;43:55-8. Exclude: not suitable for any question. [pmid: 7968720].
Lundin A. [Chronic fatigue syndrome is not medically explained. Biomedical explanation is confusing for the patient]. [Swedish]. Lakartidningen. 1999;96:4350-52. Exclude: not suitable for any question.
Lutgendorf SK, Antoni MH, Ironson G, et al. Physical symptoms of chronic fatigue syndrome are exacerbated by the stress of Hurricane Andrew. Psychosom Med. 1995;57:310-23. Exclude: < 1 year. [pmid: 7480560].
Lyles V. Chronic fatigue syndrome. Physiotherapy. 1998;84:460-1. Exclude: not suitable for any question.
Lyles V. Chronic fatigue syndrome - diagnostic dilemma. Physiotherapy. 1999;85:237-9. Exclude: not suitable for any question.
Lynch S, Fraser J. Fluoxetine and graded exercise in chronic fatigue syndrome. Br J Psychiatry. 1998;173. Exclude: not suitable for any question.
Lynch S, Main J, Seth R. Definition of chronic fatigue syndrome (CFS). Br J Psychiatry. 1991;159:439-40. Exclude: not suitable for any question. [pmid: 1819258].
Lynch S, Montgomery S, Seth R. Chronic fatigue syndrome. Br J Gen Pract. 1992;42:39-40. Exclude: not suitable for any question.
Lynch S, Seth R. Fluoxetine and chronic fatigue syndrome. Lancet. 1996;347. Exclude: not suitable for any question.
Lynch S, Seth R, Montgomery S. Antidepressant therapy in the chronic fatigue syndrome. Br J Gen Pract. 1991;41:339-42. Exclude: not suitable for any question. [pmid: 1822108]. [pmcid: 1371759].
Lynch SP, Seth RV, Main J. Monospot and VP1 tests in chronic fatigue syndrome and major depression. J R Soc Med. 1992;85:537-40. Exclude: not suitable for any question. [pmid: 1433120]. [pmcid: 1293640].
MacDonald KL, Osterholm MT, LeDell KH, et al. A case-control study to assess possible triggers and cofactors in chronic fatigue syndrome. Am J Med. 1996;100:548-54. Exclude: not suitable for any question. [pmid: 8644768].
MacHale SM, Cavanagh JT, Bennie J, Carroll S, Goodwin GM, Lawrie SM. Diurnal variation of adrenocortical activity in chronic fatigue syndrome. Neuropsychobiology. 1998;38:213-7. Exclude: not suitable for any question. [pmid: 9813459].
Machale SM, Lawrie SM, Cavanagh JT, et al. Cerebral perfusion in chronic fatigue syndrome and depression. Br J Psychiatry. 2000;176:550-6. Exclude: not suitable for any question. [pmid: 10974961].
Macintyre A. Viral illness and chronic fatigue (syndrome). Lancet. 1995;346. Exclude: not suitable for any question.
Macintyre A, Hume MC. The chronic fatigue syndrome. Postgrad Med J. 1993;69. Exclude: not suitable for any question.
MacLean G, Wessely S. Professional and popular views of chronic fatigue syndrome. [Review]. BMJ. 1994;308:776-7. Exclude: not suitable for any question. [pmid: 8142836].
Magdic B, Ilic T, Jovankic O, Cedic V. [The chronic fatigue syndrome--a clinical entity or a complex of symptoms of various pathologic conditions]. [Serbo-Croatian (Cyrillic)]. Vojnosanit Pregl. 1999;56:167-71. Exclude: not suitable for any question. [pmid: 10437422].
Make B, Jones JF. Impairment of patients with chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:43-55. Exclude: not suitable for any question.
Makela EH. Understanding chronic fatigue syndrome. Am Pharm. 1994;NS34:45-54; 55-6. Exclude: not suitable for any question. [pmid: 8209832].
Makowska Z, Kluge G, Sprusinska E. The influence of occupational and non-occupational factors on chronic fatigue in women. Pol J Occup Med Environ Health. 1992;5:323-33. Exclude: not suitable for any question. [pmid: 1298481].
Malt UF. [Exhausted by life--or mysteriously ill?]. [Norwegian]. Tidsskr Nor Laegeforen. 1995;115. Exclude: not suitable for any question.
Mandell J. Response to Dr. Massey's “Neurasthenia, psychasthenia, CFS, and related matters”. Conn Med. 1997;61:54-5. Exclude: not suitable for any question.
Manian FA. Simultaneous measurement of antibodies to Epstein-Barr virus, human herpesvirus 6, herpes simplex virus types 1 and 2, and 14 enteroviruses in chronic fatigue syndrome: is there evidence of activation of a nonspecific polyclonal immune response?. Clin Infect Dis. 1994;19:448-53. Exclude: not suitable for any question. [pmid: 7811864].
Mann AH, Mc Donald E, Cope H, Pelosi A, David A. [Epidemiologic study of chronic fatigue in primary care (general practice)]. [French]. Encephale. 1994;20:575-9. Exclude: not suitable for any question. [pmid: 7843054].
Mant D. Chronic fatigue syndrome. Lancet. 1994;344:834-5. Exclude: not suitable for any question. [pmid: 7916395].
Mantysaari M. Aerobic work capacity in chronic fatigue syndrome. BMJ. 1991;302. Exclude: not suitable for any question.
Manu P. Chronic fatigue syndrome: the fundamentals still apply. Am J Med. 2000;108:172-3. Exclude: not suitable for any question. [pmid: 11126312].
Manu P, Affleck G, Tennen H, Morse P. Hypochondriasis influences quality-of-life outcomes in patients with chronic fatigue. Psychother Psychosom. 1996;65:76-81. Exclude: not suitable for any question. [pmid: 8711085].
Manu P, Lane TJ, Matthews DA. Chronic fatigue and chronic fatigue syndrome: clinical epidemiology and aetiological classification. Ciba Found Symp. 1993;173:23-31; discussion 31-42, 1993. Exclude: not suitable for any question. [pmid: 8491100].
Manu P, Lane TJ, Matthews DA. Chronic fatigue syndromes in clinical practice. [Review]. Psychother Psychosom. 1992;58:60-8. Exclude: not suitable for any question. [pmid: 1484921].
Manu P, Lane TJ, Matthews DA. The frequency of the chronic fatigue syndrome in patients with symptoms of persistent fatigue [published erratum appears in Ann Intern Med 1988; 109:997]. Ann Intern Med. 1988;109:554-6. Include. [pmid: 3421564].
Manu P, Lane TJ, Matthews DA. The pathophysiology of chronic fatigue syndrome: confirmations, contradictions, and conjectures. Int J Psychiatry Med. 1992;22:397-408. Exclude: not suitable for any question. [pmid: 1338059].
Manu P, Lane TJ, Matthews DA. Somatization disorder in patients with chronic fatigue. Psychosomatics. 1989;30:388-95. Exclude: not suitable for any question. [pmid: 2798731].
Manu P, Lane TJ, Matthews DA, Castriotta RJ, Watson RK, Abeles M. Alpha-delta sleep in patients with a chief complaint of chronic fatigue. South Med J. 1994;87:465-70. Exclude: not suitable for any question. [pmid: 8153772].
Manu P, Lane TJ, Matthews D.A, Escobar J.I. Screening for somatization disorder in patients with chronic fatigue [published erratum appears in Gen Hosp Psychiatry 1990 Jan; 12(1):69]. Gen Hosp Psychiatry. 1989;11:294-7. Exclude: not suitable for any question. [pmid: 2663639].
Manu P, Matthews DA, Lane TJ. Food intolerance in patients with chronic fatigue. Int J Eat Disord. 1993;13:203-9. Exclude: not suitable for any question. [pmid: 8477289].
Manu P, Matthews DA, Lane TJ. Panic disorder among patients with chronic fatigue. South Med J. 1991;84:451-6. Exclude: not suitable for any question. [pmid: 2014428].
Manu P, Matthews DA, Lane TJ, Tennen H. Depression among patients with a chief complaint of chronic fatigue. J Affect Disord. 1989;17:165-72. Exclude: not suitable for any question. [pmid: 2527892].
Manu P, Lane TJ, Matthews DA. Idiopathic chronic fatigue: depressive symptoms and functional somatic complaints.. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.36-47. Exclude: not suitable for any question.
Manuel y Keenoy B, Moorkens G, Vertommen J, Noe M, Neve J, De Leeuw I. Magnesium status and parameters of the oxidant-antioxidant balance in patients with chronic fatigue: effects of supplementation with magnesium. J Am Coll Nutr. 2000;19:374-82. Exclude: not suitable for any question. [pmid: 10872900].
Marcel B, Komaroff AL, Fagioli LR, Kornish RJ 2nd, Albert MS. Cognitive deficits in patients with chronic fatigue syndrome. Biol Psychiatry. 1996;40:535-41. Exclude: not suitable for any question. [pmid: 8879474].
Marcovitch H. Managing chronic fatigue syndrome in children. BMJ. 1997;314:1635-6. Exclude: not suitable for any question. [pmid: 9193280].
Marcusson JA, Lindh G, Evengard B. Chronic fatigue syndrome and nickel allergy. Contact Dermatitis. 1999;40:269-72. Exclude: not suitable for any question. [pmid: 10344482].
Margolis J. Thoughts on definitions of disease. J Med Philos. 1986;11:233-6. Exclude: not suitable for any question. [pmid: 3794556].
Marlin RG, Anchel H, Gibson JC, Goldberg WM, Swinton M. An evaluation of multidisciplinary intervention for chronic fatigue syndrome with long-term follow-up, and a comparison with untreated controls. Am J Med. 1998;105:110S-4S. Include. [pmid: 9790492].
Maros KA. Portrait of a plague. Med J Aust. 1991;155. Exclude: not suitable for any question.
Marshall GS. Report of a workshop on the epidemiology, natural history, and pathogenesis of chronic fatigue syndrome in adolescents. [Review]. J Pediatr. 1999;134:395-405. Exclude: not suitable for any question. [pmid: 10190912].
Marshall GS, Gesser RM, Yamanishi K, Starr SE. Chronic fatigue in children: clinical features, Epstein-Barr virus and human herpesvirus 6 serology and long term follow-up. Pediatr Infect Dis J. 1991;10:287-90. Exclude: not suitable for any question. [pmid: 1648198].
Marshall PS, Forstot M, Callies A, Peterson PK, Schenck CH. Cognitive slowing and working memory difficulties in chronic fatigue syndrome. Psychosom Med. 1997;59:58-66. Exclude: not suitable for any question. [pmid: 9021867].
Marshall PS, Watson D, Steinberg P, et al. An assessment of cognitive function and mood in chronic fatigue syndrome. Biol Psychiatry. 1996;39:199-206. Exclude: not suitable for any question. [pmid: 8837981].
Martin-Du-Pan R. [Chronic fatigue syndrome, fibromyalgia and depression]. [Review] [French]. Rev Med Suisse Romande. 1990;110:923-8. Exclude: not suitable for any question. [pmid: 2244106].
Martin RWY, Ogston SA, Evans JR. Effects of vitamin and mineral supplementation on symptoms associated with chronic fatigue syndrome with Coxsackie B antibodies. J Nutr Med. 1994;4:11-23. Include.
Martin WJ. Cellular sequences in stealth viruses. Pathobiology. 1998;66:53-8. Exclude: not suitable for any question. [pmid: 9645627].
Martin WJ. Chronic fatigue syndrome. Science. 1992;255. Exclude: not suitable for any question.
Martin WJ. Detection of RNA sequences in cultures of a stealth virus isolated from the cerebrospinal fluid of a health care worker with chronic fatigue syndrome. Case report. Pathobiology. 1997;65:57-60. Exclude: not suitable for any question. [pmid: 9200191].
Martin WJ. Severe stealth virus encephalopathy following chronic-fatigue-syndrome-like illness: clinical and histopathological features. Pathobiology. 1996;64:1-8. Exclude: not suitable for any question. [pmid: 8856789].
Martin WJ, Glass RT. Acute encephalopathy induced in cats with a stealth virus isolated from a patient with chronic fatigue syndrome. Pathobiology. 1995;63:115-8. Exclude: not suitable for any question. [pmid: 8821627].
Martin WJ, Palca J. Chronic fatigue syndrome. Science. 1992;255. Exclude: not suitable for any question.
Martin WJ, Zeng LC, Ahmed K, Roy M. Cytomegalovirus-related sequence in an atypical cytopathic virus repeatedly isolated from a patient with chronic fatigue syndrome. Am J Pathol. 1994;145:440-51. Exclude: not suitable for any question. [pmid: 8053501]. [pmcid: 1887390].
Masquin A, Dumas R, Jallade S. [Clinical trial with a new antidepressive and anti-asthenia drug; Mefexamide]. [French]. J Med Lyon. 1967;48:617-27. Exclude: not suitable for any question. [pmid: 5619329].
Massey RU. Neurasthenia, psychasthenia, CFS, and related matters. Conn Med. 1996;60:627-8. Exclude: not suitable for any question. [pmid: 8952137].
Massin MM, Leroy P. A 9-year-old girl with chronic fatigue. Diagnosis: neurally mediated hypotension. Eur J Pediatr. 1999;158:761-2. Exclude: not suitable for any question. [pmid: 10485312].
Masuda A, Nozoe S, Tanaka H. Psycho-behavioral responses and cellular immune function of adults, without any organic disorders, with chronic fatigue. Jpn J Psychosom Med. 1993;33:301-8. Exclude: not suitable for any question.
Masuda A, Nozoe SI, Matsuyama T, Tanaka H. Psychobehavioral and immunological characteristics of adult people with chronic fatigue and patients with chronic fatigue syndrome. Psychosom Med. 1994;56:512-8. Exclude: not suitable for any question. [pmid: 7871106].
Masuda A, Nozoe SI, Tanaka H, Koga Y, Hatsutanmaru M. The diagnosis and treatment of chronic fatigue syndrome from the viewpoint of psychosomatic medicine: Two case reports. Jpn J Psychosom Med. 1998;38:55-63. Exclude: not suitable for any question.
Matsuda J. [Chronic fatigue syndrome: fictious or true disease?]. [Review] [Japanese]. Ryumachi. 1994;34:921-8. Exclude: not suitable for any question. [pmid: 7801207].
Matsuda J, Gohchi K. [Chronic fatigue syndrome]. [Review] [Japanese]. Ryoikibetsu Shokogun Shirizu. 1999:161-5. Exclude: not suitable for any question.
Matsuda J, Gohchi K. [Overview of our patients with chronic fatigue syndrome (CFS) from the pathoetiological aspects]. [Japanese]. Nippon Rinsho. 1992;50:2635-40. Exclude: not suitable for any question. [pmid: 1287240].
Matsuda J, Gohchi K, Gotoh N. Serum concentrations of 2',5'-oligoadenylate synthetase, neopterin, and beta-glucan in patients with chronic fatigue syndrome and in patients with major depression. J Neurol Neurosurg Psychiatry. 1994;57:1015-6. Exclude: not suitable for any question.
Matsumoto Y, Ninomiya S. [Allergy among Japanese patients with chronic fatigue syndrome]. [Japanese]. Arerugi. 1992;41:1722-5. Exclude: not suitable for any question. [pmid: 1290417].
Matsuno T, Hikita K, Matsuo T. [Chronic fatigue syndrome and psychiatric diseases]. [Review] [Japanese]. Nippon Rinsho. 1994;52:1339-44. Exclude: not suitable for any question. [pmid: 8007411].
Matthews DA, Lane TJ, Manu P. Antibodies to Epstein-Barr virus in patients with chronic fatigue. [Review]. South Med J. 1991;84:832-40. Exclude: not suitable for any question. [pmid: 1648795].
Matthews DA, Lane TJ, Manu P. Definition of the chronic fatigue syndrome. Ann Intern Med. 1988;109:511-2. Exclude: not suitable for any question. [pmid: 3415111].
Mawle AC, Nisenbaum R, Dobbins JG, et al. Immune responses associated with chronic fatigue syndrome: a case-control study. J Infect Dis. 1997;175:136-41. Exclude: not suitable for any question. [pmid: 8985207].
Mawle AC, Nisenbaum R, Dobbins JG, et al. Seroepidemiology of chronic fatigue syndrome: a case-control study. Clin Infect Dis. 1995;21:1386-9. Exclude: not suitable for any question. [pmid: 8749620].
Mawle AC, Reyes M, Schmid DS. Is chronic fatigue syndrome an infectious disease? [Review]. Infect Agents Dis. 1993;2:333-41. Exclude: not suitable for any question. [pmid: 8173816].
Mayou R. Chronic fatigue syndrome. Lancet. 1996;348:1384-5. Exclude: not suitable for any question. [pmid: 8918297].
McArdle A, McArdle F, Jackson MJ, Page SF, Fahal I, Edwards RH. Investigation by polymerase chain reaction of enteroviral infection in patients with chronic fatigue syndrome. Clin Sci. 1996;90:295-300. Exclude: not suitable for any question. [pmid: 8777836].
McBride SJ, McCluskey DR. Treatment of chronic fatigue syndrome. [Review]. Br Med Bull. 1991;47:895-907. Exclude: not suitable for any question. [pmid: 1794089].
McCluskey DR. Chronic fatigue syndrome: Its cause and a strategy for management. [Review]. Compr Ther. 1998;24:357-63. Exclude: not suitable for any question. [pmid: 9740980].
McCully KK, Natelson BH. Impaired oxygen delivery to muscle in chronic fatigue syndrome. Clin Sci. 1999;97:603-8; discussion 611-3. Exclude: not suitable for any question. [pmid: 10545311].
McCully KK, Natelson BH, Iotti S, Sisto S, Leigh JS Jr. Reduced oxidative muscle metabolism in chronic fatigue syndrome. Muscle Nerve. 1996;19:621-5. Exclude: not suitable for any question. [pmid: 8618560].
McCully KK, Sisto SA, Natelson BH. Use of exercise for treatment of chronic fatigue syndrome. [Review]. Sports Med. 1996;21:35-48. Exclude: not suitable for any question. [pmid: 8771284].
McDonald E, Cope H, David A. Cognitive impairment in patients with chronic fatigue: a preliminary study [published erratum appears in J Neurol Neurosurg Psychiatry 1993 Oct; 56(10):1142]. J Neurol Neurosurg Psychiatry. 1993;56:812-5. Exclude: not suitable for any question. [pmid: 8331359].
McDonald E, David AS, Pelosi AJ, Mann AH. Chronic fatigue in primary care attenders. Psychol Med. 1993;23:987-98. Include. [pmid: 8134522].
McEvedy CP, Beard AW. A controlled follow-up of cases involved in an epidemic of ‘benign myalgic encephalomyelitis’. Br J Psychiatry. 1973;122:141-50. Exclude: not suitable for any question. [pmid: 4714828].
McGarry F, Gow J, Behan PO. Enterovirus in the chronic fatigue syndrome. Ann Intern Med. 1994;120:972-3. Exclude: not suitable for any question. [pmid: 8172448].
McGregor NR, Dunstan RH, Butt HL, Roberts TK, Klineberg IJ, Zerbes M. A preliminary assessment of the association of SCL-90-R psychological inventory responses with changes in urinary metabolites in patients with chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:17-37. Exclude: not suitable for any question.
McGregor NR, Dunstan RH, Zerbes M, Butt HL, Roberts TK, Klineberg IJ. Preliminary determination of a molecular basis of chronic fatigue syndrome. Biochem Mol Med. 1996;57:73-80. Exclude: not suitable for any question. [pmid: 8733884].
McGregor NR, Dunstan RH, Zerbes M, Butt HL, Roberts TK, Klineberg IJ. Preliminary determination of the association between symptom expression and urinary metabolites in subjects with chronic fatigue syndrome. Biochem Mol Med. 1996;58:85-92. Exclude: not suitable for any question. [pmid: 8809350].
McKenzie R, O'Fallon A, Dale J, et al. Low-dose hydrocortisone for treatment of chronic fatigue syndrome: a randomized controlled trial. JAMA. 1998;280:1061-6. Include. [pmid: 9757853].
McKenzie R, Reynolds JC, O'Fallon A, et al. Decreased bone mineral density during low dose glucocorticoid administration in a randomized, placebo controlled trial. J Rheumatol. 2000;27:2222-6. Include. [pmid: 10990237].
McKibbon A, Eady A, Marks S. PDQ: evidence-based principles and practice. Hamilton. Ont.;St. Louis. C. Decker; 1999.
McKusick VA. On the naming of clinical disorders, with particular reference to eponyms. Medicine (Baltimore). 1998;77:1-2. Exclude: not suitable for any question. [pmcid: 126225]. [pmid: 9465859].
McLaren Howard J, Davies S, Hunnisett A. Magnesium and chronic fatigue syndrome. Lancet. 1992;340. Exclude: not suitable for any question.
McLaughlin B. Virology laboratory diagnosis of chronic fatigue syndrome. Can Dis Wkly Rep. 1991;17:51-5. Exclude: not suitable for any question. [pmid: 1669355].
McSherry J. Chronic fatigue syndrome. A fresh look at an old problem. [Review]. Can Fam Physician. 1993;39:336-40. Exclude: not suitable for any question. [pmid: 8495124].
Meggs WJ. Gulf War Syndrome, chronic fatigue syndrome, and the multiple chemical sensitivity syndrome: stirring the cauldron of confusion. Arch Environ Health. 1999;54:309-11. Exclude: not suitable for any question. [pmid: 10501144].
Mehta VK, Blume GB. A randomized trial of fluoxetine in a patient with persistent fatigue. J Am Board Fam Pract. 1995;8:230-2. Exclude: not suitable for any question. [pmid: 7618502].
Mellergard M. [Only extremely tired?] [Danish]. Ugeskr Laeger. 1997;159. Exclude: not suitable for any question.
Menezes J, Ablashi DV. Avenues for research in chronic fatigue syndrome etiology. Can Dis Wkly Rep. 1991;17:65-6. Exclude: not suitable for any question. [pmid: 1669358].
Merikangas K, Angst J. Neurasthenia in a longitudinal cohort study of young adults. Psychol Med. 1994;24:1013-24. Exclude: not suitable for any question. [pmid: 7892346].
Mertz TL. Immune and neuropsychological correlates of chronic fatigue syndrome. Diss Abstr Int B: Sci Engineeer. 1997;57. Exclude: not suitable for any question.
Merz S. [Treatment of chronic fatigue syndrome]. [Swedish]. Lakartidningen. 1999;96. Exclude: not suitable for any question.
Mesch U, Lowenthal RM, Coleman D. Lead poisoning masquerading as chronic fatigue syndrome. Lancet. 1996;347. Exclude: not suitable for any question.
Meyers D. Psychosocial factors and somatisation in chronic fatigue and allied disorders. Med J Aust. 1994;160:806-7. Exclude: not suitable for any question. [pmid: 7993418].
Michael A. Treating chronic fatigue with exercise. Exercise improves mood and sleep. BMJ. 1998;317. Exclude: not suitable for any question.
Michiels V, Cluydts R, Fischler B. Attention and verbal learning in patients with chronic fatigue syndrome. J Int Neuropsychol Soc. 1998;4:456-66. Exclude: not suitable for any question. [pmid: 9745235].
Michiels V, Cluydts R, Fischler B, Hoffmann G, Le Bon O, De MeirleirK. Cognitive functioning in patients with chronic fatigue syndrome. J Clin Exp Neuropsychol. 1996;18:666-77. Exclude: not suitable for any question. [pmid: 8941852].
Michiels V, de Gucht V, Cluydts R, Fischler B. Attention and information processing efficiency in patients with chronic fatigue syndrome. J Clin Exp Neuropsychol. 1999;21:709-29. Exclude: not suitable for any question. [pmid: 10572289].
Middleton D, Savage DA, Smith DG. No association of HLA class II antigens in chronic fatigue syndrome. Dis Markers. 1991;9:47-9. Exclude: not suitable for any question. [pmid: 1683826].
Mildon CA. Clinical observations of chronic fatigue syndrome. Can Dis Wkly Rep. 1991;17:17-9. Exclude: not suitable for any question. [pmid: 1669348].
Miller NA, Carmichael HA, Calder BD, et al. Antibody to Coxsackie B virus in diagnosing postviral fatigue syndrome. BMJ. 1991;302:140-3. Exclude: not suitable for any question. [pmid: 1847316]. [pmcid: 1668819].
Miller TW, Jay LL, Miller J, Martin W. Chronic fatigue syndrome: etiology and treatment. Todays Ther Trends. 1993;11:27-34. Exclude: not suitable for any question.
Miller WL. The experience of nine women living with chronic fatigue syndrome, as demonstrated through mental imagery, drawings, and verbal descriptions. Diss Abstr Int. 1992;53. Exclude: not suitable for any question.
Millon C, Salvato F, Blaney N, Morgan R. A psychological assessment of chronic fatigue syndrome/chronic epstein-barr virus patients. Psychol Health. 1989;3:131-41. Include.
Milton JD, Clements GB, Edwards RH. Immune responsiveness in chronic fatigue syndrome. Postgrad Med J. 1991;67:532-7. Exclude: not suitable for any question. [pmid: 1656416].
Milton JD, Morris AG, Christmas SE, Edwards RHT. Interferon production by mononuclear cells from patients with chronic fatigue syndrome. Med Sci Res. 1991;19:205-6. Exclude: not suitable for any question.
Minors DS, Pirmohammed J, Williams G, Edwards R. Circadian rhythms of activity and rectal temperature at home and in a hospital: effects of lifestyle. Chronobiol Int. 1995;12:199-205. Exclude: physiologic/n<20.
Minowa M, Jiamo M. Descriptive epidemiology of chronic fatigue syndrome based on a nationwide survey in Japan. J Epidemiol. 1996;6:75-80. Exclude: not suitable for any question. [pmid: 8795946].
Miro O, Font C, Fernandez-Sola J, et al. [Chronic fatigue syndrome: study of the clinical course of 28 cases. [Review] [38 [Spanish]. Med Clin (Barc). 1997;108:561-5. Exclude: not suitable for any question. [pmcid: 263984]. [pmid: 9395421].
Moldofsky H. Fibromyalgia, sleep disorder and chronic fatigue syndrome. [Review]. Ciba Found Symp. 1993;173:262-71. Exclude: not suitable for any question. [pmid: 8491102].
Moldofsky H. Nonrestorative sleep and symptoms after a febrile illness in patients with fibrositis and chronic fatigue syndromes. [Review]. J Rheumatol Suppl. 1989;19:150-3. Exclude: not suitable for any question. [pmid: 2691676].
Moldofsky H. Sleep, neuroimmune and neuroendocrine functions in fibromyalgia and chronic fatigue syndrome. [Review]. Adv Neuroimmunol. 1995;5:39-56. Exclude: not suitable for any question. [pmid: 7795892].
Moldofsky H. Nonrestorative sleep, musculoskeletal pain, fatigue, and psychological distress in chronic fatigue syndrome, fibromyalgia, irritable bowel syndrome, temporal mandibular joint dysfunction disorders. In: Yehuda S, Mostofsky DI, editors. Chronic fatigue syndrome. New York: Plenum Press. 1997:p.95-117. Exclude: not suitable for any question.
Montague TJ, Marrie TJ, Klassen GA, Bewick DJ, Horacek BM. Cardiac function at rest and with exercise in the chronic fatigue syndrome. Chest. 1989;95:779-84. Exclude: not suitable for any question. [pmid: 2924607].
Moorkens G, Berwaerts J, Wynants H, Abs R. Characterization of pituitary function with emphasis on GH secretion in the chronic fatigue syndrome. Clin Endocrinol (Oxf). 2000;53:99-106. Exclude: not suitable for any question. [pmcid: 298219]. [pmid: 10931086].
Moorkens G, Manuel Y, Keenoy B, et al. Magnesium deficit in a sample of the Belgian population presenting with chronic fatigue. Magnes Res. 1997;10:329-37. Exclude: not suitable for any question. [pmid: 9513929].
Moorkens G, Wynants H, Abs R. Effect of growth hormone treatment in patients with chronic fatigue syndrome: a preliminary study. Growth Horm IGF Res. 1998;8:131-3. Include. [pmid: 10990148].
Morehouse RL, Flanigan M, MacDonald DD, Braha D, Shapiro C. Depression and short REM latency in subjects with chronic fatigue syndrome. Psychosom Med. 1998;60:347-51. Exclude: not suitable for any question. [pmid: 9625223].
Morris DH, Stare FJ. Unproven diet therapies in the treatment of the chronic fatigue syndrome. [Review]. Arch Fam Med. 1993;2:181-6. Exclude: not suitable for any question. [pmid: 8275187].
Morrison LJ, Behan WH, Behan PO. Changes in natural killer cell phenotype in patients with post-viral fatigue syndrome. Clin Exp Immunol. 1991;83:441-6. Exclude: not suitable for any question. [pmid: 1706238]. [pmcid: 1535328].
Morriss R. Insomnia in the chronic fatigue syndrome. BMJ. 1993;307. Exclude: not suitable for any question.
Morriss R, Sharpe M, Sharpley AL, Cowen PJ, Hawton K, Morris J. Abnormalities of sleep in patients with the chronic fatigue syndrome. BMJ. 1993;306:1161-4. Exclude: not suitable for any question. [pmid: 8499816]. [pmcid: 1677618].
Morriss RK, Ahmed M, Wearden AJ, et al. The role of depression in pain, psychophysiological syndromes and medically unexplained symptoms associated with chronic fatigue syndrome. J Affect Disord. 1999;55:143-8. Include. [pmid: 10628883].
Morriss RK, Wearden AJ. Screening instruments for psychiatric morbidity in chronic fatigue syndrome. J R Soc Med. 1998;91:365-8. Exclude: not suitable for any question. [pmid: 9771495]. [pmcid: 1296809].
Morriss RK, Wearden AJ, Battersby L. The relation of sleep difficulties to fatigue, mood and disability in chronic fatigue syndrome. J Psychosom Res. 1997;42:597-605. Exclude: not suitable for any question. [pmid: 9226607].
Morriss RK, Wearden AJ, Mullis R. Exploring the validity of the Chalder Fatigue scale in chronic fatigue syndrome. J Psychosom Res. 1998;45:411-7. Exclude: not suitable for any question. [pmid: 9835234].
Moss-Morris R, Petrie KJ, Large RG, Kydd RR. Neuropsychological deficits in chronic fatigue syndrome: artifact or reality?. J Neurol Neurosurg Psychiatry. 1996;60:474-7. Exclude: not suitable for any question. [pmid: 8778249].
Moss-Morris R, Petrie KJ, Weinman J. Functioning in chronic fatigue syndrome: do illness perceptions play a regulatory role?. Br J Health Psychol. 1996;1:15-25. Exclude: not suitable for any question.
Moss-Morris R, Petrie KJ. The role of illness cognitions and coping in the aetiology and maintenance of chronic fatigue sundrome (CFS). In: Weinman JA, editor. Perceptions of health and illness: current research and applications. Singapore: Harwood Academic Publishers. 1997:p.411-39. Exclude: not suitable for any question.
Moss RB, Mercandetti A, Vojdani A. TNF-alpha and chronic fatigue syndrome. J Clin Immunol. 1999;19:314-6. Exclude: not suitable for any question. [pmid: 10535608].
Moyer HL Jr. “Chronic fatigue syndrome and women: can therapy help?”. Soc Work. 1992;37. Exclude: not suitable for any question.
Moyer RKT. Treatment of Chronic Fatigue Syndrome through Kinesiotherapy. Clin Kinesiol. 1998;52:18-22. Exclude: not suitable for any question.
Mulube M. Myths dispelled about chronic fatigue syndrome. BMJ. 1996;313. Exclude: not suitable for any question.
Munakata T. The socio-cultural significance of the diagnostic label “neurasthenia” in Japan's mental health care system. Cult Med Psychiatry. 1989;13:203-13. Exclude: not suitable for any question. [pmid: 2766794].
Munitz H, Hermesh H. [Chronic fatigue syndrome, clinical significance]. [Hebrew]. Harefuah. 1991;120:164-5. Exclude: not suitable for any question. [pmid: 2032653].
Munson P. Criminal language and poetic jailbreak: writing chronic fatigue immune dysfunction syndrome. Lit Med. 2000;19:19-24. Exclude: not suitable for any question. [pmid: 10824310].
Murdoch JC. Cell-mediated immunity in patients with myalgic encephalomyelitis syndrome. N Z Med J. 1988;101:511-2. Exclude: not suitable for any question. [pmid: 3261407].
Murdoch JC. Chronic fatigue syndrome. N Z Med J. 1995;108. Exclude: not suitable for any question.
Murdoch JC. Chronic fatigue syndrome. A review from the general practice perspective. Aust Fam Physician. 1992;21:1205-6. Exclude: not suitable for any question. [pmid: 1530505].
Murray JB. Psychological aspects of chronic fatigue syndrome. [Review]. Percept Mot Skills. 1992;74:1123-36. Exclude: not suitable for any question. [pmid: 1501980].
Murray RS. Myth of the chronic fatigue syndrome. West J Med. 1991;155. Exclude: not suitable for any question.
Murtagh J. Patient education. Chronic fatigue syndrome. Aust Fam Physician. 1995;24. Exclude: not suitable for any question.
Myers C, Wilks D. Comparison of Euroqol EQ-5D and SF-36 in patients with chronic fatigue syndrome. Qual Life Res. 1999;8:9-16. Exclude: not suitable for any question. [pmid: 10457734].
Naik SR, Ghoshal UC. Low grade pyrexia: is chronic fatigue syndrome a safe and justified diagnosis?. J Assoc Physicians India. 1995;43:725-6. Exclude: not suitable for any question.
Nairn C, Galbraith DN, Clements GB. Comparison of coxsackie B neutralisation and enteroviral PCR in chronic fatigue patients. J Med Virol. 1995;46:310-3. Exclude: not suitable for any question. [pmid: 7595406].
Nakaya T, Kuratsune H, Kitani T, Ikuta K. [Demonstration on Borna disease virus in patients with chronic fatigue syndrome]. [Review][Japanese]. Nippon Rinsho. 1997;55:3064-71. Exclude: not suitable for any question. [pmid: 9396313].
Nakaya T, Takahashi H, Nakamura Y, et al. Demonstration of Borna disease virus RNA in peripheral blood mononuclear cells derived from Japanese patients with chronic fatigue syndrome. FEBS Lett. 1996;378:145-9. Exclude: not suitable for any question. [pmid: 8549821].
Nakaya T, Takahashi H, Nakamura Y, et al. Borna disease virus infection in two family clusters of patients with chronic fatigue syndrome. Microbiol Immunol. 1999;43:679-89. Exclude: not suitable for any question. [pmid: 10529109].
Nasralla M, Haier J, Nicolson GL. Multiple mycoplasmal infections detected in blood of patients with chronic fatigue syndrome and/or fibromyalgia syndrome. Eur J Clin Microbiol Infect Dis. 1999;18:859-65. Exclude: not suitable for any question. [pmid: 10691196].
Natelson BH, Cheu J, Hill N, et al. Single-blind, placebo phase-in trial of two escalating doses of selegiline in the chronic fatigue syndrome. Neuropsychobiology. 1998;37:150-4. Include. [pmid: 9597672].
Natelson BH, Cheu J, Pareja J, Ellis SP, Policastro T, Findley TW. Randomized, double blind, controlled placebo-phase in trial of low dose phenelzine in the chronic fatigue syndrome. Psychopharmacology. 1996;124:226-30. Include. [pmid: 8740043].
Natelson BH, Cohen JM, Brassloff I, Lee HJ. A controlled study of brain magnetic resonance imaging in patients with the chronic fatigue syndrome. J Neurol Sci. 1993;120:213-7. Exclude: not suitable for any question. [pmid: 8138812].
Natelson BH, Ellis SP, Braonain PJ, DeLuca J, Tapp WN. Frequency of deviant immunological test values in chronic fatigue syndrome patients. Clin Diagn Lab Immunol. 1995;2:238-40. Exclude: not suitable for any question. [pmcid: 170136]. [pmid: 7697537].
Natelson BH, Johnson SK, DeLuca J, et al. Reducing heterogeneity in chronic fatigue syndrome: a comparison with depression and multiple sclerosis. Clin Infect Dis. 1995;21:1204-10. Exclude: not suitable for any question. [pmid: 8589144].
Natelson BH, LaManca JJ, Denny TN, et al. Immunologic parameters in chronic fatigue syndrome, major depression, and multiple sclerosis. Am J Med. 1998;105:43S-9S. Exclude: not suitable for any question. [pmid: 9790481].
Natelson BH, Ye N, Moul DE, et al. High titers of anti-Epstein-Barr virus DNA polymerase are found in patients with severe fatiguing illness. J Med Virol. 1994;42:42-6. Exclude: not suitable for any question. [pmid: 8308519].
Nawab SS, Miller CS, Dale JK, et al. Self-reported sensitivity to chemical exposures in five clinical populations and healthy controls. Psychiatry Res. 2000;95:67-74. Exclude: did not meet inclusion criteria. [pmid: 10904124].
Neerinckx E, Van Houdenhove B, Onghena P, Lysens R, Vertommen H, Desmet N. Medicosocial aspects of chronic fatigue syndrome and fibromyalgia. Tijdschrift Voor Geneeskunde. 1997;53:1676-80. Exclude: not suitable for any question.
Nelson E, Kirk J, McHugo G, et al. Chief complaint fatigue: a longitudinal study from the patient's perspective. Fam Pract Res J. 1987;6:175-88. Exclude: not suitable for any question. [pmid: 3455125].
Neri G, Bianchedi M, Croce A, Moretti A. [“Prolonged” decay test and auditory brainstem responses in the clinical diagnosis of the chronic fatigue syndrome]. [Italian]. Acta Otorhinolaryngol Ital. 1996;16:317-23. Exclude: not suitable for any question. [pmid: 9082825].
Neutra RR. Some preliminary thoughts on the potential contribution of epidemiology to the question of multiple chemical sensitivity. Public Health Rev. 1994;22:271-8. Exclude: not suitable for any question. [pmid: 7708939].
Nicolson GL, Bruton DM Jr, Nicolson NL. Chronic fatigue illness and Operation Desert Storm. J Occup Environ Med. 1996;38:14-6. Exclude: not suitable for any question. [pmid: 8871324].
Nimnuan C, Hotopf M, Wessely S. Medically unexplained symptoms: how often and why are they missed?. QJM. 2000;93:21-8. Exclude: not suitable for any question. [pmid: 10623778].
Nisenbaum R, Barrett DH, Reyes M, Reeves WC. Deployment stressors and a chronic multisymptom illness among Gulf War veterans. J Nerv Ment Dis. 2000;188:259-66. Exclude: not suitable for any question. [pmid: 10830562].
Nisenbaum R, Jones A, Jones J, Reeves W. Longitudinal analysis of symptoms reported by patients with chronic fatigue syndrome. Ann Epidemiol. 2000;10. Include.
Nisenbaum R, Reyes M, Mawle AC, Reeves WC. Factor analysis of unexplained severe fatigue and interrelated symptoms: overlap with criteria for chronic fatigue syndrome. Am J Epidemiol. 1998;148:72-7. Exclude: not suitable for any question. [pmid: 9663406].
Nishikai M. [Chronic fatigue syndrome--study of 51 cases treated at the Second Tokyo National Hospital]. [Japanese]. Nippon Rinsho. 1992;50:2641-7. Exclude: not suitable for any question. [pmid: 1337560].
Nishikai M, Akiya K, Tojo T, Onoda N, Tani M, Shimizu K. ‘Seronegative’ Sjogren's syndrome manifested as a subset of chronic fatigue syndrome. Br J Rheumatol. 1996;35:471-4. Exclude: not suitable for any question. [pmid: 8646439].
Nishikai M, Kosaka S. Incidence of antinuclear antibodies in Japanese patients with chronic fatigue syndrome. Arthritis Rheum. 1997;40:2095-7. Exclude: not suitable for any question.
Nix WA. [Chronic fatigue syndrome--a new disease picture?]. [Review] [German]. Nervenarzt. 1990;61:390-6. Exclude: not suitable for any question. [pmid: 2202912].
Nix WA. [The chronic fatigue syndrome: disease of the muscle or mind?].[German]. Aktuelle Neurol. 1991;18:185-7. Exclude: not suitable for any question.
Nix WA, Egle UT. [The chronic fatigue syndrome].[German]. Aktuelle Neurol. 1998;25:6-12. Exclude: not suitable for any question.
Nixon PG. Brainstem hypoperfusion in CFS. QJM. 1996;89:163-4. Exclude: not suitable for any question. [pmid: 8729560].
Nixon PG. Brainstem perfusion in CFS. QJM. 1996;89. Exclude: not suitable for any question.
Nixon PG. Chronic fatigue syndrome in Army general practice. J R Army Med Corps. 1995;141:112-3. Exclude: not suitable for any question. [pmid: 7562737].
Nixon PG. Hyperventilation and chronic fatigue syndrome. [published erratum appears in QJM 1995 Apr;88(4):299]. QJM. 1995;88:73-4. Exclude: not suitable for any question. [pmid: 7894992].
Norberg B. [Methylcobalamin and chronic fatigue]. [Swedish]. Lakartidningen. 1999;96. Exclude: not suitable for any question.
Norlin K. [A not especially informative article about chronic fatigue]. [Swedish]. Lakartidningen. 1994;91. Exclude: not suitable for any question.
Norregaard J, Bulow PM, Prescott E, Jacobsen S, Danneskiold-Samsoe B. A four-year follow-up study in fibromyalgia. Relationship to chronic fatigue syndrome. Scand J Rheumatol. 1993;22:35-8. Include. [pmid: 8434245].
Nowotny N, Kolodziejek J. Demonstration of borna disease virus nucleic acid in a patient with chronic fatigue syndrome. J Infect Dis. 2000;181:1860-2. Exclude: not suitable for any question. [pmid: 10823802].
Numerous contributors. Problem behaviors. In: Friedman SB, Fisher M, editors. Comprehensive adolescent health care. St Louis (MO). Quality Medical Publishing. 1992:p.733-811. Exclude: not suitable for any question.
Nutt D, Johnson FN. Potential applications of venlafaxine. Rev Contemp Pharmacother. 1998;9:321-31. Exclude: not suitable for any question.
Nystrom S, Lindegard B. Predisposition for mental syndromes: A study comparing predisposition for depression, neurasthenia and anxiety state. Acta Psychiatr Scand. 1975;51:69-76. Exclude: not suitable for any question. [pmid: 1119320].
O'Sullivan SJ. Alleged link between hepatitis B vaccine and chronic fatigue syndrome. CMAJ. 1992;147. Exclude: not suitable for any question.
Ogawa M, Nishiura T, Yoshimura M, et al. Decreased nitric oxide-mediated natural killer cell activation in chronic fatigue syndrome. Eur J Clin Invest. 1998;28:937-43. Exclude: not suitable for any question. [pmid: 9824439].
Ogawa R. [Chronic fatigue symptom]. [Japanese]. Kango. 1993;45:159-68. Exclude: not suitable for any question. [pmid: 8107415].
Ojo-Amaize EA, Conley EJ, Peter JB. Decreased natural killer cell activity is associated with severity of chronic fatigue immune dysfunction syndrome. Clin Infect Dis. 1994;18:S157-9. Exclude: not suitable for any question. [pmid: 8148445].
Okano M. [Viral infection and its causative role for chronic fatigue syndrome]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2617-24. Exclude: not suitable for any question. [pmid: 1337559].
Oughton RA. Chronic fatigue syndrome (CFS) in Army general practice. J R Army Med Corps. 1996;142. Exclude: not suitable for any question.
Packer TL, Foster DM, Brouwer B. Fatigue and activity patterns of people with chronic fatigue syndrome. Occup Ther J Res. 1997;17:186-99. Exclude: sample size.
Packer TL, Sauriol A, Brouwer B. Fatigue secondary to chronic illness: postpolio syndrome, chronic fatigue syndrome, and multiple sclerosis. Arch Phys Med Rehabil. 1994;75:1122-6. Exclude: not suitable for any question. [pmid: 7944918].
Pagani M, Lucini D. Chronic fatigue syndrome: a hypothesis focusing on the autonomic nervous system. [Review]. Clin Sci. 1999;96:117-25. Exclude: not suitable for any question. [pmid: 9857114].
Palca J. Does a retrovirus explain fatigue syndrome puzzle?. Science. 1990;249:1240-1. Exclude: not suitable for any question. [pmid: 2399461].
Palca J. On the track of an elusive disease. Science. 1991;254:1726-8. Exclude: not suitable for any question. [pmid: 1662410].
Pall ML. Elevated, sustained peroxynitrite levels as the cause of chronic fatigue syndrome. Med Hypotheses. 2000;54:115-25. Exclude: not suitable for any question. [pmid: 10790736].
Pamphlett R, O'Donoghue P. Antibodies against Sarcocystis and Toxoplasma in humans with the chronic fatigue syndrome. Aust N Z J Med. 1992;22:307-8. Exclude: not suitable for any question.
Pankow W, Feddersen CO, von Wichert P. [Differential therapy of chronic fatigue syndrome]. [Review] [German]. Internist. 1995;36:1156-61. Exclude: not suitable for any question. [pmid: 8567221].
Parras F, Salva F, Reina J, Gil J, Portela D, Alomar P. [Chronic fatigue syndrome associated with Epstein-Barr virus infection]. [Spanish]. Med Clin (Barc). 1989;92:619-22. Exclude: not suitable for any question. [pmcid: 263984]. [pmid: 2545980].
Patarca-Montero R. Chronic Fatigue Syndrome. J Chronic Fatigue Syndr. 1999;5. Exclude: not suitable for any question.
Patarca R, Klimas N, Sandler D, Garcia MN, Fletcher MA. Interindividual immune status variation patterns in patients with chronic fatigue syndrome: Association with gender and the tumor necrosis factor system. J Chronic Fatigue Syndr. 1996;2:13-40. Exclude: not suitable for any question.
Patarca R, Klimas NG, Lugtendorf S, Antoni M, Fletcher MA. Dysregulated expression of tumor necrosis factor in chronic fatigue syndrome: interrelations with cellular sources and patterns of soluble immune mediator expression. Clin Infect Dis. 1994;18:S147-53. Exclude: not suitable for any question. [pmid: 8148443].
Patarca R, Fletcher MA, Klimas NG. Immunological correlates of chronic fatigue syndrome. In: Goodnick PJ, Klimas NG, editors. Chronic fatigue and related immune deficiency syndromes. Washington: American Psychiatric Press. 1993:p.1-21.
Patnaik M, Komaroff AL, Conley E, Ojo-Amaize EA, Peter JB. Prevalence of IgM antibodies to human herpesvirus 6 early antigen (p41/38) in patients with chronic fatigue syndrome [published erratum appears in J Infect Dis 1995 Dec; 172(6):1643]. J Infect Dis. 1995;172:1364-7. Exclude: not suitable for any question. [pmid: 7594679].
Paulson E. Report of the working group on the possible relationship between hepatitis B vaccination and the chronic fatigue syndrome. CMAJ. 1993;149:314-6. Exclude: not suitable for any question. [pmid: 8339178]. [pmcid: 1485526].
Payne CB Jr, Sloan HE. Pulmonary function and the chronic fatigue syndrome. Ann Intern Med. 1989;111. Exclude: not suitable for any question.
Peakman M, Deale A, Field R, Mahalingam M, Wessely S. Clinical improvement in chronic fatigue syndrome is not associated with lymphocyte subsets of function or activation. Clin Immunol Immunopathol. 1997;82:83-91. Exclude: not suitable for any question. [pmid: 9000046].
Pearn J. Chronic ciguatera: one organic cause of the chronic fatigue syndrome. J Chronic Fatigue Syndr. 1996;2:29-34. Exclude: not suitable for any question.
Pearn JH. Chronic fatigue syndrome: chronic ciguatera poisoning as a differential diagnosis. Med J Aust. 1997;166:309-10. Exclude: not suitable for any question. [pmid: 9087189].
Pelcovitz D, Septimus A, Friedman SB, Krilov LR, Mandel F, Kaplan S. Psychosocial correlates of chronic fatigue syndrome in adolescent girls. J Dev Behav Pediatr. 1995;16:333-8. Exclude: not suitable for any question. [pmid: 8557833].
Pemberton S, Hatcher S, Stanley P, House A. Chronic fatigue syndrome: a way forward. Br J Occup Ther. 1994;57:381-3. Exclude: not suitable for any question.
Pepper CM, Krupp LB, Friedberg F, Doscher C, Coyle PK. A comparison of neuropsychiatric characteristics in chronic fatigue syndrome, multiple sclerosis, and major depression. J Neuropsychiatry Clin Neurosci. 1993;5:200-5. Exclude: not suitable for any question. [pmid: 8508039].
Perrin RN, Edwards J, Hartley P. An evaluation of the effectiveness of osteopathic treatment on symptoms associated with myalgic encephalomyelitis. A preliminary report. J Med Eng Technol. 1998;22:1-13. Include. [pmid: 9491353].
Perry LD. Chronic fatigue syndrome?. Pediatrics. 1999;104. Exclude: not suitable for any question.
Pesek JR, Jason LA, Taylor RR. An empirical investigation of the Envelope Theory. J Hum Behav Soc Environ. 2000;3:59-77. Exclude: not suitable for any question.
Peterson C, Millen N, Woodward R. Chronic fatigue syndrome: a problem of legitimation. Aust J Prim Health Interchange. 1999;5:65-79. Exclude: not suitable for any question.
Peterson PK. Intravenous IgG does not help in chronic fatigue syndrome. Ann Intern Med. 1991;114. Exclude: not suitable for any question.
Peterson PK, Pheley A, Schroeppel J, et al. A preliminary placebo-controlled crossover trial of fludrocortisone for chronic fatigue syndrome. Arch Intern Med. 1998;158:908-14. Include. [pmid: 9570178].
Peterson PK, Schenck C. Chronic fatigue syndrome as a “real” disease?. J Gen Intern Med. 1992;7:119-20. Exclude: not suitable for any question. [pmid: 1548537].
Peterson PK, Schenck CH, Sherman R. Chronic fatigue syndrome in Minnesota. Minn Med. 1991;74:21-6. Exclude: not suitable for any question.
Peterson PK, Shepard J, Macres M, et al. A controlled trial of intravenous immunoglobulin G in chronic fatigue syndrome. Am J Med. 1990;89:554-60. Include. [pmid: 2239975].
Peterson PK, Sirr SA, Grammith FC, et al. Effects of mild exercise on cytokines and cerebral blood flow in chronic fatigue syndrome patients. Clin Diagn Lab Immunol. 1994;1:222-6. Exclude: not suitable for any question. [pmcid: 368231]. [pmid: 7496949].
Petrie K, Moss-Morris R, Weinman J. The impact of catastrophic beliefs on functioning in chronic fatigue syndrome. J Psychosom Res. 1995;39:31-7. Exclude: <2 years. [pmid: 7760301].
Pheley AM, Melby D, Schenck C, Mandel J, Peterson PK. Can we predict recovery in chronic fatigue syndrome?. Minn Med. 1999;82:52-6. Exclude: not suitable for any question. [pmid: 10589213].
Phillips N. Chronic fatigue syndrome. Aust N Z J Psychiatry. 1992;26:329-30. Exclude: not suitable for any question. [pmid: 1642633].
Phillips N. The clinical and scientific basis of chronic fatigue syndrome: From myth towards management. Australas Psychiatry. 1998;6:186-7. Exclude: not suitable for any question.
Phillips NK. Psychosocial factors and somatisation in chronic fatigue and allied disorders. Med J Aust. 1994;161:455-6. Exclude: not suitable for any question. [pmid: 7935111].
Pieschl D, Angersbach P, Kolbe M, Toman M. [Double-blind collaborative study of centrophenoxine versus placebo in patients with neurasthenic syndromes].[German]. Nervenarzt. 1983;54:48-53. Exclude: not suitable for any question. [pmid: 6405290].
Pizzigallo E, Racciatti D, Vecchiet J. Clinical and pathophysiological aspects of chronic fatigue syndrome. J Musculoskeletal Pain. 1999;7:217-24. Exclude: not suitable for any question.
Pizzolato G, Cagnin A, Mancia D, et al. Randomised, double-blind, placebo-controlled study of pivagabine in neurasthenia. Arzneimittelforschung. 1997;47:1329-31. Exclude: not suitable for any question. [pmid: 9450159].
Plioplys AV. Antimuscle and anti-CNS circulating antibodies in chronic fatigue syndrome. Neurology. 1997;48:1717-9. Exclude: not suitable for any question. [pmid: 9191795].
Plioplys AV. Chronic fatigue syndrome?. Pediatrics. 1999;104:130-2. Exclude: not suitable for any question. [pmid: 10419399].
Plioplys AV. Chronic fatigue syndrome should not be diagnosed in children. Pediatrics. 1997;100:270-1. Exclude: not suitable for any question. [pmid: 9240812].
Plioplys AV, Plioplys S. Amantadine and L-carnitine treatment of chronic fatigue syndrome. Neuropsychobiology. 1997;35:16-23. Include. [pmid: 9018019].
Plioplys AV, Plioplys S. Electron-microscopic investigation of muscle mitochondria in chronic fatigue syndrome. Neuropsychobiology. 1995;32:175-81. Exclude: not suitable for any question. [pmid: 8587699].
Plioplys AV, Plioplys S. Serum levels of carnitine in chronic fatigue syndrome: clinical correlates. Neuropsychobiology. 1995;32:132-8. Exclude: not suitable for any question. [pmid: 8544970].
Plioplys AV, Plioplys S, Davis JS 4th. Meeting the frustrations of chronic fatigue syndrome. Hosp Pract (Off Ed). 1997;32:147-50, 153-6, 160-1. Exclude: not suitable for any question.
Plioplys S, Plioplys AV. Chronic fatigue syndrome (myalgic encephalopathy). [Review]. South Med J. 1995;88:993-1000. Exclude: not suitable for any question. [pmid: 7481975].
Pocinki AG. Fireworks over fibromyalgia, CFS, and IBS. Postgrad Med. 1997;102. Exclude: not suitable for any question.
Podell RN. Chronic fatigue syndrome: the fundamentals still apply. Am J Med. 2000;108. Exclude: not suitable for any question.
Polich J, Moore AP, Wiederhold MD. P300 assessment of chronic fatigue syndrome. J Clin Neurophysiol. 1995;12:186-91. Exclude: not suitable for any question. [pmid: 7797633].
Pollark RJ, Komaroff AL, Telford SR 3rd, et al. Borrelia burgdorferi infection is rarely found in patients with chronic fatigue syndrome. Clin Infect Dis. 1995;20:467-8. Exclude: not suitable for any question. [pmid: 7742458].
Pollet C, Natelson BH, Lange G, et al. Medical evaluation of Persian Gulf veterans with fatigue and/or chemical sensitivity. J Med. 1998;29:101-13. Exclude: not suitable for any question. [pmid: 9865452].
Pope HG, Hudson JI. A supplemental interview for forms of “affective spectrum disorder”. Int J Psychiatry Med. 1991;21:205-32. Exclude: not suitable for any question. [pmid: 1955274].
Portwood MF. Chronic fatigue syndrome--a diagnosis for consideration. [Review]. Nurse Pract. 1988;13:11-2, 15-8, 23. Exclude: not suitable for any question. [pmid: 2830563].
Potaznick W, Kozol N. Ocular manifestations of chronic fatigue and immune dysfunction syndrome. Optom Vis Sci. 1992;69:811-4. Exclude: not suitable for any question. [pmid: 1437004].
Poteliakhoff A. Adrenocortical activity and some clinical findings in acute and chronic fatigue. J Psychosom Res. 1981;25:91-5. Exclude: not suitable for any question. [pmid: 6974238].
Potempa K, Lopez M, Reid C, Lawson L. Chronic fatigue. Image J Nurs Sch. 1986;18:165-9. Exclude: not suitable for any question. [pmid: 3641780].
Powell MA. Epstein-Barr antibody titer and chronic fatigue syndrome. J Am Acad Nurse Pract. 1990;2:33-4. Exclude: not suitable for any question. [pmid: 2158339].
Powell P, Bentall RP, Nye FJ, Edwards RHT. Explanation of symptoms encourages graded exercise and improves prgnosis in chronic fatigue syndrome: a randomised controlled trial. BMJ. [In Press]. Include.
Powell P, Edwards RHT, Bentall RP. The treatment of wheelchair-bound chronic fatigue syndrome patients: two case studies of a pragmatic rehabilitation approach. Behav Cogn Psychother. 1999;27:249-60. Exclude: not suitable for any question.
Powell R, Dolan R, Wessely S. Attributions and self-esteem in depression and chronic fatigue syndromes. J Psychosom Res. 1990;34:665-73. Exclude: not suitable for any question. [pmid: 2290139].
Preston MA. The emergence of a disease: searching for a diagnostic marker and treatment for chronic fatigue immune dysfunction syndrome. Diss Abstr Int B: Sci Engineeer. 1998;59. Exclude: not suitable for any question.
Price JR, Couper J. Cognitive behaviour therapy for adults with chronic fatigue syndrome. Cochrane Database Syst Rev. 2000. CD001027. Exclude: not suitable for any question.
Price RK, North CS, Wessely S, Fraser VJ. Estimating the prevalence of chronic fatigue syndrome and associated symptoms in the community. Public Health Rep. 1992;107:514-22. Include. [pmid: 1329134]. [pmcid: 1403692].
Priest RG, Gimbrett R, Roberts M, Steinert J. Reversible and selective inhibitors of monoamine oxidase A in mental and other disorders. Acta Psychiatr Scand Suppl. 1995;386:40-3. Exclude: did not meet inclusion criteria. [pmid: 7717094].
Prieto J, Subira ML, Castilla A, Serrano M. Naloxone-reversible monocyte dysfunction in patients with chronic fatigue syndrome. Scand J Immunol. 1989;30:13-20. Exclude: not suitable for any question. [pmid: 2526966].
Prince TL, Wray BB, Huff TA. Chronic fatigue in a 43-year-old woman [clinical conference]. Ann Allergy Asthma Immunol. 1995;74:474-8. Exclude: not suitable for any question. [pmid: 7788512].
Prins JB, Bleijenberg G, Bazelmans E, et al. Cognitive behaviour therapy for chronic fatigue syndrome: a multicenter randomised controlled trial. Lancet. [In Press]. Include.
Prins JB, Bleijenberg G. Cognitivebehavior therapy for chronic fatigue syndrome: a case study. J Behav Ther Exp Psychiatry. 1999;30:325-39. Exclude: not suitable for any question. [pmid: 10759328].
Priori R, Conti F, Luan FL, Arpino C, Valesini G. Chronic fatigue: a peculiar evolution of eosinophilia myalgia syndrome following treatment with L-tryptophan in four Italian adolescents. Eur J Pediatr. 1994;153:344-6. Exclude: not suitable for any question. [pmid: 8033924].
Propsner NM. Fatigue that doesn't go away. N J Med. 1999;96:29-31. Exclude: not suitable for any question. [pmid: 10384764].
Przewlocka M. [Chronic fatigue syndrome]. [Review] [Polish]. Pol Tyg Lek. 1994;49:593-5. Exclude: not suitable for any question. [pmid: 7659620].
1291. Quillian RE. Neuropsychological functioning in chronic fatigue syndrome. Diss Abstr Int B: Sci Engineeer. 1995;56. Exclude: not suitable for any question.
Raanani P, Martinowitz U. [Chronic fatigue syndrome]. [Review] [Hebrew]. Harefuah. 1994;127:467-71. Exclude: not suitable for any question. [pmid: 7806108].
Raik E. Chronic fatigue syndrome and the medical referee. Med J Aust. 1994;160:47-8. Exclude: not suitable for any question. [pmid: 8271997].
Rand KH. Chronic fatigue syndrome: fact or fiction. Med Sect Proc. 1991:135-44. Exclude: not suitable for any question.
Rangel L, Garralda E, Levin M, Roberts H. Personality in adolescents with chronic fatigue syndrome. Eur Child Adolesc Psychiatry. 2000;9:39-45. Exclude: sample size. [pmid: 10795854].
Rangel L, Rapp S, Levin M, Garralda E. Chronic fatigue syndrome: updates on paediatric and psychological management. Curr Paediatr. 1999;9:188-93. Exclude: not suitable for any question.
Rasmussen AK, Andersen V. [Chronic fatigue]. [Danish]. Sygeplejersken. 1993;93:26-7, 31. Exclude: not suitable for any question.
Rasmussen AK, Andersen V, Nielsen H, Wiik A. [Chronic fatigue syndrome--a defined unity?]. [Review] [Danish]. Ugeskr Laeger. 1994;156:6832-6. Exclude: not suitable for any question. [pmid: 7839497].
Rasmussen AK, Nielsen H, Andersen V, et al. [Chronic fatigue syndrome--a controlled cross-sectional study (see comments)]. [Danish]. Ugeskr Laeger. 1994;156:6836-40. Exclude: not suitable for any question. [pmid: 7839498].
Rasmussen AK, Nielsen H, Andersen V, et al. Chronic fatigue syndrome--a controlled cross sectional study. J Rheumatol. 1994;21:1527-31. Exclude: not suitable for any question. [pmid: 7983659].
Ray C. Chronic fatigue syndrome and depression: conceptual and methodological ambiguities. [Review]. Psychol Med. 1991;21:1-9. Exclude: not suitable for any question. [pmid: 2047485].
Ray C. Positive and negative social support in a chronic illness. Psychol Rep. 1992;71:977-8. Exclude: social support. [pmid: 1454951].
Ray C, Jefferies S, Weir WR. Coping with chronic fatigue syndrome: illness responses and their relationship with fatigue, functional impairment and emotional status. Psychol Med. 1995;25:937-45. Exclude: not suitable for any question. [pmid: 8588012].
Ray C, Jefferies S, Weir WRC. Coping and other predictors of outcome in chronic fatigue syndrome: a 1-year follow-up. J Psychosom Res. 1997;43:405-15. Include. [pmid: 9330240].
Ray C, Jefferies S, Weir WRC. Life-events and the course of chronic fatigue syndrome. Br J Med Psychol. 1995;68:323-31. Include. [pmid: 8688371].
Ray C, Phillips L, Weir WR. Quality of attention in chronic fatigue syndrome: subjective reports of everyday attention and cognitive difficulty, and performance on tasks of focused attention. Br J Clin Psychol. 1993;32:357-64. Exclude: sample size. [pmid: 8251968].
Ray C, Weir W, Stewart D, Miller P. Ways of coping with chronic fatigue syndrome: development of an illness management questionnaire. Soc Sci Med. 1993;37:385-91. Exclude: not suitable for any question. [pmid: 8356486].
Ray C, Weir WR, Cullen S, Phillips S. Illness perception and symptom components in chronic fatigue syndrome. J Psychosom Res. 1992;36:243-56. Include. [pmid: 1564677].
Ray C, Weir WR, Phillips S, Cullen S. Development of a measure of symptoms in chronic fatigue syndrome: the profile of fatigue-related symptoms (PFRS). Psychol Health. 1992;7:27-43. Include.
Razzaboni E, Ercolani M, Chattat R. Sofferenza psicologica e comportamento di malattia in pazienti affetti da sindrome da stanchezza cronica.: Psychological distress and illness behaviour in chronic fatigue patients. Med Psicosomatica. 1999;44:19-34. Exclude: not suitable for any question.
Rebora A, Drago F. Chronic fatigue syndrome: a novel disorder with cutaneous manifestations. Dermatology. 1994;188:3-5. Exclude: not suitable for any question. [pmid: 8305753].
Redmond CK. Analysis of clinical, epidemiologic, and laboratory data on chronic fatigue syndrome. Rev Infect Dis. 1991;13:S90-3. Exclude: not suitable for any question. [pmid: 1826967].
Reeves WC, Pellett PE, Gary H Jr. The chronic fatigue syndrome controversy. Ann Intern Med. 1992;117. Exclude: not suitable for any question.
Reeves WC, Stamey FR, Black JB, Mawle AC, Stewart JA, Pellett PE. Human herpesviruses 6 and 7 in chronic fatigue syndrome: A case-control study. Clin Infect Dis. 2000;31:48-52. Exclude: not suitable for any question. [pmid: 10913395].
Regland B, Andersson M, Abrahamsson L, Bagby J, Dyrehag LE, Gottfries CG. Increased concentrations of homocysteine in the cerebrospinal fluid in patients with fibromyalgia and chronic fatigue syndrome. Scand J Rheumatol. 1997;26:301-7. Exclude: not suitable for any question. [pmid: 9310111].
Reid S, Chalder T, Cleare A, Hotopf M, Wessely S. Chronic fatigue syndrome. [Review]. BMJ. 2000;320:292-6. Exclude: not suitable for any question. [pmid: 10650029]. [pmcid: 1117488].
Reid S, Crayford T, Richards S, Nimnuan C, Hotopf M. Recognition of medically unexplained symptoms--do doctors agree?. J Psychosom Res. 1999;47:483-5. Exclude: not suitable for any question. [pmid: 10624846].
Reid S, Wessely S. Chronic fatigue syndrome and fibromyalgia: approaches to management. Curr Opin Psychiatry. 1999;12:727-32. Exclude: not suitable for any question.
Reilly PA, Littlejohn GO. Fibromyalgia and chronic fatigue syndrome. [Review]. Curr Opin Rheumatol. 1990;2:282-90. Exclude: not suitable for any question. [pmid: 2203404].
Reiss GR. Chronic fatigue syndrome. J Clin Psychiatry. 1990;51. Exclude: not suitable for any question.
Rest J. The chronic fatigue syndrome. Ann Intern Med. 1995;123. Exclude: not suitable for any question.
Reyes M, Dobbins JG, Mawle AC, et al. Risk factors for chronic fatigue syndrome: A case-control study. J Chronic Fatigue Syndr. 1996;2:17-33. Exclude: not suitable for any question.
Reyes M, Dobbins JG, Nisenbaum R, Subedar NS, Randall B, Reeves WC. Chronic fatigue syndrome progression and self-defined recovery: evidence from the CDC surveillance system. J Chronic Fatigue Syndr. 1999;5:7-17. Include.
Reyes M, Gary HEJr., Dobbins JG, et al. Surveillance for chronic fatigue syndrome: four U.S.cities, September 1989 through August 1993. MMWR Morb Mortal Wkly Rep. 1997;46:1-13. Exclude: not suitable for any question. [pmid: 9011775].
Riccio M, Thompson C, Wilson B, Morgan DJ, Lant AF. Neuropsychological and psychiatric abnormalities in myalgic encephalomyelitis: a preliminary report. Br J Clin Psychol. 1992;31:111-20. Exclude: not suitable for any question. [pmid: 1559114].
Richards J, Smith F. Chronic fatigue syndrome in children and adolescents: general practitioners' experience of the problem and their views about its treatment. Psychiatr Bull. 1998;22:203-6. Exclude: not suitable for any question.
Richards RS, Roberts TK, Dunstan RH, McGregor NR, Butt HL. Free radicals in chronic fatigue syndrome: cause or effect?. Redox Rep. 2000;5:146-7. Exclude: not suitable for any question. [pmid: 10939298].
Richards RS, Roberts TK, McGregor NR, Dunstan RH, Butt HL. Blood parameters indicative of oxidative stress are associated with symptom expression in chronic fatigue syndrome. Redox Rep. 2000;5:35-41. Exclude: not suitable for any question. [pmid: 10905542].
Richardson J, Costa DC. Relationship between SPECT scans and buspirone tests in patients with ME/CFS. J Chronic Fatigue Syndr. 1998;4:23-38. Exclude: not suitable for any question.
Richardson WS, Wilson MC, Williams JW Jr, Moyer VA, Naylor CD. Users' guides to the medical literature: XXIV. How to use an article on the clinical manifestations of disease. Evidence-Based Medicine Working Group. JAMA. 2000;284:869-75. Exclude: not suitable for any question. [pmid: 10938177].
Richman JA, Flaherty JA, Rospenda KM. Chronic fatigue syndrome: have flawed assumptions been derived from treatment-based studies?. Am J Public Health. 1994;84:282-4. Exclude: not suitable for any question. [pmid: 8296954]. [pmcid: 1615008].
Richman JA, Jason LA, Taylor RR, Jahn SC. Feminist perspectives on the social construction of chronic fatigue syndrome. Health Care Women Int. 2000;21:173-85. Exclude: not suitable for any question. [pmid: 11111464].
1333. Riddle PK. Chronic fatigue and women: a description and suggested treatment. Women Health. 1982;7:37-47. Exclude: not suitable for any question. [pmid: 7179999].
Ridsdale L. Chronic fatigue in family practice. J Fam Pract. 1989;29:486-8. Exclude: not suitable for any question. [pmid: 2681522].
Ridsdale L. Tired all the time. Br Med J. 1991;303:1490-1. Exclude: not suitable for any question. [pmid: 1685930]. [pmcid: 1671843].
Ridsdale L, Godfrey E, Chalder T, et al. Chronic fatigue in general practice: is counselling as good as cognitive behaviour therapy? A UK randomised trial. Br J Gen Pract. 2001:19-24. Include.
Riem L. [Causes and treatment of fatigue syndrome].[German]. MMW Fortschr Med. 1999;141:16-8. Exclude: not suitable for any question. [pmid: 10795163].
Rikard-Bell CJ, Waters BG. Psychosocial management of chronic fatigue syndrome in adolescence. Aust N Z J Psychiatry. 1992;26:64-72. Exclude: not suitable for any question. [pmid: 1580887].
Riley MS, O'Brien CJ, McCluskey DR, Bell NP, Nicholls DP. Aerobic work capacity in patients with chronic fatigue syndrome. BMJ. 1990;301:953-6. Exclude: not suitable for any question. [pmid: 2249024]. [pmcid: 1664147].
Rin H, Huang MG. Neurasthenia as nosological dilemma. Cult Med Psychiatry. 1989;13:215-26. Exclude: not suitable for any question. [pmid: 2766795].
Riordan HD, Jackson JA. Chronic fatigue and depression. J Orthomol Med. 1992;7:111-2. Exclude: not suitable for any question.
Robbins JM, Kirmayer LJ, Hemami S. Latent variable models of functional somatic distress. J Nerv Ment Dis. 1997;185:606-15. Include. [pmid: 9345250].
Roberts L, Byrne E. Single fibre EMG studies in chronic fatigue syndrome: a reappraisal. J Neurol Neurosurg Psychiatry. 1994;57:375-6. Exclude: not suitable for any question. [pmid: 8158191].
Roberts TK, McGregor NR, Dunstan RH, et al. Immunological and haematological parameters in patients with chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:51-65. Exclude: not suitable for any question.
Robin R, Lipkin DM, Hume GW. Taking exception to chronic fatigue syndrome prevalence findings by Price, et al. Public Health Rep. 1993;108:135-7. Exclude: not suitable for any question.
Romer FK. [Chronic fatigue syndrome and angiotensin-converting enzyme]. [Danish]. Ugeskr Laeger. 1995;157:756-7. Exclude: not suitable for any question. [pmid: 7701640].
Rosen SD. Hyperventilation and the chronic fatigue syndrome. Q J Med. 1994;87:373-4. Exclude: not suitable for any question. [pmid: 8041870].
Rosen SD, King JC, Wilkinson JB, Nixon PG. Aerobic work capacity in chronic fatigue syndrome. BMJ. 1990;301. Exclude: not suitable for any question.
Rosen SD, King JC, Wilkinson JB, Nixon PG. Is chronic fatigue syndrome synonymous with effort syndrome?. J R Soc Med. 1990;83:761-4. Exclude: not suitable for any question. [pmid: 2125315]. [pmcid: 1292947].
Rosenberg IU, Ostensen AI, Fonnelo H. [Double-blind multicenter trial in general practice on fluphenthixol versus nortriptyline in patients with anxiety-depression-asthenia (the “ADA”-syndrome)]. [Norwegian]. Tidsskr Nor Laegeforen. 1976;96:229-33, 255. Exclude: not suitable for any question. [pmid: 766298].
Roser Galard C, Juncadella Garcia E, Hernandez Hernandez A, Maymo Pijuan N. [Chronic fatigue syndrome: is it ignored in primary care?]. [Spanish]. Aten Primaria. 1995;15:587-8. Exclude: not suitable for any question.
Ross PM. Chemical sensitivity and fatigue syndromes from hypoxia/hypercapnia. Med Hypotheses. 2000;54:734-8. Exclude: not suitable for any question. [pmid: 10859679].
Rotheram EB Jr. The chronic fatigue syndrome]. Ann Intern Med. 1995;123. Exclude: not suitable for any question.
Rotheram EB Jr. Placebo responses in patients complaining of chronic fatigue. Am J Med. 1991;90. Exclude: not suitable for any question.
Rowbottom D, Keast D, Pervan Z, et al. The role of glutamine in the aetiology of the chronic fatigue syndrome: a prospective study. J Chronic Fatigue Syndr. 1998;4:3-22. Exclude: not suitable for any question.
Rowbottom D, Keast D, Pervan Z, Morton A. The physiological response to exercise in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:33-49. Exclude: not suitable for any question.
Rowbottom DG, Keast D, Green S, Kakulas B, Morton AR. The case history of an elite ultra-endurance cyclist who developed chronic fatigue syndrome. Med Sci Sports Exerc. 1998;30:1345-8. Exclude: not suitable for any question. [pmid: 9741601].
Rowe KS. Double-blind randomized controlled trial to assess the efficacy of intravenous gammaglobulin for the management of chronic fatigue syndrome in adolescents. J Psychiatr Res. 1997;31:133-47. Include. [pmid: 9201655].
Rowe KS. Five-year follow-up of young people with chronic fatigue syndrome following the double blind randomised controlled intravenous gammaglobulin trial. J Chronic Fatigue Syndr. 1999;5:97-107.
Rowe PC. Neurally mediated hypotension and chronic fatigue syndrome. Am J Med. 1998;105:15S-21S. Exclude: not suitable for any question. [pmid: 9790477].
Rowe PC, Barron DF, Calkins H, Maumenee IH, Tong PY, Geraghty MT. Orthostatic intolerance and chronic fatigue syndrome associated with Ehlers-Danlos syndrome. J Pediatr. 1999;135:494-9. Exclude: physiologic. [pmid: 10518084].
Rowe PC, Bou-Holaigah I, Kan JS, Calkins H. Is neurally mediated hypotension an unrecognised cause of chronic fatigue?. Lancet. 1995;345:623-4. Exclude: not suitable for any question. [pmid: 7898182].
Rowe PC, Calkins H. Neurally mediated hypotension and chronic fatigue syndrome. [Review]. Am J Med. 1998;105:15S-21S. Exclude: not suitable for any question.
Rowe PC, Calkins H, DeBusk K, et al. Fludrocortisone acetate to treat neurally mediated hypotension in chronic fatigue syndrome: a randomized controlled trial. JAMA. 2001;285:52-9. Include. [pmid: 11150109].
Royal Australasian College of Physicians. Working Group. Chronic fatigue syndrome: draft clinical practice guidelines on the evaluation of prolonged fatigue and the diagnosis and management of chronic fatigue syndrome [Web page]. Medical Journal of Australia. Version 1. Last updated: 1997. Available from: URL: http:www.mja.com.au/public/guides/cfs/cfs1.html Include.
Rusconi AC, Rubeo MG, Bernabei A, Valesini G. [Psychiatric aspects of chronic fatigue syndrome]. [Italian]. Med Psicosomatica. 1994;39:209-23. Exclude: not suitable for any question.
Russo J, Katon W, Clark M, Kith P, Sintay M, Buchwald D. Longitudinal changes associated with improvement in chronic fatigue patients. J Psychosom Res. 1998;45:67-76. Include. [pmid: 9720856].
Russo J, Katon W, Sullivan M, Clark M. Severity of somatization and its relationship to psychiatric disorders and personality. Psychosomatics. 1994;35:546-56. Exclude: not suitable for any question. [pmid: 7809357].
Rutherford OM, White PD. Human quadriceps strength and fatiguability in patients with post viral fatigue. J Neurol Neurosurg Psychiatry. 1991;54:961-4. Exclude: not suitable for any question. [pmid: 1800667].
Sabal N. Fireworks over fibromyalgia, CFS, and IBS. Postgrad Med. 1997;102. Exclude: not suitable for any question.
Sacco P, Hope PA, Thickbroom GW, Byrnes ML, Mastaglia FL. Corticomotor excitability and perception of effort during sustained exercise in the chronic fatigue syndrome. Clin Neurophysiol. 1999;110:1883-91. Exclude: not suitable for any question. [pmid: 10576483].
Sacerdote P, Calella G, Meroni PL, et al. Beta-endorphin concentrations are decreased in peripheral blood mononuclear cells of chronic fatigue syndrome patients: comparison with depression. J Musculoskeletal Pain. 1999;7:303-7. Exclude: not suitable for any question.
Sachs L, Evengard B. [The special physician-patient relation in connection to chronic fatigue syndrome. Anthropologists and physicians search for a new contact-model]. [Swedish]. Lakartidningen. 2000;97:176-8, 181. Exclude: not suitable for any question. [pmid: 10687348].
Sack VM, Henningsen P. [Neurasthenia and chronic fatigue syndrome - An overview of the empirical literature].[German]. Z Psychosom Med Psychoanal. 1998;44:319-37. Exclude: not suitable for any question.
Sadeh A, Carskadon MA, Acebo C, Dahl R. Chronic fatigue immune dysfunction syndrome: an epidemic?. Pediatrics. 1992;89:803-4. Exclude: not suitable for any question. [pmid: 1557290].
Sadler M. Graded exercise in chronic fatigue syndrome. Patients were selected group. BMJ. 1997;315:947-8. Exclude: not suitable for any question.
Saggini R, Pizzigallo E, Vecchiet J, Macellari V, Giacomozzi C. Alteration of spatial-temporal parameters of gait in Chronic Fatigue Syndrome patients. J Neurol Sci. 1998;154:18-25. Exclude: not suitable for any question. [pmid: 9543318].
Sairenji T, Yamanishi K, Tachibana Y, Bertoni G, Kurata T. Antibody responses to Epstein-Barr virus, human herpesvirus 6 and human herpesvirus 7 in patients with chronic fatigue syndrome. Intervirology. 1995;38:269-73. Exclude: not suitable for any question. [pmid: 8724857].
Saisch SG, Deale A, Gardner WN, Wessely S. Hyperventilation and chronic fatigue syndrome. Q J Med. 1994;87:63-7. Exclude: not suitable for any question. [pmid: 8140219].
Salit IE. The chronic fatigue syndrome: a position paper. [Review]. J Rheumatol. 1996;23:540-4. Exclude: not suitable for any question. [pmid: 8832999].
Salit IE. Precipitating factors for the chronic fatigue syndrome. J Psychiatr Res. 1997;31:59-65. Exclude: not suitable for any question. [pmid: 9201648].
Salit IE, Abbey SE, Moldofsky H, Ichise M, Garfinkel PE. Post-infectious neuromyasthenia (chronic fatigue syndrome): a summary of ongoing studies. [Review]. Can Dis Wkly Rep. 1991;17:9-12. Exclude: not suitable for any question.
Salit IE. The chronic fatigue syndrome: an update on important issues. In: Yehuda S, Mostofsky DI, editors. Chronic fatigue syndrome. New York: Plenum Press. 1997:p.51-72. Exclude: not suitable for any question.
Saltzstein BJ, Wyshak G, Hubbuch JT, Perry JC. A naturalistic study of the chronic fatigue syndrome among women in primary care. Gen Hosp Psychiatry. 1998;20:307-16. Exclude: <30. [pmid: 9788031].
Samii A, Wassermann EM, Ikoma K, et al. Decreased postexercise facilitation of motor evoked potentials in patients with chronic fatigue syndrome or depression. Neurology. 1996;47:1410-4. Exclude: not suitable for any question. [pmid: 8960719].
Sandman CA, Barron JL, Nackoul K, Goldstein J, Fidler F. Memory deficits associated with chronic fatigue immune dysfunction syndrome. Biol Psychiatry. 1993;33:618-23. Include. [pmid: 8329493].
Sargent CA, Anderson S, Budek M. Psychomotor functioning in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:53-68. Exclude: not suitable for any question.
Sarkar SN, Seastrunk JW. Development of radiology markers to assess clinically diagnosed chronic fatigue syndrome: Nuclear brain SPECT and magnetic resonance spectroscopy results. Rev Neuroradiol. 1998;11:60-5. Exclude: not suitable for any question.
Scadding JG. Fatigue syndromes. QJM. 1999;92:293-4. Exclude: not suitable for any question. [pmid: 10615486].
Schaefer C. [Chronic fatigue syndrome: an infectious disease?] [German]. Fortschr Med. 1993;111. Exclude: not suitable for any question.
Schaefer KM. Sleep disturbances and fatigue in women with fibromyalgia and chronic fatigue syndrome. J Obstet Gynecol Neonatal Nurs. 1995;24:229-33. Exclude: not suitable for any question.
Scheffers MK, Johnson R Jr, Grafman J, Dale JK, Straus SE. Attention and short-term memory in chronic fatigue syndrome patients: an event-related potential analysis. Neurology. 1992;42:1667-75. Exclude: not suitable for any question. [pmid: 1513453].
Schiraldi O. [Comments on the “chronic fatigue syndrome”]. [Italian]. Recenti Prog Med. 1991;82. Exclude: not suitable for any question.
Schluederberg A, Straus SE, Peterson P, et al. NIH conference. Chronic fatigue syndrome research. Definition and medical outcome assessment. Ann Intern Med. 1992;117:325-31. Include.
Schmaling KB, DiClementi JD, Cullum CM, Jones JF. Cognitive functioning in chronic fatigue syndrome and depression: a preliminary comparison. Psychosom Med. 1994;56:383-8. Exclude: sample size. [pmid: 7809336].
Schmaling KB, Hamilos DL, DiClementi JD, Jones JF. Pain perception in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:13-22. Exclude: sample size.
Schmaling KB, Jones JF. MMPI profiles of patients with chronic fatigue syndrome. J Psychosom Res. 1996;40:67-74. Exclude: not suitable for any question. [pmid: 8730646].
Schmaling KB, Smith WR, Buchwald DS. Significant other responses are associated with fatigue and functional status among patients with chronic fatigue syndrome. Psychosom Med. 2000;62:444-50. Exclude: not suitable for any question. [pmid: 10845358].
Schmall S. The relationship between coping focus and psychological well-being in women with chronic fatigue syndrome. Diss Abstr Int. 1992;53. Exclude: not suitable for any question.
Schmidley JW, Hines J. Folate and chronic fatigue syndrome. Neurology. 1994;44:2214-5. Exclude: not suitable for any question.
Schmitz S, Tesch H, Bohlen H, Engert A, Diehl V. [Chronic fatigue syndrome]. [Review] [German]. Med Klin. 1994;89:154-9. Exclude: not suitable for any question.
Schondorf R, Benoit J, Wein T, Phaneuf D. Orthostatic intolerance in the chronic fatigue syndrome. J Auton Nerv Syst. 1999;75:192-201. Exclude: not suitable for any question. [pmid: 10189122].
Schondorf R, Freeman R. The importance of orthostatic intolerance in the chronic fatigue syndrome. [Review]. Am J Med Sci. 1999;317:117-23. Exclude: not suitable for any question. [pmid: 10037115].
Schonfeld U. [Chronic fatigue syndrome]. [Review] [German]. Med Monatsschr Pharm. 1995;18:90-6. Exclude: not suitable for any question. [pmid: 7752988].
Schooley RT. Chronic fatigue syndrome: a manifestation of Epstein-Barr virus infection?. [Review]. Curr Clin Top Infect Dis. 1988;9. Exclude: not suitable for any question.
Schulte PA. Validation of biologic markers for use in research on chronic fatigue syndrome. [Review]. Rev Infect Dis. 1991;13:S87-9. Exclude: not suitable for any question. [pmid: 2020808].
Schutzer SE, Natelson BH. Absence of Borrelia burgdorferi-specific immune complexes in chronic fatigue syndrome. Neurology. 1999;53:1340-1. Exclude: not suitable for any question. [pmid: 10522896].
Schwartz JE, Jandorf L, Krupp LB. The measurement of fatigue: a new instrument. J Psychosom Res. 1993;37:753-62. Exclude: not suitable for any question. [pmid: 8229906].
Schwartz RB, Garada BM, Komaroff AL, et al. Detection of intracranial abnormalities in patients with chronic fatigue syndrome: comparison of MR imaging and SPECT. AJR Am J Roentgenol. 1994;162:935-41. Exclude: not suitable for any question. [pmid: 8141020].
Schwartz RB, Komaroff AL, Garada BM, et al. SPECT imaging of the brain: comparison of findings in patients with chronic fatigue syndrome, AIDS dementia complex, and major unipolar depression. AJR Am J Roentgenol. 1994;162:943-51. Exclude: not suitable for any question. [pmid: 8141022].
Schweitzer R, Kelly B, Foran A, Terry D, Whiting J. Quality of life in chronic fatigue syndrome. Soc Sci Med. 1995;41:1367-72. Include. [pmid: 8560304].
Schweitzer R, Robertson DL, Kelly B, Whiting J. Illness behaviour of patients with chronic fatigue syndrome. J Psychosom Res. 1994;38:41-9. Exclude: not suitable for any question.
Scott LV, Burnett F, Medbak S, Dinan TG. Naloxone-mediated activation of the hypothalamic-pituitary-adrenal axis in chronic fatigue syndrome. Psychol Med. 1998;28:285-93. Exclude: not suitable for any question. [pmid: 9572086].
Scott LV, Dinan TG. The neuroendocrinology of chronic fatigue syndrome. J Chronic Fatigue Syndr. 1996;2:49-59. Exclude: not suitable for any question.
Scott LV, Dinan TG. The neuroendocrinology of chronic fatigue syndrome: focus on the hypothalamic-pituitary-adrenal axis [Review]. Funct Neurol. 1999;14:3-11. Exclude: not suitable for any question. [pmid: 10321324].
Scott LV, Dinan TG. Urinary free cortisol excretion in chronic fatigue syndrome, major depression and in healthy volunteers. J Affect Disord. 1998;47:49-54. Exclude: not suitable for any question. [pmid: 9476743].
Scott LV, Medbak S, Dinan TG. Blunted adrenocorticotropin and cortisol responses to corticotropin-releasing hormone stimulation in chronic fatigue syndrome. Acta Psychiatr Scand. 1998;97:450-7. Exclude: not suitable for any question. [pmid: 9669518].
Scott LV, Medbak S, Dinan TG. Desmopressin augments pituitary-adrenal responsivity to corticotropin-releasing hormone in subjects with chronic fatigue syndrome and in healthy volunteers. Biol Psychiatry. 1999;45:1447-54. Exclude: not suitable for any question. [pmid: 10356627].
Scott LV, Medbak S, Dinan TG. The low dose ACTH test in chronic fatigue syndrome and in health. Clin Endocrinol (Oxf). 1998;48:733-7. Exclude: not suitable for any question. [pmcid: 298219]. [pmid: 9713562].
Scott LV, Salahuddin F, Cooney J, Svec F, Dinan TG. Differences in adrenal steroid profile in chronic fatigue syndrome, in depression and in health. J Affect Disord. 1999;54:129-37. Exclude: not suitable for any question. [pmid: 10403156].
Scott LV, Teh J, Reznek R, Martin A, Sohaib A, Dinan TG. Small adrenal glands in chronic fatigue syndrome: a preliminary computer tomography study. Psychoneuroendocrinology. 1999;24:759-68. Exclude: not suitable for any question. [pmid: 10451910].
See DM, Broumand N, Sahl L, Tilles JG. In vitro effects of echinacea and ginseng on natural killer and antibody-dependent cell cytotoxicity in healthy subjects and chronic fatigue syndrome or acquired immunodeficiency syndrome patients. Immunopharmacology. 1997;35:229-35. Exclude: not suitable for any question. [pmid: 9043936].
See DM, Cimoch P, Chou S, Chang J, Tilles J. The in vitro immunomodulatory effects of glyconutrients on peripheral blood mononuclear cells of patients with chronic fatigue syndrome. Integr Physiol Behav Sci. 1998;33:280-7. Exclude: not suitable for any question. [pmid: 9829439].
See DM, Tilles JG. Alpha-Interferon treatment of patients with chronic fatigue syndrome. Immunol Invest. 1996;25:153-64. Include. [pmid: 8675231].
Seelig M. Review and hypothesis: Might patients with the chronic fatigue syndrome have latent tetany of magnesium deficiency. J Chronic Fatigue Syndr. 1998;4:77-108. Exclude: not suitable for any question.
Sendrowski DP, Buker EA, Gee SS. An investigation of sympathetic hypersensitivity in chronic fatigue syndrome. Optom Vis Sci. 1997;74:660-3. Exclude: not suitable for any question. [pmid: 9323737].
Serra E. Chronic fatigue syndrome. Br J Psychiatry. 1991;158. Exclude: not suitable for any question.
Servatius RJ, Tapp WN, Bergen MT, et al. Impaired associative learning in chronic fatigue syndrome. Neuroreport. 1998;9:1153-7. Exclude: not suitable for any question. [pmid: 9601685].
Shafran SD. The chronic fatigue syndrome. [Review]. Am J Med. 1991;90:730-9. Exclude: not suitable for any question. [pmid: 2042689].
Shanks MF, Ho-Yen DO. A clinical study of chronic fatigue syndrome. Br J Psychiatry. 1995;166:798-801. Exclude: not suitable for any question. [pmid: 7663831].
Sharma A, Kendall MJ, Oyebode F, Jones D. Fluoxetine and chronic fatigue syndrome. Lancet. 1996;347:1770-1. Exclude: not suitable for any question.
Sharpe M. Chronic fatigue syndrome. [Review]. Psychiatr Clin North Am. 1996;19:549-73. Exclude: not suitable for any question. [pmid: 8856816].
Sharpe M. Cognitive behavior therapy for chronic fatigue syndrome. Am J Me. d1995;98:420-1. Exclude: not suitable for any question.
Sharpe M. Cognitive behavior therapy for chronic fatigue syndrome. Am J Psychiatry. 1998;155:1461-2. Exclude: letter. [pmid: 9766788].
Sharpe M. Cognitive behavior therapy for chronic fatigue syndrome: efficacy and implications. [Review]. Am J Med. 1998;105:104S-9S. Exclude: not suitable for any question. [pmid: 9790491].
Sharpe M. Cognitive behavior therapy for functional somatic complaints. The example of chronic fatigue syndrome. Psychosomatics. 1997;38:356-62. Exclude: not suitable for any question. [pmid: 9217406].
Sharpe M. Doctors' diagnoses and patients' perceptions. Lessons from chronic fatigue syndrome. [Review]. Gen Hosp Psychiatry. 1998;20:335-8. Exclude: not suitable for any question. [pmid: 9854644].
Sharpe M. Non-pharmacological approaches to treatment. [Review]. Ciba Found Symp. 1993;173:298-308. Exclude: not suitable for any question. [pmid: 8491104].
Sharpe M, Chalder T, Palmer I, Wessely S. Chronic fatigue syndrome. A practical guide to assessment and management. [Review]. Gen Hosp Psychiatry. 1997;19:185-99. Exclude: not suitable for any question. [pmid: 9218987].
Sharpe M, Clements A, Hawton K, Young AH, Sargent P, Cowen PJ. Increased prolactin response to buspirone in chronic fatigue syndrome. J Affect Disord. 1996;41:71-6. Exclude: not suitable for any question. [pmid: 8938208].
Sharpe M, Hawton K, Clements A, Cowen PJ. Increased brain serotonin function in men with chronic fatigue syndrome. BMJ. 1997;315:164-5. Exclude: not suitable for any question. [pmid: 9251547].
Sharpe M, Hawton K, Seagroatt V, Pasvol G. Follow up of patients presenting with fatigue to an infectious diseases clinic. BMJ. 1992;305:147-52. Include. [pmid: 1515828]. [pmcid: 1883193].
Sharpe M, Hawton K, Simkin S, et al. [Cognitive behavior therapy for chronic fatigue syndrome: a randomized controlled study].[German]. Verhaltenstherapie. 1998;8:118-24. Include.
Sharpe M, Hawton K, Simkin S, et al. Cognitive behaviour therapy for the chronic fatigue syndrome: a randomized controlled trial. BMJ. 1996;312:22-6. Include. [pmid: 8555852].
Sharpe M, Wessely S. Putting the rest cure to rest--again. BMJ. 1998;316. Exclude: not suitable for any question. [pmcid: 28562].
Sharpe MC, Archard LC, Banatvala JE, et al. A report--chronic fatigue syndrome: guidelines for research. J R Soc Med. 1991;84:118-21. Exclude: not suitable for any question. [pmid: 1999813]. [pmcid: 1293107].
Sharpe MC, Archard LC, Banatvala JE, et al. A report--chronic fatigue syndrome: guidelines for research. J R Soc Med. 1991;84:118-21. Include. [pmid: 1999813]. [pmcid: 1293107].
Sharpe M. Chronic fatigue syndrome: can the psychiatrist help? In: Hawton K, Cowen PJ, editors. Dilemmas and difficulties in the management of psychiatric patients. Oxford, England: Oxford University Press. 1990:p.231-40. Exclude: not suitable for any question.
Sharpe MC. Cognitive-behavioral therapy for patients with chronic fatigue syndrome: how? In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press. 1996:p.240-62. Exclude: not suitable for any question.
Sharpley A, Clements A, Hawton K, Sharpe M. Do patients with “pure” chronic fatigue syndrome (neurasthenia) have abnormal sleep?. Psychosom Med. 1997;59:592-6. Exclude: not suitable for any question. [pmid: 9407577].
Shefer A, Dobbins JG, Fukuda K, et al. Fatiguing illness among employees in three large state office buildings, California, 1993: was there an outbreak?. J Psychiatr Res. 1997;31:31-43. Exclude: not suitable for any question. [pmid: 9201645].
Shen Q. A commentary on “diagnosis postponed: shenjing shuairuo and the transformation of psychiatry in post-mao china,” by sing lee. Cult Med Psychiatry. 1999;23(3):397-9. Exclude: not suitable for any question.
Shepherd C. Chronic fatigue syndrome. Psychologist. 1998;11. Exclude: not suitable for any question.
Shepherd C. Chronic fatigue syndrome or myalgic encephalitis. Lancet. 1994;343. Exclude: not suitable for any question.
Shepherd C. Disagreements still exist over the chronic fatigue syndrome. BMJ. 1997;314. Exclude: not suitable for any question.
Shepherd C. Fluctuations in perceived energy and mood among patients with chronic fatique syndrome. J R Soc Med. 1992;85. Exclude: not suitable for any question.
Shepherd C. Good general care may offer as much benefit as cognitive behaviour therapy. BMJ. 1996;312. Exclude: not suitable for any question.
Shepherd C. Illness behaviour in the chronic fatigue syndrome and multiple sclerosis. Disentangling common characteristics is not so easy. BMJ. 1995;311. Exclude: not suitable for any question.
Shepherd C. Immune responsiveness in chronic fatigue syndrome. Postgrad Med J. 1992;68:66-7. Exclude: not suitable for any question. [pmid: 1561198].
Shepherd C. ME: multiple aetiologies and treatments. Br J Hosp Med. 1991;46. Exclude: not suitable for any question.
Shepherd C. Research update note on ME (ME/CFS). Br J Soc Work. 1997;27:755-60. Exclude: not suitable for any question.
Shepherd C. Viral illness and chronic fatigue (syndrome). Lancet. 1995;346:47-8. Exclude: not suitable for any question. [pmid: 7603154].
Shepherd C, Macintyre A. Graded exercise in chronic fatigue syndrome. Patients should have initial period of rest before gradual increase in activity [published erratum appears in BMJ 1997 Nov 1; 315(7116):1165]. BMJ. 1997;315. Exclude: not suitable for any question.
Shimizu T. [Neuro-psychiatric aspects of chronic fatigue syndrome]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2630-4. Exclude: not suitable for any question. [pmid: 1287239].
Shlaes JL, Jason LA. A buddy/mentor program for PWCs. CFIDS Chronicle. 1996;Winter:21-5. Include.
Shlaes JL, Jason LA, Ferrari JR. The development of the chronic fatigue syndrome attitudes test. Eval Health Prof. 1999;22:442-65. Exclude: not suitable for any question. [pmid: 10623400].
Shogam II, Rechitskii IZ. [Clinico-pathophysiologic characteristics of general sensation in patients with neurasthenia and hysterical neuroses]. [Russian]. Zh Nevropatol Psikhiatr Im S S Korsakova. 1981;81:1842-7. Exclude: not suitable for any question. [pmid: 7340328].
Shogam II, Tsybalova SM. [Clinico-laboratory examination of patients with incipient cerebral atherosclerosis, neurasthenia and apparently healthy subjects of different age groups (comparative data)]. [Russian]. Zh Nevropatol Psikhiatr Im S S Korsakova. 1985;85:45-52. Exclude: not suitable for any question. [pmid: 3984591].
Sibbald B. Chronic fatigue syndrome comes out of the closet. CMAJ. 1998;159:537-41. Exclude: not suitable for any question. [pmid: 9757184]. [pmcid: 1229658].
Siddiqui MZ. Gulf War syndrome. Cleve Clin J Med. 2000;67. Exclude: not suitable for any question.
Simpson LO. Are ME and chronic fatigue syndrome the same disease?. N Z Med J. 1990;103. Exclude: not suitable for any question.
Simpson LO. ME versus CFS. N Z Med J. 1999;112. Exclude: not suitable for any question.
Simpson LO. Myalgic encephalomyelitis and chronic fatigue syndrome. N Z Med J. 1995;108:44-5. Exclude: not suitable for any question. [pmid: 7891941].
Simpson LO, Shand BI, Olds RJ. Blood rheology and myalgic encephalomyelitis: a pilot study. Pathology (Phila). 1986;18:190-2. Exclude: not suitable for any question. [pmcid: 150358].
Sisto SA. Changes in physical activity after a treadmill exercise test in women with chronic fatigue syndrome. Diss Abstr Int B: Sci Engineeer. 1997;58. Exclude: not suitable for any question.
Sisto SA, LaManca J, Cordero DL, et al. Metabolic and cardiovascular effects of a progressive exercise test in patients with chronic fatigue syndrome. Am J Med. 1996;100:634-40. Exclude: not suitable for any question. [pmid: 8678084].
Sisto SA, Tapp W, Drastal S, et al. Vagal tone is reduced during paced breathing in patients with the chronic fatigue syndrome. Clin Auton Res. 1995;5:139-43. Exclude: not suitable for any question. [pmid: 7549414].
Sisto SA, Tapp WN, LaManca JJ, et al. Physical activity before and after exercise in women with chronic fatigue syndrome. QJM. 1998;91:465-73. Exclude: not suitable for any question. [pmid: 9797929].
Skapinakis P, Lewis G, Meltzer H. Clarifying the relationship between unexplained chronic fatigue and psychiatric morbidity: results from a community survey in Great Britain. Am J Psychiatry. 2000;157:1492-8. Include. [pmid: 10964867].
Skare JC, Sullivan JL, Milunsky A. Mapping the mutation causing the X-linked lymphoproliferative syndrome in relation to restriction fragment length polymorphisms on Xq. Hum Genet. 1989;82:349-53. Exclude: not suitable for any question. [pmid: 2567695].
Smets EM, Garssen B, Bonke B, De Haes JC. The Multidimensional Fatigue Inventory (MFI) psychometric qualities of an instrument to assess fatigue. J Psychosom Res. 1995;39:315-25. Exclude: not suitable for any question. [pmid: 7636775].
Smets EMA, Garssen B, Bonke B, Vercoulen JHMM. [The assessment of fatigue: the Multidimensional Fatigue Inventory (MFI)]. [Dutch]. Gedrag Gezondheid. 1995;23:79-85. Exclude: not suitable for any question.
Smit AA, Bolweg NM, Lenders JW, Wieling W. [No strong evidence of disturbed regulation of blood pressure in chronic fatigue syndrome]. [Review] [Dutch]. Ned Tijdschr Geneeskd. 1998;142:625-8. Exclude: not suitable for any question. [pmid: 9623125].
Smith A, Pollock J, Thomas M, Llewelyn M. The relationship between subjective ratings of sleep and mental functioning in healthy subjects and patients with chronic fatigue syndrome. Hum Psychopharmacol Clin Exper. 1996;11:161-7. Include.
Smith A, Thomas M, Borysiewicz L, Llewelyn M. Chronic fatigue syndrome and susceptibility to upper respiratory tract illness. Br J Health Psychol. 1999;4:327-35. Exclude: not suitable for any question.
Smith AP, Behan PO, Bell W, Millar K. Behavioural problems associated with the chronic fatigue syndrome. Br J Psychol. 1993;84:411-23. Include. [pmid: 8401992].
Smith AP, Borysiewicz L, Pollock J, Thomas M, Perry K, Llewelyn M. Acute fatigue in chronic fatigue syndrome patients. Psychol Med. 1999;29:283-90. Include. [pmid: 10218920].
Smith C. Tonics and chronic fatigue. Br J Gen Pract. 1999;49. Exclude: not suitable for any question.
Smith CW Jr. Practical treatment for the patient with depression and chronic fatigue. Prim Care. 1991;18:271-81. Exclude: not suitable for any question. [pmid: 1876613].
Smith MS, Mitchell J, Corey L, et al. Chronic fatigue in adolescents. Pediatrics. 1991;88:195-202. Exclude: not suitable for any question. [pmid: 1861915].
Smith RD, Scott A. The economic impact of chronic fatigue syndrome. Med J Aust. 1993;158:286-7. Exclude: not suitable for any question.
Smits MG, Nagtegaal JE, Swart AC. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:2359-60. Exclude: not suitable for any question.
Snorrason E, Geirsson A, Stefansson K. Trial of a selective acetylcholinesterase inhibitor, galanthamine hydrobromide, in the treatment of chronic fatigue syndrome. J Chronic Fatigue Syndr. 1996;2:35-54. Include.
Sobetzko HM, Stark FM. [Chronic fatigue syndrome].[German]. Nervenarzt. 1997;68:924-5. Exclude: not suitable for any question. [pmid: 9732740].
Soetekouw PM, Lenders JW, Bleijenberg G, Thien T, van der Meer JW. Autonomic function in patients with chronic fatigue syndrome. Clin Auton Res. 1999;9:334-40. Exclude: not suitable for any question. [pmid: 10638807].
Soetekouw PM, Wevers RA, Vreken P, et al. Normal carnitine levels in patients with chronic fatigue syndrome. Neth J Med. 2000;57:20-4. Exclude: not suitable for any question. [pmid: 10862998].
Sopena B, Rivera Gallego A, Martinez Vazquez C, Mardomingo P. Current aspects of chronic fatigue syndrome. Galicia Clin. 1991;63:85-8. Exclude: not suitable for any question.
Speight AN. Increased illness experience preceding chronic fatigue syndrome. J R Coll Physicians Lond. 1998;32. Exclude: not suitable for any question.
Spence VA, Khan F, Belch JJ. Enhanced sensitivity of the peripheral cholinergic vascular response in patients with chronic fatigue syndrome. Am J Med. 2000;108:736-9. Exclude: not suitable for any question. [pmid: 10924652].
Spencer P. CFS: a suitable case for treatment. Psychologist. 1998;11:223-6. Exclude: not suitable for any question.
Spranger J. [Disease, syndrome, sequence]. [Review]. Monatsschr Kinderheilkd. 1989;137:2-7. Exclude: not suitable for any question. [pmid: 2646526].
Spring SB, Tierney EL, Jolson HM. Development of outcome measures for therapeutic trials of chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:69-95. Exclude: not suitable for any question.
St George IM. Did Cook's sailors have Tapanui 'flu? --chronic fatigue syndrome on the Resolution. N Z Med J. 1996;109:15-7. Exclude: not suitable for any question. [pmid: 8628527].
Staines D. Myalgic encephalomyelitis hypothesis. Med J Aust. 1985;143. Exclude: not suitable for any question.
Starcevic V. Neurasthenia: cross-cultural and conceptual issues in relation to chronic fatigue syndrome. [Review]. Gen Hosp Psychiatry. 1999;21:249-55. Exclude: not suitable for any question. [pmid: 10514948].
Stark FM, Sobetzko HM. Approaches to coping with chronic fatigue syndrome (CFS). Zentralbl Hyg Umweltmed. 1999;202:179-90. Exclude: not suitable for any question. [pmid: 10507127].
Steele L, Dobbins JG, Fukuda K, et al. The epidemiology of chronic fatigue in San Francisco. Am J Med. 1998;105:83S-90S. Include. [pmid: 9790487].
Steer RG. Echovirus 16 orchitis and postviral fatigue syndrome. Med J Aust. 1992;156. Exclude: not suitable for any question.
Steinberg P, McNutt BE, Marshall P, et al. Double-blind placebo-controlled study of the efficacy of oral terfenadine in the treatment of chronic fatigue syndrome. J Allergy Clin Immunol. 1996;97:119-26. Include. [pmid: 8568124].
Steinberg P, Pheley A, Peterson PK. Influence of immediate hypersensitivity skin reactions on delayed reactions in patients with chronic fatigue syndrome. J Allergy Clin Immunol. 1996;98:1126-8. Exclude: not suitable for any question. [pmid: 8977518].
Steinhart MJ. Depression and chronic fatigue in the patient with heart disease. Prim Care. 1991;18:309-25. Exclude: not suitable for any question. [pmid: 1876616].
Stern K. Chronic fatigue syndrome. New disease on the horizon. J Dent Hyg. 1991;65:39-41. Exclude: not suitable for any question. [pmid: 1649915].
Stern K. Chronic fatigue syndrome: signs and symptoms. CDS Rev. 1993;86:26-9. Exclude: not suitable for any question. [pmid: 8187200].
Sternberg EM. Hyperimmune fatigue syndromes: diseases of the stress response?. [corrected] [published erratum appears in J Rheumatol 1993 May;20(5):925]. J Rheumatol. 1993;20:418-21. Exclude: not suitable for any question. [pmid: 8478845].
Sternon J, Decaux G, Hoffmann G. [Chronic fatigue syndrome]. [French]. Rev Med Brux. 1994;15:311-5. Exclude: not suitable for any question. [pmid: 7984848].
Sterzl I, Prochazkova J, Hrda P, Bartova J, Matucha P, Stejskal VDM. Mercury and nickel allergy: Risk factors in fatigue and autoimmunity. Neuroendocrinol Lett. 1999;20:221-8. Exclude: not suitable for any question. [pmid: 11462117].
Sterzl I, Zamrazil V. [Endocrinopathy in the differential diagnosis of chronic fatigue syndrome]. [Czech]. Vnitr Lek. 1996;42:624-6. Exclude: not suitable for any question. [pmid: 8984770].
Stewart DE. The changing faces of somatization. Psychosomatics. 1990;31:153-8. Exclude. [pmid: 2330395].
Stewart DE. Emotional disorders misdiagnosed as physical illness: environmental hypersensitivity, candidiasis hypersensitivity, and chronic fatigue syndrome. Int J Ment Health. 1990;19:56-68. Exclude: not suitable for any question.
Stewart J, Weldon A, Arlievsky N, Li K, Munoz J. Neurally mediated hypotension and autonomic dysfunction measured by heart rate variability during head-up tilt testing in children with chronic fatigue syndrome. Clin Auton Res. 1998;8:221-30. Exclude: not suitable for any question. [pmid: 9791743].
Stewart JM. Autonomic nervous system dysfunction in adolescents with postural orthostatic tachycardia syndrome and chronic fatigue syndrome is characterized by attenuated vagal baroreflex and potentiated sympathetic vasomotion. Pediatr Res. 2000;48:218-26. Exclude: not suitable for any question. [pmid: 10926298].
Stewart JM, Gewitz MH, Weldon A, Arlievsky N, Li K, Munoz J. Orthostatic intolerance in adolescent chronic fatigue syndrome. Pediatrics. 1999;103:116-21. Exclude: not suitable for any question. [pmid: 9917448].
Stewart JM, Gewitz MH, Weldon A, Munoz J. Patterns of orthostatic intolerance: the orthostatic tachycardia syndrome and adolescent chronic fatigue. J Pediatr. 1999;135:218-25. Exclude: not suitable for any question. [pmid: 10431117].
Stewart-Pinkham SM. Chronic fatigue syndrome: is cadmium the catalyst?. Int J Biosoc Med Res. 1990;12:21-35. Exclude: not suitable for any question.
Stone AA, Broderick JE, Porter LS, Krupp L. Fatigue and mood in chronic fatigue syndrome patients: results of a momentary assessment protocol examining fatigue and mood levels and diurnal patterns. Ann Behav Med. 1994;16:228-34. Exclude: sample size.
Stores G, Fry A, Crawford C. Sleep abnormalities demonstrated by home polysomnography in teenagers with chronic fatigue syndrome. J Psychosom Res. 1998;45:85-91. Exclude: not suitable for any question. [pmid: 9720858].
Straus SE. Chronic fatigue syndrome. BMJ. 1996;313:831-2. Exclude: not suitable for any question. [pmid: 8870557].
Straus SE. Defining the chronic fatigue syndrome. Arch Intern Med. 1992;152:1569-70. Exclude: not suitable for any question. [pmid: 1323245].
Straus SE. History of chronic fatigue syndrome. Rev Infect Dis. 1991;13:S2-7. Include. [pmid: 2020800].
Straus SE. Intravenous immunoglobulin treatment for the chronic fatigue syndrome. Am J Med. 1990;89:551-3. Exclude: not suitable for any question. [pmid: 2239974].
Straus SE. Studies of herpesvirus infection in chronic fatigue syndrome. [Review]. Ciba Found Symp. 1993;173:132-9. Exclude: not suitable for any question. [pmid: 8387907].
Straus SE, Dale JK, Peter JB, Dinarello CA. Circulating lymphokine levels in the chronic fatigue syndrome. J Infect Dis. 1989;160:1085-6. Exclude: not suitable for any question. [pmid: 2584758].
Straus SE, Dale JK, Tobi M, et al. Acyclovir treatment of the chronic fatigue syndrome. Lack of efficacy in a placebo-controlled trial. N Engl J Med. 1988;319:1692-8. Include. [pmid: 2849717].
Straus SE, Dale JK, Wright R, Metcalfe DD. Allergy and the chronic fatigue syndrome. J Allergy Clin Immunol. 1988;81:791-5. Exclude: not suitable for any question. [pmid: 2836490].
Straus SE, Komaroff AL, Wedner HJ. Chronic fatigue syndrome: point and counterpoint. J Infect Dis. 1994;170:1-6. Exclude: not suitable for any question. [pmid: 8014482].
Straus SE, McKenzie R, Demitrack MA. “Low-dose hydrocortisone for treatment of chronic fatigue syndrome: a randomized controlled trial”: reply. JAMA. 1999;281:1888-9. Exclude: not suitable for any question. [pmid: 10349886].
Straus SE, Tosato G, Armstrong G, et al. Persisting illness and fatigue in adults with evidence of Epstein-Barr virus infection. Ann Intern Med. 1985;102:7-16. Include. [pmid: 2578268].
Strayer DR, Carter WA, Brodsky I, et al. A controlled clinical trial with a specifically configured RNA drug, poly(I).poly(C12U), in chronic fatigue syndrome. Clin Infect Dis. 1994;18:88S-95S. Include.
Streeten DH. The nature of chronic fatigue. JAMA. 1998;280:1094-5. Exclude: not suitable for any question. [pmid: 9757860].
Streeten DH, Anderson GH. Is neurally mediated hypotension an unrecognised cause of chronic fatigue?. Lancet. 1995;345. Exclude: not suitable for any question.
Streeten DH, Anderson GH Jr. The role of delayed orthostatic hypotension in the pathogenesis of chronic fatigue. Clin Auton Res. 1998;8:119-24. Exclude: not suitable for any question. [pmid: 9613802].
Streeten DH, Bell DS. Long- and short-term blood pressure and RR-interval variability and psychosomatic distress in chronic fatigue syndrome. Clin Sci. 1999;97:319-22. Exclude: letter. [pmid: 10576962].
Streeten DH, Thomas D, Bell DS. The roles of orthostatic hypotension, orthostatic tachycardia, and subnormal erythrocyte volume in the pathogenesis of the chronic fatigue syndrome. Am J Med Sci. 2000;320:1-8. Exclude: not suitable for any question. [pmid: 10910366].
Streeten DHP, Bell DS. Circulating blood volume in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:3-11. Exclude: not suitable for any question.
Strickland MC. Depression, chronic fatigue syndrome, and the adolescent. Prim Care. 1991;18:259-70. Exclude: not suitable for any question. [pmid: 1876612].
Strickland P, Morriss R, Wearden A, Deakin B. A comparison of salivary cortisol in chronic fatigue syndrome, community depression and healthy controls. J Affect Disord. 1998;47:191-4. Exclude: not suitable for any question. [pmid: 9476760].
Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. 2000;283:2008-12. Exclude: not suitable for any question. [pmid: 10789670].
Studd J, Panay N. Chronic fatigue syndrome. Lancet. 1996;348. Exclude: not suitable for any question.
Suhadolnik RJ, Peterson DL, O'Brien K, et al. Biochemical evidence for a novel low molecular weight 2-5A-dependent RNase L in chronic fatigue syndrome. J Interferon Cytokine Res. 1997;17:377-85. Exclude: not suitable for any question. [pmid: 9243369].
Suhadolnik RJ, Reichenbach NL, Hitzges P, et al. Changes in the 2-5A synthetase/RNase L antiviral pathway in a controlled clinical trial with poly(I)-poly(C12U) in chronic fatigue syndrome. In Vivo. 1994;8:599-604. Exclude: not suitable for any question. [pmid: 7893988].
Suhadolnik RJ, Reichenbach NL, Hitzges P, et al. Upregulation of the 2-5A synthetase/RNase L antiviral pathway associated with chronic fatigue syndrome. Clin Infect Dis. 1994;18:S96-104. Exclude: not suitable for any question. [pmid: 8148461].
Sumaya CV. Serologic and virologic epidemiology of Epstein-Barr virus: relevance to chronic fatigue syndrome. [Review]. Rev Infect Dis. 1991;13:S19-25. Exclude: not suitable for any question. [pmid: 1850540].
Surawy C, Hackmann A, Hawton K, Sharpe M. Chronic fatigue syndrome: a cognitive approach. Behav Res Ther. 1995;33:535-44. Exclude: not suitable for any question. [pmid: 7598674].
Sutton GC. ‘Too tired to go to the support group’: a health needs assessment of myalgic encephalomyelitis. J Public Health Med. 1996;18:343-9. Exclude: not suitable for any question. [pmid: 8887847].
Suzuki T. The concept of neurasthenia and its treatment in Japan. Cult Med Psychiatry. 1989;13:187-202. Exclude: not suitable for any question. [pmid: 2766793].
Svahn DS, Wallace MT, Loudon M, Skloot F. Seeking answers to chronic fatigue syndrome. JAMA. 1998;279:1697-8. Exclude: not suitable for any question.
Swanink CM, Galama JM, Vercoulen JH, Bleijenberg G, Fennis JF, van der Meer, JW. [Chronic fatigue syndrome. I. Somatological hypothesis]. [Review] [Dutch]. Ned Tijdschr Geneeskd. 1991;135:2005-9. Exclude: not suitable for any question. [pmid: 1944665].
Swanink CM, Melchers WJ, van der Meer JW, et al. Enteroviruses and the chronic fatigue syndrome. Clin Infect Dis. 1994;19:860-4. Exclude: not suitable for any question. [pmid: 7893870].
Swanink CM, Stolk-Engelaar VM, van der Meer JW, et al. Yersinia enterocolitica and the chronic fatigue syndrome. J Infect. 1998;36:269-72. Exclude: not suitable for any question. [pmid: 9661935].
Swanink CM, van der Meer JW, Vercoulen JH, Bleijenberg G, Fennis JF, Galama JM. Epstein-Barr virus (EBV) and the chronic fatigue syndrome: normal virus load in blood and normal immunologic reactivity in the EBV regression assay. Clin Infect Dis. 1995;20:1390-2. Exclude: not suitable for any question. [pmid: 7620030].
Swanink CM, Vercoulen JH, Bazelmans E, et al. Viral antibodies in chronic fatigue syndrome. Clin Infect Dis. 1995;21:708-9. Exclude: not suitable for any question.
Swanink CM, Vercoulen JH, Bleijenberg G, Fennis JF, Galama JM, van der Meer JW. Chronic fatigue syndrome: a clinical and laboratory study with a well matched control group. J Intern Med. 1995;237:499-506. Include. [pmid: 7738491].
Swanink CM, Vercoulen JH, Galama JM, et al. Lymphocyte subsets, apoptosis, and cytokines in patients with chronic fatigue syndrome. J Infect Dis. 1996;173:460-3. Exclude: not suitable for any question. [pmid: 8568312].
Sweetman BJ. Chronic fatigue syndrome in mother and child. J R Soc Med. 2000;93:337-8. Exclude: not suitable for any question. [pmid: 10911845].
Sykes R. Chronic fatigue syndrome. Br J Psychiatry. 1997;171. Exclude: not suitable for any question.
Taerk G, Gnam W. A psychodynamic view of the chronic fatigue syndrome. The role of object relations in etiology and treatment. Gen Hosp Psychiatry. 1994;16:319-25. Exclude: not suitable for any question. [pmid: 7995502].
Taerk GS, Toner BB, Salit IE, Garfinkel PE, Ozersky S. Depression in patients with neuromyasthenia (benign myalgic encephalomyelitis). Int J Psychiatry Med. 1987;17:49-56. Exclude: not suitable for any question. [pmid: 3583562].
Takahashi H, Imai K, Katanuma A, et al. [A case of chronic fatigue syndrome who showed a beneficial effect by intravenous administration of magnesium sulphate]. [Japanese]. Arerugi. 1992;41:1605-10. Exclude: not suitable for any question. [pmid: 1492795].
Takahashi Y, Sano A, Matsuo M. An effective “transluminal balloon angioplasty” therapy for pediatric chronic fatigue syndrome with nutcracker phenomenon [letter]. Clin Nephrol. 2000;53:77-8. Exclude: not suitable for any question. [pmid: 10661488].
Tannock C, Costa DC, Brostoff J. Chronic fatigue syndrome. Preliminary report misrepresented. BMJ. 1994;308. Exclude: not suitable for any question.
Tattam A. CFS--an occupational hazard for nurses?. Aust Nurs J. 1994;2:21-2. Exclude: not suitable for any question. [pmid: 7952140].
Tavris DE. Criteria for chronic fatigue syndrome. Pa Med. 1991;94. Exclude: not suitable for any question.
Taylor RR, Jason LA. Comparing the DIS with the SCID: chronic fatigue syndrome and psychiatric comorbidity. Psychol Health. 1998;13:1087-104. Include.
Taylor RR, Jason LA, Curie CC. The prognosis of chronic fatigue in a community-based sample [unpublished manuscript]. Exclude: not suitable for any question.
Taylor RR, Jason LA, Jahn SC. Sociodemographic predictors of psychiatric disorder in individuals with and without chronic fatigue [unpublished manuscript]. Include.
Taylor RR, Jason LA, Schoeny ME. Evaluating latent variable models of functional somatic distress in a community-based sample Journal of Mental Health. [In Press]. Include.
Taylor RR, Jason LA, Torres A. Fatigue rating scales: an empirical comparison. Psychol Med. 2000;30:849-56. Exclude: not suitable for any question. [pmid: 11037093].
Teitelbaum J, Bird B. Effective treatment of severe chronic fatigue: A report of a series of 64 patients. J Musculoskeletal Pain. 1995;3:91-110. Exclude: not suitable for any question.
Teitelbaum JE, Bird B, Weiss A, Gould L. Low-dose hydrocortisone for chronic fatigue syndrome. JAMA. 1999;281. 1887-8; discussion 1888-9. Exclude: not suitable for any question.
Terman M, Levine SM, Terman JS, Doherty S. Chronic fatigue syndrome and seasonal affective disorder: comorbidity, diagnostic overlap, and implications for treatment. Am J Med. 1998;105:115S-24S. Exclude: not suitable for any question. [pmid: 9790493].
Thagard P. How scientists explain disease. Princeton (NJ): Princeton University Press; 1999. Exclude: not suitable for any question.
Thase ME. Assessment of depression in patients with chronic fatigue syndrome. [Review]. Rev Infect Dis. 1991;13:S114-8. Exclude: not suitable for any question. [pmid: 2020797].
Theorell T, Blomkvist V, Lindh G, Evengard B. Critical life events, infections, and symptoms during the year preceding chronic fatigue syndrome (CFS): an examination of CFS patients and subjects with a nonspecific life crisis. Psychosom Med. 1999;61:304-10. Exclude: not suitable for any question. [pmid: 10367610].
Thissen JP. Magnesium and chronic fatigue. Louvain Med. 1993;112:293-6. Exclude: not suitable for any question.
Thomas PK. The chronic fatigue syndrome: what do we know?. BMJ. 1993;306:1557-8. Exclude: not suitable for any question. [pmid: 8329909]. [pmcid: 1677985].
Thompson D, Hylan TR, McMullen W, Romeis ME, Buesching D, Oster G. Predictors of a medical-offset effect among patients receiving antidepressant therapy. Am J Psychiatry. 1998;155:824-7. Exclude: not suitable for any question. [pmid: 9619157].
Thoolen IM, de Vries TW. [Chronically tired or the chronic fatigue syndrome in an adolescent]. [Dutch]. Tijdschr Kindergeneeskd. 1992;60:63-7. Exclude: not suitable for any question. [pmid: 1412405].
Tiersky LA, Cicerone KD, Natelson BH, DeLuca J. Neuropsychological functioning in chronic fatigue syndrome and mild traumatic brain injury: a comparison. Clin Neuropsychologist. 1998;12:503-12. Include.
Tiersky LA, Johnson SK, Lange G, Natelson BH, DeLuca J. Neuropsychology of chronic fatigue syndrome: a critical review. [Review]. J Clin Exp Neuropsychol. 1997;19:560-86. Exclude: not suitable for any question. [pmid: 9342690].
Tiev KP, Cabane J, Imbert JC. [Treatment of chronic postinfectious fatigue: randomized double-blind study of two doses of sulbutiamine (400-600 mg/day) versus placebo]. [French]. Rev Med Interne. 1999;20:912-8. Include. [pmid: 10573727].
Tirelli U, Bernardi D, Improta S, Pinto A. Immunologic abnormalities in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1996;2:85-96. Exclude: not suitable for any question.
Tirelli U, Chierichetti F, Tavio M, et al. Brain positron emission tomography (PET) in chronic fatigue syndrome: preliminary data. Am J Med. 1998;105:54S-8S. Exclude: not suitable for any question. [pmid: 9790483].
Tirelli U, Marotta G, Improta S, Pinto A. Immunological abnormalities in patients with chronic fatigue syndrome. Scand J Immunol. 1994;40:601-8. Exclude: not suitable for any question. [pmid: 7997849].
Tirelli V, Pinto A, Marotta G, et al. Clinical and immunologic study of 205 patients with chronic fatigue syndrome: a case series from Italy. Arch Intern Med. 1993;153:116-7, 120. Include. [pmid: 8422193].
Tobi M, Morag A, Ravid Z, et al. Prolonged atypical illness associated with serological evidence of persistent Epstein-Barr virus infection. Lancet. 1982;1:61-4. Include. [pmid: 6119490].
Tomoda A, Miike T, Yamada E, et al. Chronic fatigue syndrome in childhood. Brain Dev. 2000;22:60-4. Exclude: not suitable for any question. [pmid: 10761837].
Trevor A. Chronic fatigue syndrome: what's in a name?. Can Fam Physician. 1994;40:1088-9. Exclude: not suitable for any question. [pmid: 8019181].
Trigwell P, Hatcher S, Johnson M, Stanley P, House A. “Abnormal” illness behaviour in chronic fatigue syndrome and multiple sclerosis. BMJ. 1995;311:15-8. Exclude: not suitable for any question. [pmid: 7613314].
Tripathy BK, Agarwal AK, Sangla KS, Singh CP, Chandra S. Infectious agents and immunological disturbances in relation to chronic fatigue syndrome. [Review]. J Assoc Physicians India. 1996;44:335-8. Exclude: not suitable for any question. [pmid: 9282584].
Trojani FT. [Chronic fatigue syndrome]. [Italian]. Clin Ter. 1994;144:163-6. Exclude: not suitable for any question. [pmid: 8181211].
Trojani FT. [Chronic fatigue syndrome]. [Italian]. Clin Ter. 1994;144:269-72. Exclude: not suitable for any question. [pmid: 8181223].
Trojani FT. [The chronic fatigue syndrome]. [Italian]. Clin Ter. 1994;144:373-6. Exclude: not suitable for any question. [pmid: 8205760].
Tseng WS, Di X, Ebata K, Hsu J, Yuhua C. Diagnostic pattern for neuroses in China, Japan, and the United States. Am J Psychiatry. 1986;143:1010-4. Exclude: not suitable for any question. [pmid: 3728714].
Tsung YL. Neurasthenia revisited: its place in modern psychiatry. Cult Med Psychiatry. 1989;13:105-29. Exclude: not suitable for any question.
Tuck I, Human N. The experience of living with chronic fatigue syndrome. J Psychosoc Nurs Ment Health Serv. 1998;36:15-9. Include. [pmid: 9498175].
Turner P. Pension rites [interview by Phil Cohen]. Nurs Times. 1994;90. Exclude: not suitable for any question.
Twemlow SW, Bradshaw SL Jr, Coyne L, Lerma BH. Patterns of utilization of medical care and perceptions of the relationship between doctor and patient with chronic illness including chronic fatigue syndrome. Psychol Rep. 1997;80:643-58. Exclude: not suitable for any question. [pmid: 9129381].
Tyler JL. Determining personality characteristics of chronic fatigue syndrome individuals using the mmpi. Diss Abstr Int. 1991;51. Exclude: not suitable for any question.
Tyrer P, Seivewright H, Seivewright N. Diagnosis of ‘ME’, which makes an external attribution for fatigue. Psychol Med. 1997;27:498-9. Exclude: not suitable for any question. [pmid: 9089843].
Uchida A. [Chronic fatigue immune dysfunction syndrome]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2625-9. Exclude: not suitable for any question. [pmid: 1287238].
Uchida A. [Therapy of chronic fatigue syndrome]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2679-83. Exclude: not suitable for any question. [pmid: 1287242].
Unger PM. The relationship between locus of control and health status in chronic fatigue syndrome. Diss Abstr Int B: Sci Engineeer. 1997;58. Exclude: not suitable for any question.
Ur E, White PD, Grossman A. Hypothesis: cytokines may be activated to cause depressive illness and chronic fatigue syndrome. [Review]. Eur Arch Psychiatry Clin Neurosci. 1992;241:317-22. Exclude: not suitable for any question. [pmid: 1606197].
Uslan D. Perspectives on CFS and impairment: Proposed guidelines for disability determination. J Chronic Fatigue Syndr. 1997;3:75-85. Exclude: not suitable for any question.
Valdini A. Selections from current literature: chronic fatigue syndrome. [Review]. Fam Pract. 1990;7:152-5. Exclude: not suitable for any question. [pmid: 2196194].
Valdini A, Steinhardt S, Feldman E. Usefulness of a standard battery of laboratory tests in investigating chronic fatigue in adults. Fam Pract. 1989;6:286-91. Exclude: not suitable for any question. [pmid: 2632306].
Valesini G, Conti F, Priori R. Chronic fatigue syndrome: what factors trigger it off? [Review]. Clin Exp Rheumatol. 1994;12:473-6. Exclude: not suitable for any question. [pmid: 7842526].
Van Aerde J. Chronic fatigue immune dysfunction syndrome: an epidemic?. Pediatrics. 1992;89. Exclude: not suitable for any question.
Van Amberg RJ. Idiopathic chronic fatigue. A primary disorder. [Review]. N J Med. 1990;87:319-24. Exclude: not suitable for any question. [pmid: 2191252].
Van de Luit L, Van der Meulen J, Cleophas TJM, Zwinderman AH. Amplified amplitudes of circadian rhythms and nighttime hypotension in patients with chronic fatigue syndrome: Improvement by inopamil but not by melatonin. Angiology. 1998;49:903-8. Exclude: not suitable for any question. [pmid: 9822046].
van der Feltz-Cornelis CM, van Dyck R. The notion of somatization: an artefact of the conceptualization of body and mind. Psychother Psychosom. 1997;66:117-27. Exclude: not suitable for any question. [pmid: 9176904].
van der Linden G, Chalder T, Hickie I, Koschera A, Sham P, Wessely S. Fatigue and psychiatric disorder: different or the same?. Psychol Med. 1999;29:863-8. Exclude: does not meet CFS definition. [pmid: 10473313].
van der Meer JW. Chronic fatigue syndrome. Eur J Clin Invest. 1997;27:255-6. Exclude: not suitable for any question. [pmid: 9134371].
van der Meer JW. [Chronic fatigue syndrome]. [Review] [Dutch]. Ned Tijdschr Geneeskd. 1997;141:1507-9. Exclude: not suitable for any question. [pmid: 9543735].
van der Meer JW, Rijken PM, Bleijenberg G, Thomas S, Hinloopen RJ, Bensing JM. [Indications for management in long-term, physically unexplained fatigue symptoms]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:1516-9. Exclude: not suitable for any question. [pmid: 9543738].
van der Steen WJ. Chronic fatigue syndrome: a matter of enzyme deficiencies?. Med Hypotheses. 2000;54:853-4. Exclude: not suitable for any question. [pmid: 10859701].
van der Werf SP, Prins JB, Jongen PJ, van der Meer JW, Bleijenberg G. Abnormal neuropsychological findings are not necessarily a sign of cerebral impairment: a matched comparison between chronic fatigue syndrome and multiple sclerosis. Neuropsychiatry Neuropsychol Behav Neurol. 2000;13:199-203. Exclude: not suitable for any question. [pmid: 10910092].
Van Dishoeck EA. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:2358-9. Exclude: not suitable for any question. [pmid: 9550828].
van Greure CH, Bouic PJ. Aberrant in vitro HLA-DR expression in patients with chronic fatigue. S Afr Med J. 1990;78:219-20. Exclude: not suitable for any question.
Van Houdenhove B, Fischler B, Neerinckx E. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:2360-1. Exclude: not suitable for any question.
Van Houdenhove B, Neerinckx E. [Does an overactive lifestyle increase the susceptibility to chronic fatigue syndrome?] [Dutch]. Tijdschr Psychiatrie. 1998;40:212-20. Exclude: not suitable for any question.
Van Houdenhove B, Neerinckx E. Is “ergomania” a predisposing factor to chronic pain and fatigue?. Psychosomatics. 1999;40:529-30. Exclude: not suitable for any question.
Van Houdenhove B, Onghena P, Neerinckx E, Hellin J. Does high ‘action-proneness’ make people more vulnerable to chronic fatigue syndrome? A controlled psychometric study. J Psychosom Res. 1995;39:633-40. Exclude: not suitable for any question. [pmid: 7490698].
Van Houdenhove B, Vanthuyne S, Neerinckx E. Chronic fatigue syndrome. Am J Med. 2000;109:257-9. Exclude: not suitable for any question. [pmid: 11023437].
Van Mens-Verhulst J, Bensing J. Distinguishing between chronic and nonchronic fatigue, the role of gender and age. Soc Sci Med. 1998;47:621-34. Include. [pmid: 9690845].
van Rensburg EJ. Unacceptable trends in the diagnosis of chronic fatigue syndrome. S Afr Med J. 1992;81:172-3. Exclude: not suitable for any question. [pmid: 1734566].
van Vliet C, Swaen GM, Meijers JM, Slangen J, de Boorder T, Sturmans F. Prenarcotic and neuraesthenic symptoms among Dutch workers exposed to organic solvents. Br J Ind Med. 1989;46:586-90. Exclude: not suitable for any question. [pmid: 2775680].
Vara-Thorbeck R, Guerrero JA, Ruiz-Requena E, Garcia-Carriazo M. Can the use of growth hormone reduce the postoperative fatigue syndrome?. World J Surg. 1996;20:81-6. Exclude: not suitable for any question. [pmid: 8588419].
Vecchiet L, Montanari G, Pizzigallo E, et al. Sensory characterization of somatic parietal tissues in humans with chronic fatigue syndrome. Neurosci Lett. 1996;208:117-20. Exclude: not suitable for any question. [pmid: 8859904].
Vecchiet L, Pizzigallo E, Iezzi S, Affaitati G, Vecchiet J, Giamberardino MA. Differentiation of sensitivity in different tissues and its clinical significance. J Musculoskeletal Pain. 1998;6:33-45. Exclude: not suitable for any question.
Vedhara K, Llewelyn MB, Fox JD, et al. Consequences of live poliovirus vaccine administration in chronic fatigue syndrome. J Neuroimmunol. 1997;75:183-95. Include. [pmid: 9143253].
Vercoulen JH, Bazelmans E, Swanink CM, et al. Physical activity in chronic fatigue syndrome: assessment and its role in fatigue. J Psychiatr Res. 1997;31:661-73. Exclude: not suitable for any question. [pmid: 9447571].
Vercoulen JH, Bazelmans E, Swanink CM, et al. Evaluating neuropsychological impairment in chronic fatigue syndrome. J Clin Exp Neuropsychol. 1998;20:144-56. Include. [pmid: 9777468].
Vercoulen JH, Hommes OR, Swanink CM, et al. The measurement of fatigue in patients with multiple sclerosis. A multidimensional comparison with patients with chronic fatigue syndrome and healthy subjects. Arch Neurol. 1996;53:642-9. Include. [pmid: 8929171].
Vercoulen JH, Swanink CM, Fennis JF, Galama JM, van der Meer JW, Bleijenberg G. Dimensional assessment of chronic fatigue syndrome. Dimensional assessment of chronic fatigue syndrome. 1994;38:383-92. Include.
Vercoulen JH, Swanink CM, Fennis JF, Galama JM, van der Meer JW, Bleijenberg G. Prognosis in chronic fatigue syndrome: a prospective study on the natural course. J Neurol Neurosurg Psychiatry. 1996;60:489-94. Include. [pmid: 8778251].
Vercoulen JH, Swanink CM, Galama JM, et al. The persistence of fatigue in chronic fatigue syndrome and multiple sclerosis: development of a model. J Psychosom Res. 1998;45:507-17. Include. [pmid: 9859853].
Vercoulen JH, Swanink CM, Galama JM, Fennis JF, van der Meer JW, Bleijenberg G. [Chronic fatigue syndrome. II. Psychosocial hypothesis]. [Review] [Dutch]. Ned Tijdschr Geneeskd. 1991;135:2010-4. Exclude: not suitable for any question. [pmid: 1944666].
Vercoulen JH, Swanink CM, Zitman FG, et al. Randomised, double-blind, placebo-controlled study of fluoxetine in chronic fatigue syndrome. Lancet. 1996;347:858-61. Include. [pmid: 8622391].
Vercoulen JH, Zitman FG, Fennis JFM, Galama JMD, Van Der Meer JWM, Bleijenberg G. No effect of fluoxetine in chronic fatigue syndrome; randomized double-blind placebo-controlled trial. Ned Tijdschr Geneeskd. 1997;141:1531-5. Exclude: not suitable for any question.
Vereker MI. Chronic fatigue syndrome: a joint paediatric-psychiatric approach. Arch Dis Child. 1992;67:550-5. Exclude: not suitable for any question. [pmid: 1298205].
Vermel' AE. [Chronic fatigue syndrome]. [Review] [Russian]. Klin Med (Mosk). 1999;77:11-5. Exclude: not suitable for any question. [pmcid: 358319]. [pmid: 10483156].
Versluis RG, de Waal MW, Opmeer C, Petri H, Springer MP. [Prevalence of chronic fatigue syndrome in 4 family practices in Leiden]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:1523-6. Exclude: not suitable for any question. [pmid: 9543740].
Vilikus Z, Mareckova H, Janatkova I, et al. [Risk factors for ischemic heart disease in patients with chronic fatigue syndrome]. [Czech]. Sb Lek. 1998;99:53-61. Exclude: not suitable for any question. [pmid: 9748798].
Visser J, Blauw B, Hinloopen B, et al. CD4 T lymphocytes from patients with chronic fatigue syndrome have decreased interferon-gamma production and increased sensitivity to dexamethasone. J Infect Dis. 1998;177:451-4. Exclude: not suitable for any question. [pmid: 9466535].
Vojdani A. Single aetiological agent may not be feasible in CFS patients. J Intern Med. 1999;245:410-2. Exclude: not suitable for any question. [pmid: 10356606].
Vojdani A, Choppa PC, Lapp CW. Downregulation of RNase L inhibitor correlates with upregulation of interferon-induced proteins (2-5A synthetase and RNase L) in patients with chronic fatigue immune dysfunction syndrome. J Clin Lab Immunol. 1998;50:1-16. Exclude: not suitable for any question. [pmid: 10189612].
Vojdani A, Choppa PC, Tagle C, Andrin R, Samimi B, Lapp CW. Detection of Mycoplasma genus and Mycoplasma fermentans by PCR in patients with Chronic Fatigue Syndrome. FEMS Immunol Med Microbiol. 1998;22:355-65. Exclude: not suitable for any question. [pmid: 9879928].
Vojdani A, Ghoneum M, Choppa PC, Magtoto L, Lapp CW. Elevated apoptotic cell population in patients with chronic fatigue syndrome: the pivotal role of protein kinase RNA. J Intern Med. 1997;242:465-78. Exclude: not suitable for any question. [pmid: 9437407].
Vojdani A, Lapp CW. Interferon-induced proteins are elevated in blood samples of patients with chemically or virally induced chronic fatigue syndrome. Immunopharmacol Immunotoxicol. 1999;21:175-202. Exclude: not suitable for any question. [pmid: 10319275].
Vollmer-Conna U, Hickie I, Hadzi-Pavlovic D, et al. Intravenous immunoglobulin is ineffective in the treatment of patients with chronic fatigue syndrome. Am J Med. 1997;103:38-43. Include. [pmid: 9236484].
Vollmer-Conna U, Lloyd A, Hickie I, Wakefield D. Chronic fatigue syndrome: an immunological perspective. [Review]. Aust N Z J Psychiatry. 1998;32:523-7. Exclude: not suitable for any question. [pmid: 9711366].
Vollmer-Conna U, Wakefield D, Lloyd A, et al. Cognitive deficits in patients suffering from chronic fatigue syndrome, acute infective illness or depression. Br J Psychiatry. 1997;171:377-81. Include. [pmid: 9373430].
von Mikecz A, Konstantinov K, Buchwald DS, Gerace L, Tan EM. High frequency of autoantibodies to insoluble cellular antigens in patients with chronic fatigue syndrome. Arthritis Rheum. 1997;40:295-305. Exclude: not suitable for any question. [pmid: 9041942].
Vooren PH. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141. Exclude: not suitable for any question.
Voth A. What causes chronic fatigue?. CMAJ. 1999;160. Exclude: not suitable for any question.
Vree R. Fireworks over fibromyalgia, CFS, and IBS. Postgrad Med. 1997;102. Exclude: not suitable for any question.
Wachsmuth JR, MacMillan HL. Effective treatment for an adolescent with chronic fatigue syndrome. Clin Pediatr (Phila). 1991;30:488-90. Exclude: not suitable for any question. [pmcid: 358331]. [pmid: 1914350].
Wagenmakers AJ. Chronic fatigue syndrome: the physiology of people on the low end of the spectrum of physical activity? [published erratum appears in Clin Sci (Colch) 1999 Dec;97(6):719]. Clin Sci. 1999;97:611-3. Exclude: not suitable for any question. [pmid: 10545313].
Wagner LI. Chronic fatigue syndrome, chronic fatigue, and psychiatric disorders: an examination of functional status among a national nursing sample. Diss Abstr Int B: Sci Engineeer. 1997;58. Exclude: not suitable for any question.
Wagner LI, Jason LA. Outcomes of occupational stressors on nurses: chronic fatigue syndrome--related symptoms. Nursingconnections. 1997;10:41-9. Exclude: not suitable for any question. [pmid: 9397874].
Wagner M, Krueger GRF, Ablashi DV, Whitman JE. Chronic fatigue syndrome (CFS): a critical evaluation of testing for active human herpesvirus-6 (HHV-6) infection. Review of data of 107 cases. J Chronic Fatigue Syndr. 1996;2:3-16. Exclude: not suitable for any question.
Wagner-Raphael LI, Jason LA, Ferrari JR. Chronic fatigue syndrome, chronic fatigue, and psychiatric disorders: predictors of functional status in a national nursing sample. J Occup Health Psychol. 1999;4:63-71. Include. [pmid: 10100114].
Wahlstrom L. [Does chronic fatigue syndrome have physiological or psychological causes? A wrongly formulated question may result in information]. [Review] [Swedish]. Lakartidningen. 1995;92:150-3. Exclude: not suitable for any question. [pmid: 7837848].
Wakefield D, Lloyd A, Brockman A. Immunoglobulin subclass abnormalities in patients with chronic fatigue syndrome. Pediatr Infect Dis J. 1990;9:S50-3. Exclude: not suitable for any question. [pmid: 2216608].
Wakefield D, Lloyd A, Dwyer J, Salahuddin SZ, Ablashi DV. Human herpesvirus 6 and myalgic encephalomyelitis. Lancet. 1988;1. Exclude: not suitable for any question.
Walden RJ. Is neurally mediated hypotension an unrecognised cause of chronic fatigue?. Lancet. 1995;345. Exclude: not suitable for any question.
Walford GA, Nelson WM, McCluskey DR. Fatigue, depression, and social adjustment in chronic fatigue syndrome. Arch Dis Child. 1993;68:384-8. Exclude: not suitable for any question. [pmid: 8096688].
Walker TL. Chronic fatigue syndrome. Do you know what it means?. Am J Nurs. 1999;99:70-4, 76. Exclude: not suitable for any question. [pmid: 10091575].
Wallace HL 2nd, Natelson B, Gause W, Hay J. Human herpesviruses in chronic fatigue syndrome. Clin Diagn Lab Immunol. 1999;6:216-23. Exclude: not suitable for any question. [pmcid: 95690]. [pmid: 10066657].
Wallace PG. Post-viral fatigue syndrome. Epidemiology: a critical review. [Review]. Br Med Bull. 1991;47:942-51. Exclude: not suitable for any question. [pmid: 1794092].
Walters V, Charles N. “I just cope from day to day”: unpredictability and anxiety in the lives of women. Soc Sci Med. 1997;45:1729-39. Exclude: not suitable for any question. [pmid: 9428091].
Ware NC. Society, mind and body in chronic fatigue syndrome: an anthropological view. [Review]. Ciba Found Symp. 1993;173:62-73. Exclude: not suitable for any question. [pmid: 8491108].
Ware NC. Sociosomatics and illness in chronic fatigue syndrome. Psychosom Med. 1998;60:394-401. Exclude: not suitable for any question. [pmid: 9710284].
Ware NC. Toward a model of social course in chronic illness: the example of chronic fatigue syndrome. Cult Med Psychiatry. 1999;23:303-31. Include. [pmid: 10572737].
Ware NC, Kleinman A. Culture and somatic experience: the social course of illness in neurasthenia and chronic fatigue syndrome. [Review]. Psychosom Med. 1992;54:546-60. Exclude: not suitable for any question. [pmid: 1438658].
Ware NC, Kleinman A. Depression in neurasthenia and chronic fatigue syndrome. Psychiatr Ann. 1992;22:202-8. Exclude: not suitable for any question.
Warren G, McKendrick M, Peet M. The role of essential fatty acids in chronic fatigue syndrome. A case-controlled study of red-cell membrane essential fatty acids (EFA) and a placebo-controlled treatment study with high dose of EFA. Acta Neurol Scand. 1999;99:112-6. Include. [pmid: 10071170].
Wassif WS, Sherman D, Salisbury JR, Peters TJ. Use of dynamic tests of muscle function and histomorphometry of quadriceps muscle biopsies in the investigation of patients with chronic alcohol misuse and chronic fatigue syndrome. Ann Clin Biochem. 1994;31:462-8. Exclude: not suitable for any question. [pmid: 7832572].
Watson WS, McCreath GT, Chaudhuri A, Behan PO. Possible cell membrane transport defect in chronic fatigue syndrome?. J Chronic Fatigue Syndr. 1997;3:1-13. Exclude: not suitable for any question.
Watson WS, McMillan DC, Chaudhuri A, Behan PO. Increased resting energy expenditure in the chronic fatigue syndrome. J Chronic Fatigue Syndr. 1998;4:3-14. Exclude: not suitable for any question.
Wearden A, Appleby L. Cognitive performance and complaints of cognitive impairment in chronic fatigue syndrome (CFS). Psychol Med. 1997;27:81-90. Include. [pmid: 9122311].
Wearden AJ, Appleby L. Research on cognitive complaints and cognitive functioning in patients with chronic fatigue syndrome (CFS). What conclusions can we draw? [Review]. J Psychosom Res. 1996;41:197-211. Exclude: not suitable for any question. [pmid: 8910243].
Wearden AJ, Morriss RK, Mullis R, et al. Randomised, double-blind, placebo-controlled treatment trial of fluoxetine and graded exercise for chronic fatigue syndrome [published erratum appears in Br J Psychiatry 1998; 173:89]. Br J Psychiatry. 1998;172:485-90. Include. [pmid: 9828987].
Weiger WA. Chronic fatigue syndrome. Neurology. 1993;43:1866-7. Exclude: not suitable for any question. [pmid: 8414064].
Welch JC. Abnormal erythrocytes in myalgic encephalomyelitis. N Z Med J. 1989;102. Exclude: not suitable for any question.
Welch JC. Chronic fatigue syndrome and liquorice. N Z Med J. 1995;108:234-5. Exclude: not suitable for any question. [pmid: 7661984].
Wemm KM Jr, Trestman RL. The effects of a laboratory stressor on natural killer cell function in chronic fatigue syndrome patients. Psychosomatics. 1991;32:470-1. Exclude: not suitable for any question. [pmid: 1961870].
Wemmer U. [Chronic fatigue syndrome].[German]. Biol Med. 1999;28:65-8. Exclude: not suitable for any question.
Wesnes KA, Faleni RA, Hefting NR, et al. The cognitive, subjective, and physical effects of a ginkgo biloba/panax ginseng combination in healthy volunteers with neurasthenic complaints. Psychopharmacol Bull. 1997;33:677-83. Exclude: did not meet inclusion criteria. [pmid: 9493479].
Wessely S. Chronic fatigue: reply. Am J Psychiatry. 1997;154. Exclude: not suitable for any question.
Wessely S. Chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1991;54:669-71. Exclude: not suitable for any question. [pmid: 1940935].
Wessely S. Chronic fatigue syndrome: a 20th century illness? [Review]. Scand J Work Environ Health. 1997;23:17-34. Exclude: not suitable for any question. [pmid: 9456063].
Wessely S. [Chronic fatigue syndrome. Clinical, social psychological problems and management]. [Review] [French]. Encephale. 1994;20:581-95. Exclude: not suitable for any question. [pmid: 7843055].
Wessely S. Chronic fatigue syndrome: current issues. Reviews in Medical Microbiology. 1992;3:211-6. Exclude: not suitable for any question.
Wessely S. Chronic fatigue syndrome. [Review]. J Neurol Neurosurg Psychiatry. 1991;54:669-71. Exclude: not suitable for any question. [pmid: 1940935].
Wessely S. Chronic fatigue syndrome. Summary of a report of a joint committee of the Royal Colleges of Physicians, Psychiatrists and General Practitioners. [Review]. J R Coll Physicians Lond. 1996;30:497-504. Exclude: not suitable for any question. [pmid: 8961200].
Wessely S. The epidemiology of chronic fatigue syndrome. [Review]. Epidemiol Rev. 1995;17:139-51. Exclude: not suitable for any question. [pmid: 8521932].
Wessely S. The epidemiology of chronic fatigue syndrome. [Review]. Epidemiol Psichiatr Soc. 1998;7:10-24. Exclude: not suitable for any question. [pmid: 9658678].
Wessely S. History of postviral fatigue syndrome. Br Med Bull. 1991;47:919-41. [pmid: 1794091].
Wessely S. Is neurally mediated hypotension an unrecognised cause of chronic fatigue?. Lancet. 1995;345:1112; discussion 1112-3. Exclude: not suitable for any question. [pmid: 7715356].
Wessely S. Myalgic encephalomyelitis. J R Soc Med. 1991;84:182-3. Exclude: not suitable for any question. [pmid: 2013912].
Wessely S. Myalgic encephalomyelitis: a warning: discussion paper. J R Soc Med. 1989;82:215-7. Exclude: not suitable for any question. [pmid: 2716018]. [pmcid: 1292087].
Wessely S. Neurasthenia and chronic fatigue: theory and practice in britain and america. Transcult Psychiatr Res Rev. 1994;31:173-209. Exclude: not suitable for any question.
Wessely S. The neuropsychiatry of chronic fatigue syndrome. [Review]. Ciba Found Symp. 1993;173:212-29. Exclude: not suitable for any question. [pmid: 8491099].
Wessely S. Outcome in the chronic fatigue syndrome. BMJ. 1992;305. Exclude: not suitable for any question.
Wessely S, Chalder T, Hirsch S, Pawlikowska T, Wallace P, Wright DJ. Postinfectious fatigue: prospective cohort study in primary care. Lancet. 1995;345:1333-8. Include. [pmid: 7752755].
Wessely S, Chalder T, Hirsch S, Wallace P, Wright D. The prevalence and morbidity of chronic fatigue and chronic fatigue syndrome: a prospective primary care study. Am J Public Health. 1997;87:1449-55. Include. [pmid: 9314795]. [pmcid: 1380968].
Wessely S, Chalder T, Hirsch S, Wallace P, Wright D. Psychological symptoms, somatic symptoms, and psychiatric disorder in chronic fatigue and chronic fatigue syndrome: a prospective study in the primary care setting. Am J Psychiatry. 1996;153:1050-9. Include. [pmid: 8678174].
Wessely S, David A, Butler S, Chalder T. Management of post-viral fatigue syndrome. Br J Gen Pract. 1990;40:82-3. Exclude: not suitable for any question. [pmid: 2107860]. [pmcid: 1371151].
Wessely S, Nimnuan C, Sharpe M. Functional somatic syndromes: one or many?. Lancet. 1999;354:936-9. Exclude: not suitable for any question. [pmid: 10489969].
Wessely S, Nimnuan C, Sharpe M. Functional somatic syndromes: one or many? [Review]. Lancet. 1999;354:936-9. Exclude: not suitable for any question. [pmid: 10489969].
Wessely S, Powell R. Fatigue syndromes: a comparison of chronic “postviral” fatigue with neuromuscular and affective disorders. J Neurol Neurosurg Psychiatry. 1989;52:940-8. Include. [pmid: 2571680].
Wessely S. Chronic fatigue and myalgia syndromes. In: Sartorius N, Goldberg D, editors. Psychological disorders in general medical settings. Goettingen, Germany: Hogrefe & Huber Publishers; 1990. p.82-97. Exclude: not suitable for any question.
Wessely S. Viruses and fatigue: the current status of the chronic fatigue syndrome. In: Kurstak E, editor. Psychiatry and biological factors. New York: Plenum Medical Book Co/Plenum Press; 1991. p.231-56, xx p, 311. Exclude: not suitable for any question.
Wessely S, Hotopf M, Sharpe M. Chronic fatigue and its syndromes. Oxford; New York: Oxford University Press; 1998. Include.
Wessely SC. Cognitive-behavioral therapy for patients with chronic fatigue syndrome: why?. In: Demitrack MA, Abbey SE, editors. Chronic fatigue syndrome: an integrative approach to evaluation and treatment. New York: Guilford Press; 1996. p.212-39. Exclude: not suitable for any question.
Wheeler BB. Feminist and psychological implications of chronic fatigue syndrome. Feminism Psychol. 1992;2:197-203. Exclude: not suitable for any question.
Whelton CL, Salit I, Moldofsky H. Sleep, Epstein-Barr virus infection, musculoskeletal pain, and depressive symptoms in chronic fatigue syndrome. J Rheumatol. J Rheumatol;19:939-43. Exclude: not suitable for any question. [pmid: 1328633].
White KP, Speechley M, Harth M, Ostbye. T. Co-existence of chronic fatigue syndrome with fibromyalgia syndrome in the general population: a controlled study. Scand J Rheumatol. 2000;29:44-51. Include. [pmid: 10722257].
White P. Fatigue syndrome: neurasthenia revived. [Review]. BMJ. 1989;298:1:199-200. Exclude: not suitable for any question.
White P, Fulcher K. Benefits of exercise therapy. Phys Ther. 2000;80. Exclude: not suitable for any question.
White PD. Chronic unexplained fatigue. Acta Neuropsychiatrica. 1999;11:130-3. Exclude: not suitable for any question.
White PD. Patient referral and NHS reforms. Lancet. 1992;339. Exclude: not suitable for any question.
White PD, Bruce-Jones WDA, Thomas JM, Amess J. Viruses, neurosis and fatigue: comment. J Psychosom Res. 1995;39. Exclude: not suitable for any question.
White PD, Grover SA, Kangro HO, Thomas JM, Amess J, Clare AW. The validity and reliability of the fatigue syndrome that follows glandular fever. Psychol Med. 1995;25:917-24. Exclude: not CFS. [pmid: 8588010].
White PD, Thomas JM, Amess J, et al. Incidence, risk and prognosis of acute and chronic fatigue syndromes and psychiatric disorders after glandular fever. Br J Psychiatry. 1998;173:475-81. Include. [pmid: 9926075].
White PD, Thomas JM, Amess J, Grover SA, Kangro HO, Clare AW. The existence of a fatigue syndrome after glandular fever. Psychol Med. 1995;25:907-16. Exclude: not CFS. [pmid: 8588009].
Whiteside TL, Friberg D. Natural killer cells and natural killer cell activity in chronic fatigue syndrome. [Review]. Am J Med. 1998;105:27S-34S. Exclude: not suitable for any question.
Wiggs JW. Amantidine, the old anti-Parkinson medication, being useful in the fatigue syndrome that often accompanies multiple sclerosis. S D J Med. 1991;44. Exclude: not suitable for any question.
Wigley RD. Chronic fatigue syndrome, ME and fibromyalgia. N Z Med J. 1990;103. Exclude: not suitable for any question.
Wijlhuizen T, Hamerslag M. [Chronic fatigue syndrome]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141:2361-2. Exclude: not suitable for any question. [pmid: 9550833].
Wilhelmsen I, Bodtker J. [Chronic fatigue syndrome and cognitive therapy]. [Norwegian]. Tidsskr Nor Laegeforen. 1996;116. Exclude: not suitable for any question.
Wilke WS, Fouad-Tarazi FM, Cash JM, Calabrese LH. The connection between chronic fatigue syndrome and neurally mediated hypotension. [Review]. Cleve Clin J Med. 1998;65:261-6. Exclude: not suitable for any question. [pmid: 9599909].
Williams G, Pirmohamed J, Minors D, et al. Dissociation of body-temperature and melatonin secretion circadian rhythms in patients with chronic fatigue syndrome. Clin Physiol. 1996;16:327-37. Exclude: not suitable for any question. [pmid: 8842569].
Wilson A, Hickie I, Lloyd A, et al. Longitudinal study of outcome of chronic fatigue syndrome. BMJ. 1994;308:756-9. Include. [pmid: 8142830].
Wilson A, Hickie I, Lloyd A, Hadzi-Pavlovic D, Wakefield D. Cell-mediated immune function and the outcome of chronic fatigue syndrome. Int J Immunopharmacol. 1995;17:691-4. Exclude: not suitable for any question. [pmid: 8847164].
Wilson EJ. CFS patient's protest. Physiotherapy. 1998;84:461-2. Exclude: not suitable for any question.
Wilson PM, Kusumakar V, McCartney RA, Bell EJ. Features of Coxsackie B virus (CBV) infection in children with prolonged physical and psychological morbidity. J Psychosom Res. 1989;33:29-36. Exclude: not suitable for any question. [pmid: 2538617].
Wilson PR. Myofascial pain, fibromyalgia and chronic fatigue. Clin J Pain. 1994;10:169-70. Exclude: not suitable for any question. [pmid: 7833574].
Winters EG, Quinet RJ. Chronic fatigue syndrome. [Review]. J La State Med Soc. 1992;144:260-70. Exclude: not suitable for any question. [pmid: 1619343].
Wolfersdorf M, Skiba N, Sonntag S, Hofmann P. Chronic fatigue syndrome or depression? A clinical case. Psychopharmakotherapie. 1998;5:121-3. Exclude: not suitable for any question.
Wolff LE. Dimensional assessment of chronic fatigue syndrome: a comparative study and examination of neuropsychological complaints. Diss Abstr Int B: Sci Engineeer. 1997;57. Exclude: not suitable for any question.
Won Kyoo Cho, Stollerman GH. Chronic fatigue syndrome. Hosp Pract. 1992;27:221-4, 227-30, 233-4, 236, 241-2, 244-5. Exclude: not suitable for any question.
Wong R, Lopaschuk G, Zhu G, et al. Skeletal muscle metabolism in the chronic fatigue syndrome. In vivo assessment by 31P nuclear magnetic resonance spectroscopy. Chest. 1992;102:1716-22. Exclude: not suitable for any question. [pmid: 1446478].
Woo SB, Schacterle RS, Komaroff AL, Gallagher GT. Salivary gland changes in chronic fatigue syndrome: a case-controlled preliminary histologic study. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2000;90:82-7. Exclude: not suitable for any question. [pmid: 10884641].
Wood B, Wessely S. Personality and social attitudes in chronic fatigue syndrome. J Psychosom Res. 1999;47:385-97. Exclude: not suitable for any question. [pmid: 10616232].
Wood B, Wessely S, Papadopoulos A, Poon L, Checkley S. Salivary cortisol profiles in chronic fatigue syndrome. Neuropsychobiology. 1998;37:1-4. Exclude: not suitable for any question. [pmid: 9438265].
Wood C. Fluctuations in perceived energy and mood among patients with chronic fatigue syndrome. J R Soc Med. 1992;85. Exclude: not suitable for any question.
Wood C. Tired all the time: a mind body approach to fatigue. Advances. 1987;4:56-9. Exclude: not suitable for any question.
Wood C, Magnello ME, Sharpe MC. Fluctuations in perceived energy and mood among patients with chronic fatigue syndrome. J R Soc Med. 1992;85:195-8. Exclude: not suitable for any question. [pmid: 1290537]. [pmcid: 1294721].
Wood GC, Bentall RP, Gopfert M, Dewey ME, Edwards RH. The differential response of chronic fatigue, neurotic and muscular dystrophy patients to experimental psychological stress. Psychol Med. 1994;24:357-64. Exclude: not suitable for any question. [pmid: 8084931].
Wood GC, Bentall RP, Gopfert M, Edwards RH. A comparative psychiatric assessment of patients with chronic fatigue syndrome and muscle disease. Psychol Med. 1991;21:619-28. Exclude: not suitable for any question. [pmid: 1946850].
Woods TO, Goldberg DP. Psychiatric perspectives: an overview. [Review]. Br Med Bull. 1991;47:908-18. Exclude: not suitable for any question. [pmid: 1794090].
Woodward CG, Cox RA. Epstein-Barr virus serology in the chronic fatigue syndrome. J Infect. 1992;24:133-9. Exclude: not suitable for any question. [pmid: 1314860].
Woodward RV, Broom DH, Legge DG. Diagnosis in chronic illness: disabling or enabling--the case of chronic fatigue syndrome. J R Soc Med. 1995;88:325-9. Exclude: not suitable for any question. [pmid: 7629762]. [pmcid: 1295234].
Wookey C. Viral illness and chronic fatigue (syndrome). Lancet. 1995;346. Exclude: not suitable for any question.
Wray BB, Gaughf C, Chandler FW Jr, et al. Detection of Epstein-Barr virus and cytomegalovirus in patients with chronic fatigue. Ann Allergy. 1993;71:223-6. Exclude: not suitable for any question. [pmid: 8396863].
Wright B. Chronic fatigue syndrome and heterogeneity. J R Soc Med. 1992;85. Exclude: not suitable for any question.
Wright B, Williams C, Partridge I. Management advice for children with chronic fatigue syndrome: a systematic study of information from the internet. Ir J Psychol Med. 1999;16:67-71. Exclude: not suitable for any question.
Wright JB, Beverley DW. Chronic fatigue syndrome. [Review]. Arch Dis Child. 1998;79:368-74. Exclude: not suitable for any question. [pmid: 9875054].
Wylie B. Muscle versus brain: chronic fatigue syndrome. Med J Aust. 1991;154. Exclude: not suitable for any question.
Wysenbeek AJ, Shapira Y, Leibovici L. Primary fibromyalgia and the chronic fatigue syndrome. Rheumatol Int. 1991;10:227-9. Exclude: not suitable for any question. [pmid: 2041979].
Yalcin S, Kuratsune H, Yamaguchi K, Kitani T, Yamanishi K. Prevalence of human herpesvirus 6 variants A and B in patients with chronic fatigue syndrome. Microbiol Immunol. 1994;38:587-90. Exclude: not suitable for any question. [pmid: 7968694].
Yamanishi K. [Chronic fatigue syndrome and virus infection: human herpesvirus 6 (HHV-6) infection]. [Review] [Japanese]. Nippon Rinsho. 1992;50:2612-6. Exclude: not suitable for any question. [pmid: 1337558].
Yan W. A commentary on “diagnosis postponed: shenjing shuairuo and the transformation of psychiatry in post-mao china, by sing lee.”. Cult Med Psychiatry. 1999;23(3):393-6. Exclude: not suitable for any question.
Yataco A, Talo H, Rowe P, Kass DA, Berger RD, Calkins H. Comparison of heart rate variability in patients with chronic fatigue syndrome and controls. Clin Auton Res. 1997;7:293-7. Exclude: not suitable for any question. [pmid: 9430800].
Yatham LN, Morehouse RL. Endocrine responses to fenfluramine challenge in chronic fatigue syndrome: response. Can J Psychiatry. 1996;41:130-1. Exclude: not suitable for any question.
Yatham LN, Morehouse RL, Chisholm BT, Haase DA, MacDonald DD, Marrie TJ. Neuroendocrine assessment of serotonin (5-HT) function in chronic fatigue syndrome. Can J Psychiatry. 1995;40:93-6. Exclude: not suitable for any question. [pmid: 7788624].
Yehuda S, Mostofsky DI., editors. Chronic fatigue syndrome. New York: Plenum Press; 1997. Exclude: not suitable for any question.
Yeomans JD, Conway SP. Biopsychosocial aspects of chronic fatigue syndrome (myalgic encephalomyelitis). J Infect. 1991;23:263-9. Exclude: not suitable for any question. [pmid: 1753134].
Young A. Amma therapy: a holistic approach to chronic fatigue syndrome. J Holist Nurs. 1993;11:172-82. Exclude: not suitable for any question. [pmid: 8277135].
Young AH, Sharpe M, Clements A, Dowling B, Hawton KE, Cowen PJ. Basal activity of the hypothalamic-pituitary-adrenal axis in patients with the chronic fatigue syndrome (neurasthenia). Biol Psychiatry. 1998;43:236-7. Exclude: not suitable for any question. [pmid: 9494707].
Yousef GE, Bell EJ, Mann GF, et al. Chronic enterovirus infection in patients with postviral fatigue syndrome. Lancet. 1988;1:146-50. Exclude: not suitable for any question. [pmid: 2892990].
Yu FT. [Progress in studies of chronic exhaustion syndrome and its traditional Chinese medicine therapy]. [Review] [Chinese]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1995;15:751-4. Exclude: not suitable for any question. [pmid: 8732144].
Zajdowicz TR. Chronicfatigue syndrome and military service. Mil Med. 1992;157:A3-4. Exclude: not suitable for any question. [pmid: 1454187].
Zamai L, Mariani AR, Papa S, Reno F, Vitale M. Natural killer cell function in flow cytometry. Minerva Biotecnol. 1999;11:129-37. Exclude: not suitable for any question.
Zavalishin IA, Zakharova MN. [The chronic fatigue syndrome].[Review] [Russian]. Zh Nevropatol Psikhiatr Im S S Korsakova. 1994;94:44-6. Exclude: not suitable for any question.
Zhang C, Baumer A, Mackay IR, Linnane AW, Nagley P. Unusual pattern of mitochondrial DNA deletions in skeletal muscle of an adult human with chronic fatigue syndrome. Hum Mol Genet. 1995;4:751-4. Exclude: not suitable for any question. [pmid: 7633428].
Zhang MY. The diagnosis and phenomenology of neurasthenia. A Shanghai study. Cult Med Psychiatry. 1989;13:147-61. Exclude: not suitable for any question. [pmid: 2766791].
Zhang Q, Zhou XD, Denny T, et al. Changes in immune parameters seen in Gulf War veterans but not in civilians with chronic fatigue syndrome. Clin Diagn Lab Immunol. 1999;6:6-13. Exclude: not suitable for any question. [pmcid: 95652]. [pmid: 9874656].
Zhang QW, Natelson BH, Ottenweller JE, et al. Chronic fatigue syndrome beginning suddenly occurs seasonally over the year. Chronobiol Int. 2000;17:95-9. Exclude: not suitable for any question. [pmid: 10672437].
Zheng YP, Lin KM, Yamamoto J, Zheng D. Neurasthenia in Chinese students and visiting scholars in the United States. Psychiatr Ann. 1992;22:194-8. Exclude: not suitable for any question.
Zheng YP, Lin KM, Zhao JP, Zhang MY, Yong D. Comparative study of diagnostic systems: Chinese Classification of Mental Disorders-Second Edition versus DSM-III-R. Compr Psychiatry. 1994;35:441-9. Exclude: not suitable for any question. [pmid: 7867317].
Zhou K. [Treatment of neurasthenia with combined western and traditional Chinese medicine by basing therapy on type differentiation of the disease]. [Chinese]. Chung Hua Shen Ching Ching Shen Ko Tsa Chih. 1986;19:306-8. Exclude: not suitable for any question.
Ziem G, Donnay A. Chronic fatigue, fibromyalgia, and chemical sensitivity: overlapping disorders. Arch Intern Med. 1995;155. Exclude: not suitable for any question.
Zorzenon M, Colle R, Rukh G, Barsanti LA, Botta GA, Ceccherini-Nelli L. Active HHV-6 infection in chronic fatigue syndrome patients from Italy: New data. J Chronic Fatigue Syndr. 1996;2:3-12. Exclude: not suitable for any question.
Zubieta JK, Engleberg NC, Yargic LI, Pande AC, Demitrack MA. Seasonal symptom variation in patients with chronic fatigue: comparison with major mood disorders. J Psychiatr Res. 1994;28:13-22. Exclude: not suitable for any question. [pmid: 8064638].