# References

1 Conn HF, Clohecy RJ, Conn RB. Current Diagnosis. Philadelphia (PA): W.B. Saunders. 1997. [pmcid: 176006].
2 Wessely S, Hotopf M, Sharpe M. Chronic fatigue and its syndromes. Oxford; New York: Oxford University Press. 1998. [pmcid: 325579].
3 Chronic fatigue syndrome: draft clinical practice guidelines on the evaluation of prolonged fatigue and the diagnosis and management of chronic fatigue syndrome [Web page]. Medical Journal of Australia. Version 1. 1997. Available from: URL: http:www.mja.com.au/public/guides/cfs/cfs1.html.
4 Skapinakis P, Lewis G, Meltzer H. Clarifying the relationship between unexplained chronic fatigue and psychiatric morbidity: results from a community survey in Great Britain. Am J Psychiatry. 2000;157:1492-8. [pmid: 10964867].
5 Bates DW, Schmitt W, Buchwald D, et al. Prevalence of fatigue and chronic fatigue syndrome in a primary care practice. Arch Intern Med. 1993;153:2759-65. [pmid: 8257251].
6 David A, Pelosi A, McDonald E, et al. Tired, weak, or in need of rest: fatigue among general practice attenders. BMJ. 1990;301:1199-202. [pmid: 2261560]. [pmcid: 1664364].
7 Hickie IB, Hooker AW, Hadzi-Pavlovic D, Bennett BK, Wilson AJ, Lloyd AR. Fatigue in selected primary care settings: sociodemographic and psychiatric correlates. Med J Aust. 1996;164:585-8. [pmid: 8637460].
8 Ware NC. Toward a model of social course in chronic illness: the example of chronic fatigue syndrome. Cult Med Psychiatry. 1999;23:303-31. [pmid: 10572737].
9 Tuck I, Human N. The experience of living with chronic fatigue syndrome. J Psychosoc Nurs Ment Health Serv. 1998;36:15-9. [pmid: 9498175].
10 Hart B, Grace VM. Fatigue in chronic fatigue syndrome: a discourse analysis of women's experiential narratives. Health Care Women Int. 2000;21:187-201. [pmid: 11111465].
11 Goodnick PJ, Klimas NG., editors. Chronic fatigue and related immune deficiency syndromes. Washington (DC): American Psychiatric Press. 1993. [pmcid: 372939].
12 Straus SE. History of chronic fatigue syndrome. Rev Infect Dis. 1991;13:S2-7. [pmid: 2020800].
13 Buchwald D, Sullivan JL, Komaroff AL. Frequency of ‘chronic active Epstein-Barr virus infection’ in a general medical practice. JAMA. 1987;257:2303-7. [pmid: 3033338].
14 Straus SE, Tosato G, Armstrong G, et al. Persisting illness and fatigue in adults with evidence of Epstein-Barr virus infection. Ann Intern Med. 1985;102:7-16. [pmid: 2578268].
15 Tobi M, Morag A, Ravid Z, et al. Prolonged atypical illness associated with serological evidence of persistent Epstein-Barr virus infection. Lancet. 1982;1:61-4. [pmid: 6119490].
16 DuBois RE, Seeley JK, Brus I, et al. Chronic mononucleosis syndrome. South Med J. 1984;77:1376-82. [pmid: 6093268].
17 Jones JF, Ray CG, Minnich LL, Hicks MJ, Kibler R, Lucas DO. Evidence for active Epstein-Barr virus infection in patients with persistent, unexplained illnesses: elevated anti-early antigen antibodies. Ann Intern Med. 1985;102:1-7. [pmid: 2578266].
18 Ballow M, Seeley J, Purtilo DT, St. Onge S, Sakamoto K, Rickles FR. Familial chronic mononucleosis. Ann Intern Med. 1982;97:821-5. [pmid: 7149489].
19 Camus F, Henzel D, Janowski M, Raguin G, Leport C, Vilde JL. Unexplained fever and chronic fatigue: abnormal circadian temperature pattern. Eur J Med. 1992;1:30-6. [pmid: 1341974].
20 Friedberg F, Jason LA. Understanding chronic fatigue syndrome: an empirical guide to assessment and treatment. Washington DC: American Psychological Association. 1998. [pmcid: 325579].
21 Hedges LV, Olkin I. Statistical methods for meta-analysis. Orlando (FL): Academic Press. 1985. [pmcid: 397982].
22 Lloyd AR, Hickie I, Boughton CR, Spencer O, Wakefield D. Prevalence of chronic fatigue syndrome in an Australian population. Med J Aust. 1990;153:522-8. [pmid: 2233474].
23 Sharpe MC, Archard LC, Banatvala JE, et al. A report--chronic fatigue syndrome: guidelines for research. J R Soc Med. 1991;84:118-21. [pmid: 1999813]. [pmcid: 1293107].
24 Schluederberg A, Straus SE, Peterson P, et al. NIH conference. Chronic fatigue syndrome research. Definition and medical outcome assessment. Ann Intern Med. 1992;117:325-31. [pmid: 1322076].
25 Fukuda K, Straus SE, Hickie I, Sharpe MC, Dobbins JG, Komaroff A. The chronic fatigue syndrome: a comprehensive approach to its definition and study. International Chronic Fatigue Syndrome Study Group. Ann Intern Med. 1994;121:953-9. [pmid: 7978722].
26 Krupp LB, Jandorf L, Coyle PK, Mendelson WB. Sleep disturbance in chronic fatigue syndrome. J Psychosom Res. 1993;37:325-31. [pmid: 8510058].
27 Sandman CA, Barron JL, Nackoul K, Goldstein J, Fidler F. Memory deficits associated with chronic fatigue immune dysfunction syndrome. Biol Psychiatry. 1993;33:618-23. [pmid: 8329493].
28 Schweitzer R, Kelly B, Foran A, Terry D, Whiting J. Quality of life in chronic fatigue syndrome. Soc Sci Med. 1995;41:1367-72. [pmid: 8560304].
29 Buchwald D, Pearlman T, Umali J, Schmaling K, Katon W. Functional status in patients with chronic fatigue syndrome, other fatiguing illnesses, and healthy individuals. Am J Med. 1996;101:364-70. [pmid: 8873506].
30 Komaroff AL, Fagioli LR, Doolittle TH, et al. Health status in patients with chronic fatigue syndrome and in general population and disease comparison groups. Am J Med. 1996;101:281-90. [pmid: 8873490].
31 Tiersky LA, Cicerone KD, Natelson BH, DeLuca J. Neuropsychological functioning in chronic fatigue syndrome and mild traumatic brain injury: a comparison. Clin Neuropsychologist. 1998;12:503-12.
32 Vollmer-Conna U, Wakefield D, Lloyd A, et al. Cognitive deficits in patients suffering from chronic fatigue syndrome, acute infective illness or depression. Br J Psychiatry. 1997;171:377-81. [pmid: 9373430].
33 Smith AP, Behan PO, Bell W, Millar K. Behavioural problems associated with the chronic fatigue syndrome. Br J Psychol. 1993;84:411-23. [pmid: 8401992].
34 Swanink CM, Vercoulen JH, Bleijenberg G, Fennis JF, Galama JM, van der Meer JW. Chronic fatigue syndrome: a clinical and laboratory study with a well matched control group. J Intern Med. 1995;237:499-506. [pmid: 7738491].
35 Smith A, Pollock J, Thomas M, Llewelyn M. The relationship between subjective ratings of sleep and mental functioning in healthy subjects and patients with chronic fatigue syndrome. Hum Psychopharmacol Clin Exper. 1996;11:161-7.
36 Vercoulen JH, Hommes OR, Swanink CM, et al. The measurement of fatigue in patients with multiple sclerosis. A multidimensional comparison with patients with chronic fatigue syndrome and healthy subjects. Arch Neurol. 1996;53:642-9. [pmid: 8929171].
37 Bazelmans E, Bleijenberg G, Vercoulen JH, van der Meer JW, Folgering H. The chronic fatigue syndrome and hyperventilation. [published erratum appears in J Psychosom Res 1998 Mar-Apr;44(3-4):517]. J Psychosom Res. 1997;43:371-7. [pmid: 9330236].
38 Wearden A, Appleby L. Cognitive performance and complaints of cognitive impairment in chronic fatigue syndrome (CFS). Psychol Med. 1997;27:81-90. [pmid: 9122311].
39 Vercoulen JH, Bazelmans E, Swanink CM, et al. Evaluating neuropsychological impairment in chronic fatigue syndrome. J Clin Exp Neuropsychol. 1998;20:144-56. [pmid: 9777468].
40 Smith AP, Borysiewicz L, Pollock J, Thomas M, Perry K, Llewelyn M. Acute fatigue in chronic fatigue syndrome patients. Psychol Med. 1999;29:283-90. [pmid: 10218920].
41 Wessely S, Chalder T, Hirsch S, Wallace P, Wright D. Psychological symptoms, somatic symptoms, and psychiatric disorder in chronic fatigue and chronic fatigue syndrome: a prospective study in the primary care setting. Am J Psychiatry. 1996;153:1050-9. [pmid: 8678174].
42 Baraniuk JN, Clauw DJ, Gaumond E. Rhinitis symptoms in chronic fatigue syndrome. Ann Allergy Asthma Immunol. 1998;81:359-65. [pmid: 9809501].
43 Blenkiron P, Edwards R, Lynch S. Associations between perfectionism, mood, and fatigue in chronic fatigue syndrome: a pilot study. J Nerv Ment Dis. 1999;187:566-70. [pmid: 10496512].
44 Jason LA, King CP, Taylor RR, Kennedy C. Defining chronic fatigue syndrome: methodological challenges. J Chronic Fatigue Syndr. 2000;7:17-32.
45 Jason LA, Taylor RR, Kennedy CL. Chronic fatigue syndrome, fibromyalgia, and multiple chemical sensitivities in a community-based sample of persons with chronic fatigue syndrome-like symptoms. Psychosom Med. 2000;62:655-63. [pmid: 11020095].
46 Hickie I, Lloyd A, Wakefield D, Parker G. The psychiatric status of patients with the chronic fatigue syndrome. Br J Psychiatry. 1990;156:534-40. [pmid: 2386862].
47 Morriss RK, Ahmed M, Wearden AJ, et al. The role of depression in pain, psychophysiological syndromes and medically unexplained symptoms associated with chronic fatigue syndrome. J Affect Disord. 1999;55:143-8. [pmid: 10628883].
48 Johnson SK, DeLuca J, Natelson BH. Depression in fatiguing illness: comparing patients with chronic fatigue syndrome, multiple sclerosis and depression. J Affect Disord. 1996;39:21-30. [pmid: 8835650].
49 Buchwald D, Garrity D. Comparison of patients with chronic fatigue syndrome, fibromyalgia, and multiple chemical sensitivities. Arch Intern Med. 1994;154:2049-53. [pmid: 8092909].
50 Buchwald D, Umali J, Stene M. Insulin-like growth factor-I (somatomedin C) levels in chronic fatigue syndrome and fibromyalgia. J Rheumatol. 1996;23:739-42. [pmid: 8730136].
51 Buchwald D. Fibromyalgia and chronic fatigue syndrome: similarities and differences. Rheum Dis Clin North Am. 1996;22:219-43. [pmid: 9157484].
52 Fischler B, Le Bon O, Hoffmann G, Cluydts R, Kaufman LDMK. Sleep anomalies in the chronic fatigue syndrome: a comorbidity study. Neuropsychobiology. 1997;35:115-22. [pmid: 9170115].
53 White KP, Speechley M, Harth M, Ostbye. T. Co-existence of chronic fatigue syndrome with fibromyalgia syndrome in the general population: a controlled study. Scand J Rheumatol. 2000;29:44-51. [pmid: 10722257].
54 Blakely AA, Howard RC, Sosich RM, Murdoch JC, Menkes DB, Spears GF. Psychiatric symptoms, personality and ways of coping in chronic fatigue syndrome. Psychol Med. 1991;21:347-62. [pmid: 1876640].
55 Vercoulen JH, Swanink CM, Fennis JF, Galama JM, van der Meer JW, Bleijenberg G. Dimensional assessment of chronic fatigue syndrome. J Psychosom Res. 1994;38:383-92. [pmid: 7965927].
56 Hickie I, Lloyd A, Hadzi-Pavlovic D, Parker G, Bird K, Wakefield D. Can the chronic fatigue syndrome be defined by distinct clinical features?. Psychol Med. 1995;25:925-35. [pmid: 8588011].
57 Vercoulen JH, Swanink CM, Galama JM, et al. The persistence of fatigue in chronic fatigue syndrome and multiple sclerosis: development of a model. J Psychosom Res. 1998;45:507-17. [pmid: 9859853].
58 Jason LA, Taylor RR, Kennedy CL. A factor analysis of chronic fatigue symptoms in a community-based sample. [unpublished manuscript].
59 Jason LA, Jordan KM, Richman JA, et al. A community-based study of prolonged fatigue and chronic fatigue. J Health Psychol. 1999;4:9-26.
60 Jason LA, Taylor RR. Applying cluster analysis to define a topology of chronic fatigue syndrome in a medically-evaluated, random community sample. [unpublished manuscript].
61 Jason LA, Richman JA, Rademaker AW, et al. A community-based study of chronic fatigue syndrome. Arch Intern Med. 1999;159:2129-37. [pmid: 10527290].
62 Taylor RR, Jason LA, Jahn SC. Sociodemographic predictors of psychiatric disorder in individuals with and without chronic fatigue. [unpublished manuscript].
63 Friedberg F, Dechene L, McKenzie MJI, Fontanetta R. Symptom patterns in long-duration chronic fatigue syndrome. J Psychosom Res. 2000;48:59-68. [pmid: 10750631].
64 Taylor RR, Jason LA, Schoeny ME. Evaluating latent variable models of functional somatic distress in a community-based sample Journal of Mental Health. [In Press].
65 Hall DG, Sanders SD, Replogle WH. Fatigue: a new approach to an old problem. J Miss State Med Assoc. 1994;35:155-60. [pmid: 8064846].
66 Ray C, Weir WR, Cullen S, Phillips S. Illness perception and symptom components in chronic fatigue syndrome. J Psychosom Res. 1992;36:243-56. [pmid: 1564677].
67 Ray C, Weir WR, Phillips S, Cullen S. Development of a measure of symptoms in chronic fatigue syndrome: the profile of fatigue-related symptoms (PFRS). Psychol Health. 1992;7:27-43.
68 Deary IJ. A taxonomy of medically unexplained symptoms. J Psychosom Res. 1999;47:51-9. [pmid: 10511420].
69 Robbins JM, Kirmayer LJ, Hemami S. Latent variable models of functional somatic distress. J Nerv Ment Dis. 1997;185:606-15. [pmid: 9345250].
70 Van Mens-Verhulst J, Bensing J. Distinguishing between chronic and nonchronic fatigue, the role of gender and age. Soc Sci Med. 1998;47:621-34. [pmid: 9690845].
71 Wessely S, Powell R. Fatigue syndromes: a comparison of chronic “postviral” fatigue with neuromuscular and affective disorders. J Neurol Neurosurg Psychiatry. 1989;52:940-8. [pmid: 2571680].
72 Komaroff AL, Fagioli LR, Geiger AM, et al. An examination of the working case definition of chronic fatigue syndrome. Am J Med. 1996;100:56-64. [pmid: 8579088].
73 Jason LA, Wagner L, Rosenthal S, et al. Estimating the prevalence of chronic fatigue syndrome among nurses. Am J Med. 1998;105:91S-3S. [pmid: 9790488].
74 Jason LA, Taylor SL, Johnson S, Goldston SE. Prevalence of chronic fatigue syndrome-related symptoms among nurses. Eval Health Prof. 1993;16:385-99. [pmid: 10130552].
75 Kipen HM, Hallman W, Kang H, Fiedler N, Natelson BH. Prevalence of chronic fatigue and chemical sensitivities in Gulf Registry Veterans. Arch Environ Health. 1999;54:313-8. [pmid: 10501146].
76 White PD, Thomas JM, Amess J, et al. Incidence, risk and prognosis of acute and chronic fatigue syndromes and psychiatric disorders after glandular fever. Br J Psychiatry. 1998;173:475-81. [pmid: 9926075].
77 Manu P, Lane TJ, Matthews DA. The frequency of the chronic fatigue syndrome in patients with symptoms of persistent fatigue. [published erratum appears in Ann Intern Med 1988 ;109:997]. Ann Intern Med. 1988;109:554-6. [pmid: 3421564].
78 Bazelmans E, Vercoulen JH, Swanink CM, et al. Chronic fatigue syndrome and primary fibromyalgia syndrome as recognized by GPs. Fam Pract. 1999;16:602-4. [pmid: 10625135].
79 Gunn WJ, Connell DB, Randall B. Epidemiology of chronic fatigue syndrome: the Centers for Disease Control Study. Ciba Found Symp. 1993;173:83-93. [pmid: 8387910].
80 Price RK, North CS, Wessely S, Fraser VJ. Estimating the prevalence of chronic fatigue syndrome and associated symptoms in the community. Public Health Rep. 1992;107:514-22. [pmid: 1329134]. [pmcid: 1403692].
81 Steele L, Dobbins JG, Fukuda K, et al. The epidemiology of chronic fatigue in San Francisco. Am J Med. 1998;105:83S-90S. [pmid: 9790487].
82 Kawakami N, Iwata N, Fujihara S, Kitamura T. Prevalence of chronic fatigue syndrome in a community population in Japan. Tohoku J Exp Med. 1998;186:33-41. [pmid: 9915105].
83 Wessely S, Chalder T, Hirsch S, Wallace P, Wright D. The prevalence and morbidity of chronic fatigue and chronic fatigue syndrome: a prospective primary care study. Am J Public Health. 1997;87:1449-55. [pmid: 9314795]. [pmcid: 1380968].
84 Lawrie SM, Manders DN, Geddes JR, Pelosi AJ. A population-based incidence study of chronic fatigue. Psychol Med. 1997;27:343-53. [pmid: 9089827].
85 Lawrie SM, Pelosi AJ. Chronic fatigue syndrome in the community. Prevalence and associations. Br J Psychiatry. 1995;166:793-7. [pmid: 7663830].
86 Jason LA, Taylor R, Wagner L, et al. Estimating rates of chronic fatigue syndrome from a community-based sample: a pilot study. Am J Community Psychol. 1995;23:557-68. [pmid: 8546110].
87 Buchwald D, Umali P, Umali J, Kith P, Pearlman T, Komaroff AL. Chronic fatigue and the chronic fatigue syndrome: prevalence in a Pacific Northwest health care system. Ann Intern Med. 1995;123:81-8. [pmid: 7778839].
88 McDonald E, David AS, Pelosi AJ, Mann AH. Chronic fatigue in primary care attenders. Psychol Med. 1993;23:987-98. [pmid: 8134522].
89 Wagner-Raphael LI, Jason LA, Ferrari JR. Chronic fatigue syndrome, chronic fatigue, and psychiatric disorders: predictors of functional status in a national nursing sample. J Occup Health Psychol. 1999;4:63-71. [pmid: 10100114].
90 Vercoulen JH, Swanink CM, Fennis JF, Galama JM, van der Meer JW, Bleijenberg G. Prognosis in chronic fatigue syndrome: a prospective study on the natural course. J Neurol Neurosurg Psychiatry. 1996;60:489-94. [pmid: 8778251].
91 Bombardier CH, Buchwald D. Chronic fatigue, chronic fatigue syndrome, and fibromyalgia. Disability and health-care use. Med Care. 1996;34:924-30. [pmid: 8792781].
92 Levine PH, Jacobson S, Pocinki AG, et al. Clinical, epidemiologic, and virologic studies in four clusters of the chronic fatigue syndrome. Arch Intern Med. 1992;152:1611-6. [pmid: 1323246].
93 Sharpe M, Hawton K, Seagroatt V, Pasvol G. Follow up of patients presenting with fatigue to an infectious diseases clinic. BMJ. 1992;305:147-52. [pmid: 1515828]. [pmcid: 1883193].
94 Hinds G, McCluskey DR. A retrospective study of the chronic fatigue syndrome. Proc R Coll Physicians Edinburgh. 1993;23:10-4.
95 Anderson JS, Ferrans CE. The quality of life of persons with chronic fatigue syndrome. J Nerv Ment Dis. 1997;185:359-67. [pmid: 9205421].
96 Caffery BE, Josephson JE, Samek MJ. The ocular signs and symptoms of chronic fatigue syndrome. J Am Optom Assoc. 1994;65:187-91. [pmid: 8201170].
97 Gibbons R, Pheby DFH, Richards C, Bray FI. Severe CFS/ME of juvenile onset - A report from the CHROME database. J Chronic Fatigue Syndr. 1998;4:67-80.
98 Green J, Romei J, Natelson BH. Stigma and chronic fatigue syndrome. J Chronic Fatigue Syndr. 1999;5:63-75.
99 Kruesi MJ, Dale J, Straus SE. Psychiatric diagnoses in patients who have chronic fatigue syndrome. [published erratum appears in J Clin Psychiatry 1989;50:148]. J Clin Psychiatry. 1989;50:53-6. [pmid: 2536690].
100 Millon C, Salvato F, Blaney N, Morgan R. A psychological assessment of chronic fatigue syndrome/chronic epstein-barr virus patients. Psychol Health. 1989;3:131-41.
101 Taylor RR, Jason LA. Comparing the DIS with the SCID: chronic fatigue syndrome and psychiatric comorbidity. Psychol Health. 1998;13:1087-104.
102 Hickie I, Koschera A, Hadzi-Pavlovic D, Bennett B, Lloyd A. The temporal stability and co-morbidity of prolonged fatigue: a longitudinal study in primary care. Psychol Med. 1999;29:855-61. [pmid: 10473312].
103 Bombardier CH, Buchwald D. Outcome and prognosis of patients with chronic fatigue vs chronic fatigue syndrome. Arch Intern Med. 1995;155:2105-10. [pmid: 7575071].
104 Bonner D, Ron M, Chalder T, Butler S, Wessely S. Chronic fatigue syndrome: a follow up study. J Neurol Neurosurg Psychiatry. 1994;57:617-21. [pmid: 8201336].
105 Bell IR, Baldwin CM, Schwartz GE. Illness from low levels of environmental chemicals: relevance to chronic fatigue syndrome and fibromyalgia. Am J Med. 1998;105:74S-82S. [pmid: 9790486].
106 Reyes M, Dobbins JG, Nisenbaum R, Subedar NS, Randall B, Reeves WC. Chronic fatigue syndrome progression and self-defined recovery: evidence from the CDC surveillance system. J Chronic Fatigue Syndr. 1999;5:7-17.
107 Tirelli V, Pinto A, Marotta G, et al. Clinical and immunologic study of 205 patients with chronic fatigue syndrome: a case series from Italy. Arch Intern Med. 1993;153:116-7, 120. [pmid: 8422193].
108 Russo J, Katon W, Clark M, Kith P, Sintay M, Buchwald D. Longitudinal changes associated with improvement in chronic fatigue patients. J Psychosom Res. 1998;45:67-76. [pmid: 9720856].
109 Wilson A, Hickie I, Lloyd A, et al. Longitudinal study of outcome of chronic fatigue syndrome. BMJ. 1994;308:756-9. [pmid: 8142830].
110 Ray C, Jefferies S, Weir WRC. Coping and other predictors of outcome in chronic fatigue syndrome: a 1-year follow-up. J Psychosom Res. 1997;43:405-15. [pmid: 9330240].
111 Ray C, Jefferies S, Weir WRC. Life-events and the course of chronic fatigue syndrome. Br J Med Psychol. 1995;68:323-31. [pmid: 8688371].
112 Hartz AJ, Kuhn EM, Bentler SE, Levine PH, London R. Prognostic factors for persons with idiopathic chronic fatigue. Arch Fam Med. 1999;8:495-501. [pmid: 10575388].
113 Gold D, Bowden R, Sixbey J, et al. Chronic fatigue. A prospective clinical and virologic study. JAMA. 1990;264:48-53. [pmid: 2162397].
114 Levine PH, Snow PG, Ranum BA, Paul C, Holmes MJ. Epidemic neuromyasthenia and chronic fatigue syndrome in west Otago, New Zealand. A 10-year follow-up. Arch Intern Med. 1997;157:750-4. [pmid: 9125006].
115 Hill NF, Tiersky LA, Scavalla VR, Lavietes M, Natelson BH. Natural history of severe chronic fatigue syndrome. Arch Phys Med Rehabil. 1999;80:1090-4. [pmid: 10489014].
116 Norregaard J, Bulow PM, Prescott E, Jacobsen S, Danneskiold-Samsoe B. A four-year follow-up study in fibromyalgia. Relationship to chronic fatigue syndrome. Scand J Rheumatol. 1993;22:35-8. [pmid: 8434245].
117 Wessely S, Chalder T, Hirsch S, Pawlikowska T, Wallace P, Wright DJ. Postinfectious fatigue: prospective cohort study in primary care. Lancet. 1995;345:1333-8. [pmid: 7752755].
118 Nisenbaum R, Jones A, Jones J, Reeves W. Longitudinal analysis of symptoms reported by patients with chronic fatigue syndrome. Ann Epidemiol. 2000;10.
119 Clark MR, Katon W, Russo J, Kith P, Sintay M, Buchwald D. Chronic fatigue: risk factors for symptom persistence in a 2 1/2-year follow-up study. Am J Med. 1995;98:187-95. [pmid: 7847436].
120 Rowe KS. Double-blind randomized controlled trial to assess the efficacy of intravenous gammaglobulin for the management of chronic fatigue syndrome in adolescents. J Psychiatr Res. 1997;31:133-47. [pmid: 9201655].
121 Vedhara K, Llewelyn MB, Fox JD, et al. Consequences of live poliovirus vaccine administration in chronic fatigue syndrome. J Neuroimmunol. 1997;75:183-95. [pmid: 9143253].
122 Plioplys AV, Plioplys S. Amantadine and L-carnitine treatment of chronic fatigue syndrome. Neuropsychobiology. 1997;35:16-23. [pmid: 9018019].
123 Goudsmit EM. Learning to cope with post-infectious fatigue syndrome. A follow-up study. In: Goudsmit EM. The Psychological Aspects and Management of Chronic Fatigue Syndrome [dissertation]. Middlesex, England: Brunel University. 1996. [pmcid: 190016].
124 Behan PO, Behan WM, Horrobin D. Effect of high doses of essential fatty acids on the postviral fatigue syndrome. Acta Neurol Scand. 1990;82:209-16. [pmid: 2270749].
125 Martin RWY, Ogston SA, Evans JR. Effects of vitamin and mineral supplementation on symptoms associated with chronic fatigue syndrome with Coxsackie B antibodies. J Nutr Med. 1994;4:11-23.
126 Tiev KP, Cabane J, Imbert JC. [Treatment of chronic postinfectious fatigue: randomized double-blind study of two doses of sulbutiamine (400-600 mg/day) versus placebo]. [French]. Rev Med Interne. 1999;20:912-8. [pmid: 10573727].
127 Straus SE, Dale JK, Tobi M, et al. Acyclovir treatment of the chronic fatigue syndrome. Lack of efficacy in a placebo-controlled trial. N Engl J Med. 1988;319:1692-8. [pmid: 2849717].
128 Kaslow JE, Rucker L, Onishi R. Liver extract-folic acid-cyanocobalamin vs placebo for chronic fatigue syndrome. Arch Intern Med. 1989;149:2501-3. [pmid: 2684076].
129 Lloyd A, Hickie I, Wakefield D, Boughton C, Dwyer J. A double-blind, placebo-controlled trial of intravenous immunoglobulin therapy in patients with chronic fatigue syndrome. Am J Med. 1990;89:561-8. [pmid: 2146875].
130 Peterson PK, Shepard J, Macres M, et al. A controlled trial of intravenous immunoglobulin G in chronic fatigue syndrome. Am J Med. 1990;89:554-60. [pmid: 2239975].
131 Cox IM, Campbell MJ, Dowson D. Red blood cell magnesium and chronic fatigue syndrome. Lancet. 1991;337:757-60. [pmid: 1672392].
132 Lloyd AR, Hickie I, Brockman A, et al. Immunologic and psychologic therapy for patients with chronic fatigue syndrome: a double-blind, placebo-controlled trial. Am J Med. 1993;94:197-203. [pmid: 8430715].
133 Brook MG, Bannister BA, Weir WR. Interferon-alpha therapy for patients with chronic fatigue syndrome. J Infect Dis. 1993;168:791-2. [pmid: 8354926].
134 Friedberg F, Krupp LB. A comparison of cognitive behavioral treatment for chronic fatigue syndrome and primary depression. Clin Infect Dis. 1994;18:105S-10S.
135 Strayer DR, Carter WA, Brodsky I, et al. A controlled clinical trial with a specifically configured RNA drug, poly(I).poly(C12U), in chronic fatigue syndrome. Clin Infect Dis. 1994;18:88S-95S.
136 Natelson BH, Cheu J, Pareja J, Ellis SP, Policastro T, Findley TW. Randomized, double-blind, controlled placebo-phase in trial of low dose phenelzine in the chronic fatigue syndrome. Psychopharmacology. 1996;124:226-30. [pmid: 8740043].
137 Sharpe M, Hawton K, Simkin S, et al. Cognitive behaviour therapy for the chronic fatigue syndrome: a randomized controlled trial. BMJ. 1996;312:22-6. [pmid: 8555852].
138 Steinberg P, McNutt BE, Marshall P, et al. Double-blind placebo-controlled study of the efficacy of oral terfenadine in the treatment of chronic fatigue syndrome. J Allergy Clin Immunol. 1996;97:119-26. [pmid: 8568124].
139 Vercoulen JH, Swanink CM, Zitman FG, et al. Randomised, double-blind, placebo-controlled study of fluoxetine in chronic fatigue syndrome. Lancet. 1996;347:858-61. [pmid: 8622391].
140 See DM, Tilles JG. Alpha-Interferon treatment of patients with chronic fatigue syndrome. Immunol Invest. 1996;25:153-64. [pmid: 8675231].
141 Snorrason E, Geirsson A, Stefansson K. Trial of a selective acetylcholinesterase inhibitor, galanthamine hydrobromide, in the treatment of chronic fatigue syndrome. J Chronic Fatigue Syndr. 1996;2:35-54.
142 Shlaes JL, Jason LA. A buddy/mentor program for PWCs. CFIDS Chronicle. 1996;Winter:21-5.
143 De Vinci C, Levine PH, Pizza G, et al. Lessons from a pilot study of transfer factor in chronic fatigue syndrome. Biotherapy. 1996;9:87-90. [pmid: 8993764].
144 Awdry R. Homeopathy may help ME. Int J Altern Complement Med. 1996;14:12-6.
145 Deale A, Chalder T, Marks I, Wessely S. Cognitive behavior therapy for chronic fatigue syndrome: a randomized controlled trial. Am J Psychiatry. 1997;154:408-14. [pmid: 9054791].
146 Fulcher KY, White PD. Randomised controlled trial of graded exercise in patients with the chronic fatigue syndrome. BMJ. 1997;314:1647-52. [pmid: 9180065].
147 Vollmer-Conna U, Hickie I, Hadzi-Pavlovic D, et al. Intravenous immunoglobulin is ineffective in the treatment of patients with chronic fatigue syndrome. Am J Med. 1997;103:38-43. [pmid: 9236484].
148 Field TM, Sunshine W, Hernandez-Reif M, et al. Massage therapy effects on depression and somatic symptoms in chronic fatigue syndrome. J Chronic Fatigue Syndr. 1997;3:43-51.
149 Peterson PK, Pheley A, Schroeppel J, et al. A preliminary placebo-controlled crossover trial of fludrocortisone for chronic fatigue syndrome. Arch Intern Med. 1998;158:908-14. [pmid: 9570178].
150 McKenzie R, O'Fallon A, Dale J, et al. Low-dose hydrocortisone for treatment of chronic fatigue syndrome: a randomized controlled trial. JAMA. 1998;280:1061-6. [pmid: 9757853].
151 Wearden AJ, Morriss RK, Mullis R, et al. Randomised, double-blind, placebo-controlled treatment trial of fluoxetine and graded exercise for chronic fatigue syndrome [published erratum appears in Br J Psychiatry 1998;173:89]. Br J Psychiatry. 1998;172:485-90. [pmid: 9828987].
152 Natelson BH, Cheu J, Hill N, et al. Single-blind, placebo phase-in trial of two escalating doses of selegiline in the chronic fatigue syndrome. Neuropsychobiology. 1998;37:150-4. [pmid: 9597672].
153 Moorkens G, Wynants H, Abs R. Effect of growth hormone treatment in patients with chronic fatigue syndrome: a preliminary study. Growth Horm IGF Res. 1998;8:131-3. [pmid: 10990148].
154 Perrin RN, Edwards J, Hartley P. An evaluation of the effectiveness of osteopathic treatment on symptoms associated with myalgic encephalomyelitis. A preliminary report. J Med Eng Technol. 1998;22:1-13. [pmid: 9491353].
155 Marlin RG, Anchel H, Gibson JC, Goldberg WM, Swinton M. An evaluation of multidisciplinary intervention for chronic fatigue syndrome with long-term follow-up, and a comparison with untreated controls. Am J Med. 1998;105:110S-4S. [pmid: 9790492].
156 Andersson M, Bagby JR, Dyrehag LE, Gottfries CG. Effects of staphylococcus toxoid vaccine on pain and fatigue in patients with fibromyalgia/chronic fatigue syndrome. Eur J Pain. 1998;2:133-42. [pmid: 10700309].
157 Warren G, McKendrick M, Peet M. The role of essential fatty acids in chronic fatigue syndrome. A case-controlled study of red-cell membrane essential fatty acids (EFA) and a placebo-controlled treatment study with high dose of EFA. Acta Neurol Scand. 1999;99:112-6. [pmid: 10071170].
158 Cleare AJ, Heap E, Malhi GS, Wessely S, O'Keane V, Miell J. Low-dose hydrocortisone in chronic fatigue syndrome: a randomised crossover trial. Lancet. 1999;353:455-8. [pmid: 9989716].
159 Forsyth LM, Preuss HG, MacDowell AL, Chiazze L Jr, Birkmayer GD, Bellanti JA. Therapeutic effects of oral NADH on the symptoms of patients with chronic fatigue syndrome. Ann Allergy Asthma Immunol. 1999;82:185-91. [pmid: 10071523].
160 Rowe PC, Calkins H, DeBusk K, et al. Fludrocortisone acetate to treat neurally mediated hypotension in chronic fatigue syndrome: a randomized controlled trial. JAMA. 2001;285:52-9. [pmid: 11150109].
161 Hickie IB, Wilson AJ, Wright JM, Bennett BK, Wakefield D, Lloyd AR. A randomized, double-blind placebo-controlled trial of moclobemide in patients with chronic fatigue syndrome. J Clin Psychiatry. 2000;61:643-8. [pmid: 11030484].
162 Powell P, Bentall RP, Nye FJ, Edwards RHT. Explanation of symptoms encourages graded exercise and improves prgnosis in chronic fatigue syndrome: a randomised controlled trial. BMJ. [In Press]. [pmcid: 420288].
163 Prins JB, Bleijenberg G, Bazelmans E, et al. Cognitive behaviour therapy for chronic fatigue syndrome: a multicenter randomised controlled trial. Lancet. [In Press].
164 Ridsdale L, Godfrey E, Chalder T, et al. Chronic fatigue in general practice: is counselling as good as cognitive behaviour therapy? A UK randomised trial. Br J Gen Pract. 2001:19-24.
165 Colquhoun D, Senn S. Is NADH effective in the treatment of chronic fatigue syndrome?. Ann Allergy Asthma Immunol. 2000;84:639-40. [pmid: 10875497].
166 Awdry R. Homeopathy and chronic fatigue: the search for proof. Int J Altern Complement Med. 1996;14:12:19-20.
167 McKenzie R, Reynolds JC, O'Fallon A, et al. Decreased bone mineral density during low dose glucocorticoid administration in a randomized, placebo controlled trial. J Rheumatol. 2000;27:2222-6. [pmid: 10990237].
168 Sharpe M, Hawton K, Simkin S, et al. [Cognitive behavior therapy for chronic fatigue syndrome: a randomized controlled study]. [German]. Verhaltenstherapie. 1998;8:118-24.
169 Deale A, Chalder T, Wessely S. Illness beliefs and treatment outcome in chronic fatigue syndrome. J Psychosom Res. 1998;45:77-83. [pmid: 9720857].
170 Deale A, Husain K., Chalder T, Wessely S. Long term outcome of cognitive behaviour therapy versus relaxation for chronic fatigue syndrome: a 5-year follow-up study. [unpublished manuscript].