# Future Research

The technical experts and peer reviewers identified the following questions as particularly high priority for future research related to CFS.

- How should CFS be defined such that the definition is reliable, valid, discriminatory from related conditions, and acceptable to both the lay and scientific community?
- What is the pathogenesis of CFS? Does it result from single or multiple etiologies? Can CFS be predicted in people exposed to particular physical and/or psychological challenges?
- What are valid biomarkers that are helpful in recognizing CFS?
- What disorders frequently mimic CFS and what is the most efficient approach to identify these disorders?
- How can persons with CFS be subdivided into homogeneous rather than heterogeneous groups to facilitate elucidation of underlying etiologic and pathophysiologic mechanisms?
- Are the psychiatric and neurologic conditions frequently reported in CFS a result of CFS or are an underlying, predisposing factor to developing CFS? How do the psychological and physical manifestations of CFS interact?
- What is the spectrum of the severity of functional impairment associated with CFS? How much disability is associated with CFS?
- What is the long-term natural history of CFS, as determined by large, longitudinal cohort studies that include people representative of the entire spectrum of CFS? Does natural history vary by gender or age?
- What are effective treatments for CFS, as determined by replicable randomized controlled trials with adequate numbers of participants and measurement of appropriate outcomes and adequate followup? Are therapies borrowed from related fields (e.g. sleep medicine, autonomic nervous system abnormalities, endocrinology, gastrointestinal illness, neurocognitive therapy) applicable to treatment of CFS? Does response to treatment vary by duration of illness?
- What is the comparative efficacy of cognitive behavioral therapy versus exercise therapy for people with CFS? What predicts response to either one of these therapies?
- Can reliable, standardized outcome measures that assess degree of severity and a comprehensive range of symptoms, and that are sensitive to changes in illness status be developed? Can standardized definitions of outcomes such as recovery and improvement be developed?