# Conclusions

- There were four well-recognized case definitions of CFS. The CDC is currently spearheading development of a fifth definition. Definitions have been developed primarily by expert consensus processes and have evolved over time. A few studies support the concept of a condition that is captured by the case definitions. The superiority of one case definition over another is not established. Moreover, the validity of any of the definitions is difficult to establish because there are no clear biologic markers for CFS and no effective treatments that are specific only to CFS have been identified.
- Surveys that have involved more than 100 participants showed the prevalence of CFS in community populations was less than 1% in the community. Prevalence rates reported in surveys in primary care populations ranged from approximately 0.04% to 2.6%. Our ability to interpret the reliability of these finding was limited by the following factors: use of different case definitions, variability in assessment and reporting methods, and poor response rates in the community studies.
- Prospective natural history studies had varied findings. Precise estimates of recovery, improvement, and/or relapse were not possible because of the following: few studies, selected referral populations, varied definitions of CFS, and differences in followup methods.
- Thirty-eight controlled trials evaluated multiple interventions and had mixed results.

## Immunologic Therapy

Nine placebo-controlled trials, one trial with a no-treatment control group, and one 4-arm trial that assessed immunologic therapy with and without cognitive behavioral therapy were reviewed. These 11 trials involved a total of 515 adult patients. None had more than 100 participants. Followup duration ranged from 2 to 7 months; dropout rates ranged from 2% to 13%. Immunologic therapies that were assessed included agents such as immunoglobulin, Ampligen, Acyclovir, interferon, and transfer factor. The three randomized placebo-controlled trials that evaluated immunoglobulin showed mixed results: one found general improvement with immunoglobulin, another found worse social functioning with immunoglobulin, and another found no differences between immunoglobulin and placebo. A single randomized placebo-controlled trial found twice weekly infusions of intravenous Ampligen, an agent with immunomodulatory and antiviral effects, improved physical functioning, activity level, and cognitive functioning and did not affect depression or anxiety. This high quality double-blind trial included 92 severely debilitated patients who met the 1988 CDC definition for CFS. It had a 6-month followup period and a 9% dropout rate. Participants given Ampligen had more complaints of dry skin, and participants given placebo had more complaints of insomnia. A single randomized trial found Acyclovir, an antiviral agent, increased depression, anxiety and confusion compared to placebo. A single randomized 4-arm trial found improved quality of life when transfer factor was combined with CBT compared to either therapy alone. Placebo-controlled trials that evaluated other immunologic therapies (e.g., interferon) were inconclusive. In sum, evidence from trials involving immunologic therapies was relatively scant and insufficient to conclude whether these treatments were effective or ineffective. Results regarding intravenous Ampligen, an investigational drug that is not approved by the Food and Drug Administration, in severely debilitated patients were the most promising.

## Corticosteroids

Two short-term (less than 3 months) double-blind placebo-controlled randomized trials involving 125 adults showed no benefit of mineralocorticoids (fludrocortisone) in improving general and/or functional outcomes. One of these two trials was restricted to CFS patients with neurally mediated hypotension. Two short-term (less than 3 months) double-blind placebo-controlled randomized trials involving 105 adults found low dose glucocorticoids (hydrocortisone) may improve fatigue and functioning, but at the expense of potentially dangerous suppression of adrenal function. Dropout rates in these trials ranged from 9% to 20%. In sum, evidence from these trials was scant and insufficient to conclude whether corticosteroids were effective or ineffective for CFS, but there is some evidence of harm from glucocorticoid therapy.

## Antidepressants

There were five placebo-controlled trials, involving 382 participants, that evaluated effects of antidepressants in adults with CFS. Four were randomized trials. Followup duration ranged from six weeks to six months; dropout rates ranged from 10% to 29%. Two of the five studies excluded participants with depression, while three involved mixed populations, including participants with depression. One of the randomized trials was a 4-arm trial that compared effects of an antidepressant with and without graded exercise therapy. Compared to placebo, antidepressants alone and antidepressants plus exercise showed no consistent patterns of improvement, though occasional improvements were found in some symptoms, such as increased vigor and less anxiety.

## Behavioral interventions

There were six controlled trials involving 597 adults that evaluated some form of cognitive behavioral therapy (CBT). Five were randomized trials. One of the randomized trials was a 4-arm trial that evaluated effects of CBT with and without an immunologic therapy, transfer factor. In the five randomized controlled trials, CBT was compared to an attention placebo, relaxation, guided support, counseling, and standard medical care. Trained therapists delivered CBT. Numbers of CBT sessions ranged from 6 to 16 over a period of 6 weeks to 8 months. Dropout rates at end of treatment periods ranged from 0 to 18%. Followup observations after completion of treatment sessions, ranged from 1 month to 5 years. Content of CBT sessions emphasized increasing activity and exercise, examination of psychosocial issues, and explanations of illness. Of note, although the investigators in the non-randomized trial labeled their intervention CBT, this intervention focused on coping skills and making lifestyle changes consistent with activity limitations imposed by CFS. The comparison group in the nonrandomized trial was no therapy. The randomized trial that compared CBT with counseling and the nonrandomized trial that compared “CBT” with no treatment found no differences in outcomes between groups. Randomized trials that compared CBT with standard care, relaxation, and guided support found CBT decreased fatigue and improved functional status or quality of life.

There were three randomized trials involving 350 adults that evaluated an intervention other than formal CBT that focused on increasing activity and exercise. In one, 12 weekly sessions of graded exercise therapy delivered by an exercise physiologist was compared to flexibility and relaxation therapy. The dropout rate was 29%. Participants assigned to exercise therapy had greater overall improvement, decreased fatigue symptoms and increased physical functioning compared to participants given flexibility and relaxation therapy. In the second trial, effects of graded exercise therapy delivered by a physiotherapist (8 sessions over 6 months) with and without anti-depressants were evaluated. The dropout rate at the end of treatment was 29%. No differences between groups in outcomes were found. The third randomized trial was a 4-arm trial that compared three different intensities of education aimed at encouraging graded home exercise programs with standard care. The interventions in this trial lasted for 3 to 4 months and included instructions for participants to examine predisposing and perpetuating psychosocial factors and causal explanations of illness. These interventions were described as briefer than formal CBT and were not delivered by trained CBT therapists. The dropout rate was 14%. Participants assigned to any of the educational interventions had greater overall improvement, decreased fatigue symptoms and increased physical functioning compared to standard care. No differences between the three intervention groups were found.

In sum, behavioral therapies that emphasize increasing activity and physical exercise have generally resulted in decreased symptoms of fatigue and improvements in functional status and quality of life. Whether formal and comprehensive CBT delivered by experienced therapists is superior to graded exercise programs alone is not clear. Also, it is unlikely that the beneficial effects of such general treatments are specific or limited only to patients with CFS. In other words, although these therapies may help some people with CFS, their effectiveness does not help establish an underlying etiology or cause of CFS.

## Other pharmacological agents or supplements

One small randomized, double-blind placebo-controlled trial involving 32 adults who are magnesium-deficient, found intramuscular magnesium sulfate given weekly for six weeks improved overall wellness and energy and reduced pain and distress. One small double-blind placebo-controlled trial in 35 adults found oral nicotinamide adenine dinucleotide given daily for four weeks improved general well-being. Small short-term trials evaluating galanthamine, growth hormone, essential fatty acids, and liver extract provided insufficient evidence to conclude whether these therapies were or were not effective in improving symptoms or functional outcomes.

## Complementary therapies

One small, placebo-controlled randomized trial of homeopathy in 64 adults was inconclusive. One small, randomized trial in 20 adults found massage therapy led to improvements in fatigue, sleep, myalgia, depression and anxiety compared to sham transcutaneous electrical nerve stimulation. One non-randomized trial in 80 adults found osteopathic therapy improved general health compared to normal care.

Existing case definitions for CFS appear to characterize a distinct group of patients with fatigue; however, the validity and superiority of any particular case definition is not well established. Surveys examining the prevalence of CFS suggest community prevalence rates less than 1%. Available studies do not provide precise or reliable estimates of recovery from CFS. Although several therapies for CFS have been evaluated in controlled trials, we have limited ability to either rule in or rule out benefits of most therapies due to problems in trial designs, such as small sample sizes and short followup duration. Behavioral interventions aimed at increasing activity levels have consistently improved quality of life and functional status outcomes; even though behavioral interventions appear to help patients cope with their condition, beneficial effects of such therapies are likely not specific to chronic fatigue syndrome.