# Results

## Question 1. What are the Existing Case Definitions for Chronic Fatigue Syndrome?

In 1988 Holmes et al. published the first case definition for CFS in the mainstream peer reviewed medical literature. The Centers for Disease Control and Prevention (CDC) adopted this definition. To meet this definition, patients had to present with new onset of persistent or relapsing, debilitating fatigue or easy fatigability with no previous history of similar symptoms. The fatigue could not be alleviated by bed rest, and had to impair daily activity below 50% of premorbid activity for at least 6 months. Eight or more of 11 minor symptom criteria had to be met. Other medical and psychiatric conditions that produced similar symptoms by proper history, exam, and laboratory analysis had to be excluded. Symptoms must have occurred at or after the onset of fatigue and have continued or been recurrent for at least 6 months.

Symptom criteria included: 1) mild fever or chills, 2) sore throat, 3) painful lymph nodes, 4) unexplained generalized muscle weakness, 5) myalgia, 6) post-exertional fatigue (lasting more than 24 hrs), 7) new onset generalized headaches, 8) migratory arthralgia without joint swelling or redness, 9) neuropsychiatric complaints (one or more of the following: photophobia, forgetfulness, excessive irritability, confusion, difficulty in thinking or concentrating, depression), 10) sleep disturbance (hypersomnia or insomnia), and 11) acute onset (over a few hours to a few days) of main symptom complex. To count, physical criteria had to be documented by a physician on at least two occasions, at least one month apart. Physical criteria included: 1) low grade fever, 2) nonexudative pharyngitis, and 3) palpable or tender anterior posterior cervical or axillary lymph nodes.

Australian and British working case definitions for CFS were developed in the early 1990s. Several Australian definitions were proposed. One of the most widely referenced definitions was used and reported by Lloyd et al.^22^ These criteria required the following for a diagnosis of CFS: 1) chronic persisting or relapsing fatigue of a generalized nature for greater than 6 months that is exacerbated by minor exercise and that causes significant disruption of usual daily activities, 2) neuropsychiatric dysfunction including impairment of concentration evidenced by difficulty in completing mental tasks which were easily accomplished before the onset of the syndrome and new onset of short-term memory impairment, and 3) no alternative diagnosis found by history or physical exam over a six-month period. Persons with a previous history of psychosis were excluded from the accepted cases.

In 1991, Sharpe, Wessely and White along with a multidisciplinary group of CFS researchers proposed a set of criteria known as the Oxford or British criteria.^23^ Their case definition required a minimum duration of six months of fatigue that had a definite onset and that was associated with functional impairment. As with the Australian definition, psychiatric illness was not an exclusion criterion, except in the instance of either substance abuse or psychosis. They defined multiple associated symptoms, such as myalgia, mood disturbance, and sleep disturbance. Post-infectious fatigue was listed as a subcategory of CFS with identical features occurring after a known infective episode.

Schluederberg et al. suggested a refinement to the 1988 CDC definition in 1992.^24^ The proposed refinement was based on proposed changes discussed at a 1991 National Institute of Allergy and Infectious Diseases/National Institute of Mental Health workshop. The proposed changes were that a diagnosis of CFS could be made only excluding: 1) specific psychiatric disorders (psychotic depression, bipolar disorder, and schizophrenia); 2) substance abuse; and 3) specific infectious diseases (e.g., chronic active hepatitis, HIV infection). Additionally, the proposed changes allowed for a diagnosis of CFS co-existing with the following: 1) fibromyalgia; 2) etiologically known, treatable infectious diseases that have resolved in terms of their acute clinical and laboratory features, but in whom fatigue and other subjective complaints persist despite appropriate therapy; 3) non-psychotic depression, either concurrent, 1 month post-onset or 6 months or more before onset; and 4) panic, generalized anxiety, or somatoform disorders. Many of these suggestions were incorporated into the 1994 CDC definition that is described below.

In 1994, a second CDC definition was proposed by an international collaborative group that included authors of the 1988 CDC, 1990 Australian, and 1991 British definitions.^25^ This definition was developed in response to critiques that the original Holmes' CDC definition limited the number of CFS cases diagnosed because of its strict exclusion of patients with histories of psychiatric complaints. The revised 1994 definition did not consider all psychiatric disorders, such as anxiety disorders and less severe forms of depression, as exclusionary diagnoses for CFS. Specifically, the 1994 definition does not exclude anxiety disorders and less severe forms of depression, but does exclude substance abuse, eating disorders, dementia and psychosis including psychotic depression. Other changes included eliminating all physical signs from the inclusion criteria, decreasing the number of required symptoms from 8 to 4, and limiting the list of symptoms to 8 from 11.

Table 1 displays features of both CDC case definitions and of the Australian and Oxford definitions. All definitions require the presence of prolonged disabling fatigue for at least six months. In addition, the Australian and Oxford definitions require the presence of mental fatigue or mild cognitive impairment. All four of the case definitions require the exclusion of explanatory medical illnesses, though they differ in the extent to which medical conditions should be sought and ruled out. Finally, all four of the case definitions require the exclusion of some psychiatric conditions, with the 1988 CDC criteria being the most restrictive as it excluded persons with multiple newly diagnosed or historical psychiatric conditions.

Table 1. Case definitions of CFS

Criteria | CDC-1988 | CDC-1994 | Australian 1990 | UK/Oxford-1991
Minimum duration (months) | 6 | 6 | 6 | 6
Functional impairment | 50% decrease in activity | Substantial | Significant disruption of usual activities | Disabling
Cognitive or neuropsychiatric symptoms | May be present | May be present | Required | Mental fatigue required
Other symptoms | 8 required | 4 required | Not specified | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Neuropsychologic complaints (one or more of the following: photophobia, transient visual scotomata, forgetfulness, excessive irritability, confusion, difficulty thinking, inability to concentrate, depression) | Substantial impairment in short-term memory or concentration | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Sore throat | Sore throat | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Painful lymph nodes in the anterior or posterior cervical or axillary distribution | Tender lymph nodes | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Muscle discomfort or myalgia | Muscle pain | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Migratory arthralgia without joint swelling or redness | Multi-joint pain without swelling or redness | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Generalized headaches (of a type, severity, or pattern that is different from headaches the patient may have had in the premorbid state) | Headaches of a new type, pattern or severity | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Sleep disturbance | Unrefreshing sleep | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Prolonged (24 hours or greater) generalized fatigue from levels of exercise that would have been easily tolerated in the patient's premorbid state | Post-exertional malaise lasting more than 24 hours. | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Mild fever or chills | | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Unexplained generalized muscle weakness | | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
Other symptoms | Description of the main symptom complex as initially developing over a few hours to a few days | | | Not required, but other symptoms may be present, particularly myalgia, mood and sleep disturbance
New onset | Required | Required | Not required | Required
Medical exclusions | Extensive list of known physical causes | Clinically important | Known physical causes | Known physical causes
Psychiatric exclusions | New onset or history of: anxiety disorder, depressive disorder including endogenous depression and bipolar disorder, schizophrenia, substance abuse | Melancholic (severe, major) or psychotic depression, substance abuse, bipolar disorders, eating disorder, schizophrenia, dementia, delusional disorders | Psychosis, bipolar disorder, substance abuse, eating disorder | Psychosis, bipolar disorder, eating disorder, organic brain disease

Studies that have evaluated the validity of different definitions and manifestations of fatigue are described under the question entitled, “Which case definitions, if any, have been substantiated or validated with reliably discriminating constellations of symptoms?” Of note, existing case definitions have been developed primarily using expert opinion and/or expert consensus processes. None have been well validated. The CDC is spearheading ongoing efforts to continuously refine the definition of CFS; a newly refined case definition is expected in 2001 (personal communication).

## Question 2. Which Case Definitions, if any, Have Been Substantiated or Validated with Reliably Discriminating Constellations of Symptoms?

### General Overview of Studies

In 29 studies, authors compared symptoms between CFS patients and healthy participants, CFS and depressed patients, or CFS and multiple sclerosis patients.^26-41,41-53^ In 12 reports, authors used multivariate methods to identify groupings of clinical manifestations that might distinguish CFS.^52,54-64^ Multivariate techniques that were used included: cluster analysis, principal component analysis, latent class analysis, logistic regression analysis, factor analysis, discriminant analysis and structural equation modeling. Definitions of these techniques are provided in the glossary. Several studies that used similar comparison or multivariate techniques were excluded because they did not clearly study patients who met one of the prespecified definitions of CFS.^65-71^

### Simple Group Comparison Studies

The 30 studies that compared frequencies of specific symptoms among different groups of patients are summarized in Table 4. The table lists studies according to the definition of CFS that was used. It tabulates study results regarding the predominant symptoms that are listed in the various case definitions, and shows comparisons between CFS patients and other groups.

Table 4. Examples of reported prevalence of chronic fatigue syndrome among large community and primary care populations

Study | Sample | Criteria | Ascertainment | Prevalence
Jason^61^ 1999 Chicago N = 28,673 | Community Response rate: 65% for initial telephone screen; 41% of persons with CFS-like symptoms completed physician examination | CDC 1994 | Self-reported symptoms followed by physician examination | 0.42 %
Steele^81^ 1998 San Francisco N = 16,970 | Community Response rate: 87% | CDC 1994 | Self-report | 0.08 to 0.2%
Kawakami^82^ 1998 Japan N = 508 | Community Response rate: 27% | CDC 1988 Oxford Australian | Self-report | 0% 1.5% 1.5%
Wessely^83^ 1997 Britain N = 2,376 | Primary care Response rate: 83% | CDC 1988 CDC 1994 Oxford Australian | Self-report** | 1.2% 2.6% 2.2% 1.4%
Lawrie^84^ 1997 Scotland N = 695 | Community Response rate: 78% | Oxford | Self-report | 0.7% (0.4% 1yr incidence)
Lawrie^85^ 1995 Scotland N= 1,039 | Community Response rate: 71% | Oxford | Self-report | 0.6%
Jason^86^ 1995 Chicago n = 1,031 | Community Response rate: 89% | CDC 1988 CDC 1994 Oxford Australian | Interviews and medical records | 0.1% 0.1% 0.2% 0.2%
Buchwald^87^ 1995 Seattle N = 4,000 | Health maintenance organization roster Response rate: 77% | CDC 1988 | Self-report | 0.1 to 0.3%
McDonald^88^ 1993 Britain N = 686 | Primary care Response rate: not reported; 1071 questionnaires completed from all adults of a 7500 patient population | Oxford | Self-report | 2.5%
Gunn^79^ 1993 US N = 590 | Surveillance referrals to CDC Response rate: 57% | CDC 1988 | Referral by physicians | 0.004 to 0.01%
Bates^5^ 1993 US N = 1,000 | Primary care Response rate: 99% | CDC 1988 Oxford Australian | Self-report | 0.3% 0.4% 1%
Price^80^ 1992 US N = 13,538 | Community (ECA) Response rate: 75% | CDC 1988* | Self-report | 0.007%
Lloyd^22^ 1990 Australia N = 104 practitioners N = 500 CFS patients | Surveillance referrals from general practitioners Response rate: 98% | Australian | Practitioner-report | 0.04%

* Retrospective assessment of only 7 of 11 minor symptoms

** Physical findings were not included for CDC 1988 definitioN

There are several problems with the studies that compare symptoms among groups of patients. First, participants with CFS in these studies were chosen because they met criteria for one of the four definitions of CFS. This results in incorporation bias, whereby “common symptoms” of CFS are bound to occur at a much higher frequency than in unselected samples. Second, many of the studies involved only referred patients who were followed in specialty clinics. Third, studies used different definitions and instruments to measure the same symptom(s). Fourth, not all studies evaluated the same symptoms. Even if measured, the authors may have only reported the symptoms that showed significant differences between groups.

The authors most commonly reported the following: functional status, fatigue, concentration ability, and depressive symptoms. Compared to healthy participants as well as patients with multiple sclerosis, participants with CFS almost always had greater impaired function, more problems with concentration, more depressive symptoms and greater fatigue. Compared to depressed participants, study participants with CFS generally had greater impaired function and more somatic symptoms, but fewer depressive symptoms.

In one study, Komaroff examined the adequacy of the CDC 1988 case definition and the frequency of 11 minor symptoms in patients with CFS compared to patients with multiple sclerosis or depression.^72^ He found that 92% of the patients with CFS had at least 8 minor symptoms. Symptoms that commonly occurred in all three groups of patients were muscle weakness, arthralgia and sleep disturbance. Symptoms that appeared more unique to patients with CFS that were not listed in the CDC 1988 definition were anorexia and nausea.

### Multivariate Classification Studies

Of 12 reports that used multivariate techniques to help distinguish groups of patients, 3 examined very focused or limited dimensions of CFS, ^52,54,57^ 3 characterized subgroups of patients with CFS, ^56,60,63^ and 8 evaluated multiple dimensions of CFS (Table 5).^55,58-64^

Table 5. Prospective studies with one-year or greater followup data on outcomes of CFS

Study | Participants (Age and illness duration in years) | Diagnostic Criteria and Followup | Baseline Measures | Followup Measures
Reyes^106^ 1999 N = 155 | 155 adults from CDC surveillance system Women: 85% White: 97% Median illness: 4.4 | CDC 1988 Followup: 91% Median followup time: 5.9 yrs | | Cumulative probability of recovery at 5 yrs: 31% and at 10 yrs 48% 57% of patients reporting recovery continued to feel recovered 6 months later
Russo^108,119^ 1998 US N = 98 | 98 adults from referral CFS clinic Women: not given Avg. age: 40 Avg. illness: 5.5 | CDC 1988 Followup: 80% Average followup time: 2.5 yrs | 1. Health perceptions 6.37 + 12.84; 2. Physical functioning 36.98 + 30.21; 3. Role functioning 23.16 + 35.17; 4. Mental health 51.14 + 21.74; 5. General health questionnaire 12.67 + 7.86; 6. Modified symptom questionnaire 4.22 + 4.47 | 1. 12.68 + 18.59^*^; 2. 39.08 + 33.17; 3. 27.57 + 38.67; 4. 62.63 + 21.95*; 5. 7.98 + 7.71^*^; 6. 2.74 + 2.90^**^; ^*^Significant improvement, p < .001 ^**^p < .01 Predictors of improvement: younger age, fewer physical signs, and lower (worse) initial scores on mental health and general health questionnaire. 41% improved or recovered 69% no change or worse
Ray^110,111^ 1997,1995 Britain N = 137 | 137 adults from a hospital out-patient clinic Women: 70% Avg. age: 37 Mean illness: 3.4 | Oxford plus fatigue precipitated by minimal exertion Followup: 88% Followup time: 1 yr | Fatigue score 4.03 + 1.14 Impairment score 22.47 + 5.83 | 3.34 + 1.35^*^ 20.12 + 7.25^*^ ^*^Significant improvement, p < 0.001 64% improved 15% worsened 21% unchanged Poorer outcomes were predicted by illness duration, subjective cognitive impairment, and somatic symptoms and not by anxiety, depression, or general emotional distress.
Vercoulen^90^ 1996 Netherlands N = 246 | 298 “self-referred” adults Women: 76% Avg. age: 39 Mean illness: 8.4 | Oxford Followup: 83% Followup time: 1.5 yrs | 57% employed | 29% employed 3% recovered 17% improved 60% unchanged 20% worse Improvement was positively predicted by sense of control over symptoms, lower fatigue severity
Bombardier^103,91^ 1995 N = 445 | 226 adults from referral CFS clinic Women: 84% Avg. age: 38 Avg. illness 5 | CDC 1988 with Schluederberg modification Followup: 89% Followup time: 1.5 yrs | 37% unemployed 27% part time | 61% some improvement 46% continued to meet symptom criteria for CFS 35% unemployed 19% part time Dysthymia reported at initial interview predicted overall less improvement
Wilson^109^ 1994 Australia N = 139 | 103 adults previously enrolled in treatment trials (immunoglobulin, leukocyte extract, cognitive behavior) Women: 72% Avg. age: 41 Mean illness: 5.6 y | Australian Followup: 74% Mean followup time: 3.2 yrs | | 6% recovered 63% improved 30% unable to work 25% receiving disability 20% no physical activity 39% no social activity mean Karnofsky score 76.3 + 8.8
Tirelli^107^ 1993 Italy N = 205 | 205 adults Setting: unclear Women: 61% Median age: 33 Median illness: 3 | CDC 1988 Followup: unclear Followup time: 1 yr | | 1 yr followup 2% no symptoms 9% substantial resolution 89% persistent symptoms

#### Studies that examined limited dimensions of CFS

Fischler compared sleep patterns between 49 patients who met the Oxford criteria for CFS with sleep patterns of 20 healthy participants.^52^ Sleep initiation and sleep maintenance disturbances were commonly observed among CFS patients and not among healthy participants. Using discriminant analysis, the authors showed that sleep disturbances correctly classified most of the patients with CFS.

Blakely^54^ used discriminant analysis to investigate the psychological characteristics of patients with chronic fatigue syndrome. Forty-two patients with CFS as defined by the 1988 CDC case definition were compared to 39 patients with chronic pain and 72 healthy participants. There was considerable overlap in psychological symptoms between patients with CFS and patients with chronic pain; approximately one-fourth of the patients in these groups had similar psychological profiles. There was less overlap between patients with CFS and healthy participants; approximately 90% of the healthy participants had psychological profiles that were distinct from patients with CFS or chronic pain.

Vercoulen studied 51 patients who met Oxford criteria for CFS and 50 patients with multiple sclerosis.^57^ He used structural equation modeling to explore a hypothesized model in which behavioral, cognitive, and affective factors might play a role in perpetuating fatigue. He found positive associations between cognitive and behavioral factors and the persistence of fatigue.

The three studies described above had multiple problems that limit their generalizability.^52,54,57^ They involved relatively small selected study samples and focused on limited aspects of CFS. As such, their results must be considered exploratory.

#### Study that examined subgroups of patients with CFS

Hickie evaluated 565 patients who met Australian criteria for CFS.^56^ Self-reported symptoms, depression, course of illness, impact of illness on social and occupational functioning, illness behavior and general health status were assessed. Using latent variable models, two groups of patients with CFS were identified. One group of patients (27% of the sample) frequently reported multiple severe symptoms, such as fatigue, headache, inability to concentrate, disturbed sleep and memory, joint and muscle pain, nausea, and palpitations. The other larger group of patients (73% of the sample) reported fewer and less severe symptoms. This latter, larger group was characterized by a greater proportion of men (33% v 18%), shorter duration of illness (5.9 v 8.3 years), less severe course of illness (61% v 80%), lower current psychiatric morbidity, fewer medical consultations (14.3 v 19.9 visits previous 12 months), less disability (49% v 60% currently unemployed; 23% v 38% receiving disability benefits; and 1.5% v 7.4% housebound), and less previous treatment with antidepressants (35% v 48%).

#### Studies that evaluated multiple dimensions of CFS

Vercoulen studied 298 self-referred patients with CFS who met Oxford criteria.^55^ Participants completed a battery of functional status and general well-being instruments that included the following: the Checklist Individual Strength-CIS, self-reported complaints, the Beck Depression Inventory, the Sickness Impact Profile-SIP, the CIS Activity subscale, the Multidimensional Health Locus of Control, the SIP social life subscale, and the Symptom Checklist-SCL90 sleep problems subscale. Using principal component factor analysis, the authors identified nine dimensions of manifestations that characterized patients with CFS. The nine dimensions were psychological well-being, functional impairment in daily life, sleep disturbances, avoidance behavior, concentration problems, causal attributions related to the complaints, social functioning, and self-efficacy expectations, and subjective experience.

Friedberg^63^ evaluated symptom patterns in CFS patients who had been ill for 10 or more years using principal component analysis. The 286 CFS patients had been diagnosed using the 1994 CDC case definition and were compared to 179 healthy controls (spouses/partners/significant others). The factor analysis resulted in three conceptually distinct dimensions with one factor, cognitive problems, accounting for 30% of the variance. The other two factors were flu-like symptoms (6.4% of the variance) and neurologic symptoms (4.1% of the variance).

There were a series of reports based on a single, large, unselected, random community sample. ^58-62,64^ These studies examined multiple dimensions of CFS, rigorously assessed a comprehensive set of symptoms, and attempted to determine the diagnostic validity of the 1994 CDC criteria. Of 28,673 people who were called, 18,675 (65%) completed the study interview. Of these, 780 individuals reported chronic fatigue. They were classified into three subgroups: 408 CFS-like individuals (self-reported chronic fatigue with at least 4 of the CDC 1994 symptoms); 304 ICF-like individuals (idiopathic chronic fatigue); and 68 CF-explained-like individuals (chronic fatigue explained by medical or psychiatric conditions).

A principal component analysis resulted in a four-factor solution that explained 38% of the total variance. The four components were lack of energy, physical exertion, cognitive functioning, and fatigue and rest. Scores on these four components differed significantly among the three subgroups of patients (i.e., CFS-like, ICF-like, CF-explained) differed significantly. The CFS-like and the CF-explained-like groups had more severe lack of energy, exhibited more severe fatigue following physical exertion, and demonstrated more severe cognitive problems than the ICF-like group. The CFS-like group reported higher fatigue following rest or sleep compared to the ICF-like group that reported less severe fatigue.

In a followup analysis of 166 of the 408 CFS-like individuals who agreed to a structured psychiatric interview and a complete physical exam, individuals were reclassified as chronic fatigue syndrome (CFS), idiopathic chronic fatigue (ICF), chronic fatigue explained by a medical condition (CFM) or chronic fatigue explained by a psychiatric condition (CFP).^61^ The characteristics of the patients' fatigue fell into three clusters: 1) relatively low post-exertional fatigue; 2) most severe post-exertional fatigue and most improvement in fatigue following rest; and 3) high post-exertional fatigue and fatigue not alleviated by rest. The majority of patients with CFS (69%) fell into cluster 3.

Jason and colleagues conducted additional analyses to evaluate the diagnostic validity of somatic symptoms associated with five functional somatic syndromes: CFS, fibromyalgia, irritable bowel syndrome, depression, and anxiety.^64^ Confirmatory factor analysis on 21 symptoms yielded a five-factor solution that specifically distinguished the five functional somatic symptoms from one another. The factor grouping for CFS included chronic fatigue, sore throat, lymph node pain, post-exertional malaise, memory/concentration problems, and unrefreshing sleep. The five-factor solution had reasonably good fit for the data. In contrast, a confirmatory factor analysis that tested the proposition that all five disorders represent a single underlying functional somatic distress syndrome did not fit the data well. Logistic regression showed that only the CFS symptom factor was significantly associated with actual CFS diagnosis as determined by two independent physicians.

### Summary

The evidence that substantiates the existing case-definitions of CFS is limited. Investigations have been limited because there are no definitive biological markers that can be used to independently establish a diagnosis. Studies that compare findings in patients with CFS with findings in healthy individuals or patients with other conditions do not provide an adequate basis for validation of any particular case-definitions. They are severely limited because most of them have selected patients based on a case definition that often includes symptoms or findings that are then compared. Few studies have involved large unselected populations or used comprehensive assessment methods to evaluate whether a distinct group of findings characterize and differentiate CFS from other conditions. As the scope of this review was limited to studies that used an existing case definition of CFS, some high quality studies that differentiate characteristics of patients with unexplained fatigue may have been missed. Regardless, one large community study that was reviewed suggested that there are some characteristics that likely distinguish CFS.^59^ These are post-exertional fatigue not alleviated by rest and a cluster of symptoms that include chronic fatigue, sore throat, lymph node pain, post-exertional malaise, memory/concentration problems, and unrefreshing sleep. These characteristics are included in existing case definitions. However, no studies have established the superiority of one existing case definition over another.

## Question 3. What are the Prevalence and Natural History of Chronic Fatigue Syndrome?

### Prevalence

Several factors influence the reported prevalence of chronic fatigue syndrome including the following:

the definition or criteria that are used for diagnosis;

the relative intensity of methods used to exclude other medical and/or psychiatric conditions;

the method (e.g., self-report, physician report, chart review) of ascertainment;

the time course of ascertainment (e.g., retrospective, prospective);

the type of population that is studied (e.g., community, clinic);

the sampling method (e.g., random, consecutive, referred, volunteers); and

the response rate of the population that is studied.

In general, more restrictive definitions of chronic fatigue syndrome, such as those that exclude concomitant psychiatric diagnoses, require longer duration of fatigue, and/or demand that multiple other medical illnesses have been excluded, lead to lower estimates of prevalence compared to less restrictive definitions. In general, community populations have lower prevalence of illness and disease than clinic or hospital populations. However, conditions that are particularly mild, under-recognized, not accepted/addressed by the medical care system, or perceived as stigmatizing for social or financial reasons could conceivably be as or more common in community than clinical populations.

We show several examples of prevalence estimates of chronic fatigue syndrome that have been published since 1990 in Table 2. Studies that addressed prevalence in special populations, such as nurses, Gulf War veterans, and patients with infections or known fatigue are not reviewed.^73-77^ Studies in which physicians relied on their memories to estimate numbers of patients with CFS that they were caring for also were not reviewed.^78^

Table 2. Simple group comparison studies on CFS case-defining symptoms

Case Definition | Author | FUNC | FATG | MLSE | THRO | LYMP | MUSC | JOIN | HEAD | SLEP | MEMR | CONC | FEVR | WEAK | DEPR
CFS vs. Healthy Controls
CDC 1988 | Komaroff^72^ 1996 | | | x | x | x | x | x | x | x | x | x | x | x | x
CDC 1988 | Krupp^26^ 1993 | | x | | | | | | | x | | | | | x
CDC 1988 | Sandman^27^ 1993 | | | | | | | | | | x
CDC 1988 | Schweitzer^28^ 1995 | x
CDC 1988 | Buchwald^29^ 1996 | x
CDC 1988 | Komaroff^30^ 1996 | x
CDC 1988 | Tiersky^31^ 1998 | | | | | | | | | | | x
Australia 1990 | Vollmer-Conna^32^ 1997 | | | | | | | | | | | | | | x
Oxford 1991 | Smith^33^ 1993 | | | | | | | | | | | x | | | x
Oxford 1991 | Swanink^34^ 1995 | x | x | | | | | | | | | x | | | x
Oxford 1991 | Smith^35^ 1996 | x | x | | | | | | | x
Oxford 1991 | Fischler^52^ 1997 | | | | | | | | | x
Oxford 1991 | Vercoulen^36^ 1996 | x | x | x | [image] | x | x | x | x | x | x | x | | x
Oxford 1991 | Bazelmans^37^ 1997 | x | x | | | | | | | | | | | | x
Oxford 1991 | Wearden^38^ 1997 | | | | | | | | | | | x
Oxford 1991 | Wessely^41^ | | x | | x | | x | x | x | x
Oxford 1991 | Vercoulen^39^ 1998 | | | | | | | | | | x | x
Oxford 1991 | Smith^40^ 1999 | | x | | x | x | x | x | x | x | x | x | x | | x
CDC 1994 | Wessely^41^ 1996 | | | x | x | x | x | x | x | x | x | | x | x
CDC 1994 | Baraniuk^42^ 1998 | | x
CDC 1994 | Blenkiron^43^ 1999 | | x
CDC 1994 | Jason^44^ 2000 | | | x | x | x | x | x | x | x | x | x
CDC 1994 | Jason^45^ 2000 | x [image] | [image]
CFS vs. Depression
CDC 1998 | Hickie^46^ 1990 | | | | | | | | | | | | | | [image]
CDC 1998 | Komaroff^72^ 1996 | | | x | x | x | x | x | x | [image] [image] | x | [image] | x | x | [image] [image]
CDC 1998 | Komaroff^30^ 1996 | x
CDC 1998 | Buchwald^29^ 1996 | x | x
Australia 1990 | Vollmer-Conna^32^ 1997 | | | | | | | | | | | | | | [image]
Oxford 1991 | Morriss^47^ 1999 | [image] | x | | | | | | | | | | | | [image]
CDC 1994 | Johnson^48^ 1996 | | | | | | | | | | | | | | [image]
CFS vs. Multiple Sclerosis
CDC 1998 | Schweitzer^28^ 1995 | x
CDC 1998 | Komaroff^72^ 1996 | | | x | x | x | x | [image] | x | x | [image] | x | x | [image] | x
CDC 1998 | Krupp^26^ 1993 | | x | | | | | | | x | | | | | x
CDC 1994 | Johnson^48^ 1996

Symbols x -chronic fatigue patients had greater difficulty than patients in the comparison group, and the difference was statistically significant

-chronic fatigue patients had less difficulty than patients in the comparison group, and the difference was statistically significant

-chronic fatigue patients did not differ significantly from patients in the comparison group

Abbreviations

FUNC-Functional Impairment

FATG-Fatigue

MLSE-Malaise

THRO-Sore throat

LYMP-Lymph nodes

MUSC-Muscle pain

JOIN-Joint pain

HEAD-Headache

SLEP-Sleep

MEMR-Memory

CONC-Concentration

FEVR-Fever/chills

WEAK-Muscle weakness

DEPR-Depression

The prevalence of CFS in community populations ranged from approximately 0.1 to 0.7%. Of note, lower prevalence bounds of less than 0.01% were reported in a large surveillance study with poor response rates and in a retrospective analysis of a community survey that did not ascertain all possible minor symptoms associated with current definitions of chronic fatigue syndrome.^79,80^ The reported prevalence in primary care populations ranged from approximately 0.04% to 2.6%. Use of different case definitions and differences between primary care practices in different countries probably accounted for the varied estimates. In general, use of the 1988 CDC criteria, which are the most stringent, appeared associated with the lowest prevalence estimates.

### Natural History

We found multiple studies relevant to the natural history of chronic fatigue syndrome.^83,84,87-90,90-117^ Of these, seven met all inclusion criteria (Table 3). Others were excluded for the following reasons: retrospective or cross-sectional data,^94,97,98^ abstract only,^118^ mixed CFS with other patient data,^89,92,93^ lack of case definition developed specifically for CFS,^102,105^ short followup,^117^ and small sample sizes.^83,84,87,88,95,96,99-101,104,112-116^

Table 3. Multivariate psychometric studies on CFS clinical manifestations

Study/Participants | Design/Methods | Findings/Conclusion
Blakely^54^ 1991 Case-Definition: CDC 1988 Source: General practice clinics (CFS and healthy controls), Pain clinic (chronic pain patients) Location: New Zealand Mean Age: 39 years % Female: 61 Mean Duration of Illness: 5.2 years (CFS) | Objective: Investigate the psychological characteristics of chronic fatigue syndrome. Design: Battery of psychometric instruments (General Health Questionnaire, Beck Depression Inventory, Minnesota Multiphasic Personality Inventory, Lazarus Ways of Coping Inventory) N Surveyed: 243 (58 CFS, 81 CP or chronic pain, 104 healthy controls) N Analyzed: 153 (42 CFS, 39 CP or chronic pain, 72 healthy controls) | Discriminant analysis correctly classified 65.4% of cases. There was a marked overlap of classification for CFS and CP, and some overlap between CP and controls. 88% of healthy controls were correctly classified; only 55% of CFS and 44% of chronic pain patients were correctly classified. 26% of CFS patients were misclassified as chronic pain; 27% of chronic pain was misclassified as CFS.
Vercoulen^55^ 1994 Case-Definition: Oxford 1991 Source: Self-referred patients Location: Netherlands % Female: 75 Median Duration of Illness: 5 years | Objective: Identify dimensions of CFS using principal component analysis and to provide a description of patients presenting with unexplained fatigue using these dimensions. Design: Survey questionnaire (present illness, specialist visits, treatment) and fatigue, complaints, psychological well-being, daily functioning, avoidance behavior, cognitions and attributions, social interactions, and sleep disturbances questionnaires). N Surveyed: 395 N Analyzed: 298 | Principal component analysis results in 8 easily interpreted and named factors (psychological well-being, functional impairment in daily life, sleep disturbances, avoidance behavior, concentration problems, causal attributions related to the complaints, social functioning, and self-efficacy expectations) and one difficult-to-interpret factor and named “subjective experience.” Fatigue severity predicted by dimensions psychological well-being, functional impairment, and self-efficacy expectations using stepwise multiple regression analysis (R^2^=.51)
Hickie^56^ 1995 Case-Definition: Australian 1990 Source: CFS clinical registry Location: Australia Mean Age: 38 years % Female: 71 Mean Duration of Illness: 6.5 years | Objective: To determine whether patients diagnosed as having CFS constitute a clinically homogeneous class using multivariate statistical analyses to derive symptom patterns and potential patient subclasses. Design: Patient survey using a self-report symptom instrument (40 symptoms), sociodemographic data, Zung depression scale, course of illness, impact of illness on social and occupational functioning, illness behavior, and the General Health Questionnaire. N Surveyed: 770 N Analyzed: 565 | Latent class analysis resulted in two subgroups with distinguishable clinical features: 1) 27% of patients having characteristics suggestive of somatoform disorders; and 2) 73% presenting a more limited combination of fatigue and neuropsychological symptoms, and only moderate disability but remained clinically heterogeneous. Significant differences between the two groups suggested that Group 1 patients were almost twice as likely to be male, had fewer years duration of illness and less likely to have abilities limited by fatigue, muscle/joint pain, poor concentration, depression and amotivation. Group 2 patients also had lower scores on psychological symptoms, CFS symptom history and severity, fewer visits to the doctor, less disability, less likely to sleep > 4 hours in the daytime, and less likely to be treated with antidepressants.
Fischler^52^ 1997 Case Definition: Oxford 1991 Source: Fatigue clinic (CFS); students, administrative, nursing and medical personnel (controls) Location: Belgium Mean Age: 36 years % Female: 72 Mean Duration of Illness: 6.4 years | Objective: Compare polysomnographic data between CFS patients and healthy controls; assess whether there is an association between primary sleep disorders and disability in CFS. Design: Psychiatric interviews with SCID-P; other instruments included Hamilton Rating Scale for Depression, Sickness Impact Profile, multiple sleep variables with polysomnography. Discriminant analysis used with sleep variables. N Analyzed: 49 CFS, 20 healthy controls | Discriminant analysis showed a high level of correct classification of CFS patients and healthy controls. Sleep-onset latency and the number of stage shifts/hour contributed significantly to the discriminant function. The mean REM latency and the percentage of patients with a shortened REM latency were similar in CFS and healthy controls.
Vercoulen^57^ 1998 Case-Definition: Oxford 1991 Source: not reported Location: Netherlands Mean Age: 36 years % Female: 71 Median Duration of Illness: 5 years | Objective: Clarify ambiguities in previous studies on demographic and social factors and fatigue. Design: Structural equation modeling (causal modeling) using battery of instruments including Checklist Individual Strength, Beck Depression Inventory, Somatization Subscale of Symptom Checklist, Home Activities Subscale and Mobility Subscale of Sickness Impact Profile, Physical Activities Rating Scale, Causal Attributions List, Pain Cognition List. N Analyzed: 51 CFS, 50 multiple sclerosis (MS) | “Attributing complaints to a somatic cause produced low levels of physical activity, which in turn had a causal effect on fatigue severity. Depression had to be deleted from the model. Sense of control over symptoms and focusing on bodily symptoms each had a direct causal effect on fatigue. The model showed an excellent fit for CFS patients, but was rejected for MS patients. Therefore, a new model for MS patients had to be developed in which sense of control had a causal effect on fatigue. In the MS model, no causal relationship was found between the physical state as measured by the Expanded Disability Status Score and fatigue or functional impairment. The present study shows that cognitive and behavioral factors are involved in the persistence of fatigue. Treatment should be directed at these factors. The processes involved in the subjective experience of fatigue in CFS were different from the processes related to fatigue in MS.”
Jason^58^ 1999 unpublished Jason^59^ 1999 Case-Definition: CDC 1994 Source: Random community sample Location: United States Mean Age: 44 (chronic fatigue) % Female: 67 (chronic fatigue) Mean Duration of Illness: 4.0 years | Objective: Address important issues involving the actual factor structure of symptoms of chronic fatigue within a community sample of individuals, unbiased by help-seeking behavior. Design: Community-based study of a random sample of 28,673 residential/working telephone numbers, using a CFS Screening Questionnaire containing a Fatigue Scale and other scales addressing symptoms of CFS and fatigue duration of fatigue. N Surveyed: 18,675 completing interview N Analyzed: 780 of 18,676 with chronic fatigue (408 CFS-like: chronic fatigue and 4+ CDC 94 symptoms; 304 ICF-like: idiopathic chronic fatigue; 68 with exclusionary medical or psychiatric conditions or CF-explained-like) | Principal component analysis resulted in a four-factor solution explaining 38% of total variance: lack of energy, physical exertion, cognitive functioning, and fatigue and rest. Compared to ICF-like, CFS-like had significantly more of the following symptoms: sore throat, painful glands, muscle aches or pain, feel worse for >24 hours after exercising, new headaches, joints pain, not rested after a night of sleep, concentration/memory interfere with work/study; and more difficulty with lack of energy, physical exertion, cognitive functioning, greater fatigue following rest or sleep. Compared to CF-explained, CFS-like had significantly more of the following symptoms: sore throat, painful glands, muscle aches or pain, not rested after a night of sleep.
Jason^60^ 1999 unpublished Jason^61^ 1999 Case-Definition: CDC 1994 Source: Random community sample Location: United States Mean Age: ≈ 35 Female: 74 Mean Duration of Illness: not reported | Objective: Using cluster analysis, provide further empirical support for the observation of distinct aspects of chronic fatigue, and clarify differences between different subgroups of individuals with chronic fatigue in a smaller sample of CFS-like individuals undergoing full psychiatric and medical evaluation; and identify unique symptom and severity patterns. Design: Community-based study, n = 28,673. N Surveyed: 18,675 completing interview, 780 with chronic fatigue N Analyzed: 166 of 408 CFS-like individuals: chronic fatigue and 4+ CDC 94 symptoms | 166 individuals classified by independent physician review panel into four groups: chronic fatigue syndrome (CFS), idiopathic chronic fatigue (ICF), chronic fatigue explained by medical condition (CFM), or chronic fatigue explained by psychiatric condition (CFP). CFS group had more severe post-exertional fatigue than ICF; CFM had more severe post-exertional fatigue than ICF and CFP. Cluster analysis resulted in three clusters: 1) relatively low post-exertional fatigue (n=1); 2) most severe post-exertional fatigue and most improvement in fatigue following rest (n=47); and 3) high post-exertional fatigue and fatigue not alleviated by rest (n=117)
Taylor^62^ 2000 unpublished Case-Definition: CDC 1994 Source: Random community sample Location: United States Mean Age: not reported % Female: not reported Mean Duration of Illness: not reported | Objective: Compare rates of psychiatric diagnosis among individuals with chronic fatigue and a healthy control group in a randomly selected, diverse community-based urban sample; and explore whether various sociodemographic indicators predicted higher or lower rates of Axis I psychiatric disorders. Design: Community-based study, n = 28,673 N Surveyed: 18, 675 completing interview; and completing the SCID (Structural Clinical Interview for DSM-IV): 408 identified as having chronic fatigue profiles, 199 controls N Analyzed: 301 (227 of 408 CF and 74 of 199 controls) | In a forward stepwise logistic regression analysis with current psychiatric diagnosis as the dependent variable, significant predictors were chronic fatigue status and socioeconomic status. In a forward stepwise logistic regression analysis with lifetime psychiatric diagnosis as the dependent variable, significant predictors were chronic fatigue status and work status
Taylor^64^ 2000 unpublished Case-Definition: CDC 1994 Source: Random community sample Location: United States Mean Age: not reported % Female: not reported Mean Duration of Illness: not reported | Objective: Evaluate the diagnostic validity of somatic symptoms associated with CFS, Fibromyalgia, Somatic Depression, Somatic Anxiety, and Irritable bowel syndrome. Design: Community-based study, n = 28,673 N Surveyed: 18, 675 completing interview; and completing the SCID (Structural Clinical Interview for DSM-IV): 408 identified as having chronic fatigue profiles, 199 controls N Analyzed: 213 individuals who underwent medical and psychological work-up. Of the 166 individuals reporting a CFS-like condition and 47 controls, 26 were diagnosed as CFS only, 18 were diagnosed with FMS only, and 6 were diagnosed with CFS & FMS. | Confirmatory factor analysis on 21 symptoms yielded a 5-factor solution that specifically distinguished the 5 functional somatic disorders from one another. The 5 distinct functional somatic disorder model had a reasonably good fit to the data. In contrast, a confirmatory analysis that tested the proposition that all 5 disorders represent a single underlying functional somatic distress syndrome did not fit the data well. Logistic regression predicting actual FMS diagnoses from the five-syndrome factor scores showed that only the FMS symptom factor score was significantly associated with actual FMS diagnosis. Logistic regression predicting actual CFS diagnoses from the five-syndrome factor scores showed that only the CFS symptom factor was significantly associated with actual CFS diagnosis.
Friedberg^63^ 2000 Case Definition: CDC 1994 Source: Advertisements in CFS journals/newsletters and physician referrals (CFS), and spouses/partners/significant-others of CFS participants (healthy controls) Mean Age: 49 years % Female: 67 Median Duration of Illness: 16 years (long duration CFS) and 3 years (short duration CFS) | Objective: Evaluate symptom patterns in patients with CFS who were ill for 10 or more years using Symptom Checklist, CES-D, Brief Symptoms Inventory, and Illness Management Questionnaire. Design: Simple group comparison, matched controls N Analyzed: 286 CFS and 179 healthy controls | Principal component analysis of illness-related symptoms in long-duration CFS yielded three conceptually distinct dimensions with the cognitive problems factor accounting for a substantial portion (30.5%) of the variance; of the remaining factors, flu-like symptoms accounted for 6.4% and neurologic symptoms 4.1% of the variance. Long-duration CFS patients had significantly greater percentage on the following symptoms compared to short-duration CFS: work block, bumping into things, putting the wrong word in, trouble with directions, and burning sensations. A number of viral and immune-related illnesses were reported at significantly higher frequencies in CFS patients than in healthy controls including chicken-pox/shingles, chronic sinus infections, infectious mononucleosis, herpes I/II, and hepatitis.

The seven prospective studies with more than 30 participants that had a followup duration of at least one year are outlined in Table 3. Two of the studies involved patients recruited from the same referral clinic in Seattle; some of the same patients may have participated in both studies.^103,108^ In all, approximately 1,000 people with CFS, almost all of whom have been recruited from referral settings, were followed in these studies. More than two-thirds of the participants have been middle-aged women. Rates of self-reported global or overall improvement at 12 to 18 months have ranged from 11% to 64%.^90,103,107,110^ Rates of self-reported worsening of symptoms at 12 to 18 months in two studies were 15% and 20%.^90,110^ One study from the CDC surveillance system estimated that the cumulative probability of recovery at five years was 31%.^106^ Six months after the first reported recovery, 28% reported return of symptoms of fatigue while 15% were not classified as recovered or relapsed because of incomplete data. ^106^

## Question 4. Do Controlled Studies Show that Particular Therapies Improve Clinical Symptoms of CFS, When Compared to Placebo, No Therapy, or Each Other?>

### Overview of the Evidence

There were 38 controlled trials examining various therapies for the treatment of chronic fatigue syndrome among adults. One trial involving adolescents and treatment with immunoglobulin was found but for the purpose of this report, not reviewed further.^120^ One trial examining the effect of exposure to polio vaccine was found, but the vaccine was not administered as a therapeutic agent and therefore, excluded from further review.^121^ One trial comparing an antiviral to amino acid therapy was found, but the only data reported were pre- and posttest results for each separate arm and therefore, not reviewed further.^122^ Four trials were found but excluded from this report because the authors used a case-definition other than one of the four allowed in the selection criteria, or they did not report the case-definition that was used. Excluded trials examined a multidisciplinary therapeutic approach, essential fatty acid therapy, vitamin/mineral therapy, or sulbutiamine.^123-126^

In this section, we present eight tables that summarize the controlled trials by particular characteristics. Table 6 classifies the controlled trials according to the CFS definition they used, their country of origin and year the study was published. Table 7 categorizes the studies by types of therapy and Tables 8 and 9 (at the end of this section) present relevant information regarding study methods, intervention protocol, participants and outcomes for each trial. Tables 10 through 13 (at the end of this section) present a method for qualitatively summarizing the literature.

Table 10. Immunologic and supplemental therapies (vs. placebo): General health and somatic outcomes

Intervention Type | Case Definition | Study | Therapy | Quality | | | | General | | | Somatic
Intervention Type | Case Definition | Study | Therapy | A | B | N | D% | I M P R | Q O L | W E L L | F A T G | V I G R | S L E P | S E V R | P A I N | M Y L G | H E A D | A R T H | P F A T | W E A K | D I Z Z
Immunologic | CDC 1988 | Strauss^127^ | Antiviral | R | D | 27 | 11% | | | [image] | [image] | [image]
Immunologic | CDC 1988 | Steinberg^138^ | Antihistamine | R | D | 30 | 7% | | | | [image] | | [image] | | | [image] | [image] | [image] | [image] | [image]
Immunologic | CDC 1988 | Lloyd^129^ | Immunomodulator | R | D | 49 | 4% | ↑ | [image]
Immunologic | CDC 1988 | Peterson^130^ | Immunomodulator | R | D | 30 | 7% | | | | [image] | | [image] | | | [image] | [image] | [image] | [image] | [image]
Immunologic | CDC 1988 | See^140^ | Immunomodulator | R | D | 30 | 13% | | [image]
Immunologic | CDC 1988 | Strayer^135^ | Immunomodulator/Antiviral | R | D | 92 | 9%
Immunologic | CDC 1994 | De Vinci^143^ | Transfer Factor | R | D | 20 | 10% | [image]
Immunologic | CDC 1994 | Andersson^156^ | Vaccine | U | D | 28 | 14% | ↑ | | | | | [image] | | [image]
Immunologic | Australia 1990 | Vollmer-Conna^147^ | Immunomodulator | R | D | 99 | 4% | | [image] | | [image] | [image]
Immunologic | Australia 1990 | Vollmer-Conna^147^ | Immunomodulator | R | D | 99 | 4% | | [image] | | [image] | [image]
Immunologic | Australia 1990 | Vollmer-Conna^147^ | Immunomodulator | R | D | 99 | 4% | | [image] | | [image] | [image]
Immunologic | Australia 1990 | Lloyd^132^ | Transfer Factor | R | D | 90 | 2% | | [image] | | [image]
Supplement | CDC 1988 | Cox^131^ | Magnesium | R | D | 32 | 3% | | | ↑ | | ↑ | [image] | | ↑
Supplement | CDC 1988 | Kaslow^128^ | Liver Extract | R | D | 15 | 7% | | | | | [image] | | [image]
Supplement | Oxford 1991 | Warren^157^ | Essential Fatty Acid | R | D | 50 | 24% | | | | | | | [image]
  Symbols and Abbreviations: Results: ↑ Favors therapy group [image] No difference between groups ↓ Favors placebo group | Quality | Outcome Variables: IMPR-Improvement QOL-Quality of Life WELL-Wellness FATG-Fatigue | VIGR-Vigor/Energy SLEP-Sleep Disturbance SEVR-Symptom Severity PAIN-Pain MYLG-Myalgia | HEAD-Headache ARTH-Arthralgia PFAT-Postexertional Fatigue WEAK-Muscle Weakness DIZZ-Dizziness/Lightheadedness
    A: | Assignment Method R - Randomized; N - Not Randomized; U - Unclear
    B: | Blinding D - Double-blinded; N - Not Blinded; U - Unclear
    N: | # Enrolled D%: % Dropout

Table 11. Pharmacologic therapies (vs. placebo): General health and somatic outcomes

Intervention Type | Case Definition | Study | Therapy | Quality | | | | General | | | Somatic
Intervention Type | Case Definition | Study | Therapy | A | B | N | D% | I M P R | Q O L | W E L L | F A T G | V I G R | S L E P | S E V R | P A I N | M Y L G | H E A D | A R T H | P F A T | W E A K | D I Z Z
Pharmacologic | CDC 1988 | Natelson^136^ | Antidepressant | R | D | 24 | 25% | ↑
Pharmacologic | CDC 1988 | Natelson^152^ | Antidepressant | N | U | 25 | 24% | ↑ | | | | ↑ | | [image]
Pharmacologic | CDC 1988 | McKenzie^150^ | Glucocorticoid | R | D | 70 | 10% | | | [image] | [image] | [image] | | [image]
Pharmacologic | CDC 1988 | Peterson^149^ | Mineralcorticoid | R | D | 25 | 20% | | | [image] | [image] | [image] | [image] | | [image] | [image] | [image] | [image] | | | [image]
Pharmacologic | CDC 1994 | Hickie^161^ | Antidepressant | R | D | 90 | 14% | [image] | | | [image] | ↑
Pharmacologic | CDC 1994 | Cleare^158^ | Glucocorticoid | R | D | 35 | 9% | [image] | | | ↑
Pharmacologic | CDC 1994 | Rowe^160^ | Mineralcorticoid | R | D | 100 | 17% | [image] | | [image] | [image] | [image]
Pharmacologic | CDC 1994 | Forsyth^159^ | NADH | R | D | 35 | 26% | ↑
Pharmacologic | Oxford 1991 | Vercoulen^139^ | Antidepressant | R | D | 107 | 10% | [image] | | | [image] | | [image]
Pharmacologic | Oxford 1991 | Wearden^151^ | Antidepressant | R | D | 136 | 29% | | | | [image]
  Symbols and Abbreviations: Results: ↑ Favors therapy group [image] No difference between groups ↓ Favors placebo group | Quality | Outcome Variables: IMPR-Improvement QOL-Quality of Life WELL-Wellness FATG-Fatigue | VIGR-Vigor/Energy SLEP-Sleep Disturbance SEVR-Symptom Severity PAIN-Pain MYLG-Myalgia | HEAD-Headache ARTH-Arthralgia PFAT-Postexertional Fatigue WEAK-Muscle Weakness DIZZ-Dizziness/Lightheadedness
    A: | Assignment Method R - Randomized; N - Not Randomized; U - Unclear
    B: | Blinding D - Double-blinded; N - Not Blinded; U - Unclear
    N: | # Enrolled D%: % Dropout

Table 12. Behavioral therapies with/without immunologic therapy contrasts: General health and somatic outcomes

Intervention Type | Case Definition | Study: Therapy Contrast | Quality | | | | General | | | Somatic
Intervention Type | Case Definition | Study: Therapy Contrast | A | B | N | D% | I M P R | Q O L | W E L L | F A T G | V I G R | S L E P | S E V R | P A I N | M Y L G | H E A D | A R T H | P F A T | W E A K | D I Z Z
Immunologic and Behavioral | Australia 90 | Lloyd:^132^ Transfer factor & CBT (reestablish activity) vs. drug placebo & “CBT placebo” (attend clinic) | R | D | 90 | 2% | | ↑ | | [image]
Behavioral | Australia 90 | Lloyd:^132^ CBT (reestablish activity) & drug placebo vs. drug placebo & “CBT placebo” (attend clinic) | R | D | 90 | 2% | | [image] | | [image]
Behavioral | Oxford 91 | Sharpe:^137^ CBT (increase activity) & medical care vs. medical care only | R | N | 60 | 0% | | | | ↑
Behavioral | CDC 94 | Deale:^145^ CBT(increase activity) vs. relaxation | R | N | 60 | 12% | ↑ | | [image] | ↑
Behavioral | CDC 94 | Ridsdale:^164^ CBT (activity planning) vs. counseling; (CFS subgroup) | R | N | 45 | 18% | | | | [image]
Behavioral | CDC 94 | Prins:^163^ CBT (increase activity) vs. guided support group | R | N | 278 | 3% | | ↑ | | ↑
Behavioral | CDC 94 | Prins:^163^ CBT (increase activity) vs. no treatment | R | N | 278 | 3% | | [image] | | ↑
Behavioral | CDC 88 | Friedberg:^134^ CBT: (activity limitations) vs. no treatment | N | D | 64 | 0% | | | | [image] | | | [image]
  Symbols and Abbreviations: Results: ↑ Favors therapy group [image] No difference between groups ↓ Favors placebo group | Quality | Outcome Variables: IMPR-Improvement QOL-Quality of Life WELL-Wellness FATG-Fatigue | VIGR-Vigor/Energy SLEP-Sleep Disturbance SEVR-Symptom Severity PAIN-Pain MYLG-Myalgia | HEAD-Headache ARTH-Arthralgia PFAT-Postexertional Fatigue WEAK-Muscle Weakness DIZZ-Dizziness/Lightheadedness
    A: | Assignment Method R - Randomized; N - Not Randomized; U - Unclear
    B: | Blinding D - Double-blinded; N - Not Blinded; U - Unclear
    N: | # Enrolled D%: % Dropout

Table 13. Behavioral therapies with/without pharmacologic therapy, complementary/alternative medicine therapies, and other therapy contrasts: General health and somatic outcomes

Intervention Type | Case Definition | Study: Therapy Contrast | Quality | | | | General | | | Somatic
Intervention Type | Case Definition | Study: Therapy Contrast | A | B | N | D% | I M P R | Q O L | W E L L | F A T G | V I G R | S L E P | S E V R | P A I N | M Y L G | H E A D | A R T H | P F A T | W E A K | D I Z Z
Pharmacologic and Behavioral | Oxford 91 | Wearden:^151^ Fluoxetine with graded exercise vs. placebo only | R | D | 136 | 29% | | | | [image]
Behavioral | Oxford 91 | Wearden:^151^ Graded exercise with drug placebo vs. placebo only^151^ | R | D | 136 | 29% | | | | [image]
Behavioral | Oxford 91 | Fulcher:^146^ Graded exercise vs. flexibility/relaxation | R | N | 66 | 29% | ↑ | | ↑ | ↑ | | [image]
Behavioral | Oxford 91 | Powell:^162^ Exercise education, maximum intervention vs. standard care | R | N | 148l | 14% | ↑ | | | ↑
Behavioral | Oxford 91 | Powell:^162^ Exercise education, telephone intervention vs. standard care | R | N | 148l | 14% | ↑ | | | ↑
Behavioral | Oxford 91 | Powell:^162^ Exercise education, minimum intervention vs. standard care | R | N | 148l | 14% | ↑ | | | ↑
Complementary/Alternative Medicine | CDC 88 | Field:^148^ Massage therapy vs. sham TENS | R | N | 20 | 0% | | | | ↑ | | ↑ | | | ↑
Complementary/Alternative Medicine | CDC 88 | Perrin:^154^ Osteopathy vs. normal care | N | N | 80 | 28% | ↑
Other | CDC 94 | Shlaes:^142^ Social support (buddy/mentor) vs. waiting list (no treatment) | N | N | 12 | 17% | | | | ↑
  Symbols and Abbreviations: Results: ↑ Favors therapy group [image] No difference between groups ↓ Favors placebo group | Quality | Outcome Variables: IMPR-Improvement QOL-Quality of Life WELL-Wellness FATG-Fatigue | VIGR-Vigor/Energy SLEP-Sleep Disturbance SEVR-Symptom Severity PAIN-Pain MYLG-Myalgia | HEAD-Headache ARTH-Arthralgia PFAT-Postexertional Fatigue WEAK-Muscle Weakness DIZZ-Dizziness/Lightheadedness
    A: | Assignment Method R - Randomized; N - Not Randomized; U - Unclear
    B: | Blinding D - Double-blinded; N - Not Blinded; U - Unclear
    N: | # Enrolled D%: % Dropout

Table 14. Immunologic and supplemental therapies (vs. placebo): Functional, mood and cognitive outcomes

Intervention Type | Case Definition | Study | Therapy | Quality | | | | Functional | | | | | Mood | | | | | | Cognitive
Intervention Type | Case Definition | Study | Therapy | A | B | N | D% | P H Y S | A C T V | I M P R | S O C L | W O R K | D E P R | A N X Y | M N T L | D S T R | C O N F | M F T G | M E M R | C O G N | C O N C
Immunologic | CDC 1988 | Strauss^127^ | Antiviral | R | D | 27 | 11% | | | | | | ↓ | ↓ | | | ↓
Immunologic | CDC 1988 | Steinberg^138^ | Antihistamine | R | D | 30 | 7% | [image] | | | [image] | | | | [image]
Immunologic | CDC 1988 | Lloyd^129^ | Immunomodulator | R | D | 49 | 4% | | | | | | [image]
Immunologic | CDC 1988 | Peterson^130^ | Immunomodulator | R | D | 30 | 7% | [image] | | | ↓ | | | | [image]
Immunologic | CDC 1988 | See^140^ | Immunomodulator | R | D | 30 | 13%
Immunologic | CDC 1988 | Strayer^135^ | Immunomodulator/Antiviral | R | D | 92 | 9% | ↑ | ↑ | | | | [image] | [image] | | | | | | ↑
Immunologic | CDC 1994 | De Vinci^143^ | Transfer Factor | R | D | 20 | 10%
Immunologic | CDC 1994 | Andersson^156^ | Vaccine | U | D | 28 | 14% | | | | | | [image] | | | | | | [image] | | [image]
Immunologic | Australia 1990 | Vollmer-Conna^147^ | Immunomodulator | R | D | 99 | 4% | | [image] | | | | [image] | | | | [image]
Immunologic | Australia 1990 | Vollmer-Conna^147^ | Immunomodulator | R | D | 99 | 4% | | [image] | | | | [image] | | | | [image]
Immunologic | Australia 1990 | Vollmer-Conna^147^ | Immunomodulator | R | D | 99 | 4% | | [image] | | | | [image] | | | | [image]
Immunologic | Australia 1990 | Lloyd^132^ | Transfer Factor | R | D | 90 | 2% | | [image] | | | | [image] | | | | [image]
Supplement | CDC 1988 | Cox^131^ | Magnesium | R | D | 32 | 3% | [image] | | | [image] | | | | | ↑
Supplement | CDC 1988 | Kaslow^128^ | Liver Extract | R | D | 15 | 7% | | [image] | | | | | | [image]
Supplement | Oxford 1991 | Warren^157^ | Essential Fatty Acid | R | D | 50 | 24% | | | | | | [image]
  Symbols and Abbreviations: Results: ↑ Favors therapy group [image] No difference between groups ↓ Favors placebo group | Quality | Outcome Variables: PHYS-Physical functioning ACTV-Activity level IMPR-Impairment/impact SOCL-Social functioning | WORK-Occupational functioning DEPR-Depression ANXY-Anxiety MNTL-Mental health DSTR-Distress | CONF-Confusion MFTG-Mental fatigue MEMR-Memory/forgetfulness COGN-Cognitive function CONC-Concentration
    A: | Assignment Method R - Randomized; N - Not Randomized; U - Unclear
    B: | Blinding D - Double-blinded; N - Not Blinded; U - Unclear
    N: | # Enrolled D%: % Dropout

Table 15. Pharmacologic therapies (vs. placebo): Functional, mood and cognitive outcomes

Intervention Type | Case Definition | Study | Therapy | Quality | | | | Functional | | | | | Mood | | | | | | Cognitive
Intervention Type | Case Definition | Study | Therapy | A | B | N | D% | P H Y S | A C T V | I M P R | S O C L | W O R K | D E P R | A N X Y | M N T L | D S T R | C O N F | M F T G | M E M R | C O G N | C O N C
Pharmacologic | CDC 1988 | Natelson^136^ | Antidepressant | R | D | 24 | 25% | | | [image] | [image] | | [image]
Pharmacologic | CDC 1988 | Natelson^152^ | Antidepressant | N | U | 25 | 24% | | | [image] | [image] | | [image] | ↑
Pharmacologic | CDC 1988 | McKenzie^150^ | Glucocorticoid | R | D | 70 | 10% | | [image] | [image] | | | [image] | [image] | | [image]
Pharmacologic | CDC 1988 | Peterson^149^ | Mineralcorticoid | R | D | 25 | 20% | [image] | | | [image] | [image] | [image] | | | [image] | [image] | | [image] | | [image]
Pharmacologic | CDC 1994 | Hickie^161^ | Antidepressant | R | D | 90 | 14% | | | [image] | | | [image]
Pharmacologic | CDC 1994 | Cleare^158^ | Glucocorticoid | R | D | 35 | 9% | [image] | | ↑ | ↑ | ↑
Pharmacologic | CDC 1994 | Rowe^160^ | Mineralcorticoid | R | D | 100 | 17% | [image] | [image] | | | | [image] | | [image] | | | [image]
Pharmacologic | CDC 1994 | Forsyth^159^ | NADH | R | D | 35 | 26%
Pharmacologic | Oxford 1991 | Vercoulen^139^ | Antidepressant | R | D | 107 | 10% | [image] | | [image] | [image] | | [image] | | [image] | | | | | [image]
Pharmacologic | Oxford 1991 | Wearden^151^ | Antidepressant | R | D | 136 | 29% | | | | | | [image]
  Symbols and Abbreviations: Results: ↑ Favors therapy group [image] No difference between groups ↓ Favors placebo group | Quality | Outcome Variables: PHYS-Physical functioning ACTV-Activity level IMPR-Impairment/impact SOCL-Social functioning | WORK-Occupational functioning DEPR-Depression ANXY-Anxiety MNTL-Mental health DSTR-Distress | CONF-Confusion MFTG-Mental fatigue MEMR-Memory/forgetfulness COGN-Cognitive function CONC-Concentration
    A: | Assignment Method R - Randomized; N - Not Randomized; U - Unclear
    B: | Blinding D - Double-blinded; N - Not Blinded; U - Unclear
    N: | # Enrolled D%: % Dropout

Table 16. Behavioral therapies with/without immunologic therapy: Functional, mood and cognitive outcomes

Intervention Type | Case Definition | Study: Therapy Contrast | Quality | | | | Functional | | | | | Mood | | | | | | Cognitive
Intervention Type | Case Definition | Study: Therapy Contrast | A | B | N | D% | P H Y S | A C T V | I M P R | S O C L | W O R K | D E P R | A N X Y | M N T L | D S T R | C O N F | M F T G | M E M R | C O G N | C O N C
Immunologic and Behavioral | Australia 90 | Lloyd:^132^ Transfer factor & CBT (reestablish activity) vs. drug placebo & “CBT placebo” (attend clinic) | R | D | 90 | 2% | | [image] | | | | [image] | | | | [image]
Behavioral | Australia 90 | Lloyd:^132^ CBT (reestablish activity) & drug placebo vs. drug placebo & “CBT placebo” (attend clinic) | R | D | 90 | 2% | | [image] | | | | [image] | | | | [image]
Behavioral | Oxford 91 | Sharpe:^137^ CBT (increase activity) & medical care vs. medical care only | R | N | 60 | 0% | | ↑ | ↑ | | | ↑ | [image]
Behavioral | CDC 94 | Deale:^145^ CBT(increase activity) vs. relaxation | R | N | 60 | 12% | ↑ | | ↑ | ↑ | ↑ | [image]
Behavioral | CDC 94 | Ridsdale:^164^ CBT (activity planning) vs. counseling; (CFS subgroup) | R | N | 45 | 18% | | | | [image] | | [image] | [image]
Behavioral | CDC 94 | Prins:^163^ CBT (increase activity) vs. guided support group | R | N | 278 | 3% | ↑ | | ↑ | | [image] | | | ↑
Behavioral | CDC 94 | Prins:^163^ CBT (increase activity) vs. no treatment | R | N | 278 | 3% | ↑ | | ↑ | | [image] | | | ↑ [image]
Behavioral | CDC 88 | Friedberg:^134^ CBT: (activity limitations) vs. no treatment | N | D | 64 | 0% | | | | | | [image] | | | [image]
  Symbols and Abbreviations: Results: ↑ Favors therapy group [image] No difference between groups ↓ Favors placebo group | Quality | Outcome Variables: PHYS-Physical functioning ACTV-Activity level IMPR-Impairment/impact SOCL-Social functioning | WORK-Occupational functioning DEPR-Depression ANXY-Anxiety MNTL-Mental health DSTR-Distress | CONF-Confusion MFTG-Mental fatigue MEMR-Memory/forgetfulness COGN-Cognitive function CONC-Concentration
    A: | Assignment Method R - Randomized; N - Not Randomized; U - Unclear
    B: | Blinding D - Double-blinded; N - Not Blinded; U - Unclear
    N: | # Enrolled D%: % Dropout

Table 17. Behavioral therapies with/without pharmacologic therapy, complementary/alternative medicine therapies, and other therapy contrasts: Functional, mood and cognitive outcomes

Intervention Type | Case Definition | Study: Therapy Contrast | Quality | | | | Functional | | | | | Mood | | | | | | Cognitive
Intervention Type | Case Definition | Study: Therapy Contrast | A | B | N | D% | P H Y S | A C T V | I M P R | S O C L | W O R K | D E P R | A N X Y | M N T L | D S T R | C O N F | M F T G | M E M R | C O G N | C O N C
Pharmacologic and Behavioral | Oxford 91 | Wearden:^151^ Fluoxetine with graded exercise vs. placebo only | R | D | 136 | 29% | | | | | | [image]
Behavioral | Oxford 91 | Wearden:^151^ Graded exercise with drug placebo vs. placebo only^151^ | R | D | 136 | 29% | | | | | | [image]
Behavioral | Oxford 91 | Fulcher:^146^ Graded exercise vs. flexibility/relaxation | R | N | 66 | 29% | ↑ | | | | | [image] | [image] | | | | [image]
Behavioral | Oxford 91 | Powell:^162^ Exercise education, maximum intervention vs. standard care | R | N | 148l | 14% | ↑
Behavioral | Oxford 91 | Powell:^162^ Exercise education, telephone intervention vs. standard care | R | N | 148l | 14% | ↑
Behavioral | Oxford 91 | Powell:^162^ Exercise education, minimum intervention vs. standard care | R | N | 148l | 14% | ↑
Complementary/Alternative Medicine | CDC 88 | Field:^148^ Massage therapy vs. sham TENS | R | N | 20 | 0% | | | | | | ↑ | ↑
Complementary/Alternative Medicine | CDC 88 | Perrin:^154^ Osteopathy vs. normal care | N | N | 80 | 28%
Other | CDC 94 | Shlaes:^142^ Social support (buddy/mentor) vs. waiting list (no treatment) | N | N | 12 | 17% | | | | | | [image] | | | [image]
  Symbols and Abbreviations: Results: ↑ Favors therapy group [image] No difference between groups ↓ Favors placebo group | Quality | Outcome Variables: PHYS-Physical functioning ACTV-Activity level IMPR-Impairment/impact SOCL-Social functioning | WORK-Occupational functioning DEPR-Depression ANXY-Anxiety MNTL-Mental health DSTR-Distress | CONF-Confusion MFTG-Mental fatigue MEMR-Memory/forgetfulness COGN-Cognitive function CONC-Concentration
    A: | Assignment Method R - Randomized; N - Not Randomized; U - Unclear
    B: | Blinding D - Double-blinded; N - Not Blinded; U - Unclear
    N: | # Enrolled D%: % Dropout

Table 6. Controlled trials: country of origin by publication year and case definition

Year | CDC 1988 | Australia 1990 | Oxford 1991 | CDC 1994
1988 | U.S.^127^
1989 | U.S.^128^
1990 | Australia^129^
| U.S.^130^
1991 | U.K.^131^ | U.K.^131^
1992
1993 | U.K.^133^ | Australia^132^
1994 | U.S.^134,135^
1995
1996 | U.S.^136,138,140^ | | Iceland^141^ | U.S.^136,142,143^
| | | Netherlands^139^
| | | U.K.^137,144^
1997 | U.S.^148^ | Australia^147^ | U.K.^145,146^ | U.K.^145^
1998 | U.K.^154^ | | U.K.^151^ | Belgium^153^
| U.S.^149,150,152^ | | | Canada^155^
| | | | Sweden^156^
| | | | U.S.^149,150,152^
1999 | | | U.K.^157,158^ | U.K.^158^
| | | | U.S.^159^
2000 | | | U.K.^162^ | Australia^161^
| | | | Netherlands^163^
| | | | U.K.^164^
| | | | U.S.^160^

Note: References appearing more than once reflects studies where authors used more than one case definition.

Table 7. Controlled trials: types of therapies studied

# of Trials | Intervention Category | Treatment | | Comparison Group
1^127^ | Immunological | Antiviral | | Placebo
1^138^ | Immunological | Antihistamine | | Placebo
1^156^ | Immunological | Vaccine | | Placebo
1^135^ | Immunological | Immunomodulator/Antiviral | | Placebo
3^129,130,147^ | Immunological | Immunomodulator | Immunoglobulin | Placebo
1^143^ | Immunological | Immunomodulator | Transfer Factor | Placebo
1^140^ | Immunological | Immunomodulator | Interferon | Placebo
1^133^ | Immunological | Immunomodulator | Interferon | No Treatment
1^132^ | Immunological and Behavioral | Immunomodulator (Transfer Factor) and Cognitive Behavioral Therapy | | Placebo and/or Attention (Attend Clinic) Control
2^149,160^ | Pharmacological (other than Immunological) | Steroid | Mineralcorticoid | Placebo
2^150,158^ | Pharmacological (other than Immunological) | Steroid | Glucocorticoid | Placebo
1^141^ | Pharmacological (other than Immunological) | Anticholinergic | | Placebo
1^153^ | Pharmacological (other than Immunological) | Hormone | | Placebo
1^159^ | Pharmacological (other than Immunological) | NADH | | Placebo
4^136,139,152,161^ | Pharmacological (other than Immunological) | Antidepressant | | Placebo
1^151^ | Pharmacological and Behavioral | Antidepressant and Graded Exercise | | Placebo and/or Non-Specific Advice Control
5^134,137,145,163,164^ | Behavioral | Cognitive Behavioral Therapy | | Medical Care; Relaxation; Counseling; Natural Course; or No Treatment
1^146^ | Behavioral | Graded Exercise Therapy | | Flexibility and Relaxation
1^162^ | Behavioral | Educational Intervention | | Standard Medical Care
1^144^ | Complementary and Alternative Therapy | Homeopathy | | Placebo
1^148^ | Complementary and Alternative Therapy | Massage Therapy | | Sham TENS
1^154^ | Complementary and Alternative Therapy | Osteopathy | | Normal Care
1^131^ | Nutritional Supplements | Magnesium | | Placebo
1^157^ | Nutritional Supplements | Essential Fatty Acids | | Placebo
1^128^ | Nutritional Supplements | Liver Extract | | Placebo
1^142^ | Other Interventions | Social Support | | Waiting List
1^155^ | Other Interventions | Comprehensive Care | | NoTreatment (Assessed Only)

#### Chronology of controlled trials

Table 6 classifies the controlled trials according to the CFS definition they used, their country of origin and year the study was published. The earliest of these trials was reported in 1988.^127^ The frequency of subsequent trials when initially reported in the medical literature was as follows: one in 1989;^128^ two in 1990;^129,130^one in 1991;^131^ two in 1993;^132,133^ two in 1994;^134,135^ nine in 1996;^136-144^four in 1997;^145-148^ eight in 1998;^149-156^ three in 1999^157-159^ and five in 2000.^160-164^

#### Case definitions

The trials used different CFS case definitions for enrolling patients and the selection appears to have been based primarily on when the study was conducted and which case definitions were available. Seven studies used more than one case definition to enroll patients or stated that enrolled patients met the criteria of multiple case definitions.^131,136,145,149,150,152,158^ Of the 38 controlled trials included in this evidence report, 26% used the CDC 1988 case definition to enroll patients (3 of these 10 studies used this earlier definition only even though these studies were published between 1996 and 1999); 8% used the Australia 1990 case definition, 24% used the Oxford 1991 case definition, and the remaining 42% used the CDC 1994 case definition (trials using more than one case definition were counted, for this purpose, as using whichever case definition was the latest).

#### Study origin

Approximately three-fourths of the controlled trials that met the selection criteria for this report were conducted in the United States (42%) or the United Kingdom (34%). Sixteen percent were conducted in Australia (11%) or the Netherlands (5%). The remaining studies (11%) were equally divided between Belgium, Canada, Iceland and Sweden.

#### Types of therapies studied

Thirty-six of the 38 controlled trials compared a single therapy to a placebo or other type of control group. The two remaining trials were multi-arm trials comparing an immunological therapy (an immunomodulatory, transfer factor/dialyzable leukocyte extract) with or without cognitive behavioral therapy (CBT),^132^ and a pharmacological therapy (an antidepressant, fluoxetine) with or without graded exercise.^151^ The trial comparing transfer factor with or without CBT used a drug placebo and an “attention” placebo defined as “attending clinic;” the antidepressant with or without exercise study used a drug placebo and as a placebo for excise, gave non-specific advice regarding activity level. Of the remaining 36 single-therapy trials, 23 compared the therapy to a placebo. Nine of these placebo-controlled single-therapy trials compared an immunological therapy to placebo: antiviral,^127^ antihistamine,^138^ immunomodulator (immunoglobulin,^129,130,147^ interferon,^140^ and a transfer factor using dialyzable extract from immune lymphocytes^143^) an immunomodulator/antiviral (Ampligen),^135^ and a vaccine (staphylococcus toxoid).^156^ The remaining single-therapy immunological trial compared an immunomodulator (interferon) to a no treatment comparison group.^133^ Eleven of the single-therapy placebo-controlled trials evaluated a pharmacological therapy: steroids (fludrocortisone^149,160^ and hydrocortisone^150,158^), anticholinergic (galanthamine),^141^ growth hormone,^153^ NADH (nicotinamide adenine dinucleotide),^159^ or antidepressants (phenelzine, fluoxetine, moclobemide and selegiline).^136,139,152,161^ Three single-therapy, placebo controlled trials evaluated a supplement: magnesium,^131^ essential fatty acid,^157^ and liver extract.^128^ The remaining single-therapy, placebo-controlled trial intervened with homeopathic therapies.^144^ Five of the remaining single-therapy trials evaluated complex multidimensional therapies including CBT, social support and therapy described as “comprehensive.” The five CBT trials compared CBT to: medical care,^137^ relaxation,^145^ counseling,^164^ natural course (no treatment),^163^ or no treatment.^134^ The social support trial compared a “buddy/mentor” program to a waiting-list control.^142^ The “comprehensive” therapy intervention compared a multitude of services (e.g., optimal medical management, treatment of affective or anxiety disorders, CBT, etc.) to a no treatment control.^155^ Four trials compared a physical intervention: graded exercise vs. flexibility and relaxation,^146^ an educational intervention about the importance of exercise vs. standard medical care,^162^ massage therapy vs. sham TENS,^148^ and osteopathy vs. normal care.^154^

#### Quality of the trials

Six trials were clearly not randomized^128,134,142,152,154,155^ and randomization was unclear in one trial.^156^ Among trials that evaluated immunologic, nutritional supplements, or pharmacologic agents, all but two were reported as double-blinded.^133,152^ Among non-pharmacologic/non-immunologic trials, double-blinding was not reported in eleven studies;^134,137,142,145,146,148,154,155,162-164^Numbers of CFS participants in the studies were fewer than 90 except for nine studies that had sample sizes ranging from 90 to 278.^132,135,139,147,151,160-163^Dropout rates ranged from 0 to 69%; three-fourths of the studies had dropout rates less than 20%. Approximately 20% of the studies used an intention to treat analyses. Follow-up periods, from baseline, ranged from 1 week to 32 months. Seventy-five percent of the studies had follow-up periods less than 6 months, eight percent had follow-up periods of 7-8 months, and thirteen percent had follow-up periods of 11-12 months.

### Description and Results of Trials

What follows is a narrative description of the trials for each treatment and the trials' results. At the end of this section, tables are provided providing summary descriptive information and study results. Randomized trials are summarized in Table 8; the trials clearly not randomized and one trial in which randomization was unclear are summarized in Table 9. The information provided in these two tables include study methods (design features, sample size and dropout rates), characteristics about the intervention (type of treatment, specific therapy and placebo or other contrast, treatment protocol and duration of therapy), characteristics about the patients (case definition used to enroll patients, whether patients with psychiatric conditions were excluded, where the study was conducted and source of patients, length of followup, and demographic patient characteristics), and types of outcomes measured and reported by the authors (general, somatic, functional, mood and cognitive). Study results are summarized in terms of statistically significant differences between patients receiving the therapy under investigation and those receiving a placebo (or no treatment, standard care, etc.) in Tables 10 through 17. For this project, we only include clinical outcomes (physiological outcomes are excluded) with reported between-group significance tests results.

Table 8. Evidence tables of randomized controlled trials

Author/Year Study Methods | Intervention Characteristics | Patient Characteristics | Outcomes Reported (How Measured)^*^
Straus^127^ 1988 Randomized: yes Double-blinded: yes Crossover Trial: yes # Enrolled: 27 % Dropout: 11% # Analyzed: 24 | Intervention: Antiviral Treatment: Acyclovir (n=27) Comparison: Placebo (n=27) Protocol: Intravenous placebo or acyclovir (500 mg/m^2^) every 8 hours for 7 days of hospitalization, then discharged to take placebo or 800 mg acyclovir tablets 4x daily for 30 days; 6-week washout period. Duration of Therapy: 5 weeks | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: United States Patient Source: NIH referrals Mean Illness Duration: 6.8 years Mean Age: 34.1 years % Female: 70% Baseline to Followup: 11 weeks
  General: | Wellness
  Somatic: | Fatigue, Vigor (POMS)
  Functional: | Rest (hours per day)
  Mood: | Anxiety, Depression, Anger (POMS)
  Cognitive: | Confusion (POMS)
Steinberg^138^ 1996 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 30 % Dropout: 7% # Analyzed: 28 | Intervention: Antihistamine Treatment: Terfenadine (n=15) Comparison: Placebo (n=15) Protocol: Terfenadine or placebo, 60 mg twice daily Duration of Therapy: 2 months | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: United States Patient Source: Patient registry Illness Duration: not reported Mean Age: 36.2 years % Female: 77% Baseline to Followup: 2 months
  General: | Health perceptions (MOS)
  Somatic: | Symptoms: fatigue, post-exertional fatigue, muscle weakness, myalgia, sleep disturbance, headache, arthralgia (percent)
  Functional: | Physical, Social functioning (MOS)
  Mood: | Mental Health (MOS)
Strayer^135^ 1994 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 92 % Dropout: 9% # Analyzed: 84 | Intervention: Immunomodulator/Antiviral Treatment: Ampligen (n=45) Comparison: Placebo (n=47) Protocol: Ampligen intravenous infusion, four 200-mg doses initially, followed by 400 mg 2x-weekly, or saline placebo of equal volume Duration of Therapy: 6 months | Case Definition: CDC 1988 Additional entry criteria: Severely debilitated (KPS score 20 to 60) Psychiatric Exclusions: yes Location: United States Patient Source: not stated Mean Illness Duration: 5.2 years Mean Age: 40.7 years % Female: 75% Baseline to Followup: 6 months
  Functional: | Physical performance (KPS), Activity (ADL)
  Mood: | Anxiety, Depression (SCL)
  Cognitive: | Cognitive deficit (SCL)
Lloyd^129^ 1990 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 49 % Dropout: 4% # Analyzed: 49 | Intervention: Immunomodulator Treatment: IgG (n=23) Comparison: Placebo (n=26) Protocol: 3 intravenous influsions of immunoglobulin or placebo solution (maltose) at a dose of 2 g/kg/month Duration of Therapy: 3 months | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: Australia Patient Source: not stated Median Illness Duration: 3.9 years Mean Age: 36.0 years % Female: 49% Baseline to Followup: 6 months
  General: | Improvement (reduction in symptoms, improvement in functional capacity) Quality of Life (QAL)
  Functional: | Change in work, leisure, social activities
  Mood: | Depression (HAMD, Zung)
Peterson^130^ 1990 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 30 % Dropout: 7% # Analyzed: 28 | Intervention: Immunomodulator Treatment: IgG (n=15) Comparison: Placebo (n=15) Protocol: 6 intravenous infusions of immunoglobulin or placebo solution (albumin) at a dose of 1 g/kg/month Duration of Therapy: 5 months | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: United States Patient Source: Research program Mean Illness Duration: 3.8 years Mean Age: 40.8 years % Female: 73% Baseline to Followup: 5 months
  General: | Health perception (MOS)
  Somatic: | Symptom severity (fatigue, post-exertional fatigue, muscle weakness, myalgia, arthralgia, sleep disturbance, headache) Physical and social functioning
  Functional: | (MOS) Mental health (MOS)
  Mood:
Vollmer-Conna^147^ 1997 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 99 % Dropout: 4% # Analyzed: 99 | Intervention: Immunomodulator Treatment 1: 0.5 g/kg IgG (n=22) Treatment 2: 1.0 g/kg IgG (n=28) Treatment 3: 2.0 g/kg IgG (n=23) Comparison: Placebo (n=26) Protocol: 3 intravenous infusions administered at monthly intervals or placebo (albumin/maltose) Duration of Therapy: 3 months | Case Definition: Australia 1990 Psychiatric Exclusions: no Location: Australia Patient Source: not stated Mean Illness Duration: 6.3 years Mean Age: 39.8 years % Female: 76% Baseline to Followup: 6 months
  General: | Quality of Life (QAL)
  Somatic: | Energy, Fatigue (POMS)
  Functional: | Daily activity (KPS; hours per day)
  Mood: | Depression (POMS)
  Cognitive: | Confusion (POMS)
De Vinci^143^ 1996 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 20 % Dropout: 10% # Analyzed: 20 | Intervention: Transfer Factor Treatment: Dialyzable extract from immune lymphocytes (n=14) Comparison: Placebo (n=6) Protocol: Capsules of ‘specific’ TF (known activity against Epstein-Barr virus, human herpes virus 6 and cytomegalovirus), 90-970 days, or placebo (unspecific TF or lactose placebo) 140-360 days Duration of Therapy: 90-970 days (mean 328 days) | Case Definition: CDC 1994 Psychiatric Exclusions: not stated Location: United States Patient Source: not reported Illness Duration: not reported Mean Age: 35 % Female: 60% Baseline to Followup: End of treatment
  General: | Clinical Improvement (diminished sore throat, muscular and/or joints pain, headaches, increased ability of mental concentration)
Lloyd^132^ 1993 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 90 % Dropout: 2% # Analyzed: 88 | Intervention: Transfer Factor (DLE - dialyzable leukocyte extract) and/or Cognitive Behavioral Therapy (CBT) Treatment 1: DLE & CBT (n=20) Treatment 2: DLE & “attend clinic” (n=26) Treatment 3: CBT and saline placebo (n=21) Comparison: Saline placebo & “attend clinic” (n=23) Protocol: DLE (5x10^8^ leukocytes/dose), 8 biweekly intramuscular injections or normal saline placebo; CBT (delivered by 3 psychiatrists who focused on behavioral and psychological issues, difficulties that warranted attitude shifts, attitude changes, and concepts of being active including a home-based graded exercise schedule), 6 biweekly sessions, or “attend clinic” placebo Duration of Therapy: 4 months | Case Definition: Australia 1990 Psychiatric Exclusions: no Location: Australia Patient Source: not stated Median Illness Duration: 5.5 years Mean Age: 39.6 years % Female: 76% Baseline to Followup: 7 months
  General: | Quality of Life (QAL)
  Somatic: | Fatigue, Vigor (POMS)
  Functional: | Physical capacity (diaries), Daily activity (KPS), Non-sedentary hours
  Mood: | Anger, Anxiety, Depression (POMS)
  Cognitive: | Confusion (POMS)
See^140^ 1996 Randomized: yes Double-blinded: yes Crossover Trial: yes # Enrolled: 30 % Dropout: 13% # Analyzed: 26 | Intervention: Immunomodulator Treatment: Interferon-(α2a (n=15) Comparison: Placebo (n=15) Protocol: 3 million units of interferon-(α2b administered subcutaneously thrice weekly; comparison group treated after 3 month followup; washout period not stated, or placebo (NaCl) Duration of Therapy: 3 months | Case Definition: CDC 1988 Psychiatric Exclusions: no Location: United States Patient Source: Referrals by local internists and university faculty Mean Illness Duration: 4.6 years Mean Age: 37.2 years % Female: 80% Baseline to Followup: 4 months
  General: | Quality of Life
Brook^133^ 1993 Randomized: yes Double-blinded: no Crossover Trial: no # Enrolled: 20 % Dropout: 10% # Analyzed: 20 | Intervention: Immunomodulator Treatment: Interferon-α2b (n=11) Comparison: No treatment (n=9) Protocol: 3 million units of interferon-α2b administered subcutaneously thrice weekly; comparison group treated after 3 month followup Duration of Therapy: 3 months | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: United Kingdom Patient Source: not reported Illness Duration: 1-11 years Mean Age: not reported % Female: 70% Baseline to Followup: 6 months | Functional: Activity (ECOG)
Peterson^149^ 1998 Randomized: yes Double-blinded: yes Crossover Trial: yes # Enrolled: 25 % Dropout: 20% # Analyzed: 20 | Intervention: Mineralcorticoid Treatment: Fludrocortisone (n=22) Gp 2: Placebo (n=24) Protocol: Fludrocortisone acetate tablet (0.1 initially; dosed doubled to 0.2 mg if patient reported no improvement in fatigue after first two weeks of treatment) or lactose placebo; 6-week washout period. Duration of Therapy: 6 weeks | Case Definition: CDC 1988/CDC 1994 Psychiatric Exclusions: no Location: United States Patient Source: Patient registries, regional CFS research program and local CFS clinic Mean Illness Duration: 7.0 years Mean Age: 39.7 years % Female: 76% Baseline to Followup: 6 weeks
  General: | General well-being (MOS)
  Somatic: | Symptom severity: fatigue, unrefreshing sleep, sore throat, joint pains, muscle pains, headaches, painful lymph nodes, lightheadedness (VAS) Functional status: physical,
  Functional: | social, role limitations (MOS) Emotional well-being (MOS), Depression (VAS), Positive
  Mood: | affect (PANAS) Concentration, Forgetfulness (VAS); Reaction time (HICK)
  Cognitive:
Rowe^160^ 2000 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 100 % Dropout: 17% # Analyzed: 83 | Intervention: Mineralcorticoid Treatment: Fludrocortisone (n=50) Comparison: Placebo (n=50) Protocol: Fludrocortisone (one capsule of 0.025 mg capsule/day for 1 week, then increased to 2 capsules per day for 1 week, then 4 per day for remaining 7 weeks) or methylcellulose placebo. Duration of Therapy: 9 weeks (started 2 weeks after table-tilt test screen) | Case definition: CDC 1994; patients with neurally-mediated hypotension Psychiatric Exclusions: yes Location: United States Patient Source: CFS patient registries; ads with patient advocacy programs, local newspapers and internet postings Mean Illness Duration: 6.4 years Mean Age: 36.8 years % Female: 66% Baseline to Followup: 11 weeks
  General: | Wellness
  Somatic: | Fatigue, Vigor (POMS)
  Functional: | Physical function (MOS), Activity (DASI)
  Mood: | Depression (BDI), Mental health (MOS)
  Cognitive: | Mental fatigue (WMFI)
McKenzie^150,167^ 1998, 2000 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 70 % Dropout: 10% # Analyzed: 65-68 | Intervention: Glucocorticoid Treatment: Hydrocortisone (n=35) Comparison: Placebo (n=35) Protocol: Oral hydrocortisone, 13 mg/m^2^ of body surface area every morning and 3 mg/m^2^ every afternoon, or placebo, for 12 weeks Duration of Therapy: 3 months | Case definition: CDC 1988/94 Psychiatric Exclusions: yes Location: United States Patient Source: not reported Mean Illness Duration: 4.4 years Mean Age: 37.5 years % Female: 80% Baseline to Followup: 3 months
  General: | Wellness
  Somatic: | Symptom severity (SCL), Fatigue, Vigor (POMS)
  Functional: | Sickness impact (SIP), Activity Depression (BDI, HAMD), Anger,
  Mood: | Anxiety (POMS) Confusion (POMS)
  Cognitive:
Cleare^158^ 1999 Randomized: yes Double-blinded: yes Crossover Trial: yes # Enrolled: 35 % Dropout: 9% # Analyzed: 32 | Intervention: Glucocorticoid Treatment: Hydrocortisone (n=32) Comparison: Placebo (n=32) Protocol: Hydrocortisone (5 mg first 16 patients, 10 mg for remainder) or placebo first for 28 days before crossover to other treatment; washout not reported Duration of Therapy: 1 month | Case Definition: CDC 1994/Oxford 1991 Psychiatric Exclusions: yes Location: United Kingdom Patient Source: CFS clinics Meant Illness Duration: 3.0 years Mean Age: 35.3 years % Female: 57% Baseline to Followup: 1 month
  General: | Improvement
  Somatic: | Fatigue (CFQ)
  Functional: | Physical function, Role limitation (MOS), Disability (WSAS) Psychological symptoms (GHQ)
  Mood:
Snorrason^141^ 1996 Randomized: yes Double-blinded: yes Crossover Trial: yes # Enrolled: 49 % Dropout: 20% # Analyzed: 30-40 | Intervention: Anticholinergic Treatment: Galanthamine (n=25) Comparison: Placebo (n=24) Protocol: Galanthamine hydrobromide (10 mg t.i.d., reached by escalating dosage) or matched treatment with placebo tablets; 70% of patients followed this schedule and remaining 30% dosage reduced due to adverse effects. Originally designed as a parallel trial, changed to optional crossover after 2 weeks; washout not reported. Duration of Therapy: 2-8 weeks | Case Definition: Oxford 1991 Psychiatric Exclusions: yes Location: Iceland Patient Source: General and rheumatological outpatient clinics Mean Illness Duration: 12.8 years Mean Age: 43.9 years % Female: 86% Baseline to Followup: 1-8 weeks
  Somatic: | Fatigue, Myalgia, Sleep, Dizziness (VAS)
  Functional: | Work capacity (VAS)
  Mood: | Anxiety (STAIS, DSM), Depression, Emotional instability (DSM)
  Cognitive: | Concentration (WMS), Memory (WMS, VAS)
Moorkens^153^ 1998 Randomized: yes Double-Blinded: yes Crossover Trial: no # Enrolled: 20 % Dropout: 15% # Analyzed: 17 | Intervention: Hormone Treatment: Growth hormone (n=10) Comparison: Placebo (n=10) Protocol: Growth hormone therapy, 6.7 μg/kg/day, or placebo for 12 weeks, then all patients enrolled in open trial with GH Duration of Therapy: 3 months RCT, 9 months open trial | Case Definition: CDC 1994 Psychiatric Exclusions: no Location: Belgium Patient Source: CFS clinic Illness Duration: not reported Mean Age: not reported % Female: 65% Baseline to Followup: 12 months
  General: | Quality of Life (NHP, QOL)
Forsyth^159^ 1999 Randomized: yes Double-blinded: yes Crossover Trial: yes # Enrolled: 35 % Dropout: 26% # Analyzed: 26 | Intervention: Nicotinamide Adenine Dinucleotide (NADH) Treatment: NADH (n=26) Comparison: Placebo (n=26) Protocol: NADH, two 5mg tablets daily, for a 4-week period; 4-week washout period. Duration of Therapy: 4 weeks | Case Definition: CDC 1994 Psychiatric Exclusions: yes Location: United States Patient Source: Referrals and recruited from medical center Mean Illness Duration: 7.2 years Mean Age: 39.6 years % Female: 65% Baseline to Followup: 4 weeks
  General: | Symptom Improvement
Natelson^136^ 1996 Randomized: yes Double-blinded: yes Crossover Trial: yes # Enrolled: 24 % Dropout: 25% # Analyzed: 18 | Intervention: Antidepressant Treatment: Phenelzine (n=15) Comparison: Placebo (n=9) Protocol: First 2 weeks placebo phase-in all patients, 1 placebo pill per day; then phenelzine or placebo during 2^nd^ 2 weeks with patients in active treatment group receiving one 15-mg tablet phenelzine per day alternating with placebo; during final two weeks, patients in active treatment group received one 15-mg tablet per day; placebo group took one placebo pill per day. Duration of Therapy: 4 weeks | Case Definition: CDC 1988/94 Psychiatric Exclusions: yes Location: United States Patient Source: CFS center Illness Duration: not reported Mean (SD) Age: 34.6 yrs (2.8) % Female: 83% Baseline to Followup: 6 weeks (includes 2 week placebo phase-in)
  Somatic: | Symptom severity (Checklist), Fatigue (POMS, FSS), Vigor (POMS) Functional status (FSQ), Activity
  Functional: | (ADL), Disability (ISS) Depression (POMS, CESD) Confusion (POMS)
  Mood:
  Cognitive:
Hickie^161^ 2000 Randomized: yes Double-Blinded: yes Crossover Trial: no # Enrolled: 90 % Dropout: 14% # Analyzed: 90 | Intervention: Antidepressant Treatment: Moclobemide (n=47) Comparison: Placebo (n=43) Protocol: Moclobemide or placebo at one 150-mg tablet 2x daily for 1 week, then increased to 450 mg/day, then increased to 600 mg/day if tolerated Duration of Therapy: 6 weeks | Case Definition: CDC 1994 Psychiatric Exclusions: yes Location: Australia Patient Source: Infectious disease and immunology outpatient clinics Mean Illness Duration: 1.7 years Mean Age: 43.5 years % Female: 54% Baseline to Followup: 6 weeks
  General: | Improvement
  Somatic: | Fatigue, Vigor (POMS)
  Functional: | Disability (KPS)
  Mood: | Depression (POMS)
Vercoulen^139^ 1996 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 107 % Dropout: 10% # Analyzed: 96 | Intervention: Antidepressant Treatment: Fluoxetine (n=54) Comparison: Placebo (n=53) Protocol: Fluoxetine or placebo 20 mg per day; groups sub-divided into depressed and non-depressed patients. Duration of Therapy: 2 months | Case Definition: Oxford 1991 Psychiatric Exclusions: yes Location: Netherlands Patient Source: Referrals to general outpatient clinic Mean Illness Duration: 5.5 years Mean Age: 38.9 years % Female: 76% Baseline to Followup: 4 months
  General: | Recovery
  Somatic: | Fatigue (CIS, SIP)
  Mood: | Depression (BDI)
Wearden^151^ 1998 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 136 % Dropout: 29% # Analyzed: 136 | Intervention: Antidepressant and Graded Exercise Therapy (GET) Treatment 1: Fluoxetine & GET (n=33) Treatment 2: GET & drug placebo (n=34) Treatment 3: Fluoxetine and exercise placebo (n=35) Comparison: Placebo only (n=34) Protocol: All patients attended hospital on 8 sessions for treatment by physiotherapist. GET included instructions to carry out preferred aerobic activity for 20 minutes, 3x per week; GET placebo patients not offered any specific advice but told to do what they felt capable and to rest when felt needed. Fluoxetine or placebo, 20 mg daily. Duration of Therapy: 6 months | Case Definition: Oxford 1991 Psychiatric Exclusions: yes Location: United Kingdom Patient Source: Referrals to outpatient clinic Median Illness Duration: 2.3 years Mean Age 38.7 years % Female: 71% Baseline to Followup: 3 and 6 months
  General: | Health perception (MOS)
  Somatic: | Fatigue (CFQ), Pain (MOS)
  Functional: | Physical function, Role or occupational function, Social function (MOS; Functional work capacity (BERG) Depression (HADS)
  Mood:
Kaslow^128^ 1989 Randomized: no Double-blinded: yes Crossover Trial: yes # Enrolled: 15 % Dropout: 7% # Analyzed: 14 | Intervention: Supplement Treatment: LEFAC (n=15) Comparison: Placebo (n=15) Protocol: LEFAC (extract of bovine liver, 10 μg/mL, with folic acid, .4 mg/mL, and cyanocobalamin, 100 μg/mL) or placebo. Self-administration of 2-mL IM injections daily, 1-week supply; returned after one week for alternate therapy; then all patients entered in open trial for 2 additional weeks. Duration of Therapy: 1 week | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: United States Patient Source: Community physician or self-referral Illness Duration: not reported Mean Age 40.4 years % Female: 78% Baseline to Followup: 1 week
  Somatic: | Energy, Overall symptoms
  Functional: | Daily activities (FSQ)
  Mood: | Mental health (FSQ)
Cox^131^ 1991 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 32 % Dropout: 3% # Analyzed: 31 | Intervention: Supplement Treatment: Magnesium (n=15) Comparison: Placebo (n=17) Protocol: Magnesium sulfate (1 g in 2 ml) or placebo (2 ml water), intramuscular, weekly Duration of Therapy: 6 weeks | Case Definition: CDC 1988/Australia 1990 Psychiatric Exclusions: no Location: United Kingdom Patient source: Complementary medicine research center and general practitioners Illness Duration: not reported Mean Age: 36.4 years % Female: 69% Baseline to Followup: 6 weeks
  General: | Health profile (NHP)
  Somatic: | Energy, Pain, Sleep (NHP)
  Functional: | Social isolation, Physical mobility (NHP) Emotional reactions (NHP)
  Mood:
Warren^157^ 1999 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 50 % Dropout: 24% # Analyzed: 38 | Intervention: Essential Fatty Acids Treatment: EFA (Efamol Marine) (n=24) Comparison: Placebo (n=26) Protocol: EFA (evening primrose oil and concentrated fish oil), two 500-mg capsules, 4x day or sunflower oil placebo (same number of capsules) Duration: 3 months | Case Definition: Oxford 1991 Psychiatric Exclusions: no Location: United Kingdom Patient Source: Referrals to regional infectious disease unit Mean Illness Duration: 4.0 years Mean Age: 37.1 years % Female: 58% Baseline to Followup: 3 months
  General: | Improvement (Self-report)
  Somatic: | Symptom severity (PSC)
  Mood: | Depression (BDI)
Sharpe^137,168^ 1996, 1998 Randomized: yes Double-blinded: no Crossover Trial: no # Enrolled: 60 % Dropout: 0% # Analyzed: 60 | Intervention: Cognitive Behavioral Therapy Treatment: CBT and medical care (n=30) Comparison: Medical care only (n=30) Protocol: CBT - consisting of 16 one-hour individual treatment sessions delivered by three experienced cognitive therapists that focused on explanation of illness, strategies to increase gradual and consistent increases in activity, active problem solving for interpersonal and occupational difficulties, and avoidance of excessive perfectionism and self-criticisms; Medical care - general practitioner followup Duration of Therapy: 4 months | Case Definition: Oxford 1991 Psychiatric Exclusions: yes Location: United Kingdom Patient Source: Outpatient clinic referrals Mean Illness Duration: 2.6 years Mean Age: 36.0 years % Female: 68% Baseline to Followup: 5, 8, 12 months
  General: | Overall change
  Somatic: | Fatigue (severity)
  Functional: | Activity (KPS, Interference; # days in bed/week)
  Mood: | Anxiety, Depression (HADS)
Deale^145,169,170^ 1997, 1998, 2000 Randomized: yes Double-blinded: no Crossover Trial: no # Enrolled: 60 % Dropout: 12% # Analyzed: 53 | Intervention: Cognitive Behavioral Therapy Treatment: CBT (n=30) Comparison: Relaxation (n=30) Protocol: CBT consisting of 13 weekly sessions aimed at establishing a program of consistent planned activity and rest; a sleep routine; graded increases in activity and cognitive restructuring of unhelpful illness beliefs and assumptions. Relaxation included progressive muscle relaxation, visualization and rapid relaxation. Duration of Therapy: 4 to 6 months | Case Definition: Oxford 1991/CDC 1994 Psychiatric Exclusions: yes Location: United Kingdom Patient Source: Referrals to CFS clinic Mean Illness Duration: 4.0 years Mean Age: 34.5 years % Female: 68% Followup: 1-, 3-, and 6-month post-treatment; 5 years
  General: | Improvement (global)
  Somatic: | Fatigue (severity, degree, improvement)
  Functional: | Functional Impairment (MOS, WSAS, Long-term goals)
  Mood: | Anxiety (GHQ), Depression (GHQ, BDI)
Ridsdale^164^ 2000 Randomized: yes Double-Blinded: no Crossover Trial: no # Enrolled: 160 (45 with CFS) % Dropout: 19.4% (18% CFS) # Analyzed: 129 (37 CFS) | Intervention: Cognitive Behavioral Therapy Treatment: CBT (n=80, 25 CFS) Comparison: Counseling (n=80, 20 CFS) Protocol: CBT was delivered by qualified therapists focused on activity planning, homework, establishing a sleep routine and other cognitive interventions. Counseling was delivered by qualified counselors and focused on a psychodynamic model of client-centered therapy. 6 therapy sessions (content video-taped and validated by independent raters). Duration of Therapy: 3 months | Case-Definition: Other/CDC 1994 Psychiatric Exclusions: yes Location: United Kingdom Patient Source: General practice patients Mean Illness Duration: 3.2 years Mean Age: 39.4 years % Female: 73% Baseline to Followup: 6 months
  General: | General Health (MOS) with care Fatigue (CFQ)
  Somatic: | Social Adjustment (MOS)
  Functional: | Anxiety, Depression (HADS)
  Mood:
Prins^163^ 2000 Randomized: yes Double-Blinded: no Crossover Trial: no # Enrolled: 278 % Dropout: 3% # Analyzed: 270 | Intervention: Cognitive Behavioral Therapy Treatment 1: CBT (n=93) Treatment 2: Guided support (n=94) Comparison: Natural course (n=91) Protocol: CBT consisting of 16 sessions delivered by 13 behavioral therapists focused on self-control, restructuring fatigue-related cognitions, attaining base level of daily activity, gradual increases of physical activity, and returning to work or personal activities; Guided Support consisting of 11 meetings delivered by a social worker aimed at exchanging experiences and obtaining mutual understandings; Natural course was defined as no intervention. Duration of Therapy: 8 months | Case-Definition: CDC 1994 Psychiatric Exclusions: no Location: Netherlands Patient Source: Internal medicine department outpatient clinic Mean Illness Duration: 5.6 years Mean Age: 36.7 years % Female: 78% Baseline to Followup: 8, 14 months
  General: | Quality of Life (EQ), Improvement (self-rated)
  Somatic: | Fatigue Severity (CIS)
  Functional: | Functional Impairment (SIP), Functional Status (KPS), Hours working
  Mood: | Psychological Well-Being (SCL)
Fulcher^146^ 1997 Randomized: yes Double-blinded: no Crossover Trial: yes # Enrolled: 66 % Dropout: 29% # Analyzed: 66 | Intervention: Graded Exercise Therapy (GET) Treatment: GET (n=33) Comparison: Flexibility/relaxation (n=33) Protocol: GET included 12 weeks of supervised treatment and next week's exercise prescription. Lab sessions supervised by exercise physiologist. Flexibility/relaxation included 12 weekly sessions and taught stretching routine and relaxation techniques; specifically told to avoid extra physical activities. Duration of Therapy: 12 weeks | Case Definition: Oxford 1991 Psychiatric Exclusions: yes Location: United Kingdom Patient Source: Clinic referrals Median Illness Duration: 2.7 years Mean Age: 37.2 years % Female: 74% Baseline to Followup: 3 and 12 months after supervised treatment
  General: | Overall change
  Somatic: | Fatigue; Sleep (PSQI)
  Functional: | Physical function (MOS)
  Mood: | Anxiety, Depression (HADS)
Powell^162^ 2000 Randomized: yes Double-Blinded: no Crossover Trial: no # Enrolled: 148 % Dropout: 14% # Analyzed: 148 | Intervention: Educational Intervention Treatment 1: Maximum educational intervention (MAX) (n=38) Treatment 2: Telephone intervention (TEL) (n=39) Treatment 3: Minimal educational intervention (MIN) (n=37) Comparison: Standardized medical care (n=34) Protocol: One of three educational intervention groups about evidence on physical and psychological effects of physical deconditioning and circadian dysrhythmia, with the intention of encouraging a self-managed graded exercise program (2 individual treatment sessions, 2 telephone follow-up calls, comprehensive educational pack. Minimal intervention (MIN) included no further treatment; Telephone intervention (TEL) included 7 additional calls; Maximum intervention (MAX) included 7 additional face-to-face sessions. Comparison group included standardized medical care (advice and return to primary care). Duration of Therapy: 3-4 months | Case-Definition: Oxford 1991 Psychiatric Exclusions: yes Location: United Kingdom Patient Source: Patient referrals to chronic fatigue clinic and infectious disease outpatient clinic. Mean Illness Duration: 4.3 years Mean Age: 33.4 years % Female: 78% Baseline to Followup: 3 months, 6 months, 1 year
  General: | Global change
  Somatic: | Fatigue (CFQ), Sleep
  Functional: | Physical function (MOS)
  Mood: | Anxiety, Depression (HADS)
Awdry^144,166^ 1996 Randomized: yes Double-blinded: yes Crossover Trial: no # Enrolled: 64 % Dropout: 5% # Analyzed: 61 | Intervention: Alternative Therapy Treatment: Homoeopathy (n=32) Comparison: Placebo (n=32) Protocol: Single selected homoeopathic remedies (with emphasis on symptoms and person with the symptoms) or placebo (inert powder). Duration of Therapy: 12 months | Case Definition: Oxford 1991 Psychiatric Exclusions: no Location: United Kingdom Patient source: Volunteer patients Mean Illness Duration: 5.1 years Mean Age: 40.2 years % Female: 70% Baseline to Followup: 12 months
  General: | Improvement
  Somatic: | Fatigue, Sleep
  Functional: | Disability, Employment
  Mood: | Mood disturbance
Kaslow^128^ 1989 Randomized: no Double-blinded: yes Crossover Trial: yes # Enrolled: 15 % Dropout: 7% # Analyzed: 14 | Intervention: Supplement Treatment: LEFAC (n=15) Comparison: Placebo (n=15) Protocol: LEFAC (extract of bovine liver, 10 μg/mL, with folic acid, .4 mg/mL, and cyanocobalamin, 100 μg/mL) or placebo. Self-administration of 2-mL IM injections daily, 1-week supply; returned after one week for alternate therapy; then all patients entered in open trial for 2 additional weeks. Duration of Therapy: 1 week | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: United States Patient Source: Community physician or self-referral Illness Duration: not reported Mean Age 40.4 years % Female: 78% Baseline to Followup: 1 week
  Somatic: | Energy, Overall symptoms
  Functional: | Daily activities (FSQ)
  Mood: | Mental health (FSQ)
Field^148^ 1997 Randomized: yes Double-Blinded: no Crossover Trial: no # Enrolled: 20 % Dropout: 0% # Analyzed: 20 | Intervention: Massage Therapy Treatment: Massage (n=10) Comparison: SHAM TENS (n=10) Protocol: Massage, twice each week by trained massage therapist consisting of gentle pressure to arms, torso, legs and head. SLAM TENS (attention and tactile stimulation control) also provided by massage therapist; TENS device used but never turned on (no electrical current) Duration of Therapy: 5 weeks | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: United States Patient Source: Physician referral Illness Duration: not reported Mean Age: 47 years % Female: 80% Baseline to Followup: 5 weeks
  Somatic: | Pain (MPQ, PSQ), Sleep (PSQ), Fatigue, Somatic symptoms (PFRS)
  Mood: | Emotional distress (PRFA), Depression (POMS, CESD), Anxiety (STAIS) Cognitive distress (PRFA)
  Cognitive:

*Abbreviations ADL: Activities of Daily Living BDI: Beck Depression Inventory BERG: Bosch ERG 551 Ergometer BSI: Brief Symptom Inventory CESD: Center for Epidemiology Studies Depression Scale CFQ: Chalder Fatigue Questionnaire CIS: Checklist Individual Strength CGI: Clinical Global Impressions COPE: Coping Strategies Scales CPRS: Comprehensive Psychopathological Rating Scale DAIS: Duke Activity Status Index DSM: DSM-III-R ECOG: Eastern Cooperative Oncology Group Activity Scale EQ: EuroQol Quality of Life visual analogue scale FRCS: Fatigue-Related Cognitions Scale FSQ: Functional Status Questionnaire FSRS: Fatigue Self-Rating Scale FSS: Fatigue Severity Scale GHQ: General Health Questionnaire HADS: Hospital Anxiety and Depression Scale HAMD: Hamilton Depression Rating Scale HICK: Hick Paradigm Reaction Time ISS: Illness Severity Scale KPS: Karnofsky Performance Scale MOS/SF36: Medical Outcomes Study Short Form MPQ: McGill Pain Questionnaire NHP: Nottingham Health Profile PANAS: Positive and Negative Affect Scale POMS: Profile of Mood States PFRS: Profile of Fatigue-Related Symptoms PSC: Physical Symptom Checklist PSQ: Pain and Sleep Questionnaire PSQI: Pittsburgh Sleep Quality Index QAL: Quality of Life visual analogue scale QOL: Quality of Life assessment in GH-deficient adults questionnaire SCL: Symptom Checklist SCL-90 SIP: Sickness Impact Profile STAIS: State and Trait Anxiety Index of Spielberger SX: Symptom Severity Checklist VAS: Symptom severity visual analogue scale WMFI: Wood Mental Fatigue Inventory WMS: Wechsler Memory Scale WSAS: Work and Social Adjustment Scale Zung: Zung Depression Scale

Table 9. Evidence tables of non-randomized controlled trials

Author/Year Study Methods | Intervention Characteristics | Patient Characteristics | Outcomes Reported (How Measured)*
Andersson^156^ 1998 Randomized: unclear Double-Blinded: yes Crossover Trial: no # Enrolled: 28 % Dropout: 14% # Analyzed: 24 | Intervention: Vaccine Treatment: Staphylococcus toxoid vaccine (n = 14) Comparison: Placebo (n = 14) Protocol: Vaccine given at increasing doses containing .01, .05, .1, .2, .5 and 1.0 ml of fully potent vaccine, or sterile water placebo; 1 injection weekly. Duration of Therapy: 12 weeks | Case-Definition: CDC 1994 and fibromyalgia Psychiatric Exclusions: no Location: Sweden Patient Source: Referral from care centers, hospitals, psychiatric units Mean Illness Duration: 12.9 years Mean Age: 47.0 years % Female: 100% Baseline to Followup: 12 weeks
  General: | Improvement (CGI)
  Somatic: | Severity of Illness (CGI), Pain (VAS), Sleep (CPRS)
  Mood: | Depression (Zung), Psychiatric symptoms (CPRS) Concentration, Memory (CPRS)
  Cognitive:
Natelson ^152^ 1998 Randomized: no Double-Blinded: unclear Crossover Trial: yes # Enrolled: 25 % Dropout: 24% # Analyzed: 19 | Intervention: Antidepressant Treatment: Selegiline (n=25) Comparison: Placebo (n=25) Protocol: 2 weeks placebo phase-in, 1 placebo pill 2x daily; next 2 weeks, 1 5-mg tablet of selegiline replaced 1 of the placebo pills; final 2 weeks, 1 5-mg selegiline tablet 2x daily; washout period not stated. Duration of Therapy: 6 weeks | Case Definition: CDC 1988/94 Psychiatric Exclusions: yes Location: United States Patient Source: CFS Center Illness Duration: not reported Mean Age: not reported % Female: not reported Baseline to Followup: 12, 26 weeks
  Somatic: | Fatigue (FSS), Vigor (POMS, ISS), Symptom severity (SX) Disability (FSQ)
  Functional: | Tension, Anxiety (POMS),
  Mood: | Depression (POMS, CESD)
Friedberg^134^ 1994 Randomized: no Double-blinded: yes Crossover Trial: no # Enrolled: 64 % Dropout: 0% # Analyzed: 64 | Intervention: Cognitive Behavioral Therapy Treatment 1: CBT (n=22 CFS) Treatment 2: CBT(n=22 depressed) Comparison: No treatment (n=22) Protocol: 6 weekly sessions focusing on coping; relaxation, tolerance, coping skills and cognitive restructuring. Emphasis on lifestyle changes compatible with activity limitations imposed by CFS. Duration of Therapy: 6-9 weeks | Case Definition: CDC 1988 Psychiatric Exclusions: not stated Location: United States Patient Source: Outpatients with CFS, neurology clinic, and local CFS support group; depressed patients of author Mean Illness Duration: 4.1 years Mean Age: 36.9 years % Female: 75 Baseline to Followup: 6-9 weeks
  Somatic: | Fatigue (FSS)
  Mood: | Depression (CESD), Psychological distress (BSI) Fatigue-related thinking (FRCS)
  Cognitive:
Perrin^154^ 1998 Randomized: no Double-Blinded: no Crossover Trial: no # Enrolled: 80 % Dropout: 28% # Analyzed: 58 | Intervention: Osteopathic Therapy Treatment: Osteopathic therapy (n=40) Comparison: Normal care (n=40) Protocol: Twenty sessions (minimum) including multiple osteopathic treatments. Duration of Therapy: 12 months | Case Definition: CDC 1988 and London criteria for ME Psychiatric Exclusions: yes Location: United Kingdom Patient Source: Patient referrals; control volunteers Illness Duration: not reported Age Range: 18 to 55 years % Female: 68% Baseline to Followup: 12 months
  Somatic: | Symptom severity (BDI, NHP, PFRS, general health, back pain, anxiety, sleep, cognitive function)
Shlaes^142^ 1996 Randomized: no Double-Blinded: no Crossover Trial: no # Enrolled: 12 % Dropout: 17% # Analyzed: 10 | Intervention: Social Support Treatment: Buddy and Mentor (n=6) Comparison: Waiting list control (n=6) Protocol: Buddy 1 hour per week (emotional support, social companionship and instrumental support), Mentor 2 hours per month (information and emotional support regarding living with CFS). Duration of Therapy: 4 months | Case Definition: CDC 1994 Psychiatric Exclusions: not stated Location: United States Patient Source: CFS specialists, support groups, CFS Association Illness Duration: not reported Age Range: 36 to 57 years % Female: 75% Baseline to Followup: 4 months
  Somatic: | Physical fatigue (FSRS)
  Functional: | Physical functioning (MOS), Coping (COPE)
  Mood: | Depression (CESD), Psychological functioning (MOS), Psychological distress (BSI) Cognition Mental fatigue (FSRS)
Marlin^155^ 1998 Randomized: no Double-Blinded: no Crossover Trial: no # Enrolled: 71 % Dropout: 69% # Analyzed: 22 | Intervention: Comprehensive Multidisciplinary Intervention (CMI) Treatment: CMI (n=51) Comparison: Assessed only (n=20) Protocol: Bringing patient under optimal medical management, treating ongoing affective or anxiety disorder pharmacologically, and implementing a comprehensive CBT program by therapist in patient's own environment (individually tailored but included physical exercise, sleep management, activity management, regulation of stimulant intake and reduction in use of symptomatic medications, cognitive intervention designed to deal with patient's beliefs concerning nature of disorder, participation of patient's family, and efforts to establish specific vocational and avocational goals. Duration of Therapy: 3-8 months | Case-Definition: CDC 1994 Psychiatric Exclusions: not stated Location: Canada Patient Source: Multidisciplinary clinic Mean Illness Duration: 4.1 years Mean Age: 41.6 years % Female: 77% Mean Baseline to Followup: 32 months
  Functional: | Return to work

*Abbreviations ADL: Activities of Daily Living BDI: Beck Depression Inventory BERG: Bosch ERG 551 Ergometer BSI: Brief Symptom Inventory CESD: Center for Epidemiology Studies Depression Scale CFQ: Chalder Fatigue Questionnaire CIS: Checklist Individual Strength CGI: Clinical Global Impressions COPE: Coping Strategies Scales CPRS: Comprehensive Psychopathological Rating Scale DAIS: Duke Activity Status Index DSM: DSM-III-R ECOG: Eastern Cooperative Oncology Group Activity Scale EQ: EuroQol Quality of Life visual analogue scale FRCS: Fatigue-Related Cognitions Scale FSQ: Functional Status Questionnaire FSRS: Fatigue Self-Rating Scale FSS: Fatigue Severity Scale GHQ: General Health Questionnaire HADS: Hospital Anxiety and Depression Scale HAMD: Hamilton Depression Rating Scale HICK: Hick Paradigm Reaction Time ISS: Illness Severity Scale KPS: Karnofsky Performance Scale MOS/SF36: Medical Outcomes Study Short Form MPQ: McGill Pain Questionnaire NHP: Nottingham Health Profile PANAS: Positive and Negative Affect Scale POMS: Profile of Mood States PFRS: Profile of Fatigue-Related Symptoms PSC: Physical Symptom Checklist PSQ: Pain and Sleep Questionnaire PSQI: Pittsburgh Sleep Quality Index QAL: Quality of Life visual analogue scale QOL: Quality of Life assessment in GH-deficient adults questionnaire SCL: Symptom Checklist SCL-90 SIP: Sickness Impact Profile STAIS: State and Trait Anxiety Index of Spielberger SX: Symptom Severity Checklist VAS: Symptom severity visual analogue scale WMFI: Wood Mental Fatigue Inventory WMS: Wechsler Memory Scale WSAS: Work and Social Adjustment Scale Zung: Zung Depression Scale

### Immunological Interventions

#### Antiviral Therapy

One randomized trial examined the efficacy of antiviral therapy comparing acyclovir to placebo.^127^ Patients were enrolled in the study using CDC 1988 criteria, had an average duration of illness of 6.8 years, an average age of 34 years and were 70% female. The trial was double-blinded and had an 11% dropout rate. The study showed that treatment was associated with differences in some mood states: levels of anxiety (p=.02), depression (p=.02) and confusion (p<.01) were significantly greater, and anger was marginally greater (p=.07), during acyclovir treatment than during placebo treatment, whereas vigor (p=.12) and wellness scores (p>.5) decreased during acyclovir treatment but not significantly. However, during the treatment phase when patients reported feeling better, their mood profiles revealed significantly higher levels of vigor (p=.03) and sense of wellness (p=.02) as well as a reduction in fatigue (p<.01).

#### Antihistamine Therapy

One randomized trial compared the antihistamine terfenadine (60 mg, twice daily for 2 months) to placebo.^138^ Patients were enrolled using the CDC 1988 criteria. The patients had an average age of 36.2 years and were 77% female; duration of illness was not reported. The trial was double-blinded and had a 7% dropout rate. No therapeutic benefit from terfenadine was detected in terms of symptom relief, improved physical or social functioning, health perceptions, or mental health.

#### Vaccine Therapy

One trial compared staphylococcus toxoid vaccine to placebo given at increasing doses (.01 to 1.0 ml of fully potent vaccine) weekly for 12 weeks (the trial is described in Table 9 because the report did not clearly state if patients were randomized).^156^ Patients were enrolled using the CDC 1994 criteria and also had to have been diagnosed with fibromyalgia. Average duration of illness was 12.9 years, average age was 47 years and all of the patients were female. The trial was reported as double-blinded and had a 14% dropout rate. Patients treated with vaccine were more likely to improve overall clinically than those treated with placebo (p<.05). The two groups did not differ, however, with respect to being worried, concentration difficulties, memory difficulties, sleep difficulties and vegetative symptoms, depression, or pain (p>.05).

#### Immunomodulator/Antiviral

One randomized trial evaluated the efficacy of Ampligen at four doses of 200 mg, then 400 mg twice weekly for 6 months, for treating CFS compared to placebo.^135^ Patients were enrolled using CDC 1988 criteria and the study was limited to severely debilitated patients (Karnofsky performance scores between 20 to 60). Patients' duration of illness averaged 5.2 years with and average age of 35.5 years; 75% of the patients were women. The trial was double-blinded and had a dropout rate of 9%. After 24 weeks, patients receiving Ampligen had increased Karnofsky performance scores (p<.03), exhibited a greater ability to do work during exercise treadmill testing (p=.01), displayed an enhanced capacity to perform the activities of daily living (p<.04), had a reduced cognitive deficit (p=.05) and required less use of other medications (p<.05). Participants given the investigational drug Ampligen had more complaints of dry skin, and participants given placebo had more complaints of insomnia.

#### Immunoglobulin Therapy

Three randomized, placebo-controlled trials evaluated the efficacy of immunoglobulin therapy.^129,130,147^ Two of the trials^129,130^ used the CDC 1988 criteria for enrolling patients, and one^147^ used the 1990 Australian criteria. Patients in the three trials were similar in mean age (36.0, 40.8 and 39.8 years), with patients in one trial^147^ reporting an average duration of illness (6.3 years) twice that of the other two (3.9 and 3.8 years), respectively. The percentage of female patients in the three trials was 49%, 73% and 76%, respectively. All three trials were double-blinded. One study had a dropout rate of 7%.^130^ The remaining two studies had dropout rates of 4% each and reported using an intention-to-treat analysis. Treatment dosages for the three trials were: three monthly treatments at 2 g/kg body weight;^129^ six monthly treatments at 1g/kg;^130^ and the third adult trial employed a dose-response test with three monthly treatments at 0.5, 1 and 2 g/kg.^147^

In the trial that evaluated a 2-g/kg dosage over three months,^129^ patients receiving the immunoglobulin were more likely to have reduction in symptoms and improvement in functional capacity than patients receiving placebo (p=.02). There were no statistically significant differences in quality of life or depression scores. In the trial that evaluated a at 1 g/kg dosage over six months,^130^ there were no statistically significant differences between treatment and placebo on any of the outcome measures except social functioning (favored placebo, p<.05). In the dose response trial,^147^ no statistically significant differences were observed between any of the three dosage levels and placebo groups for any of the reported outcomes.

#### Transfer Factor Therapy

One randomized pilot study compared oral transfer factors (dialyzable extract from immune lymphocytes), with known specific activity against Epstein-Barr virus, Cytomegalovirus and Human Herpes Virus-6, to controls with treatment ranging form 90 to 970 days (mean 328 days).^143^ The authors implied that the 1994 CDC definition of CFS was used. Average duration of illness was not reported, average age was 35 years and 60% of the patients were women. The trial was double-blinded and 10% of the patients dropped out, but the authors reported using an intention-to-treat analysis strategy. However, only 6 of 20 patients were assigned as controls while 14 received active treatment. Also, the 6 patients originally assigned as controls first received unspecific transfer factor, but the investigators “later” switched them to lactose placebo capsules when it became apparent that unspecific transfer factor was associated with clinical effects. Subjective improvement in sore throat, myalgia, arthralgia, headaches or concentration, which was determined by patients and physicians, was reported among 9 of 14 patients given specific transfer factors compared with 3 of 6 patients assigned to the control group, but this difference was not significant (p=.46).

In a separate randomized trial using a four-arm design, investigators compared a transfer factor (dialyzable leukocyte extract, DLE) with cognitive behavioral therapy (CBT, a psychological program with home-based exercise) to DLE-only (attended clinic instead of receiving CBT), CBT and drug placebo, or placebo-only.^132^ Patients were enrolled using the Australia 1990 criteria. Average duration of illness was 5.5 years, average age was 39.6 years and 76% of the patients were women. The trial was double-blinded and only 2% percent of the patients dropped out. All four groups were similar and the end of the study and the only statistically significant difference between the groups was for patients receiving the combination DLE/CBT who recorded a greater improvement in quality of life (p<.05).

#### Interferon Therapy

One randomized trial compared ∞-2a interferon (3 million units, 3 times per week for 12 weeks) to placebo.^140^ Patients were enrolled using CDC 1988 criteria and the trial was double-blinded. The trial had a 13% dropout rate. The average duration of illness was 4.6 years and the average age was 37.2 years; 80% of the patients were female. Compared to placebo, there was no statistically significant improvement in quality of life or clinical well-being for patients receiving interferon.

In a separate study, twenty patients were randomized to receive immediate therapy or to be treated after 3 months of followup, using three mega units of interferon-α2b.^133^ The illness duration of the patients ranged from 1 to 11 years, 70% were women and average age was not reported. The trial was not double-blinded and 10% of the patients dropped out of the study; the authors used an intention-to-treat analysis strategy. The authors did not report any results comparing treated patients to waiting-control patients. Overall, 19 of the 20 patients eventually were treated and 18 tolerated the 12 weeks of therapy. At the end of the study, three patients were reported to have completely recovered (and remained so after 12 months). Two additional patients were improved at the end of followup and eight months later; in all five patients, improvement was first evident one to three months after treatment had ended. The only difference between the responders and nonresponders was that four of the five responders (compared to one of five nonresponders) had detectable coxsackievirus antibody in serum.

### Pharmacologic Interventions (excluding Immunological Therapies)

#### Corticosteroid Therapies

Four randomized trials compared steroid therapy to placebo. Two trials evaluated the mineralocorticoid, fludrocortisone.^149,160^ The other two trials evaluated the glucocorticoid, hydrocortisone.^150,158^ All four trials were double-blinded. The two fludrocortisone trials had dropout rates of 17-20%; the two hydrocortisone trials had dropout rates of 9-10%.

Fludrocortisone dosages were 0.1-0.2 mg per day for 6 weeks in one trial^149^ and 1 tablet (0.1 mg) per day initially and increasing up to 4 tablets per day over 9 weeks in the other trial.^160^ One fludrocortisone trial used CDC 1988/1994 criteria to enroll patients^149^ and the other used CDC 1994;^160^ the patients in the latter trial also had to be diagnosed with neurally mediated hypotension (NMH). The CFS-NHM patients were similar in age (36.8 years) and duration of illness (6.4 years) compared to patients in the other fludrocortisone trial (39.7 years and 6.4 years, respectively); 76% of the patients in the “non-NMH” fludrocortisone trial were female compared to 66% in the “NMH” trial.

In the “non-NMH” fludrocortisone trial, there were no statistically significant differences between patients in the treatment and placebo groups in severity of any symptom or in a test of function for the 20 patients who completed both arms of the crossover trial.^149^ After treatment with fludrocortisone, patients had an average reduction in the severity of lightheadedness of 5.3 at baseline to 4.0 at followup, compared to 5.1 to 5.4 after treatment with placebo (p=.06). After treatment with fludrocortisone, patient time on a treadmill increased from baseline to followup an average of 19.3 to 22.8 minutes, compared to when treated with placebo of 20.0 to 20.2 minutes (p=.08).

In the other fludrocortisone trial, there was no significant difference in the proportion of patients with at least a 15-point improvement in global Wellness scores (14% in fludrocortisone patients, 10% in placebo patients, p=.76).^160^ The mean change in global Wellness scores from baseline to followup was 3.8 for the fludrocortisone patients and 2.7 for the placebo patients (p=.07). There were no significant differences between the two groups on any other outcome measure.

Hydrocortisone dosages were 16 mg/m^2^ body surface per day over 12 weeks,^150^ and 5 or 10 mg per day for 4 weeks.^158^ One hydrocortisone trial used CDC 1988/1994 case definitions to enroll patients^150^ and the other trial used the CDC 1988/Oxford 1991 case definitions.^158^ Patients in both hydrocortisone trials were similar in age (35.3 to 37.5 years), while patients in one trial^150^ had longer duration of illness (4.5 years) and were more likely to be women (80%) compared to the other trial (3.0 years and 57% women).^158^

In the 12-week hydrocortisone trial, patients in the treatment group generally were not statistically different that those in the placebo group for any of the outcome measures.^150^ Treatment group patients did have higher wellness scores (p=.06) and lower anxiety scores (p=.08) than placebo patients that neared statistical significance. Hydrocortisone patients recorded improvement of at least 5, 10, or 15 points on the Wellness scale in higher percentages than control group patients, (5 points, 53% vs. 29%, p=.04; 10 points, 33% vs. 14%, p=.07; and 15 points, 20% vs. 6%, p=.08). Hydrocortisone patients also reported consistently more days in which their average improvement was greater than that of the control group (p<.001, Sign test). Of note, adrenal function was significantly depressed in patients receiving hydrocortisone.

In the four-week hydrocortisone trial, the two doses (5 and 10 mg) had no differential effect on fatigue scores (p=.09) and were therefore combined for comparison against placebo.^158^ Compared to placebo, patients in the treatment group had a greater decrease in mean fatigue score (7.2 vs. 3.3, p<.01). Treatment group patients were more likely to “respond fully” (28% vs. 9%, p=.05), more likely to have a “clinically significant fall in fatigue” (34% vs. 13%, p=.04) and more likely to improve on the clinicians' assessments with the clinical global impression scale (21% vs. 6%, p=.07).

#### Anticholinergic Therapy

One randomized crossover trial compared an anticholinergic inhibitor (galantamine hydrobromide, 10 mg t.i.d., escalating dosage) to placebo over a two-to-eight-week period.^141^ Patients were enrolled using the Oxford 1991 case definition, had an average illness duration of 12.8 years, mean age of 43.9 years and were 86% female. The trial was double-blinded and had a 20% dropout rate. Significant improvements were reported for patients on anticholinergic therapy and for patients on placebo with respect to sleep and myalgia; neither group had significant improvement with respect to fatigue, work capacity, memory or dizziness. The authors did not report any between-group analysis results.

A large trial of 400 patients comparing galanthamine to placebo has been conducted based in part on the positive results reported in the crossover trial described above.^17^ Feedback received during the peer review process of this report suggest the trial may have had negative results and attempts to retrieve unpublished findings from the manufacturer were unsuccessful.

#### Hormone Therapy

One randomized trial compared growth hormone therapy (6.7 μg/kg/day) to placebo for three months.^153^ At the end of the trial all remaining patients (17 of 20) were given growth hormone therapy for an open period of nine months.^153^ Patients were enrolled using the CDC 1994 criteria. Age and duration of illness were not reported; 65% were female. The trail was double-blinded and had a 15% dropout rate. Quality of life did not improve significantly during GH treatment. Quality of life changes were not reported for the placebo group, or as a between-group comparison.

#### Nicotinamide Adenine Dinucleotide (NADH) Therapy

A randomized, placebo controlled, crossover trial of nicotinamide adenine dinucleotide (NADH) was conducted, using a stabilized oral absorbable form (ENADA® with a dosage of 2 5-mg tablets per day over a four-week period.^159^ Patients were enrolled using the CDC 1994 criteria. Average age of patients was 39.6 years and they had an average duration of illness of 7.2 years; 65% of the patients were female. The trial was double-blinded and had a 26% dropout rate. Using an arbitrarily developed symptom scoring system (essentially a percentage of the total possible symptom score which ranged from 50 to 200), 31% of the patients showed 10% improvement while on NADH therapy compared to only 8% while on placebo (p<.05). The findings of this trial may be limited as detailed in a letter to the editor suggesting potential flaws in data transformations and analyses.^165^ In their response to the criticism, the authors pointed out their choice of an analysis strategy was based on the study being preliminary in nature and not a definitive study. As part of the peer review process for this report, several concerns were voiced regarding the quality of this trial.

#### Antidepressant Therapy

Five trials evaluated antidepressant therapy.^136,139,151,152,161^ One randomized trial compared phenelzine to placebo.^136^ One randomized trial compared moclobemide to placebo.^161^ One randomized trial compared fluoxetine to placebo.^139^ A second randomized, 4-arm trial compared fluoxetine with graded exercise, fluoxetine with an exercise placebo, graded exercise with drug placebo, and an arm with exercise and drug placebos.^151^ The fifth trial was not randomized and compared selegiline to placebo. The four randomized trials were also double-blinded and blinding was unclear in the selegiline trial.

The trial evaluating phenelzine and the trial evaluating selegiline enrolled patients using the CDC 1988/94 case definition, the trial evaluating moclobemide used the CDC 1994 definition, and the 2-arm and 4-arm trials evaluating fluoxetine used the Oxford 1991 definition. Patients in the phenelzine trial had an average age of 34.6 years, were 83% women, and had a dropout rate of 25%; illness duration was not reported.^136^ Patients in the moclobemide trial had an average age of 43.5 years, were 54% women, had an average duration of illness of 1.7 years, and had a 14% dropout rate; an intention-to-treat analysis strategy was used.^161^ Patients in the 2-arm fluoxetine trial had an average age of 38.9 years, were 76% women, had an average duration of illness of 5.5 years, and had a dropout rate of 10%.^139^ Patients in the 4-arm fluoxetine trial had an average age of 38.7 years, were 71% women, had an average duration of illness of 2.3 years, and had a dropout rate of 29%; an intention-to-treat analysis strategy was used.^151^ The non-randomized selegiline trial had a dropout rate of 24%, and summary statistics were not reported on mean age, duration of illness or gender distribution.^152^

The patients in the phenelzine trial were given placebo for two weeks, then 15 mg of phenelzine every other day for two weeks, then 15 mg daily for two weeks. The patients in the moclobemide trial were given 300-600 mg daily over six weeks. Patients in the 2-arm fluoxetine trial were given 20 mg fluoxetine daily for two months; those in the 4-arm fluoxetine trial were given 20 mg fluoxetine (or drug placebo) daily for 6 months, graded exercise or exercise placebo that was defined as “a review of activity diaries by the physiotherapist.” Patients in the selegiline trial patients were give one placebo pill twice a day for two weeks, then one 5 mg selegiline pill and one placebo pill each day for two weeks, then a 5 mg pill selegiline twice a day for two weeks.

There were no significant changes between patients receiving phenelzine patients compared to placebo for any of the measured outcomes.^136^ In the moclobemide trial, patients receiving the active agent had significantly increased vigor (p<.05) compared to placebo, but did not improve on other measures (improvement, disability, fatigue or depression).^161^ In the non-randomized selegiline trial, patients receiving active treatment, compared to placebo, improved significantly on three variables.^152^ On the Profile of Mood States instrument, tension/anxiety was reduced and vigor was improved (p<.01); and on the Functional Status Questionnaire, sexual relations were improved for the 12 patients responding to this question (p<.03).

In the 2-arm fluoxetine trial, there were no significant differences between patients receiving the antidepressant compared to placebo, for any of the measured outcomes.^139^ In the 4-arm fluoxetine trial, patients were more likely to drop out of exercise than non-exercise treatment (p=.05).^151^ In an intention-to-treat analysis of these data, the patients in the two exercise groups were less likely (p=.025) to meet case definition for fatigue (92%) than patients receiving exercise placebo (94%) at 26 weeks; and more likely to improve in functional work capacity at 12 (p=.005) and 26 (p=.03) weeks. Fluoxetine had a significant effect on depression at week 12 only (p=.04), and exercise significantly improved health perception (p=.012) and fatigue (p=.028) at 28 weeks.

### Behavioral Interventions

#### Cognitive Behavioral Therapy

One 4-arm randomized trial evaluated cognitive behavioral therapy (CBT) with and without immunological therapy (transfer factor) and four randomized trials evaluated CBT alone.^132,137,145,163,164^ One non-randomized study evaluated CBT alone in a group of CFS patients and a group of patients with depression.^134^ The 4-arm cognitive behavioral therapy with and without immunological therapy has been previously described with other immunological therapy trials.^132^ There was a striking difference between the trials in terms of how CBT was characterized. The four randomized CBT trials were characterized by CBT emphasizing increased activity levels, and compared patients receiving CBT to patients receiving medical care only,^137^ relaxation therapy,^145^ counseling,^164^ and guided support or natural course (no treatment).^163^ In the non-randomized trial, CBT was characterized by an emphasis on lifestyle changes compatible with the limitations placed on the patient by CFS, rather than on increasing activity levels; CFS and depression patients receiving CBT in this trial were compared to patients receiving no treatment.^134^

The CBT/immunological therapy trial enrolled patients using the Australia 1990 case definition,^132^ whereas one randomized trial used the Oxford 1991 criteria,^137^ two trials used the CDC 1994 criteria,^163,164^ and the remaining randomized trial used both the Oxford 1991 and CDC 1994 criteria.^145^ The non-randomized trial used the CDC 1988 criteria.^134^ The 4-arm CBT/immunological trial and the non-randomized CBT trial were described as double-blinded. The 2-arm randomized CBT trials were not double-blinded; only one of the four described blinding methods for assessment of outcomes.^145^ The 4-arm trial had a dropout rate of 2%, the trial comparing CBT to medical care only had zero dropouts, the trial comparing CBT to relaxation had a 12% dropout rate, the trial comparing CBT to counseling had a dropout rate of 18%, and the CBT/guided support trial (compared to natural course or no treatment) had a dropout rate of 3%. The 3-arm non-randomized CBT trial had zero dropouts.

Patients in the 4-arm CBT/immunological therapy trial had an average age of 39.6 years, were 76% women, and had an average illness duration of 5.5 years. Patients in the randomized trial comparing CBT to medical care only had an average age of 36.0 years, were 68% women, and had an average illness duration of 2.6 years. In the randomized trial comparing CBT to relaxation, patients had an average age of 34.5 years, were 68% women, and had an average illness duration of 4.0 years. Patients in the randomized trial comparing CBT to counseling had an average age of 39.4 years, were 73% women and had an average illness duration of 3.2 years. Patients in the randomized trial comparing CBT to guided support to no treatment had an average age of 36.7 years, were 78% women and had an average illness duration of 5.6 years. In the non-randomized 3-arm trial comparing CBT to no treatment, patients had an average age of 36.9 years, were 75% women and had an average illness duration of 4.1 years.

In the 4-arm randomized CBT/immunological therapy trial, all four groups were similar at the end of the study with the only statistically significant difference between the groups was for patients receiving the combination CBT/transfer factor who recorded a greater improvement in quality of life (p<.05).^132^ In the randomized trial comparing CBT to medical care only, the percentage of patients who had attained normal functioning on the Karnofsky scale (score > 80) was significantly greater in the CBT group (73%) than in the medical care group (27%) at 12 months (p<.01); the percentage with an improvement of at least 10 points also was significantly higher in the CBT group (73%) than in the medical care group (23%), (p<.01).^137^ Patients receiving CBT improved more with respect to: percentage interference with activities, number of days in bed per week, distance walked in six minutes, and fatigue severity at five, eight and 12 months; and depression at eight and 12 months. Each of these between-group comparisons was statistically significant (confidence interval for difference between change scores excluded zero, p-values were not reported).

In the randomized trial comparing CBT to relaxation, 70% of the CBT group improved at 6 months compared to 19% of those in the relaxation group (p<.01).^145^ The combined improvement in physical functioning and fatigue was such that by final followup, 48% of the CBT patients no longer fulfilled the CFS diagnostic criteria compared to only 7% of the patients receiving relaxation training (p<.02). Patients in the CBT group also performed better on the Work and Social Adjustment Scale (p<.01), the Long-term Goals Rating (p<.01), the Fatigue Problem Rating (p<.01) and the Fatigue Questionnaire (p<.01). Compared to patients in the relaxation group, higher percentages of CBT patients reported feeling “better or much better” on Global Improvement (70% vs. 31%, p<.01), and “satisfied or very satisfied” with treatment outcome (78% vs. 50%, p<.05); higher percentages of CBT patients were rated “better or much better” by assessor rating for physical functioning (80% vs. 26%, p<.01) and fatigue (72% vs. 17%, p<.01). Patients receiving CBT were statistically more likely to remain improved after five years compared to those in the relaxation group and were working more hours; the two groups were not different with respect to general health, fatigue or physical functioning.

In the randomized trial comparing CBT to counseling, patients receiving CBT group did not improve compared to those receiving counseling with respect to fatigue, social functioning, depression or anxiety.^164^ In the 3-arm study comparing CBT to guided support or natural course, CBT patients were statistically more likely that those in guided support to improve with respect to quality of life, fatigue, physical function, functional impairment and mental health; the patients in the two groups were similar with respect to hours working on a job.^163^ Compared to natural course patients, those in the CBT group were statistically more likely to improve with respect to fatigue, physical functional status, functional impairment and mental health (at 8 months, not at 14 months); patients in the two groups were similar with respect to quality of life and hours working on a job. The authors did not report findings comparing guided support to natural course patients, but the percent clinical significant improvement for fatigue severity (13% vs. 13%, respectively), functional status (16% vs. 12%) and overall improvement (17% vs. 30%) for both groups were very similar; both groups had much lower percentage clinical improvement than patients receiving CBT for these three outcomes (33%, 41% and 57%, respectively), at post-test (8 months). A similar pattern was reported at followup (14 months).

In the non-randomized trial comparing CBT (emphasizing lifestyle changes compatible with limitations imposed by CFS) to no-treatment, there were no significant differences between the groups with respect to depression or stress symptoms at termination of treatment.^134^ Fatigue severity remained significantly elevated for both CFS groups (those receiving CBT and no treatment) than for the depressed patients receiving CBT (p<.0002).

#### Graded Exercise Therapy

One 4-arm randomized trial evaluated graded exercise therapy (GET) with and without antidepressant therapy (fluoxetine) and one randomized trial evaluated GET alone.^146,151^ The 4-arm trial compared GET with fluoxetine, GET with drug placebo, and fluoxetine with an exercise placebo (no specific advice offered; told to do what they felt capable of doing and to rest when needed) to exercise and drug placebos.^151^ The 2-arm trial compared GET (supervised weekly aerobic exercise sessions with home exercise prescription) to flexibility/relaxation training.^146^ Patients in both trials were enrolled using the Oxford 1991 criteria.

Patients in the 4-arm fluoxetine trial had an average age of 38.7 years, were 71% women, had an average duration of illness of 2.3 years; the trial had a dropout rate of 29%.^151^ In the 2-arm trial, patients had an average age of 37.2 years, were 75% female and had an average illness duration of 2.7 years; the trial had a dropout rate of 29%.^146^ Intention-to-treat analysis strategies were used in both studies. The 4-arm trial was double-blinded (other than receiving exercise or exercise placebo). Patients in the 2-arm trial could not be blinded but randomization was achieved blindly to the psychiatrist and independently of the exercise physiologist.

In the 4-arm GET/fluoxetine trial, patients were more likely to drop out of exercise than non-exercise treatment (p=.05).^151^ In an intention-to-treat analysis of these data, the patients in the two exercise groups were less likely (p=.025) to meet case definition for fatigue (92%) than patients receiving exercise placebo (94%) at 26 weeks; and more likely to improve in functional work capacity at 12 (p=.005) and 26 (p=.03) weeks. Fluoxetine had a significant effect on depression at week 12 only (p=.04), and exercise significantly improved health perception (p=.012) and fatigue (p=.028) at 28 weeks. In the 2-arm trial, patients in the exercise group were more likely to rate themselves improved (52%) than in the flexibility/relaxation group (27%), p = .04^146^ Compared to flexibility/relaxation, patients in the exercise group were significantly better in fatigue (p=.04), functional capacity (p=.01) and fitness (p=.03).

#### Educational Intervention

A randomized 4-arm trial evaluated the efficacy of education explaining symptoms to encourage graded exercise about the importance of exercise.^162^ The trial compared three levels of educational intervention to a group of patients receiving standard medical care only. All patients in the three educational arms received two individual treatment sessions, two telephone followup calls, and a comprehensive educational packet. The patients in the “minimal” intervention group received no further treatment. Those in the “telephone” group received seven additional followup calls. Those in the “maximum” group received seven additional face-to-face sessions. Patients were enrolled using the Oxford 1991 criteria and the trial was not double-blinded. Patients had an average age of 33.4 years, were 78% female, and had an average illness duration of 4.3 years. The trial had a dropout rate of 14%. The patients in all three educational intervention arms, compared to patients receiving standard medical care, were statistically more likely to improve overall and with respect to fatigue and physical functioning. However, there were no statistically significant differences between patients in any of the three educational arms.

### Complementary and Alternative Medicine Interventions

#### Homeopathic Therapy

One randomized trial compared homeopathic therapies to placebo.^166^ Patients were enrolled using the Oxford 1991 case definition. The trial was double-blinded and had a 5% dropout rate. Patients had an average age of 40.2 years, were 70% female, and had an average illness duration of 5.1 years. A greater percentage of patients in the homeopathic group improved compared to placebo, but the authors do not provide any statistical analysis results for within- or between-group comparisons.

#### Massage Therapy

One randomized trial compared massage therapy to an attention control using sham TENS.^148^ Patients were enrolled using CDC 1988 criteria. The trial was not double-blinded and reported zero dropouts. Patients had an average age of 47 years and were 80% female; duration of illness was not reported. Patients in the massage therapy group, compared to sham TENS, significantly improved on depression (p<.05), anxiety (p<.05), fatigue (p<.05), sleep (p<.05), severity of symptoms (p<.05) and pain (p<.05).

#### Osteopathic Therapy

One non-randomized trial compared osteopathic therapy to normal care.^154^ Patients were enrolled using the CDC 1988 criteria and also had to meet the London criteria for ME. The trial was not double-blinded and had a dropout rate of 28%. Patients ranged in age from 18 to 55 years and were 68% female; duration of illness was not reported. Patients receiving osteopathy were statistically more likely to be improved overall.

### Nutritional Supplement Interventions

#### Magnesium Therapy

One randomized trial compared weekly injections (over 6 weeks) of 50% injectable magnesium sulfate (1 g in 2 ml) to placebo.^131^ Patients were enrolled using the CDC 1988 and Australia 1990 criteria. The patients had an average age of 36.4 years and were 69% female; duration of illness was not reported. The trial was double-blinded and had a 3% dropout rate. Patients in the treatment group improved significantly in overall health (Nottingham Health Profile, p<.01) energy (p<.01), pain (p=.01) and emotional reactions (p=.01). Eighty percent of those in the treatment group claimed to have benefited from treatment compared to only 18% of the placebo group (p<.01). The average red blood cell magnesium level, at baseline, was 1.29 mmol for patients in the treatment group and 1.28 mmol for patients in the placebo group. At the end of the study, red blood cell magnesium increased in patients receiving active treatment an average of 0.57 mmol but decreased in those receiving placebo by 0.02 mmol (no significance tests reported); after treatment, red blood cell magnesium was within the normal range in all patients receiving active treatment but in only one patient receiving placebo.

#### Essential Fatty Acid Therapy

One randomized trial compared essential fatty acid (EFA, 4000 mg per day for 3 months; Enfamil Marine capsules containing evening primrose oil and concentrated fish oil) to placebo (sunflower oil).^157^ Patients were enrolled using the Oxford 1991 criteria. Patients had an average age of 37.1 years, were 58% female, and had an average illness duration of 4.0 years. The trial was double-blinded and had a dropout rate of 24%. Symptom scores for both groups improved with time, but the placebo group improved more than the treatment group, though the change was not statistically significant.

#### Liver Extract Therapy

One randomized trial compared an extract of bovine liver (LEFAC, 10 μg/mL cyanocobalamin equivalent, containing 0.4 mg/mL folic acid and 100 μg/mL cyanocobalamin, self-administered by 2-mL injections for one week) to placebo.^128^ Patients were enrolled using the CDC 1988 criteria. The patients had an average age of 40.4 years and were 78% female; duration of illness was not reported. The trial was double-blinded and had a dropout rate of 7%. There were no statistically significant differences between treatment and placebo groups, and the authors reported a strong placebo response.

### Other Interventions

#### Social Support Therapy

One nonrandomized, unblinded trial with 12 participants evaluated the efficacy of social support using a buddy/mentor program compared to no treatment.^142^ Buddies were individuals in the community willing to spend one hour per week with the patient for the purpose of providing emotional support, social companionship and instrumental support.

Mentors were individuals with CFS who were willing to spend two hours per month of phone contact with the patient providing information and emotional support regarding living with CFS; the program duration was four months.The study participants were enrolled using the CDC 1994 criteria (personal communication), ranged in age from 36 to 57 years and were 75% female; duration of illness was not reported. Six participants were assigned buddies and mentors based on whether such persons were living in the same area, while the remaining six participants were put on a waiting list. The participants receiving the buddy/mentor program reportedly had significantly greater reductions in fatigue (p<.03), and marginally significant increases in positive thinking (p=.08), but were not different from the no-treatment participants with respect to depression, psychological distress, perceived stress, coping strategies and perceived social support.

#### Comprehensive Therapy

In a non-randomized, unblinded trial, patients receiving a comprehensive, multidisciplinary intervention (including medical, psychological and behavioral therapies) were compared to another group of patients who had been assessed but not treated.^155^ The patients were enrolled using the CDC 1994 definition and had an average illness duration of 4.1 years, an average age of 41.6 years and were 77% female. The trial had a dropout rate of 69%. Three-fifths of the treated group had returned to work at the completion of therapy but these results were not contrasted with patients in the assessment-only group.

### Summary of the Evidence

The array of interventions presented in this systematic review reflects, in part, the difficulty in treating a disease that has not been uniformly defined or accepted. The interventions are represented by a mixture of pharmacological (including immunological) and non-pharmacological therapies, varying dosages and duration of therapies, different populations (case definition and patient source), and different exclusion criteria resulting in a body of literature that is conceptually and clinically heterogeneous. Adding to this heterogeneity is the multitude of patient outcomes that were measured (both at the construct and operationalization levels) and reported, and the array of instruments used to measure the constructs. Due to the substantial heterogeneity, members of the technical expert panel agreed with our recommendation to not quantitatively synthesize the individual study findings using meta-analysis.

In lieu of a quantitative synthesis, individual study findings are qualitatively summarized by presenting the statistical significance results of between-group contrasts (e.g., immunoglobulin vs. placebo, cognitive behavioral therapy vs. no treatment) as one of three possible conclusions: 1) results favoring patients receiving the active therapy; 2) results favoring patients receiving the placebo (or no therapy or other therapy); or 3) no statistically significant difference between patients in either group. This presentation of statistical significance results is provided in Tables 10 through 17.

The tables present only the statistical significance of between-group contrasts and only when reported by the authors or when, in the absence of reporting, a significance test could be employed with the information provided. Within-group significance test results (e.g., baseline to followup differences within a single study arm) are not reported in these tables and studies only reporting within-group results are therefore omitted. Similarly, studies with more than two arms are represented more than once as they offered multiple contrasts. Finally, only those variables, which were reported most often across all studies, are included; variables that were unique to a single study are not represented in these tables.

The rows are sorted by type of intervention and CFS case definition. Information is also provided regarding the quality of each study in terms of method of assignment (randomized or not), blinding (double-blinded or not double-blinded), number of patients enrolled in the study and the dropout percent. Outcomes are presented a series of two sets of tables. The first set presents outcomes grouped by those of a more general nature (improvement, quality of life, and wellness), and those of a more somatic nature (fatigue, vigor and/or energy, sleep disturbances, severity of symptoms, pain, myalgia, headache, arthralgia, post-exertional fatigue, muscle weakness, and dizziness and/or lightheadedness). The second set of tables present outcomes sorted by functional (physical functioning, activity level, impairment and/or impairment, social functioning, occupational functioning), mood (depression, anxiety, mental health, distress, confusion and mental fatigue) and cognitive (memory and/or forgetfulness, cognitive function, and concentration) groupings.

Between-group significance test results were not always measured and/or reported by all studies or by all contrasts within multi-arm studies. Of those reporting between-group significance test results, fatigue was reported most often (31 contrasts) followed by depression (28 contrasts). Overall improvement was the next most frequently reported (17 contrasts), followed by physical functional status (16 contrasts), and activity and vigor/energy (11 contrasts each). Quality of life, functional impairment, and social functional status were each reported in ten contrasts, followed by wellness, sleep, anxiety and confusion, each reported in 8 contrasts. The remaining outcomes were reported less frequently.

Using symbols to represent significance tests in favor of the group of patients receiving the active therapy (↑), favoring patients receiving the “placebo” or no treatment (↓), or no statistically significant difference in outcomes between patients in either group ([image]), the most striking pattern in this series of tables is the inconclusiveness of study findings regarding the efficacy of most therapies for CFS. The most consistent pattern of improvement of outcomes was provided by behavioral interventions and particularly those that emphasize increased activity levels. General, these behavioral interventions significantly improved fatigue and functional status. Most of the evidence regarding efficacy of immunologic and other pharmacologic therapies are inconclusive. In the Acyclovir trial, patients receiving the active agent were significantly more depressed, confused and higher levels of anxiety than those receiving placebo. One trial of Ampligen suggests improvement in functional status. One trial of hydrocortisone, a glucocorticoid, may improve fatigue and functional status, but may also result in significant suppression of adrenal function. The evidence regarding efficacy of anti-depressants is inconclusive. Magnesium sulfate therapy may be beneficial for CFS patients who are magnesium deficient. The evidence regarding efficacy of other therapies is inconclusive.