# Appendix B: Glossary of included terms

Absolute risk reduction (ARR): The risk difference in outcome rates between two experimental groups. It is the difference between the unexposed or control event rate (CER) and the treated or experimental event rate (EER).

Bias: Systematic error in study design that may skew the truth.

Blinded, masked, or unaware: Blinded studies purposely deny access to information in order to keep that information from influencing some measurement, observation, or process. The intent of blinding is to reduce bias. In a single-blinded trial, the study subject is not aware of which group or intervention the subject has been assigned. In a double-blinded trial, neither the study subject nor the study staff is aware of which group or intervention the subject has been assigned.

Case-control: A comparison of causal factors, clinical findings, or exposures in a group of cases and a group of controls. Cases already possess the outcome of interest at the time the causal factors are measured. Incidence and risk cannot be measured directly; relative risk is estimated by the odds ratio.

Case series: A description of a group of individuals with a particular disease.

Cluster analysis: A statistical technique for classifying individuals into a coherent set of categories, such as diagnostic groups, based on a similarities among individuals on a set of measurements. In contrast, discriminant analysis is used when the categories are either unknown or unspecified prior to conducting the analysis.

Cohort: A study of a defined population at risk, whereby the cases are ascertained by continuous surveillance and the comparison group is not selected, but evolves naturally. Exposure is measured before development of disease. Incidence, risk, and relative risk are measured directly. Prospective cohorts collect follow-up observations after the study has begun, whereas retrospective cohorts use follow-up observations that have been recorded in the past.

Cointervention: Interventions other than the primary treatment under study. If other interventions, such as the use of bedrest or low salt diets, are applied differently to the treated and comparison groups, biased or erroneous interpretations are possible.

Confidence interval (CI): A range of values consistent with the experimental data that provides a measure of precision or uncertainty. The frequently used 95% CI is commonly defined as the range of values within which we can be 95% sure that the true value lies for the whole population of patients from whom the study patients were selected. CIs provide us with the “neighborhood” within which the true value likely resides. Clinical research provides a “point estimate” of effect from a sample of patients; and CIs express the degree of uncertainty or imprecision on either side of the point estimate. The width of the CI is largely affected by the square root of the sample size; thus the larger the sample size, the more narrow/precise is the CI.

Confirmatory factor analysis: A type of factor analysis where the number and type of coherent constructs or dimensions measured by a set of questionnaires or questionnaire items are known; and, the researcher assigns questionnaire scores or items to the known constructs prior to the analysis. Confirmatory factor analysis tests hypotheses about the number and type of constructs measured and whether or not the questionnaire scores or items are correctly assigned to the hypothesized constructs. See Factor Analysis.

Confounding variable: This technical phrase is used for any characteristic of the study subjects, study setting, or interventions that is extraneous to the study question, that could cause (or influence the chance of) the clinical events of interest and that might be unevenly distributed between the treatment groups. For example, in a study of whether gray hair causes death, since advancing age is associated with gray hair, and advancing age is also associated with mortality, then age could be considered a confounding variable.

Construct: A name we give to condition or quality nature that we cannot observe directly, but whose existence and properties can be inferred from actions or events that we can see.

Cronbach's Alpha: A statistical measure of the internal reliability or consistency of questionnaire items that measure a common construct: such as, fatigue or fatigue severity. Its values range from 0 to 1. The closer the number is to 1, the greater the association among the items; thus, measuring the degree to which the items reliably or consistently measure the construct.

Delphi process: A consensus-building technique used to establish an agreed upon set of assumptions, opinions, judgments or numerical values used in research. It is most often used in decision analysis and economic evaluations.

Discriminant analysis: A multivariate statistical technique used to identify which measurements-among a set of measurements, such as, clinical signs and symptoms or scores on questionnaires-distinguish one category of individuals from another. The categories into which individuals are classified are known prior to the analysis.

Dropout: When a study subject withdraws or is removed from a study group for any reason, that subject is termed a dropout.

Effect size: A statistical measure of the magnitude of a treatment effect; usually measured in terms of the size of a mean difference or the strength of a relationship.

Efficacy: The ability of an agent to produce intentional actions, effects, or results in a therapy situation. Efficacy is commonly used to describe how well an agent works in the controlled settings of research studies, rather than in routine clinical practice.

Exploratory factor analysis: A type of factor analysis where neither the number nor type of coherent constructs or dimensions being measured are known or specified prior to the analysis. See Factor Analysis.

Factor analysis: A multivariate statistical technique used to identify the number and type of coherent constructs or dimensions captured in a set of measurements (such as, scores on questionnaires) or questionnaire items. Factor Analysis can take one of two forms: exploratory or confirmatory. The form or type of factor analysis used depends on how much is known about the number and type of coherent constructs prior to the analysis and whether or not the researcher specifies the assignment of measures and items to each construct prior to the analysis.

Incidence: Number of new cases of disease occurring during a specified period of time; expressed as a percentage of the number of people at risk.

Intercorrelation matrix: A symmetric tabular arrangement of simple correlations among measurements.

Latent class analysis: A multivariate statistical technique used to characterize unobserved or latent categorical variables based on an analysis of observed or manifest categorical measures. It is a categorical data analog to factor analysis. See Factor Analysis.

Latent variable: A name given to an unobserved construct (such as, Fatigue) whose existence can only be inferred or measured indirectly from a set of observed measures.

Latent variables models: A multivariate statistical technique that analyzes the structural relationships among a set of latent variables. Other terms used to describe this statistical technique are Structural Equation Models or LISREL Models

LISREL model: A name derived from a specific statistical software package use to analyze Latent Variables Models or Structural Equation Models.

Linear regression: A statistical technique to predict the value of a single continuous response variable from the values on one or more explanatory or predictor variables. Analyses involving more than one predictor variable are referred to as Multiple Linear Regression analyses. See also Stepwise Selection.

Logistic regression: A statistical technique to predict the value of a single dichotomous (yes/no, true/false, alive/dead) response variable from the values on one or more explanatory or predictor variables. Analyses involving more than one predictor variable are referred to as Multiple Logistic Regression analyses. See also Stepwise Selection.

Longitudinal study: A research design that collects repeated measurements on a sample of individuals over specified intervals. The aim of a longitudinal study is to reveal patterns of change with respect to developmental issues or the progression or recovery following a disease or some other historical or environmental event.

Meta-analysis: A systematic review that uses quantitative tools to summarize the results.

Meta-regression: A class of procedures used to test hypotheses about the relationship between a study-level effect size estimate and one or more explanatory variables.

Multivariate statistical methods: A class of statistical techniques that permits the simultaneous analysis of 2 or more dependent or response measures.

Non-equivalent group design: A quasi-experimental research design where some process other than randomization is used to assign conditions of interest to individuals. Conditions of nature, such as a subject characteristic or an environmental event or exposure, are used to assign individuals to the groups. Synonymous terms include non-equivalent control group studies or post hoc studies.

Odds: The probability that an adverse event will occur divided by the probability that it will not occur.

Odds ratio: A ratio that describes the odds that a patient in an exposed or intervention group suffers an adverse event relative to the odds that a control patient suffers an adverse event. When the outcome of interest is infrequent, the odds ratio very closely approximates the relative risk.

Point estimate: This phrase refers to the actual numerical result of the effect size found in a trial. The word “estimate” reminds us that any single result may not be the absolute truth, but rather an estimate of the true value.

Probability: A number between 0 and 1 that indicates how likely an event is to occur.

Practice guidelines: Systematically developed statements to assist practitioner and patient decisions about appropriate health care for specific clinical circumstances. They are a set of statements, directions, or principles presenting current clinical rules or policy concerning proper indications for performing a procedure or treatment or for the proper management of specific clinical problems.

Prevalence: Proportion of persons affected with a particular disease at a specified time. Prevalence rates obtained from high quality studies can inform the clinician's efforts to set anchoring pretest probabilities for their patients.

Principle component analysis: A type of exploratory factor analysis used to reduce a set of measures into a smaller number of latent variables. See Factor Analysis.

Prognosis: The possible outcomes of a disorder and the frequency with which they can be expected to occur.

Publication bias: Because studies producing positive results are more likely to be published than those producing negative results, systematic reviews that include only published studies may be susceptible to “publication bias,” thus yielding results more positive than the true effect.

Randomized controlled trial (RCT): An experimental research study where the allocation of participants to groups is by a formal chance process such that each patient has an independent fixed (generally equal) chance of selection for either the intervention or comparison group. Investigators assess results comparing outcomes in the treatment and control groups. This process is meant to reduce bias and to provide the fairest and most rigorous comparison of efficacy of a treatment.

Rechallenge: A test of recurrence of a specific event or side effect upon re-administration or re-exposure of an agent.

Relative risk (RR): This phrase denotes one of several ways to quantitatively describe the strength of association between a suspected cause and its presumed effect. The relative risk is a ratio of two risks, namely the risk of the outcome in those exposed to the suspected cause compared with the risk of the outcome in those not exposed. A relative risk of one represents no association between the suspected cause and the presumed effect. A relative risk above one means the exposure is associated with the outcome, and the larger the number the stronger the association. Conversely, a relative risk smaller than one means the exposure is “negatively associated” with the outcome, which suggests the exposure may protect against the outcome.

Reliability: A property of a questionnaire or psychological test that assesses the consistency of scores across time, samples of items or raters.

Risk difference: The difference between the proportion of events that occur in the intervention group and the proportions that occur in the control group.

Risk ratio: The measure of the relative risk of an outcome in the intervention group compared to the risk in the control group.

Structural equation modeling (SEM): A multivariate statistical technique that simultaneously uses factor analysis to define latent variables and latent variable modeling to analyze the structural relations among the latent variable. See Latent Variable Models

Sensitivity analysis: Any test of the stability of the conclusions of the health care evaluation over a range of probability estimates, value judgments, and assumptions about the structure of the decisions to be made.

Statistical heterogeneity: The term applied when differences between study results are not due to chance alone. Significant heterogeneity suggests important variances in the studies. Sources of heterogeneity include different types of study participants, varying diagnoses, different treatment strategies, and multiple outcome measures.

Stepwise selection: A statistical technique used with multiple linear or logistic regression to reduce a large set of predictor variables to a smaller subset that predicts the response or outcome nearly as well as the larger set of predictor variables. See also Logistic Regression and Multiple Linear Regression.

Systematic review (SR): Comprehensive summary of best available evidence that: addresses sharply defined questions, systematically identifies pertinent evidence, and critically appraises and synthesizes studies.