# Appendix A: Contributors

## Acknowledgments

We owe a major debt of gratitude to the following teams of multidisciplinary experts who assisted in preparing this report.

### Technical Experts

Our panel of technical experts played an active role throughout the preparation of this report, particularly in these areas:

- Selecting the research questions,
- Suggesting the types of data to be abstracted from pertinent studies,
- Guiding the selection of relevant data to include in the evidence tables,
- Reviewing the draft report, and
- Suggesting effective methods to disseminate the final report to health professionals, policy makers and consumers.

- Susan Abbey, MD
- Program Head: Medical Psychiatry
- University of Toronto, Toronto, Ontario, Canada

- Dedra Buchwald, MD
- Director, Chronic Fatigue Syndrome Cooperative Research Center
- University of Washington
- Seattle, WA
- Representing: American College of Physicians/American Society of Internal Medicine

- Peter Campion, PhD, FRCGP, MRCP
- Professor of Primary Care Medicine
- University of Hull
- Representing: United Kingdom National Task Force on CFS/ME

- Mark Demitrack, MD
- Eli Lilly & Company
- Indianapolis, IN

- Sudhir Gupta, MD, PhD
- Professor of Medicine
- Chief Basic & Clinical Immunology
- University of California, Irvine
- Irvine, CA
- Representing: American Association for Chronic Fatigue Syndrome

- Leonard A. Jason, PhD
- DePaul University
- Department of Psychology
- Chicago, IL

- James F. Jones, MD
- National Jewish Medical and Research Center
- Denver, CO

- Nancy G. Klimas, MD
- Professor of Medicine
- University of Miami
- Coral Gables, FLA

- Robert H. Loblay, MD
- Senior Lecturer, Immunology
- Department of Medicine
- University of Sydney, Australia
- Representing: Royal Australasian College of Physicians Working Group on CFS

- David Morens, MD
- National Institutes of Health
- Representing: National Institute for Allergy and Infectious Disease (ex-officio)

- Kathy Rabin, JD
- Rabin & Rabin, Co.
- Boston, MA
- CFS Patient/Consumer

- William (Bill) Reeves, MD, MSPH
- Chief, Viral Exanthems and Herpesvirus Branch
- Centers for Disease Control and Prevention
- Atlanta, GA
- Representing: Centers for Disease Control and Prevention (ex-officio)

- John H. Renner, MD (served until his death in September 2000)
- President
- National Council for Reliable Health Information
- Independence, MO
- Representing: American Association of Family Physicians

- Joan Shaver, PhD, RN, FAAN
- Professor and Dean
- University of Chicago
- College of Nursing
- Chicago, IL

- Eng M Tan, MD
- Scripps Research Institute
- Department of Molecular and Experimental Medicine
- La Jolla, CA

- Vicki C. Walker
- Research and Public Policy Project Manager
- Charlotte, NC
- Representing: The Chronic Fatigue and Immune Dysfunction Syndrome Association of America

- Peter D. White, MD
- Senior Lecturer, Psychological Medicine
- St. Bartholomew's and the Royal London School of Medicine and Dentistry of Queen Mary and Westfield College
- London, UK

### Peer Reviewers

The following reviewers offered feedback on the draft report.

- Edgar R. Black, MD
- Chief Medical Officer
- Blue Cross Blue Shield of the Rochester Area
- Rochester, NY

- Pascale De Becker, PhD
- Faculty of Medicine and Pharmacy
- Vrije Universiteit Brussel
- Brussels, Belgium

- Terry E. Hedrick, MA, PhD
- CFS patient, retired. Formerly Assistant Comptroller General for Program Evaluation, US General Accounting Office
- Cobb Island, MD

- Ian Hickie, MD
- St. George's Hospital
- Kogarah, Australia

- Anthony L. Komaroff, MD
- Professor of Medicine
- Editor in Chief, Harvard Health Publications
- Harvard Medical School
- Boston, MA

- Paul H. Levine, MD
- Clinical Professor of Epidemiology and Biostatistics
- The George Washington University School of Public Health and Health
- Services
- Washington, DC

- Andrew Lloyd, MBBS, MD, FRACP
- Associate Professor
- Inflammation Research Unit
- School of Pathology
- University of New South Wales
- Sydney, Australia

- Phillip K. Peterson, MD
- Professor of Medicine
- University of Minnesota Medical School
- Director, Division of Infectious Diseases
- Department of Medicine
- Hennepin County Medical Center
- Minneapolis, MN

- Peter Rowe, MD
- Professor, Department of Pediatrics
- Johns Hopkins University School of Medicine
- Baltimore MD

- Michael Sharpe, MD
- Senior Lecturer, Psychological Medicine
- Department of Psychiatry, The University of Edinburgh,
- Edinburgh, UK

- Amanda J Sowden PhD
- Associate Director
- NHS Centre for Reviews and Dissemination
- University of York
- York UK

- Jonathan Sterling
- Treasurer
- Chronic Fatigue and Immune Dysfunction Syndrome Association of America
- Oradell, NJ

- Umberto Tirelli, MD
- Director Division of Medical Oncology A
- Chief CFS Unit
- National Cancer Institute
- Aviano, Italy

- Simon Wessely, MD, FRCP
- Professor of Epidemiological and Liaison Psychiatry
- Guy's, King's & St Thomas' School of Medicine and Institute of Psychiatry
- London, UK

- Theresa L. Whiteside, PhD
- Director, UPCI Immunologic Monitoring and Diagnostic Laboratory
- Professor of Pathology
- Department of Pathology
- University of Pittsburgh School of Medicine
- Pittsburgh, PA

### San Antonio Evidence-based Practice Center Staff

- Director, principal investigator
- Cynthia D. Mulrow, MD, MSc, FACP

- Project director
- Gilbert Ram?rez, DrPH

- Statistician
- John E. Cornell, PhD

- Data abstractors
- Christine Aguilar, MD, MPH
- Jodi Sapp, RN

- Research trainee
- Karen Allsup, BS

- Librarian
- Molly Harris, AHIP, MLS, MA

- Technical writer, peer review coordinator
- Karen Stamm

- Administration/Computer resources
- Annie Almanza
- Linn Morgan
- Dave Mullins