# Appendixes

Appendix A: Contributors

Appendix B: Glossary of included terms