# Evidence Tables

Evidence Table 1. RCTs and CCTs With Nonherbal Comparison Arms

First author
Year | | | | | Intervention groups
Title | | Diagnosis | | | Intervention
Location | | Diagnostic criteria | | | Plant parts used
Study design | | Gender | | Time at followup | # Entering study
Jodad | | Age | | | # Completing study | | Outcomes
Azad Khan | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Placebo, diet | | Arm 1 outcomes: FBS, PPBS
1979 | | Diagnostic criteria: | FBS and GTT
Coccinia indica in the treatment of patients with diabetes mellitus | | | | | Plant part: | N/A | 2-hour PPBS decreased from 255.1 to 252.0 (ns). FBS decreased from 195.5mg/dl to 181.3mg/dl(NS)
| | % Female: | 18 | | Preparation: | N/A
| | % under 18: | Not reported | | N entering: | 20
Location of treatment: | India Sub-continent | % over 65: | Not reported | | N completing: | 16
Study design: | RCT | | | | Arm 2: Coccinia indica , diet | | Arm 2 outcomes: FBS, PPBS
Total Jadad score: | 4 | | | | Plant part: | Leaf | 2-hour PPBS decreased from 245.4 to 186.9 (p<0.01). FBS decreased from 178.8mg/dl to 122.1mg/dl (p<0.01)
Randomized: | Yes | | | | Preparation: | Freeze-dried leaf powder
Randomization appropriate: | Not described | | | | N entering: | 18
Double-blind: | Yes | | | | N completing: | 16
Blinding appropriate: | Yes
Withdrawals/dropouts described: | Yes
Agrawal | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Placebo, diet | | Arm 1 outcomes: FBS, PPBS, cholesterol
1996 | | Diagnostic criteria: | FBS and GTT
Randomized placebo-controlled, single-blind trial of holy basil leaves in patients with non-insulin-dependent diabetes mellitus | | | | | Plant part: | Leaf | Placebo before holy basil in this group.
| | % Female: | 38 | | Preparation: | Powdered leaf | FBS decreased from 132.4 mg/dl to 97.2 (p<0.01). Over all the FBS changed by –17.6% (p<0.001), the PPBS changed by –7.3% (p<0.02) and the serum cholesterol changed by 6.5% (p<0.05) with holy basil therapy.
| | % under 18: | 0 | | N entering: | 40
| | % over 65: | 0 | | N completing: | 40
Location of treatment: | India Sub-continent
Study design: | RCT
Total Jadad score: | 1 | | | | Arm 2: Holy basil, diet | | Arm 2 outcomes: FBS, PPBS, cholesterol
Randomized: | Yes
Randomization appropriate: | Not described | | | | Plant part: | Leaf | Holy basil before placebo in this group. For results see arm 1.
Double-blind: | No | | | | Preparation: | Powdered leaf
Blinding appropriate: | Not applicable | | | | N entering: | 40
Withdrawals/dropouts described: | No | | | | N completing: | 40
Chandola^*^ | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: C. tamala , diet | | Arm 1 outcomes: FBS
1980a | | Diagnostic criteria: | FBS and GTT
Hypoglycaemic response of C.tamala in patients of maturity onset (insulin independent) diabetes | | | | | Plant part: | Leaf | Mean fasting blood sugar improved from 153.44 mg/dl to 112.65 mg/dl (p<0.001) at the end of 1 month.
| | % Female: | 5 | | Preparation: | Dried powder
| | % under 18; | 0 | | N entering: | N/A
Location of treatment: | India Sub-continent | % over 65: | 13 | | N completing: | 32
Study design: | CCT
Total Jadad score: | 0
Randomized: | No
Randomization appropriate: | No
Double-blind: | No | | | | Arm 2: Diet | | The mean fasting blood sugar increased from 156.37 mg/dl to 164.12 mg/dl (p<0.01) at the end of 1 month.
Blinding appropriate: | No
Withdrawals/dropouts described: | No | | | | Plant part: | N/A
| | | | | Preparation: | N/A
| | | | | N entering: | N/A
| | | | | N completing: | 8
Kamble | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: No intervention | | Arm 1 outcomes: GTT, cholesterol, phospholipid, triglycerides, free fatty acids
1996 | | Diagnostic criteria: | FBS and GTT
Efficacy of Coccinia indica W. & A. in diabetes mellitus | | | | | Plant part: | N/A
| | % Female; | Not reported | | Preparation: | N/A
| | % under 18; | 0 | | N entering: | Not reported
Location of treatment: | India Sub-continent | % over 65; | 0 | | N completing: | 15
Study design: | CCT | | | | Arm 2: Diet | | Arm 2 outcomes: GTT, cholesterol, phospholipid, triglycerides, free fatty acids
Total Jadad score: | 0 | | | | Plant part: | N/A
Randomized: | No | | | | Preparation: | N/A
Randomization appropriate: | No | | | | N entering: | Not reported
Double-blind: | No | | | | N completing: | 30
Blinding appropriate: | No
Withdrawals/dropouts described: | No
| | | | | Arm 3: Coccinia indica , diet | | Arm 3 outcomes: GTT, cholesterol, phospholipid, triglycerides, free fatty acids
| | | | | Plant part: | Leaf
| | | | | Preparation: | Tea/decoction, decoction evaporated to paste | The arm 3 patients showed a statistically significant reduction in mean fasting blood sugar from 160 to 110 mg/dl (p<0.001) and a significant decrease in blood sugar levels after glucose tolerance tests (p<0.001). Additionally, after 12 weeks, Coccinia indica-treated patients showed significant reductions in cholesterol (p<0.001) phospholipid (p<0.05) triglicerides (p<0.001), and free fatty acids ((p<0.001).
| | | | | N entering: | Not reported
| | | | | N completing: | 25
| | | | | Arm 4: Oral hypoglycemic, diet | | Arm 4 outcomes: GTT, cholesterol, phospholipid, triglycerides, free fatty acids
| | | | | Plant part: | N/A
| | | | | Preparation: | N/A | FBS improved from 165 to 120 mg/dl (p<0.1) and PPBS from 292 to 152 mg/dl (p<0.05).
| | | | | N entering: | Not reported
| | | | | N completing: | 15
Kohli | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Eugenia jambolana | | Outcomes: Clinical symptoms, FBS, GTT
1993 | | Diagnostic criteria: | FBS and GTT
A clinical trial of Jambu (Eugenia jambolana) in non-insulin dependant diabetes mellitus | | | | | Plant part: | Seed | The study showed a statistically significant reduction in mean fasting blood sugar of 51.86 mg/dl at 2 months (p<0.001) but not at 3 months. The study also demonstrated a significant reduction in the response to the glucose tolerance test at both 2 months (p<0.001) and at 3 months (p<0.001).
| | % Female; | Not reported | | Preparation: | powdered
| | % under 18: | Not reported | | N entering | 30
Location of treatment: | India Sub-continent | % over 65: | Not reported | | N completing: | 9
Study design: | CCT
Total Jadad score: | 1
Randomized: | No | | | | Arm 2: Oral hypoglycemic
Randomization appropriate: | No
Double-blind: | No | | | | Plant part: | N/A
Blinding appropriate: | No | | | | Preparation: | N/A
Withdrawals/dropouts described: | Yes | | | | N entering: | Not reported
| | | | | N completing: | 6
Baskaran | | Diagnosis: | Type 2 diabetes | More than 6 months | Arm 1: Gymnema sylvestre , oral hypoglycemic | | Arm 1 outcomes: FBS, Hb A_1c_, cholesterol, triglycerides
1990 | | Diagnostic criteria: | FBS and HbA_1c_
Antidiabetic effect of a leaf extract from Gymnema sylvestre in non-insulin-dependent diabetes mellitus patients
| | % Female; | 23 | | Plant part: | Leaf | Mean fasting blood sugar (FBS) improved from 174 mg/dl to 124 mg/dl (p<0.001). Hb A_1c_ improved from 11.9% to 8.48% (p<0.001). Cholesterol improved from 260 mg/dl to 231 mg/dl (p<0.001)
| | % under 18: | 0 | | Preparation: | GS4
| | % over 65: | 0 | | N entering: | 22
Location of treatment: | India Sub-continent | | | | N completing: | 22
Study design: | CCT
| | | | | Arm 2: Oral hypoglycemic | | Arm 2 outcomes: FBS, Hb A_1c_, cholesterol, triglycerides
Total Jadad score: | 0
Randomized: | No | | | | Plant part: | N/A
Randomization appropriate: | No | | | | Preparation: | N/A | Mean FBS changed from 150 mg/dl to 157 mg/dl, mean Hb A_1c_ from 10.2 to 10.47, mean cholesterol worsened from 252 mg/dl to 261 mg/dl (p<0.05)
Double-blind: | No | | | | N entering: | 25
Blinding appropriate: | No | | | | N completing: | 25
Withdrawals/dropouts described: | No
Shanmugasundaram | | Diagnosis: | Type 1 diabetes | Before and after 6 months | Arm 1: UCC, insulin | | Arm 1 outcomes: Insulin requirements, FBS, Hb A_1c_, cholesterol, triglycerides, free fatty acids
1990b | | Diagnostic criteria: | FBS and HbA_1c_
Use of Gymnema sylvestreleaf extract in the control of blood glucose in insulin-dependent diabetes mellitus | | | | | Plant part: | N/A
| | % Female: | Not reported | | Preparation: | N/A
| | % under 18: | Not reported | | N entering: | 37 | Arm 1 showed a decrease in Hb A_1c_ from an initial value of 12.7 to 11.8% after 10-12 months. Insulin requirement per day remained the same. FBS decreased from 233 to 224 mg/dl and cholesterol decreased from 225 to 209 mg/dl at 10-12 months.
| | % over 65: | 0 | | N completing: | 37
Location of treatment: | India Sub-continent
Study design: | CCT
Total Jadad score: | 1
Randomized: | No
Randomization appropriate: | No | | | | Arm 2: Gymnema sylvestre , insulin | | Arm 2 outcomes: Insulin requirements, FBS, Hb A_1c_, cholesterol, triglycerides, free fatty acids.
Double-blind: | No
Blinding appropriate: | No | | | | Plant part: | Leaf
Withdrawals/dropouts described: | Yes | | | | Preparation: | GS4 extract
| | | | | N entering: | 27 | Arm 2 showed a decrease in Hb A_1c_ from an initial value of 12.8 to 9.5 (p<0.01) at 6-8 months after treatment. Similarly, insulin requirement decreased from 60 units/day to 45 units/day, FBS decreased from 232 to 177 mg/dl and cholesterol decreased from 206 to 208 mg/dl at 6-8 months.
| | | | | N completing: | 27

RCT = randomized control trial: FBS = fasting blood sugar: UBS =urinary blood sugar UCC = usual customary care NS = not significant

CCT = clinical controlled trial: GTT = glucose tolerance test PPBS = post-prandial blood sugar N/A = not available / not applicable Hb A_1c_ = hemoglobin A_1c_

* NOTE: Chandola (1980a) presents three studies; one study appears in each Evidence Table and in “Characteristics of Studies Not Included in Further Analysis” in Appendix L.

Evidence Table 2. Pre/Post Comparison Studies

First author
Year | | | | | Intervention groups
Title | | Diagnosis | | | Intervention
Location | | Diagnostic criteria | | | Plant parts used
Study design | | Gender | | Time at followup | # Entering study
Jodad | | Age | | | # Completing study | | Outcomes
Chandola* | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: C. tamala, diet | | Outcomes: FBS, 1-hour and 2-hour post-pradinal blood sugar.
1980a | | Diagnostic criteria: | FBS and GTT
Hypoglycaemic response of C.tamala in patients of maturity onset (insulin independent) diabetes | | | | | Plant part: | Leaf
| | % Female: | 4 | | Preparation: | Dried powder | FBS improved from 144.84 to 103.51mg/dl (p<0.001). 1 hour post prandial blood sugar improved from 258.64 to 206.89 mg/dl (p<0.001). 2 hour post-prandial blood sugar improved from 236.15 to 170.59 (p<0.001).
| | % under 18: | 0 | | N entering: | N/A
Location of treatment: | India Sub-continent | % over 65: | 12 | | N completing | 25
Study design: | Case series
Kamble | | Diagnosis | Normal, type 1, and type 2 diabetes | 6 months or less | Arm 1: None | | Arm 1 outcomes: FBS, lactate dehydrogenase, glucose-6-phosphatase, lipoprotein lipase.
1998
Influence of Coccinia indica on certain enzymes in glycolytic and lipolytic pathway in human diabetes | | Diagnostic criteria | FBS | | Plant part | N/A
| | | | | Preparation | N/A
| | % Female | Not reported | | N entering | 30 | See Arm 3.
Location of Tx | India Sub-continent | % under 18 | Not reported | | N completing | 30
Study design | Case series | % over 65 | Not reported | | Arm 2: None | | Arm 2 outcomes: FBS, lactate dehydrogenase, glucose-6-phosphatase, lipoprotein lipase.
| | | | | Plant part | N/A
| | | | | Preparation | N/A
| | | | | N entering | X | See Arm 3.
| | | | | N completing | 15
| | | | | Arm 3: Coccinia indica | | Arm 3 outcomes: FBS, lactate dehydrogenase, glucose-6-phosphatase, lipoprotein lipase.
| | | | | Plant part | Leaf
| | | | | Preparation | N/A, dried extract
| | | | | N entering | X | The mean fasting blood sugar decreased from 365 mg/dl to 112 mg/dl (p not reported) and there were statistically significant decreases in glucose-6- phosphatase, lactate dehydrogenase and lipoprotein lipase levels (p<0.001).
| | | | | N completing | 15
Kuppurajan | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Coccinia indica | | Arm 1 outcomes: lipids
1986 | | Diagnostic criteria: | FBS and GTT
Hypoglycaemic effect of Coccinia indica in diabetes mellitus | | | | | Plant part: | Stem | In the responder group (n=12), FBS improved from 127.1 to 95.5 mg/dl and 2- hour PPBS from 242.4 to 168.4 mg/dl. In the nonresponder group (n=4), FBS increased from 123.0 to 182.5 mg/dl and 2-hour PPBS from 205.0 to 285.5 mg/dl.
| | % Female: | Not reported | | Preparation: | Powdered
| | % under 18: | 0 | | N entering: | N/A
Location of treatment: | India Sub-continent | % over 65: | 0 | | N completing | 10
Study design: | Case series
| | | | | Arm 2: Coccinia indica | | Results were reported combined for both Arm 1 and Arm 2.
| | | | | Plant part: | Stem
| | | | | Preparation | powdered
| | | | | N entering | N/A
| | | | | N completing | 6
Kuppu Rajan | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Fenugreek, diet | | Outcomes: Cholesterol, triglycerides, and blood sugar
1998 | | Diagnostic criteria: | FBS and GTT
Hypoglycemic and hypotriglyceridemic effects of Methika churna (Fenugreek) | | | | | Plant part: | Seed
| | % Female: | 40 | | Preparation: | Powdered | Statically significant reductions in final and initial values in the blood sugar at 1 hour (mean difference -40.20+/-16.03 p<0.02) and at 2 hours (mean difference -49.47+/- 19.27 p<0.02). There were also significant reductions in serum cholesterol (mean difference -17.40+/- 4.22 p<0.001) and serum triglycerides(mean difference -13.25+/-6.51 p<0.05) values from initial and final stages.
| | % under 18: | 0 | | N entering: | 15
Location of treatment: | India Sub-continent | % over 65: | 0 | | N completing | 15
Study design: | Case series
Kumar | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Ayush 82, diet | | Arm 1 outcomes: Clinical symptoms, FBS, PPBS, cholesterol
1999 | | Diagnostic criteria: | Ayurvedic and FBS
Clinical evaluation of single and herbo-mineral compound drugs in the management of Madhumeha | | | | | Plant part: | Leaf and seed
| | | | | Preparation: | Ayurvedic preparation, herb & mineral | FBS improved from 169.17 mg/dl to 120.9 mg/dl (p<0.001) and post prandial blood sugar fell from 218.4 mg/dl to 172.9 mg/dl (p< 0.001) after treatment. Cholesterol levels decreased from 251.6 to 225.33 (p< 0.001) after treatment.
| | % Female: | 55
| | % under 18: | 0 | | N entering: | 30
Location of treatment: | India Sub-continent | % over 65: | 0 | | N completing | 30
Study design: | CCT
Total Jadad score: | 0
Randomized: | No
Randomization appropriate: | No
Double-blind: | No | | | | Arm 2: Chandraprabhavati, Mineral, Pterocarpus marsupium, diet | | Arm 2 outcomes: Clinical symptoms, FBS, PPBS, cholesterol
Blinding appropriate: | No
Withdrawals/dropouts described: | No
| | | | | Plant part: | N/A | FBS improved from 168.37 mg/dl to 119.2 mg/dl (p<0.001) and post-prandial blood sugar fell from 234.07 to 181.83 mg/dl. (p<0.001) Cholesterol levels decreased from 239.1 to 223.63 after treatment (p<0.001).
| | | | | Preparation: | N/A
| | | | | N entering: | 30
| | | | | N completing: | 30
| | | | | Arm 3: Fenugreek, diet | | Arm 3 outcomes: Clinical symptoms, FBS, PPBS, cholesterol
| | | | | Plant part: | Seed
| | | | | Preparation: | Powdered | FBS improved from 174.63 mg/dl to 121.06 mg/dl (p<0.001) and post-prandial blood sugar decreased from 236.53 to 183.83 mg/dl (p<0.001). Cholesterol levels also decreased from 218.14 mg/dl to 198.29 (p<0.001) after treatment.
| | | | | N entering: | 51
| | | | | N completing: | 51
Sharma | | Diagnosis | Type 2 diabetes | 6 months or less | Arm 1: Diet | | Arm 1 outcomes: FBS, PPBS, insulin levels, symptoms
1996a | | Diagnostic criteria: | GTT
Use of fenugreek seed powder in the management of non-insulin dependent diabetes mellitus | | | | | Plant part: | N/A
| | % Female | 26 | | Preparation: | N/A | See Arm 2
| | % under 18 | 0 | | N entering: | 10
Location of Tx | India Sub-continent | % over 65 | Not reported | | N completing | 10
Study design: | CCT
Total Jadad score: | 0
Randomized: | No
Randomization appropriate: | No | | | | Arm 2: Fenugreek | | Arm 2 outcomes: FBS, PPBS, insulin levels, symptoms
Double-blind: | No
Blinding appropriate: | No | | | | Plant part | Seed
Withdrawals/dropouts described: | No | | | | Preparation: | N/A powder | The study demonstrated a significant reduction in the serum insulin levels of 12.4 μU/L (p<0.05) and in blood glucose levels up to 2 hours after glucose load of 87.62 mg/dl (p<0.001). The mean urinary excretion of glucose was reduced by 13% (p<0.001) and there was a significant reduction in Glycosylated Hemoglobin of 1.2 % (p<0.001).
| | | | | N entering: | 60
| | | | | N completing: | 60
Indian Council of Medical Research (ICMR) | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Pterocarpus marsupium, diet | | Otcomes: Clinical symtoms, quality of life, FBS, PPBS, Hb A_1c_
1998 | | Diagnostic criteria: | FBS and Hb A_1c_
Flexible dose open trial of Vijayasar in cases of newly-diagnosed non-insulin-dependent diabetes mellitus. | | | | | Plant part: | Bark, and heartwood
| | % Female: | Not reported | | Preparation: | Tea/decoction, dried aqueous decoction | Mean FBS fell from 151mg/dl to 119 mg/dl (p<0.001). Mean Hb A_1c_ fell from 9.8 to 9.4 (p<0.001) and mean post-prandial blood sugar fell from 216 mg/dl to 171 mg/dl (p< 0.001).
| | % under 18: | 0
| | % over 65: | 0 | | N entering: | 124
Location of treatment: | India Sub-continent | | | | N completing: | 93
Study design: | Cohort
Goyal | | Diagnosis: Normal and type 2 diabetes | | 6 months or less | Arm 1: Vinca rosea | | Arm 1 outcomes: Clinical symptoms, FBS, PPBS
1999 | | Diagnostic criteria: | FBS
Study on Sadabahar (Vinca rosea Linn.) in Madhumeha (diabetes mellitus) | | | | | Plant part: | Leaf
| | % Female: | Not reported | | Preparation: | Paste | FBS improved from 131.37 mg/dl to 98.98 mg/dl (p<0.001). Post-prandial blood sugar fell from 224.90 mg/dl to 144.24 mg/dl (p<0.001) after 1 month of treatment.
| | % under 18: | Not reported | | N entering: | Not reported
Location of treatment | India Sub-continent | % over 65: | Not reported | | N completing | 25
Study design: | CCT
Total Jadad score: | 0
Randomized: | No
Randomization appropriate: | No | | | | Arm 2: Vinca rosea, oral hypoglycemic | | Arm 2 outcomes: Clinical symptoms, FBS, PPBS
Double-blind: | No
Blinding appropriate: | No | | | | Plant part: | Leaf
Withdrawals/dropouts described: | No | | | | Preparation: | Paste | FBS improved from 217.45 mg/dl to 91.55 mg/dl (p<0.001). Post-prandial blood sugar fell from 314.50 mg/dl to 140 mg/dl (p<0.001).
| | | | | N entering: | Not reported
| | | | | N completing: | 10
| | | | | Arm 3: Vinca rosea | | Arm 3 outcomes: Clinical symptoms, FBS, PPBS
| | | | | Plant part: | Leaf
| | | | | Preparation: | Paste | This group consisted of normal non-diabetic patients. No significant decreases in FBS or PPBS were noted.
| | | | | N entering: | Not reported
| | | | | N completing: | 10
| | | | | Arm 4: Vinca rosea | | Arm 4 outcomes: Clinical symptoms, FBS, PPBS
| | | | | Plant part: | Leaf
| | | | | Preparation: | Paste | This group consisted of diabetic patients who were given just one dose of Vinca rosea. No significant decreases in FBS or PPBS were noted
| | | | | N entering: | 5
| | | | | N completing: | 5
Chowdhary | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Ayush 82, diet | | Otcomes: FBS, PPBS, clinical symptoms
1998 | | Diagnostic criteria: | FBS, UBS, and GTT
Hypoglycaemic effect of a coded formulation: Ayush-82 | | | | | Plant part: | Leaf and seed | The study showed a statistically significant reduction in mean fasting blood sugar of 25.21 mg/dl (p<0.001) and a reduction in mean post-prandial blood sugar of 30.4 mg/dl (p<0.001).
| | | | | Preparation: | Ayurvedic preparation, herb & mineral
| | % Female: | 48
Location of treatment: | India Sub-continent | % under 18: | 0 | | N entering: | 100
Study design: | Cohort | % over 65: | Not reported | | N completing: | 89
Pandey | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Ayush 82, Shuddha Shilajitu, diet | | Otcome: Clinical symptoms, FBS, PBS
1995 | | Diagnostic criteria: | FBS and GTT
An effective Ayurvedic hypoglycemic formulation | | | | | Plant part: | Leaf and seed | FBS in males decreased from 195+/- 48 mg/dl to 131+/- 64 mg/dl (p<0.001) and PPBS decreased from 288 to 204 mg/dl (p<0.001).
| | % Female: | 48 | | Preparation: | Ayurvedic preparation, herb & mineral
Location of treatment: | India Sub-continent | % under 18: | 0
Study design: | Case series | % over 65: | Not reported | | N entering: | 80
| | | | | | | FBS in females decreased from 191+/- 48 mg/dl to 141+/- 64 mg/dl (p<0.001) and PPBS decreased from 279 to 201 mg/dl (p<0.001).
Shankar | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Abraga Chendooram (Black mica, Borax, Trianthema decandra, Adhatoda zeylanica and Ficus benghalensis), diet | | Otcomes: FBS, PPBS
1995 | | Diagnostic criteria: | Ayurvedic, FBS, UBS, and GTT
Clinical studies of the effect of Abraga (Mica) chendooram in the treatment of diabetes mellitus (Neerazhivu) | | | | | | | The study showed a statistically significant reduction in mean fasting blood sugar of 62.30 mg/dl (p<0.005) and a reduction in mean post prandial blood sugar of 84.70 mg/dl (p<0.005).
| | % Female: | 43 | | Plant part: | Leaf and root
| | % under 18: | 0 | | Preparation: | Ayurvedic preparation, Herb & mineral
Location of treatment: | India Sub-continent | % over 65: | Not reported
Study design: | Case series | | | | N entering: | Not reported
| | | | | N completing: | 130
Maji | | Diagnosis: | Type 1 and type 2 diabetes | 6 months or less | Arm 1: D-400, diet | | Arm 1 outcomes: FBS, PBS, cholesterol, HDL, LDL
1995
Clinical trial of D-400, a herbomineral preparation in diabetes mellitus | | Diagnostic criteria: | FBS, GTT, and Hb A_1c_ | | Plant part: | N/A
| | | | | Preparation: | Ayurvedic preparation, herbs & minerals | PPBS decreased from 262.00 mg/dl to 141.16 mg/dl (p<0.01). FBS decreased from 208.47 mg/dl to 113.05 mg/dl (p<0.01) and cholesterol decreased from 194.82 to 172.00 mg/dl (p<0.01).
Location of treatment: | India Sub-continent | % Female: | Not reported | | N entering: | Not reported
Study design: | Cohort | % under 18: | 0 | | N completing: | 19
| | % over 65: | Not reported
| | | | | Arm 2: D-400, diet | | Arm 2 outcomes: FBS, PPBS, cholesterol, HDL, LDL
| | | | | Plant part: | N/A
| | | | | Preparation: | Ayurvedic preparation, herb & mineral | PPBS decreased from 284.13 mg/dl to 131.00 mg/dl. FBS decreased from 219.88 mg/dl to 109.00 mg/dl (p<0.01) and cholesterol decreased from 182.57 to 162.29 mg/dl (p<0.01).
| | | | | N entering: | Not reported
| | | | | N completing: | 8
| | | | | Arm 3: D-400, diet | | Arm 3 outcomes: FBS, PPBS, cholesterol, HDL, LDL
| | | | | Plant part: | N/A
| | | | | Preparation: | Ayurvedic preparation | PPBS decreased from 311.17 mg/dl to 302.17 mg/dl (ns). FBS decreased from 267.33 mg/dl to 215.00 mg/dl (ns) and cholesterol decreased from 182.83 to 166.50 mg/dl (p<0.01).
| | | | | N entering: | Not reported
| | | | | N completing: | 6
Sircar | | Diagnosis: | Type 2 diabetes | Before and after 6 months | Arm 1: MA-471 Enicostema littorale (H. chota chiretta), Phyllanthus niruri (H. Bhuimale), Terminalia arjuna (H. arjun), Eugenia jambolana , Melia azadirachta, Aegle marmelos, Momordica charantia , Asphaltum (black bitumin/ mineral pitch) , diet | | Arm 1 outcomes: Clinical symptoms, FBS, PPBS, Hb A_1c_, cholesterol, triglycerides
1996 | | Diagnostic criteria: | FBS, GTT, Hb A_1c_
Hypoglycemic, hypolipidemic and general beneficial effects of an herbal mixture MA-471 | | | | | | | PPBS pre-treatment 292.73 mg/dl vs. post treatment 221.09 mg/dl (p<0.001). FBS improved 168.72 mg/dl to 124 mg/dl (p<0.001). The Hb A_1c_ decreased from 10.3% to 7.3% (p<0.05) and cholesterol decreased from 236.4 to 182.3 mg/dl (p<0.01).
| | % Female: | Not reported
Location of treatment: | India Sub-continent | % under 18: | Not reported
Study design: | Cohort | % over 65: | Not reported
| | | | | Plant part: | N/A
| | | | | Preparation: | Ayurvedic preparation, herb & mineral
| | | | | N entering: | 15
| | | | | N completing: | 13
| | | | | Arm 2: MA-471 Enicostema littorale (H. chota chiretta), Phyllanthus niruri (H. Bhuimale), Terminalia arjuna (H. arjun), Eugenia jambolana , Melia azadirachta, Aegle marmelos, Momordica charantia , Asphaltum (black bitumin/ mineral pitch) , diet and withdrawl of oral hypoglycemic agent. | | Arm 2 outcomes: Clinical symptoms, FBS, PPBS, Hb A_1c_, cholesterol, triglycerides
| | | | | | | PPBS pre-treatment 173.63 mg/dl vs. post treatment 171.82 mg/dl (NS). FBS improved 116.91 mg/dl to 103.64 mg/dl (NS). The Hb A_1c_ increased from 7.0% to 7.6% (NS) and cholesterol decreased from 242.3 to 171.5 mg/dl (p<0.001).
| | | | | Plant part: | N/A
| | | | | Preparation: | Ayurvedic preparation, herb & mineral
| | | | | N entering: | 30
| | | | | N completing: | 25
| | | | | Arm 3: MA-471 Enicostema littorale (H. chota chiretta), Phyllanthus niruri (H. Bhuimale), Terminalia arjuna (H. arjun), Eugenia jambolana , Melia azadirachta, Aegle marmelos, Momordica charantia , Asphaltum (black bitumin/ mineral pitch) , diet, oral hypoglycemic | | Arm 3 outcomes: Clinical symptoms, FBS, PPBS, Hb A_1c_, cholesterol, triglycerides
| | | | | | | PPBS pre-treatment 249.64 mg/dl vs. post-treatment 171.27 mg/dl (p<0.001). FBS improved 151.64 mg/dl to 102.90 mg/dl (p<0.01). The Hb A_1c_ decreased from 10.1% to 6.4% (p<0.05) and cholesterol decreased from 227.6 to 17.4 mg/dl (p<0.01).
| | | | | Plant part: | N/A
| | | | | Preparation: | Ayurvedic preparation
| | | | | N entering: | 15
| | | | | N completing: | 12
Shankar | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Sandana Podi-a: Santalum album, Andropogon citratus, Vetiveria zizanioides , Syzygium aromaticum Anacyclus pyrethrum, Tinospora cordifolia, Silajit, diet | | Outcomes: Clinical symptoms, FBS, PPBS
1994 | | Diagnostic criteria: | FBS, GTT, and Siddha 2
Clinical assessment of the effects of Sandana | | | | | | | Mean FBS before treatment was 164.5mg/dl which decreased to 114.7 mg/dl (p<0.01).
(Sandal) podi-a in the treatment of diabetes mellitus
(Neerazhiv) | | % Female: | 40
| | % under 18: | 0 | | Plan part: | Root, bark, and flower | Mean PPBS before treatment was 281.7 mg/dl which decreased to 171.25 mg/dl (p<0.01).
Location of treatment: | India Sub-continent | % over 65: | Not reported | | Preparation: | Ayurvedic preparation, herb & mineral
Study design: | Case series
| | | | | N entering: | 20
| | | | | N completing: | 20
Sivaprakasam | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Triphala (Terminalia bellerica, Phyllanthus embelica and Terminalia chebula) with Salacia chinnensis. | | Outcomes: Clinical symptoms and blood glucose
1984 | | Diagnostic criteria: | Ayurvedic, FBS, UBS, and GTT
Siddha remedy for diabetes mellitus
| | | | | | | The mean blood sugar for the group improved from 303.88 mg/dl to 184.68 mg/dl.
Location of treatment: | India Sub-continent | % Female: | 24 | | Plan part: | Root and bark
Study design: | Case series | % under 18: | 0 | | Preparation: | Ayurvedic preparation, powdered
| | % over 65: | 0 | | N entering: | Not reported
| | | | | N completing: | 25

* NOTE: Chandola (1980a) presents three studies; one study appears in each Evidence Table and in “Characteristics of Studies Not Included in Further Analysis” in Appendix L.

RCT = randomized control trial FBS = fasting blood sugar UBS = urinary blood sugar UCC = usual customary care NS = not significant

CCT = clinical controlled trial GTT = glucose tolerance test PPBS = post-prandial blood sugar N/A = not available / not applicable Hb A_1c_ = hemoglobin A_1c_ HDL = high density lipoprotein LDL = low density lipoprotein